# Evidence and Quality Tables

Appendix C1 Evidence Table of Included Studies of Benefits and Harms of Treatment of Vitamin D Deficiency

Appendix C2 Evidence Table of Nested Case-Control Studies From the Women's Health Initiative Trial

Appendix C3 Quality Ratings of Included Randomized, Controlled Trials