# Detailed Methods

## Appendix B1 Search Strategies

### Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)

Search Strategy:

--------------------------------------------------------------------------------

1. exp Vitamin D/
2. Vitamin D Deficiency/
3. exp Mass Screening/
4. Diagnostic Tests, Routine/
5. 3 or 4
6. 1 or 2
7. 5 and 6
8. ((take or taking or takes or give or giving or prescri$ or provid$ or oral$ or parenteral$ or diet$ or food$ or pill or pills or tablet$) adj5 supplement$ adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$)).mp.
9. (supplement$ adj5 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
10. 8 or 9
11. exp Vitamin D/ad, ae, ct, po, tu, to [Administration & Dosage, Adverse Effects, Contraindications, Poisoning, Therapeutic Use, Toxicity]
12. 10 or 11
13. 2 and 12
14. limit 13 to english language
15. limit 13 to abstracts
16. 14 or 15
17. limit 16 to “all adult (19 plus years)”

### Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)

Search Strategy:

--------------------------------------------------------------------------------

1. exp vitamin d/
2. vitamin d deficiency/
3. 1 or 2
4. exp Mass Screening/
5. Diagnostic Tests, Routine/
6. 4 or 5
7. 3 and 6
8. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 ((((low or lower or circulat$ or blood or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
9. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 ((((low or lower or circulat$ or blood or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (hypovitamin$ adj d))).mp.
10. 8 or 9
11. 3 and 10
12. 7 or 11
13. limit 12 to english language
14. limit 12 to abstracts
15. 13 or 14
16. limit 15 to “all adult (19 plus years)”
17. exp Epidemiologic Studies/
18. 16 and 17
19. limit 16 to (controlled clinical trial or guideline or meta analysis or randomized controlled trial)
20. 18 or 19
21. exp “Outcome and Process Assessment (Health Care)”/
22. 16 and 21
23. exp Vital Statistics/
24. 16 and 23
25. mo.fs.
26. pc.fs.
27. 25 or 26
28. 16 and 27
29. 20 or 22 or 24 or 28

### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 ((((low or lower or circulat$ or blood or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
2. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 (hypovitamin$ adj d)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 or 2
4. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
5. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 (hypovitamin$ adj d)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
6. 4 or 5
7. ((take or taking or takes or give or giving or prescri$ or provid$ or oral$ or parenteral$ or diet$ or food$ or pill or pills or tablet$) adj5 supplement$ adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$)).mp.
8. (supplement$ adj5 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
9. 7 or 8

### Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

--------------------------------------------------------------------------------

1. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 ((((low or lower or circulat$ or blood or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
2. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 (hypovitamin$ adj d)).mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 or 2
4. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
5. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 (hypovitamin$ adj d)).mp. [mp=title, abstract, full text, keywords, caption text]
6. 4 or 5
7. ((take or taking or takes or give or giving or prescri$ or provid$ or oral$ or parenteral$ or diet$ or food$ or pill or pills or tablet$) adj5 supplement$ adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$)).mp.
8. (supplement$ adj5 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
9. 7 or 8

### Database: EBM Reviews - Database of Abstracts of Reviews of Effects

Search Strategy:

--------------------------------------------------------------------------------

1. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 ((((low or lower or circulat$ or blood or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
2. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 (hypovitamin$ adj d)).mp. [mp=title, full text, keywords]
3. 1 or 2
4. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
5. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 (hypovitamin$ adj d)).mp. [mp=title, full text, keywords]
6. 4 or 5
7. ((take or taking or takes or give or giving or prescri$ or provid$ or oral$ or parenteral$ or diet$ or food$ or pill or pills or tablet$) adj5 supplement$ adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$)).mp.
8. (supplement$ adj5 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
9. 7 or 8

### Database: EBM Reviews - Health Technology Assessment Search Strategy

--------------------------------------------------------------------------------

1. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 ((((low or lower or circulat$ or blood or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
2. ((risk$ or presence or prevalence or danger$ or complicat$ or morbid$ or comorbid$ or mortal$) adj7 (hypovitamin$ adj d)).mp. [mp=title, text, subject heading word]
3. 1 or 2
4. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
5. ((diagnos$ or detect$ or determin$ or find$ or found or discover$ or identif$ or undiagnos$ or undetect$ or asymptomat$ or preclinical$ or pre-clinical$ or underlying or screen$ or test or tests or testing or tested or assay$ or accura$ or predict$) adj7 (hypovitamin$ adj d)).mp. [mp=title, text, subject heading word]
6. 4 or 5
7. ((take or taking or takes or give or giving or prescri$ or provid$ or oral$ or parenteral$ or diet$ or food$ or pill or pills or tablet$) adj5 supplement$ adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$)).mp.
8. (supplement$ adj5 ((((low or lower or circulat$ or blood or serum or hematolog$) adj3 (level$ or amount$)) or insuffic$ or defic$ or status or depriv$) adj5 (vitamin d or vitamin d3 or Cholecalciferol$ or Hydroxycholecalciferol$ or Calcifediol or Dihydroxycholecalciferol$ or Calcitriol or Dihydroxyvitamin D or Ergocalciferol$ or Dihydrotachysterol$))).mp.
9. 7 or 8

## Appendix B2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | KQs 1, 3: Nonpregnant adults age ≥18 years who are generally healthy. Study participants are either:; - Unselected or low-risk, or; - Selected for increased risk for vitamin D deficiency based on certain characteristics, including participants who are older, have darker skin pigmentation (blacks or Hispanics), or are obese or institutionalized; KQ 2: Nonpregnant adults age ≥18 years who are generally healthy. Study participants are either:; - Unselected or low-risk, or; - Selected for increased risk for vitamin D deficiency; KQ 4: Nonpregnant adults age ≥18 years who are generally healthy with vitamin D deficiency. Study participants are either:; - Unselected or low-risk, or; - Selected for increased risk for vitamin D deficiency | Selected populations with conditions including clinical signs of vitamin D deficiency, osteoporosis, malabsorption, granuloma-forming disorders, chronic kidney disease, hepatic failure, cancer, coronary heart disease, diabetes/glucose intolerance, immune disorders, high risk for falls, polycystic ovarian syndrome, and multiple sclerosis
Interventions | Vitamin D_2_ or D_3_ (with or without calcium); food-based interventions if vitamin D dose is quantified and doses differ between comparison groups | Nonoral routes of vitamin D delivery; dietary intake (unless a food-based intervention, as described under inclusion criteria); ultraviolet light exposure; multivitamins
Comparators | KQs 1, 2: Screening KQs 3, 4: Placebo, no treatment, usual care | KQs 1, 2: No screening KQs 3, 4: Different dosages of vitamin D
Outcomes | KQs 1, 3: Health outcomes include decreased morbidity from osteoporosis/fractures, falls, diabetes mellitus, cardiovascular disease, cancer, and immune diseases; improved depression; improved psychosocial functioning as measured by quality of life instruments; physical fitness capacity or performance; physical functioning as measured by scores on physical subscales of quality of life measures; disability (global measures only, such as activities of daily living); mortality; outcomes reported at ≥8 weeks after start of intervention or the baseline assessment (if the intervention start cannot be determined) (required) KQs 2, 4: Mortality; renal outcomes (e.g., kidney stones); soft tissue calcification; adverse events (e.g., gastrointestinal symptoms) | KQs 1, 3: Improved functioning (except as enumerated under health outcomes); intermediate physiological outcomes (examined as contextual question); behavioral changes (e.g., physical activity, diet); outcomes reported <8 weeks after start of the intervention or the baseline assessment (if time from intervention start cannot be determined); baseline vitamin D level not reported or not deficient KQs 2, 4: None
Settings | Studies conducted in primary care or feasible for conducting in or referral from primary care, including institutionalized settings. For an intervention to be feasible for primary care referral, it would need to be conducted as part of a health care setting or be widely available in the community at a national level. United States, Canada, United Kingdom, and other geographic settings generalizable to the United States | Studies performed in countries with populations not similar to the United States; studies conducted in schools or work sites, unless primary care–feasible
Timing | KQs 1, 3: ≥8 weeks KQs 2, 4: Any duration | KQs 1, 3: <8 weeks KQs 2, 4: None
Study types and designs | KQs 1, 3: Systematic reviews or meta-analyses of randomized or controlled clinical trials, primary reports of randomized or controlled clinical trials KQs 2, 4: Systematic reviews or meta-analyses of randomized or controlled clinical trials, primary reports of randomized or controlled clinical trials, and large cohort or case-control studies; studies must have an appropriate comparison group | KQs 1, 3: Nonsystematic reviews, letters to the editor, cohort or case-control studies, noncomparative studies, and comparative efficacy trials; reviews not in English KQs 2, 4: Nonsystematic reviews, letters to the editor, noncomparative studies, and comparative efficacy trials; reviews not in English

## Appendix B3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, hand searching, and suggestions by experts.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

§ Studies may have provided data for more than one key question.

¶ Studies may have more than one published article; there were 27 unique studies but a total of 35 articles included.

Appendix B3 is a flow diagram that summarizes the search and selection of articles. There were 3,652 citations identified by searching MEDLINE, the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and other sources including reference lists, hand searching, and suggestions by experts. Of these 2,253 were excluded at the abstract level because they did not address a key question or only addressed background information. The remaining 1,399 articles were pulled and reviewed for relevance to the key questions. There were 1,364 full-text articles excluded for the following reasons: did not address a key question or meet inclusion criteria but only provided background information or only addressed one of the contextual questions, wrong population, wrong intervention, wrong outcomes, wrong study design, wrong publication type, foreign language, inadequate duration, a study included in an included systematic review, which did not provide original data, a review not meeting our requirements, wrong comparison, and for the treatment key questions studies that did not report baseline 25(OH)D levels or partipant 25(OH)D levels were not deficient. 27 studies in 35 publications were included in the final report. Some studies may have addressed more than one key question. For Key Questions 1 and 2, there were 0 studies identified. 17 studies adressed Key Question 3 and 24 addressed Key Question 4.

## Appendix B4 List of Excluded Studies

Key to Exclusion Codes

2 | Doesn't address a key question or meet inclusion criteria, but pulled to provide background information
3 | Doesn't address a key question or meet inclusion criteria, but pulled for contextual question(s)
4 | Wrong population
5 | Wrong intervention
6 | Wrong outcomes
7 | Wrong study design for key question
8 | Wrong publication type
9 | Foreign language
10 | Inadequate duration
11 | Included in an included systematic review, no original data
12 | Wrong comparison
13 | Systematic review not meeting our requirements
14 | Baseline 25(OH)D level not reported
15 | Baseline 25(OH)D levels not deficient

Abrahamsen B, Masud T, Avenell A, et al. Patient level pooled analysis of 68 500 patients from seven major vitamin D fracture trials in US and Europe. BMJ (Online). 2010;340(7738):139. Exclusion code: 6.
Afzal S, Nordestgaard BG, Bojesen SE. Plasma 25-hydroxyvitamin D and risk of non-melanoma and melanoma skin cancer: a prospective cohort study. J Invest Dermatol. 2013;133(3):629-636. Exclusion code: 3. [pmid: 23190899].
Arem H, Weinstein SJ, Horst RL, et al. Serum 25-hydroxyvitamin D and risk of oropharynx and larynx cancers in Finnish men. Cancer Epidemiol Biomarkers Prev. 2011;20(6):1178-1184. Exclusion code: 3. [pmid: 21527582].
Bergman GJD, Fan T, McFetridge JT, Sen SS. Efficacy of vitamin D3 supplementation in preventing fractures in elderly women: A meta-analysis. Curr Med Res Opin. 2010;26(5):1193-1201. Exclusion code: 13. [pmid: 20302551].
Bjorkhem I, Holmberg I. Mass Fragmentography of 25 hydroxyvitamin D3. Quantitative mass spectrometry in life sciences II : proceedings of the second international symposium. State University of Ghent. June 13-16, 1978. de Leenheer AP, Roncucci RR, van Peteghem C, editors. 1978. Exclusion code: 2.
Björkhem I, Holmberg I. [45]. Mass fragmentographic assay of 25-hydroxyvitamin D3. Donald B, McCormick LDW, editors. Methods in Enzymology. Academic Press. 1980;67:385-393. Exclusion code: 2.
Buttigliero C, Monagheddu C, Petroni P, et al. Prognostic role of vitamin d status and efficacy of vitamin D supplementation in cancer patients: a systematic review. Oncologist. 2011;16(9):1215-1227. Exclusion code: 4. [pmid: 21835895].
Carter GD. Accuracy of 25-hydroxyvitamin D assays: confronting the issues. Curr Drug Targets. 2011;12(1):19-28. Exclusion code: 2. [pmid: 20795940].
Cranney A, Weiler HA, O'Donnell S, Puil L. Summary of evidence-based review on vitamin D efficacy and safety in relation to bone health. Am J Clin Nutr. 2008;88(2):513S-519S. Exclusion code: 13. [pmid: 18689393].
de Boer IH, Levin G, Robinson-Cohen C, et al. Serum 25-hydroxyvitamin D concentration and risk for major clinical disease events in a community-based population of older adults: a cohort study. [Summary for patients in Ann Intern Med. 2012 May 1;156(9):I36; PMID: 22547485]. Ann Intern Med. 2012;156(9):627-634. Exclusion code: 3. [pmid: 22547472].
De Souto Barreto P, Lapeyre-Mestre M, Mathieu C, et al. A multicentric individually-tailored controlled trial of education and professional support to nursing home staff: Research protocol and baseline data of the IQUARE study. J Nutr Health Aging. 2013;17(2):173-178. Exclusion code: 5. [pmid: 23364498].
Demetriou ET, Travison TG, Holick MF. Treatment with 50,000 IU vitamin D(2) every other week and effect on serum 25-hydroxyvitamin D(2), 25-hydroxyvitamin D(3), and total 25-hydroxyvitamin D in a clinical setting. Endocr Pract. 2012;18(3):399-402. Exclusion code: 12. [pmid: 22440989].
Donald IP, Pitt K, Armstrong E, Shuttleworth H. Preventing falls on an elderly care rehabilitation ward. Clin Rehabil. 2000;14(2):178-185. Exclusion code: 5. [pmid: 10763795].
Ensrud KE, Blackwell TL, Cauley JA, et al. Circulating 25-hydroxyvitamin D levels and frailty in older men: the osteoporotic fractures in men study. J Am Geriatr Soc. 2011;59(1):101-106. Exclusion code: 3. [pmid: 21226680].
Fang F, Kasperzyk JL, Shui I, et al. Prediagnostic plasma vitamin D metabolites and mortality among patients with prostate cancer. PLoS ONE. [Electronic Resource]. 2011;6(4):e18625. Exclusion code: 3. [pmid: 21494639].
Forouhi NG, Ye Z, Rickard AP, et al. Circulating 25-hydroxyvitamin D concentration and the risk of type 2 diabetes: Results from the European Prospective Investigation into Cancer (EPIC)-Norfolk cohort and updated meta-analysis of Prospective studies. Diabetologia. 2012;55(8):2173-2182. Exclusion code: 3. [pmid: 22526608].
Gallagher JC, Jindal P, Lynette MS. Vitamin D does not Increase Calcium Absorption in Young Women: A Randomized Clinical Trial. J Bone Miner Res. 2013. Exclusion code: 6.
Ganji V, Milone C, Cody MM, McCarty F, Wang YT. Serum vitamin D concentrations are related to depression in young adult US population: the Third National Health and Nutrition Examination Survey. Int Arch Med. 2010;3:29. Exclusion code: 7. [pmid: 21067618].
Grant WB, Tuohimaa P. Geographic variation of prostate cancer mortality rates in the United States: Implications for prostate cancer risk related to vitamin D [3] (multiple letters). Int J Cancer. 2004;111(3):470-472. Exclusion code: 8. [pmid: 15221981].
Haines TP, Bennell KL, Osborne RH, Hill KD. Effectiveness of targeted falls prevention programme in subacute hospital setting: randomised controlled trial. BMJ. 2004;328(7441):676. Exclusion code: 5. [pmid: 15031238].
Healey F, Monro A, Cockram A, Adams V, Heseltine D. Using targeted risk factor reduction to prevent falls in older in-patients: a randomised controlled trial. Age Ageing. 2004;33(4):390-395. Exclusion code: 5. [pmid: 15151914].
Hojskov CS, Heickendorff L, Moller HJ. High-throughput liquid-liquid extraction and LCMSMS assay for determination of circulating 25(OH) vitamin D3 and D2 in the routine clinical laboratory. Clin Chim Acta. 2010;411(1-2):114-116. Exclusion code: 2. [pmid: 19850018].
Holick MF. Evidence-based D-bate on health benefits of vitamin D revisited. Dermato-Endocrinology. 2012;4(2):183-190. Exclusion code: 8. [pmid: 22928075].
Izaks GJ. Fracture prevention with vitamin D supplementation: considering the inconsistent results. BMC Musculoskelet Disord. 2007;8:26. Exclusion code: 13. [pmid: 17349055].
Lai JKC, Lucas RM, Clements MS, Roddam AW, Banks E. Hip fracture risk in relation to vitamin D supplementation and serum 25-hydroxyvitamin D levels: A systematic review and meta-analysis of randomised controlled trials and observational studies. BMC Public Health. 2010;10. Exclusion code: 13.
LeBlanc E, Chou R, Zakher B, Daeges M, Pappas M. Screening for Vitamin D Deficiency: Systematic Review for the U.S. Preventive Servies Task Force Recommendation. [in press]. Rockville (MD). 2014. Exclusion code: 2.
Lee DM, Tajar A, O'Neill TW, et al. Lower vitamin D levels are associated with depression among community-dwelling European men. J Psychopharmacol. 2011;25(10):1320-1328. Exclusion code: 7. [pmid: 20823081].
Lensmeyer GL, Wiebe DA, Binkley N, Drezner MK. HPLC method for 25-hydroxyvitamin D measurement: comparison with contemporary assays. Clin Chem. 2006;52(6):1120-1126. Exclusion code: 2. [pmid: 16574756].
Ma Y, Zhang P, Wang F, Yang J, Liu Z, Qin H. Association between vitamin D and risk of colorectal cancer: A systematic review of prospective studies. J Clin Oncol. 2011;29(28):3775-3782. Exclusion code: 3. [pmid: 21876081].
Maddock J, Berry DJ, Geoffroy MC, Power C, Hyppönen E. Vitamin D and common mental disorders in mid-life: Cross-sectional and prospective findings. Clin Nutr. 2013;32(5):758-764. Exclusion code: 3. [pmid: 23395104].
Maunsell Z, Wright DJ, Rainbow SJ. Routine isotope-dilution liquid chromatography-tandem mass spectrometry assay for simultaneous measurement of the 25-hydroxy metabolites of vitamins D2 and D3. Clin Chem. 2005;51(9):1683-1690. Exclusion code: 2. [pmid: 16020493].
Mayo NE, Gloutney L, Levy AR. A randomized trial of identification bracelets to prevent falls among patients in a rehabilitation hospital. Arch Phys Med Rehabil. 1994;75(12):1302-1308. Exclusion code: 5. [pmid: 7993168].
Mitri J, Muraru MD, Pittas AG. Vitamin D and type 2 diabetes: a systematic review. Eur J Clin Nutr. 2011;65(9):1005-1015. Exclusion code: 3. [pmid: 21731035].
Mora JR, Iwata M, Von Andrian UH. Vitamin effects on the immune system: Vitamins A and D take centre stage. Nature Reviews Immunology. 2008;8(9):685-698. Exclusion code: 13.
Muir SW, Montero-Odasso M. Effect of vitamin D supplementation on muscle strength, gait and balance in older adults: a systematic review and meta-analysis. J Am Geriatr Soc. 2011;59(12):2291-2300. Exclusion code: 13. [pmid: 22188076].
Nanri A, Mizoue T, Matsushita Y, et al. Association between serum 25-hydroxyvitamin D and depressive symptoms in Japanese: analysis by survey season. Eur J Clin Nutr. 2009;63(12):1444-1447. Exclusion code: 7. [pmid: 19690578].
Norman PE, Powell JT. Vitamin D, shedding light on the development of disease in peripheral arteries. Arterioscler Thromb Vasc Biol. 2005;25(1):39-46. Exclusion code: 7. [pmid: 15499037].
Parviainen MT, Savolainen KE, Korhonen PH, Alhava EM, Visakorpi JK. An improved method for routine determination of vitamin D and its hydroxylated metabolites in serum from children and adults. Clin Chim Acta. 1981;114(2-3):233-247. Exclusion code: 2. [pmid: 6974620].
Pilz S, Dobnig H, Tomaschitz A, et al. Low 25-hydroxyvitamin D is associated with increased mortality in female nursing home residents. J Clin Endocrinol Metab. 2012;97(4):E653-E657. Exclusion code: 3. [pmid: 22319037].
Pilz S, Iodice S, Zittermann A, Grant WB, Gandini S. Vitamin D status and mortality risk in CKD: A meta-analysis of prospective studies. Am J Kidney Dis. 2011;58(3):374-382. Exclusion code: 4. [pmid: 21636193].
Pilz S, Tomaschitz A, März W, et al. Vitamin D, cardiovascular disease and mortality. Clin Endocrinol. 2011;75(5):575-584. Exclusion code: 13.
Puts MTE, Visser M, Twisk JWR, Deeg DJH, Lips P. Endocrine and inflammatory markers as predictors of frailty. Clin Endocrinol. 2005;63(4):403-411. Exclusion code: 3.
Reid IR, Bolland MJ. Role of vitamin D deficiency in cardiovascular disease. Heart. 2012;98(8):609-614. Exclusion code: 13. [pmid: 22373722].
Reid IR, Bolland MJ, Grey A. Effect of calcium supplementation on hip fractures. Osteoporos Int. 2008;19(8):1119-1123. Exclusion code: 7. [pmid: 18286218].
Reid IR, Bolland MJ, Grey A. Effects of vitamin D supplements on bone mineral density: a systematic review and meta-analysis. Lancet. 2014;383(9912):146-155. Exclusion code: 3. [pmid: 24119980].
Saliba W, Barnett O, Rennert HS, Rennert G. The risk of all-cause mortality is inversely related to serum 25(OH)D levels. J Clin Endocrinol Metab. 2012;97(8):2792-2798. Exclusion code: 3. [pmid: 22648653].
Sattar N, Welsh P, Panarelli M, Forouhi NG. Increasing requests for vitamin D measurement: costly, confusing, and without credibility. Lancet. 2012;379(9811):95-96. Exclusion code: 8. [pmid: 22243814].
Sawka AM, Ismaila N, Cranney A, et al. A scoping review of strategies for the prevention of hip fracture in elderly nursing home residents. PLoS One. 2010;5(3). Exclusion code: 13.
Schaller F, Sidelnikov E, Theiler R, et al. Mild to moderate cognitive impairment is a major risk factor for mortality and nursing home admission in the first year after hip fracture. Bone. 2012;51(3):347-352. Exclusion code: 5. [pmid: 22705148].
Schwendimann R, Milisen K, Buhler H, De Geest S. Fall prevention in a Swiss acute care hospital setting Reducing multiple falls. J Gerontol Nurs. 2006;32(3):13-22. Exclusion code: 5. [pmid: 16544453].
Shao T, Klein P, Grossbarda ML. Vitamin D and breast cancer. Oncologist. 2012;17(1):36-45. Exclusion code: 13. [pmid: 22234628].
Song Y, Wang L, Pittas AG, et al. Blood 25-hydroxy vitamin D levels and incident type 2 diabetes: A meta-analysis of prospective studies. Diabetes Care. 2013;36(5):1422-1428. Exclusion code: 3. [pmid: 23613602].
Szulc P, Duboeuf F, Marchand F, Delmas PD. Hormonal and lifestyle determinants of appendicular skeletal muscle mass in men: the MINOS study. Am J Clin Nutr. 2004;80(2):496-503. Exclusion code: 7. [pmid: 15277176].
Tideiksaar R, Feiner CF, Maby J. Falls prevention: the efficacy of a bed alarm system in an acute-care setting. Mt Sinai J Med. 1993;60(6):522-527. Exclusion code: 5. [pmid: 8121429].
Vassallo M, Vignaraja R, Sharma JC, et al. The effect of changing practice on fall prevention in a rehabilitative hospital: the Hospital Injury Prevention Study. J Am Geriatr Soc. 2004;52(3):335-339. Exclusion code: 5. [pmid: 14962145].
Vieth R. Enzyme kinetics hypothesis to explain the U-shaped risk curve for prostate cancer vs. 25-hydroxyvitamin D in Nordic countries [1]. Int J Cancer. 2004;111(3):468. Exclusion code: 8. [pmid: 15221979].
Wolpin BM, Ng K, Bao Y, et al. Plasma 25-hydroxyvitamin D and risk of pancreatic cancer. Cancer Epidemiol Biomarkers Prev. 2012;21(1):82-91. Exclusion code: 3. [pmid: 22086883].
Yao SG, Fine JB. A review of vitamin D as it relates to periodontal disease. Compendium of continuing education in dentistry (Jamesburg, N.J. : 1995). 2012;33(3):166-171. quiz 172, 182. Exclusion code: 8.
Zhao G, Ford ES, Li C. Associations of serum concentrations of 25-hydroxyvitamin D and parathyroid hormone with surrogate markers of insulin resistance among U.S. adults without physician-diagnosed diabetes: NHANES, 2003-2006. Diabetes Care. 2010;33(2):344-347. Exclusion code: 7. [pmid: 19846799].
Check your vitamin D intake to avoid multiple health consequences. Three 2008 studies link low vitamin D levels to depression, hip fractures, and increased risk of death. Duke Med Health News. 2008;14(11):9-10. Exclusion code: 8.
Do low vitamin D levels increase risk for hip fracture?. [Original report in Ann Intern Med. 2008 Aug 19; 149(4):242-50; PMID: 18711154]. Ann Intern Med. 4. 2008;149:I42. Exclusion code: 8. [pmid: 18711151].
Extra vitamin D may keep you mobile in later years. Harv Health Lett. 2012;37(10):8. Exclusion code: 8.
Abbas S, Chang-Claude J, Linseisen J. Plasma 25-hydroxyvitamin D and premenopausal breast cancer risk in a German case-control study. Int J Cancer. 2009;124(1):250-255. Exclusion code: 6. [pmid: 18839430].
Abbas S, Linseisen J, Chang-Claude J. Dietary vitamin D and calcium intake and premenopausal breast cancer risk in a German case-control study. Nutr Cancer. 2007;59(1):54-61. Exclusion code: 7. [pmid: 17927502].
Abbas S, Linseisen J, Slanger T, et al. The Gc2 allele of the vitamin D binding protein is associated with a decreased postmenopausal breast cancer risk, independent of the vitamin D status. Cancer Epidemiol Biomarkers Prev. 2008;17(6):1339-1343. Exclusion code: 6. [pmid: 18559548].
Abbas S, Linseisen J, Slanger T, et al. Serum 25-hydroxyvitamin D and risk of post-menopausal breast cancer--results of a large case-control study. Carcinogenesis. 2008;29(1):93-99. Exclusion code: 6. [pmid: 17974532].
Abbas S, Nieters A, Linseisen J, et al. Vitamin D receptor gene polymorphisms and haplotypes and postmenopausal breast cancer risk. Breast Cancer Res. 2008;10(2):R31. Exclusion code: 6. [pmid: 18419802].
Abbasi M, Hashemipour S, Hajmanuchehri F, Kazemifar AM. Is vitamin D deficiency associated with non specific musculoskeletal pain?. Glob J Health Sci. 2013;5(1):107-111. Exclusion code: 4. [pmid: 23985112].
Abnet CC, Chen W, Dawsey SM, et al. Serum 25(OH)-vitamin D concentration and risk of esophageal squamous dysplasia. Cancer Epidemiol Biomarkers Prev. 2007;16(9):1889-1893. Exclusion code: 7. [pmid: 17855710].
Abnet CC, Chen Y, Chow W-H, et al. Circulating 25-hydroxyvitamin D and risk of esophageal and gastric cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):94-106. Exclusion code: 4. [pmid: 20562192].
Abrams SA, Hicks PD, Hawthorne KM. Higher serum 25-hydroxyvitamin D levels in school-age children are inconsistently associated with increased calcium absorption. J Clin Endocrinol Metab. 2009;94(7):2421-2427. Exclusion code: 4. [pmid: 19383779].
Abu-Mouch S, Fireman Z, Jarchovsky J, Zeina AR, Assy N. Vitamin D supplementation improves sustained virologic response in chronic hepatitis C (genotype 1)-naive patients. World J Gastroenterol. 2011;17(47):5184-5190. Exclusion code: 6. [pmid: 22215943].
Adams JS, Hewison M. Hypercalcemia caused by granuloma-forming disorders. Primer on the Metabolic Bone Diseases and Disorders of Mineral Metabolism. 6 ed. Washington, D.C. American Society for Bone and Mineral Research. 2006:200-202. Exclusion code: 8.
Adams JS, Lee G. Gains in bone mineral density with resolution of vitamin D intoxication. Ann Intern Med. 1997;127(3):203-206. Exclusion code: 15. [pmid: 9245225].
Adams JS, Modlin RL, Diz MM, Barnes PF. Potentiation of the macrophage 25-hydroxyvitamin D-1-hydroxylation reaction by human tuberculous pleural effusion fluid. J Clin Endocrinol Metab. 1989;69(2):457-460. Exclusion code: 4. [pmid: 2502557].
Agborsangaya CB, Surcel HM, Toriola AT, et al. Serum 25-hydroxyvitamin D at pregnancy and risk of breast cancer in a prospective study. Eur J Cancer. 2010;46(3):467-470. Exclusion code: 4. [pmid: 20022237].
Ahn J, Peters U, Albanes D, et al. Serum vitamin D concentration and prostate cancer risk: a nested case-control study. J Natl Cancer Inst. 2008;100(11):796-804. Exclusion code: 7. [pmid: 18505967].
Ahonen MH, Tenkanen L, Teppo L, Hakama M, Tuohimaa P. Prostate cancer risk and prediagnostic serum 25-hydroxyvitamin D levels (Finland). Cancer Causes Control. 2000;11(9):847-852. Exclusion code: 3. [pmid: 11075874].
Akhter N, Sinnott B, Mahmood K, Rao S, Kukreja S, Barengolts E. Effects of vitamin D insufficiency on bone mineral density in African American men. Osteoporos Int. 2009;20(5):745-750. Exclusion code: 6. [pmid: 18820989].
Aksnes L, Aarskog D. Plasma concentrations of vitamin D metabolites in puberty: Effect of sexual maturation and implications for growth. J Clin Endocrinol Metab. 1982;55(1):94-101. Exclusion code: 4. [pmid: 6978890].
Ala-Houhala M, Koskinen T, Koskinen M, Visakorpi JK. Double blind study on the need for vitamin D supplementation in prepubertal children. Acta Paediatr Scand. 1988;77(1):89-93. Exclusion code: 4. [pmid: 3285637].
Albanes D, Mondul AM, Yu K, et al. Serum 25-hydroxy vitamin D and prostate cancer risk in a large nested case-control study. Cancer Epidemiol Biomarkers Prev. 2011;20(9):1850-1860. Exclusion code: 4. [pmid: 21784952].
Al-Delaimy WK, Rimm E, Willett WC, Stampfer MJ, Hu FB. A prospective study of calcium intake from diet and supplements and risk of ischemic heart disease among men. Am J Clin Nutr. 2003;77(4):814-818. Exclusion code: 5. [pmid: 12663277].
Alele JD, Luttrell LM, Hollis BW, Luttrell DK, Hunt KJ, Group VS. Relationship between vitamin D status and incidence of vascular events in the Veterans Affairs Diabetes Trial. Atherosclerosis. 2013;228(2):502-507. Exclusion code: 4. [pmid: 23608249].
Allali F, El Aichaoui S, Saoud B, Maaroufi H, Abouqal R, Hajjaj-Hassouni N. The impact of clothing style on bone mineral density among post menopausal women in Morocco: a case-control study. BMC Public Health. 2006;6:135. Exclusion code: 5. [pmid: 16712731].
Allen SH, Shah JH. Calcinosis and metastatic calcification due to vitamin D intoxication. A case report and review. Horm Res. 1992;37(1-2):68-77. Exclusion code: 7. [pmid: 1398478].
Almquist M, Bondeson AG, Bondeson L, Malm J, Manjer J. Serum levels of vitamin D, PTH and calcium and breast cancer risk-a prospective nested case-control study. Int J Cancer. 2010;127(9):2159-2168. Exclusion code: 6. [pmid: 20112341].
Al-oanzi ZH, Tuck SP, Raj N, et al. Assessment of vitamin D status in male osteoporosis. Clin Chem. 2006;52(2):248-254. Exclusion code: 7. [pmid: 16339300].
Aloia J, Bojadzievski T, Yusupov E, et al. The relative influence of calcium intake and vitamin D status on serum parathyroid hormone and bone turnover biomarkers in a double-blind, placebo-controlled parallel group, longitudinal factorial design. J Clin Endocrinol Metab. 2010;95(7):3216-3224. Exclusion code: 15. [pmid: 20463100].
Aloia JF. African Americans, 25-hydroxyvitamin D, and osteoporosis: a paradox. Am J Clin Nutr. 2008;88(2):545S-550S. Exclusion code: 2. [pmid: 18689399].
Aloia JF, Dhaliwal R, Shieh A, et al. Vitamin D supplementation increases calcium absorption without a threshold effect. Am J Clin Nutr. 2013. Exclusion code: 15.
Aloia JF, Li-Ng M. Re: epidemic influenza and vitamin D. Epidemiol Infect. 2007;135(7):1095-1096. author reply 1097-1098. Exclusion code: 8. [pmid: 17352842].
Aloia JF, Talwar SA, Pollack S, Feuerman M, Yeh JK. Optimal vitamin D status and serum parathyroid hormone concentrations in African American women. Am J Clin Nutr. 2006;84(3):602-609. Exclusion code: 6. [pmid: 16960175].
Aloia JF, Vaswani A, Yeh JK, Ellis K, Yasumura S, Cohn SH. Calcitriol in the treatment of postmenopausal osteoporosis. Am J Med. 1988;84(3 PART 1):401-408. Exclusion code: 4. [pmid: 3279769].
Aloia JF, Vaswani A, Yeh JK, Ross PL, Flaster E, Dilmanian FA. Calcium supplementation with and without hormone replacement therapy to prevent postmenopausal bone loss. Ann Intern Med. 1994;120(2):97-103. Exclusion code: 5. [pmid: 8256988].
American Society for Clinical Pathology. Choosing Wisely. Chicago, IL. 2012. Exclusion code: 2.
Amir E, Cecchini RS, Ganz PA, et al. 25-Hydroxy vitamin-D, obesity, and associated variables as predictors of breast cancer risk and tamoxifen benefit in NSABP-P1. Breast Cancer Res Treat. 2012;133(3):1077-1088. Exclusion code: 4. [pmid: 22415479].
Amir E, Simmons CE, Freedman OC, et al. A phase 2 trial exploring the effects of high-dose (10,000 IU/day) vitamin D(3) in breast cancer patients with bone metastases. Cancer. 2010;116(2):284-291. Exclusion code: 4. [pmid: 19918922].
Amrein K, Sourij H, Wagner G, et al. Short-term effects of high-dose oral vitamin D3 in critically ill vitamin D deficient patients: a randomized, double-blind, placebo-controlled pilot study. Crit Care. 2011;15(2):R104. Exclusion code: 4. [pmid: 21443793].
Andersen R, Brot C, Mejborn H, et al. Vitamin D supplementation does not affect serum lipids and lipoproteins in Pakistani immigrants. Eur J Clin Nutr. 2009;63(9):1150-1153. Exclusion code: 3. [pmid: 19352377].
Andersen R, Molgaard C, Skovgaard LT, et al. Effect of vitamin D supplementation on bone and vitamin D status among Pakistani immigrants in Denmark: a randomised double-blinded placebo-controlled intervention study. Br J Nutr. 2008;100(1):197-207. Exclusion code: 2. [pmid: 18208636].
Anderson F, Smith H, Raphael H, et al. Effect of annual intramuscular vitamin D3 supplementation on fracture risk in 9440 community-living older people: the Wessex fracture prevention trial. [Abstract]. J Bone Miner Res. 2004;19(S1):S2-S58. Exclusion code: 7. [pmid: 15505937].
Anderson JL, May HT, Horne BD, et al. Relation of vitamin D deficiency to cardiovascular risk factors, disease status, and incident events in a general healthcare population. Am J Cardiol. 2010;106(7):963-968. Exclusion code: 3. [pmid: 20854958].
Anderson LN, Cotterchio M, Vieth R, Knight JA. Vitamin D and calcium intakes and breast cancer risk in pre- and postmenopausal women. Am J Clin Nutr. 2010;91(6):1699-1707. Exclusion code: 5. [pmid: 20392891].
Anglin RES, Samaan Z, Walter SD, McDonald SD. Vitamin D deficiency and depression in adults: systematic review and meta-analysis. Br J Psychiatry. 2013;202:100-107. Exclusion code: 13. [pmid: 23377209].
Annweiler C, Allali G, Allain P, et al. Vitamin D and cognitive performance in adults: a systematic review. Eur J Neurol. 2009;16(10):1083-1089. Exclusion code: 7. [pmid: 19659751].
Annweiler C, Montero-Odasso M, Hachinski V, Seshadri S, Bartha R, Beauchet O. Vitamin D concentration and lateral cerebral ventricle volume in older adults. Mol Nutr Food Res. 2013;57(2):267-276. Exclusion code: 7. [pmid: 23281306].
Annweiler C, Schott AM, Berrut G, Fantino B, Beauchet O. Vitamin D-related changes in physical performance: a systematic review. J Nurt Health Aging. 2009;13(10):893-898. Exclusion code: 13.
Annweiler C, Schott AM, Montero-Odasso M, et al. Cross-sectional association between serum vitamin D concentration and walking speed measured at usual and fast pace among older women: the EPIDOS study. J Bone Miner Res. 2010;25(8):1858-1866. Exclusion code: 7. [pmid: 20205167].
Arden NK, Crozier S, Smith H, et al. Knee pain, knee osteoarthritis, and the risk of fracture. Arthritis Rheum. 2006;55(4):610-615. Exclusion code: 5. [pmid: 16874784].
Aregbesola A, Voutilainen S, Nurmi T, Virtanen JK, Ronkainen K, Tuomainen TP. Serum 25-hydroxyvitamin D3 and the risk of pneumonia in an ageing general population. J Epidemiol Community Health. 2013;67(6):533-536. Exclusion code: 3. [pmid: 23596250].
Armas LAG, Hollis BW, Heaney RP. Vitamin D2 is much less effective than vitamin D3 in humans. J Clin Endocrinol Metab. 2004;89(11):5387-5391. Exclusion code: 10. [pmid: 15531486].
Arthur RS, Piraino B, Candib D, et al. Effect of low-dose calcitriol and calcium therapy on bone histomorphometry and urinary calcium excretion in osteopenic women. Miner Electrolyte Metab. 1990;16(6):385-390. Exclusion code: 4. [pmid: 2089252].
Autier P, Boniol M, Pizot C, Mullie P. Vitamin D status and ill health: a systematic review. Lancet Diabetes Endocrinol. 2014;2(1):76-89. Exclusion code: 2. [pmid: 24622671].
Autier P, Gandini S. Vitamin D supplementation and total mortality: A meta-analysis of randomized controlled trials. Arch Intern Med. 2007;167(16):1730-1737. Exclusion code: 13. [pmid: 17846391].
Avenell A, Cook JA, Maclennan GS, Macpherson GC. Vitamin D supplementation to prevent infections: a sub-study of a randomised placebo-controlled trial in older people (RECORD trial, ISRCTN 51647438). Age Ageing. 2007;36(5):574-577. Exclusion code: 14. [pmid: 17702768].
Avenell A, Cook JA, MacLennan GS, McPherson GC, group Rt. Vitamin D supplementation and type 2 diabetes: a substudy of a randomised placebo-controlled trial in older people (RECORD trial, ISRCTN 51647438). Age Ageing. 2009;38(5):606-609. Exclusion code: 14. [pmid: 19617604].
Avenell A, Gillespie WJ, Gillespie LD, O'Connell D. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database Syst Rev. 2009;(4). Exclusion code: 13.
Avenell A, Gillespie WJ, Gillespie LD, O'Connell DL. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane database of systematic reviews (Online). 2005;(3). Exclusion code: 13.
Avenell A, Grant AM, McGee M, McPherson G, Campbell MK, McGee MA. The effects of an open design on trial participant recruitment, compliance and retention--a randomized controlled trial comparison with a blinded, placebo-controlled design. Clin Trials. 2004;1(6):490-498. Exclusion code: 6. [pmid: 16279289].
Avenell A, MacLennan GS, Jenkinson DJ, et al. Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). J Clin Endocrinol Metab. 2012;97(2):614-622. Exclusion code: 14. [pmid: 22112804].
Avenell A, Mak CSJ, O'Connell D. Vitamin D and vitamin D analogues for preventing fractures in post-menopausal women and older men. Cochrane Database Syst Rev. 2014;(4). Exclusion code: 13.
Bacon CJ, Gamble GD, Horne AM, Scott MA, Reid IR. High-dose oral vitamin D3 supplementation in the elderly. Osteoporos Int. 2009;20(8):1407-1415. Exclusion code: 12. [pmid: 19101755].
Baeksgaard L, Andersen KP, Hyldstrup L. Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int. 1998;8(3):255-260. Exclusion code: 14. [pmid: 9797910].
Bailey BA, Manning T, Peiris AN. Vitamin D testing patterns among six Veterans Medical Centers in the southeastern United States: links with medical costs. Mil Med. 2012;177(1):70-76. Exclusion code: 6. [pmid: 22338984].
Bailey BA, Manning T, Peiris AN. The impact of living in rural and urban areas: vitamin D and medical costs in veterans. J Rural Health. 2012;28(4):356-363. Exclusion code: 6. [pmid: 23017006].
Bair TL, May HT, Horne BD, et al. Abstract 1147: Vitamin D Deficiency is Strongly Associated With Incident Death and Cardiovascular Disease in a General Healthcare Population. American Heart Association 2009 Annual Meeting Abstract 1147 (Circulation). 2009;120:S455. Exclusion code: 8.
Baker MR, McDonnell H, Peacock M, Nordin BEC. Plasma 25-hydroxy vitamin D concentrations in patients with fractures of the femoral neck. Br Med J. 1979;1(6163):589. Exclusion code: 7. [pmid: 427455].
Bakhtiyarova S, Lesnyak O, Kyznesova N, Blankenstein MA, Lips P. Vitamin D status among patients with hip fracture and elderly control subjects in Yekaterinburg, Russia. Osteoporos Int. 2006;17(3):441-446. Exclusion code: 7. [pmid: 16328605].
Bao Y, Ng K, Wolpin BM, Michaud DS, Giovannucci E, Fuchs CS. Predicted vitamin D status and pancreatic cancer risk in two prospective cohort studies. Br J Cancer. 2010;102(9):1422-1427. Exclusion code: 14. [pmid: 20389298].
Barbour KE, Houston DK, Cummings SR, et al. Calciotropic hormones and the risk of hip and nonspine fractures in older adults: The health ABC study. J Bone Miner Res. 2012;27(5):1177-1185. Exclusion code: 3. [pmid: 22228250].
Barger-Lux MJ, Heaney RP, Dowell S, Chen TC, Holick MF. Vitamin D and its major metabolites: serum levels after graded oral dosing in healthy men. Osteoporos Int. 1998;8(3):222-230. Exclusion code: 12. [pmid: 9797906].
Barnes MS, Horigan G, Cashman KD, et al. Maintenance of wintertime vitamin D status with cholecalciferol supplementation is not associated with alterations in serum cytokine concentrations among apparently healthy younger or older adults. J Nutr. 2011;141(3):476-481. Exclusion code: 6. [pmid: 21270359].
Barnes MS, Robson PJ, Bonham MP, Strain JJ, Wallace JMW. Effect of vitamin D supplementation on vitamin D status and bone turnover markers in young adults. Eur J Clin Nutr. 2006;60(6):727-733. Exclusion code: 15. [pmid: 16391584].
Barnett CM, Nielson CM, Shannon J, et al. Serum 25-OH vitamin D levels and risk of developing prostate cancer in older men. Cancer Causes and Control. 2010;21(8):1297-1303. Exclusion code: 3. [pmid: 20383574].
Baron JA, Beach M, Wallace K, et al. Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev. 2005;14(3):586-589. Exclusion code: 5. [pmid: 15767334].
Barrett-Connor E, Laughlin GA, Li H, et al. The association of concurrent vitamin D and sex hormone deficiency with bone loss and fracture risk in older men: The osteoporotic fractures in men (MrOS) study. J Bone Miner Res. 2012;27(11):2306-2313. Exclusion code: 3. [pmid: 22777902].
Basile LA, Taylor SN, Wagner CL, Horst RL, Hollis BW. The effect of high-dose vitamin D supplementation on serum vitamin D levels and milk calcium concentration in lactating women and their infants. Breastfeed Med. 2006;1(1):27-35. Exclusion code: 4. [pmid: 17661558].
Bates CJ, Hamer M, Mishra GD. A study of relationships between bone-related vitamins and minerals, related risk markers, and subsequent mortality in older British people: the National Diet and Nutrition Survey of People Aged 65 Years and Over. Osteoporos Int. 2012;23(2):457-466. Exclusion code: 14. [pmid: 21380638].
Battault S, Whiting SJ, Peltier SL, Sadrin S, Gerber G, Maixent JM. Vitamin D metabolism, functions and needs: from science to health claims. Eur J Nutr. 2013;52(2):429-441. Exclusion code: 7. [pmid: 22886046].
Becker C, Kron M, Lindemann U, et al. Effectiveness of a multifaceted intervention on falls in nursing home residents. J Am Geriatr Soc. 2003;51(3):306-313. Exclusion code: 5. [pmid: 12588573].
Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-1101. Exclusion code: 6. [pmid: 7786990].
Beilfuss J, Berg V, Sneve M, Jorde R, Kamycheva E. Effects of a 1-year supplementation with cholecalciferol on interleukin-6, tumor necrosis factor-alpha and insulin resistance in overweight and obese subjects. Cytokine. 2012;60(3):870-874. Exclusion code: 15. [pmid: 22925537].
Belderbos ME, Houben ML, Wilbrink B, et al. Cord blood vitamin D deficiency is associated with respiratory syncytial virus bronchiolitis. Pediatrics. 2011;127(6):e1513-e1520. Exclusion code: 4. [pmid: 21555499].
Bell NH. 25-Hydroxyvitamin D3 reverses alteration of the vitamin D-endocrine system in blacks. Am J Med. 1995;99(6):597-599. Exclusion code: 6. [pmid: 7503080].
Bener A, El Ayoubi HR. The role of vitamin D deficiency and osteoporosis in breast cancer. Int J Rheum Dis. 2012;15(6):554-561. Exclusion code: 7. [pmid: 23253239].
Berggren M, Stenvall M, Olofsson B, Gustafson Y. Evaluation of a fall-prevention program in older people after femoral neck fracture: a one-year follow-up. Osteoporos Int. 2008;19(6):801-809. Exclusion code: 4. [pmid: 18030411].
Bergink AP, Uitterlinden AG, Van Leeuwen JPTM, et al. Vitamin D status, bone mineral density, and the development of radiographic osteoarthritis of the knee: The Rotterdam Study. JCR. 2009;15(5):230-237. Exclusion code: 3. [pmid: 19654490].
Berlin T, Bjorkhem I. Lack of effects of an increased pool of 25-hydroxyvitamin D3 on urinary excretion of calcium in healthy subjects. Contrib Nephrol. 1987;58:143-147. Exclusion code: 6. [pmid: 2826077].
Berry DJ, Hesketh K, Power C, Hypponen E. Vitamin D status has a linear association with seasonal infections and lung function in British adults. Br J Nutr. 2011;106(9):1433-1440. Exclusion code: 6. [pmid: 21736791].
Bertone-Johnson ER. Prospective studies of dietary vitamin D and breast cancer: More questions raised than answered. Nutr Rev. 2007;65(10):459-466. Exclusion code: 13. [pmid: 17972440].
Bertone-Johnson ER, Chen WY, Holick MF, et al. Plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D and risk of breast cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(8):1991-1997. Exclusion code: 3. [pmid: 16103450].
Bertone-Johnson ER, Powers SI, Spangler L, et al. Vitamin D supplementation and depression in the women's health initiative calcium and vitamin D trial. Am J Epidemiol. 2012;176(1):1-13. Exclusion code: 14. [pmid: 22573431].
Bhan A, Rao A, Rao D. Osteomalacia as a result of vitamin D deficiency. Endocrinol Metab Clin North Am. 2010;39(2):321. Exclusion code: 2. [pmid: 20511054].
Biancuzzo RM, Clarke N, Reitz RE, Travison TG, Holick MF. Serum concentrations of 1,25-dihydroxyvitamin D2 and 1,25-dihydroxyvitamin D3 in response to vitamin D2 and vitamin D3 supplementation. J Clin Endocrinol Metab. 2013;98(3):973-979. Exclusion code: 6. [pmid: 23386645].
Biancuzzo RM, Young A, Bibuld D, et al. Fortification of orange juice with vitamin D(2) or vitamin D(3) is as effective as an oral supplement in maintaining vitamin D status in adults. Am J Clin Nutr. 2010;91(6):1621-1626. Exclusion code: 6. [pmid: 20427729].
Biesalski HK, Aggett PJ, Anton R, et al. 26th Hohenheim Consensus Conference, September 11, 2010 Scientific substantiation of health claims: evidence-based nutrition. Nutrition. 2011;27(10 Suppl):S1-20. Exclusion code: 8. [pmid: 21700425].
Bilinski K, Boyages J. Association between 25-hydroxyvitamin D concentration and breast cancer risk in an Australian population: an observational case-control study. Breast Cancer Res Treat. 2013;137(2):599-607. Exclusion code: 7. [pmid: 23239153].
Binet A, Kooh SW. Persistence of vitamin D-deficiency rickets in Toronto in the 1990s. Can J Public Health. 1996;87(4):227-230. Exclusion code: 4. [pmid: 8870299].
Bischoff-Ferarri HA, Willett WC, Orav EJ, Kiel DP, Dawson-Hughes B. Re: Fall prevention with Vitamin D. Author's reply. BMJ. 2011;342. Exclusion code: 8.
Bischoff-Ferrari H. Vitamin D: what is an adequate vitamin D level and how much supplementation is necessary?. Best Pract Res Clin Rheumatol. 2009;23(6):789-795. Exclusion code: 7. [pmid: 19945690].
Bischoff-Ferrari H. Health effects of vitamin D. Dermatol Ther. 2010;23(1):23-30. Exclusion code: 7. [pmid: 20136906].
Bischoff-Ferrari HA. Optimal serum 25-hydroxyvitamin D levels for multiple health outcomes. Adv Exp Med Biol. 2008;624:55-71. Exclusion code: 8. [pmid: 18348447].
Bischoff-Ferrari HA. Relevance of vitamin D in muscle health. Rev Endocr Metab Disord. 2012;13(1):71-77. Exclusion code: 8. [pmid: 22020957].
Bischoff-Ferrari HA, Borchers M, Gudat F, Durmuller U, Stahelin HB, Dick W. Vitamin D receptor expression in human muscle tissue decreases with age. J Bone Miner Res. 2004;19(2):265-269. Exclusion code: 4. [pmid: 14969396].
Bischoff-Ferrari HA, Conzelmann M, Stahelin HB, et al. Is fall prevention by vitamin D mediated by a change in postural or dynamic balance?. Osteoporos Int. 2006;17(5):656-663. Exclusion code: 3. [pmid: 16508700].
Bischoff-Ferrari HA, Dawson-Hughes B, Baron JA, et al. Calcium intake and hip fracture risk in men and women: a meta-analysis of prospective cohort studies and randomized controlled trials. Am J Clin Nutr. 2007;86(6):1780-1790. Exclusion code: 5. [pmid: 18065599].
Bischoff-Ferrari HA, Dawson-Hughes B, Platz A, et al. Effect of high-dosage cholecalciferol and extended physiotherapy on complications after hip fracture: a randomized controlled trial. Arch Intern Med. 2010;170(9):813-820. Exclusion code: 4. [pmid: 20458090].
Bischoff-Ferrari HA, Dawson-Hughes B, Staehelin HB, et al. Fall prevention with supplemental and active forms of vitamin D: a meta-analysis of randomised controlled trials. Br Med J (Clin Res Ed). 2009;339. Exclusion code: 13.
Bischoff-Ferrari HA, Dawson-Hughes B, Stocklin E, et al. Oral supplementation with 25(OH)D3 versus vitamin D3: effects on 25(OH)D levels, lower extremity function, blood pressure, and markers of innate immunity. J Bone Miner Res. 2012;27(1):160-169. Exclusion code: 12. [pmid: 22028071].
Bischoff-Ferrari HA, Dawson-Hughes B, Willett WC, et al. Effect of Vitamin D on falls: a meta-analysis. JAMA. 2004;291(16):1999-2006. Exclusion code: 13. [pmid: 15113819].
Bischoff-Ferrari HA, Dietrich T, Orav EJ, Dawson-Hughes B. Positive association between 25-hydroxy vitamin D levels and bone mineral density: A population-based study of younger and older adults. Am J Med. 2004;116(9):634-639. Exclusion code: 6. [pmid: 15093761].
Bischoff-Ferrari HA, Dietrich T, Orav EJ, et al. Higher 25-hydroxyvitamin D concentrations are associated with better lower-extremity function in both active and inactive persons aged > or =60 y. Am J Clin Nutr. 2004;80(3):752-758. Exclusion code: 7. [pmid: 15321818].
Bischoff-Ferrari HA, Giovannucci E, Willett WC, Dietrich T, Dawson-Hughes B. Estimation of optimal serum concentrations of 25-hydroxyvitamin D for multiple health outcomes. Am J Clin Nutr. 2006;84(1):18-28. Exclusion code: 2. [pmid: 16825677].
Bischoff-Ferrari HA, Kiel DP, Dawson-Hughes B, et al. Dietary calcium and serum 25-hydroxyvitamin D status in relation to BMD among U.S. adults. J Bone Miner Res. 2009;24(5):935-942. Exclusion code: 7. [pmid: 19113911].
Bischoff-Ferrari HA, Orav EJ, Dawson-Hughes B. Effect of cholecalciferol plus calcium on falling in ambulatory older men and women: a 3-year randomized controlled trial. Arch Intern Med. 2006;166(4):424-430. Exclusion code: 15. [pmid: 16505262].
Bischoff-Ferrari HA, Shao A, Dawson-Hughes B, Hathcock J, Giovannucci E, Willett WC. Benefit-risk assessment of vitamin D supplementation. Osteoporos Int. 2010;21(7):1121-1132. Exclusion code: 7. [pmid: 19957164].
Bischoff-Ferrari HA, Willett WC, Orav EJ, et al. A pooled analysis of vitamin D dose requirements for fracture prevention. N Engl J Med. 2012;367(1):40-49. Exclusion code: 13. [pmid: 22762317].
Bischoff-Ferrari HA, Willett WC, Wong JB, Giovannucci E, Dietrich T, Dawson-Hughes B. Fracture prevention with vitamin D supplementation: a meta-analysis of randomized controlled trials. JAMA. 2005;293(18):2257-2264. Exclusion code: 13. [pmid: 15886381].
Bischoff-Ferrari HA, Willett WC, Wong JB, et al. Prevention of nonvertebral fractures with oral vitamin D and dose dependency: A meta-analysis of randomized controlled trials. Arch Intern Med. 2009;169(6):551-561. Exclusion code: 13. [pmid: 19307517].
Bischoff-Ferrari HA, Zhang Y, Kiel DP, Felson DT. Positive association between serum 25-hydroxyvitamin D level and bone density in osteoarthritis. Arthritis Rheum. 2005;53(6):821-826. Exclusion code: 4. [pmid: 16342101].
Bjelakovic G, Gluud LL, Nikolova D, et al. Vitamin D supplementation for prevention of mortality in adults. Cochrane Database Syst Rev. 2011;(8). Exclusion code: 13.
Bjelakovic G, Gluud LL, Nikolova D, et al. Vitamin D supplementation for prevention of mortality in adults. Cochrane Database Syst Rev. 2014;(1). Exclusion code: 13.
Bjorkman M, Sorva A, Risteli J, Tilvis R. Vitamin D supplementation has minor effects on parathyroid hormone and bone turnover markers in vitamin D-deficient bedridden older patients. Age Ageing. 2008;37(1):25-31. Exclusion code: 4. [pmid: 17965037].
Bjorkman M, Sorva A, Tilvis R. Vitamin D supplementation has no major effect on pain or pain behavior in bedridden geriatric patients with advanced dementia. Aging Clin Exp Res. 2008;20(4):316-321. Exclusion code: 6. [pmid: 18852544].
Bjorkman MP, Sorva AJ, Tilvis RS. C-reactive protein and fibrinogen of bedridden older patients in a six-month vitamin D supplementation trial. J Nutr Health Aging. 2009;13(5):435-439. Exclusion code: 6. [pmid: 19390750].
Blicher TM, Jorgensen HL, Schwarz P, Wulf HC. Low levels of vitamin D are associated with increased mortality in patients attending a university hospital in Denmark. Scand J Clin Lab Invest. 2013;73(1):24-28. Exclusion code: 4. [pmid: 23190364].
Blum M, Dolnikowski G, Seyoum E, et al. Vitamin D(3) in fat tissue. Endocrine. 2008;33(1):90-94. Exclusion code: 5. [pmid: 18338271].
Bodnar LM, Catov JM, Simhan HN, Holick MF, Powers RW, Roberts JM. Maternal vitamin D deficiency increases the risk of preeclampsia. J Clin Endocrinol Metab. 2007;92(9):3517-3522. Exclusion code: 4. [pmid: 17535985].
Bodnar LM, Catov JM, Zmuda JM, et al. Maternal serum 25-hydroxyvitamin D concentrations are associated with small-for-gestational age births in white women. J Nutr. 2010;140(5):999-1006. Exclusion code: 4. [pmid: 20200114].
Bodnar LM, Krohn MA, Simhan HN. Maternal vitamin D deficiency is associated with bacterial vaginosis in the first trimester of pregnancy. J Nutr. 2009;139(6):1157-1161. Exclusion code: 4. [pmid: 19357214].
Bodnar LM, Simhan HN, Powers RW, Frank MP, Cooperstein E, Roberts JM. High prevalence of vitamin D insufficiency in black and white pregnant women residing in the northern United States and their neonates. J Nutr. 2007;137(2):447-452. Exclusion code: 4. [pmid: 17237325].
Bogh MKB, Gullstrand J, Svensson A, Ljunggren B, Dorkhan M. Narrowband ultraviolet B three times per week is more effective in treating vitamin D deficiency than 1600 IU oral vitamin D3 per day: a randomized clinical trial. Br J Dermatol. 2012;167(3):625-630. Exclusion code: 12. [pmid: 22632734].
Boland R. Role of vitamin D in skeletal muscle function. Endocr Rev. 1986;7(4):434-448. Exclusion code: 8. [pmid: 3536463].
Bolland MJ, Avenell A, Baron JA, et al. Effect of calcium supplements on risk of myocardial infarction and cardiovascular events: meta-analysis. BMJ. 2010;341:c3691. Exclusion code: 5. [pmid: 20671013].
Bolland MJ, Barber PA, Doughty RN, et al. Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ. 2008;336(7638):262-266. Exclusion code: 5. [pmid: 18198394].
Bolland MJ, Grey A, Avenell A, Gamble GD, Reid IR. Calcium supplements with or without vitamin D and risk of cardiovascular events: Reanalysis of the Women's Health Initiative limited access dataset and meta-analysis. BMJ. 2011;342(7804). Exclusion code: 14.
Bolland MJ, Grey A, Gamble GD, Reid IR. Calcium and vitamin D supplements and health outcomes: a reanalysis of the Women's Health Initiative (WHI) limited-access data set. Am J Clin Nutr. 2011;94(4):1144-1149. Exclusion code: 14. [pmid: 21880848].
Bolland MJ, Grey A, Gamble GD, Reid IR. The effect of vitamin D supplementation on skeletal, vascular, or cancer outcomes: a trial sequential meta-analysis. Lancet Diabetes Endocrinol. 2014. Exclusion code: 2.
Bonjour JP, Benoit V, Pourchaire O, Rousseau B, Souberbielle JC. Nutritional approach for inhibiting bone resorption in institutionalized elderly women with vitamin D insufficiency and high prevalence of fracture. J Nurt Health Aging. 2011;15(5):404-409. Exclusion code: 10.
Boonen S, Broos P, Verbeke G, et al. Calciotropic hormones and markers of bone remodeling in age-related (type II) femoral neck osteoporosis: alterations consistent with secondary hyperparathyroidism-induced bone resorption. J Gerontol A Biol Sci Med Sci. 1997;52(5):M286-293. Exclusion code: 7. [pmid: 9310082].
Boonen S, Lips P, Bouillon R, Bischoff-Ferrari HA, Vanderschueren D, Haentjens P. Need for additional calcium to reduce the risk of hip fracture with vitamin d supplementation: evidence from a comparative metaanalysis of randomized controlled trials. J Clin Endocrinol Metab. 2007;92(4):1415-1423. Exclusion code: 14. [pmid: 17264183].
Boonen S, Mohan S, Dequeker J, et al. Down-regulation of the serum stimulatory components of the insulin-like growth factor (IGF) system (IGF-I, IGF-II, IGF binding protein [BP]-3, and IGFBP-5) in age-related (type II) femoral neck osteoporosis. J Bone Miner Res. 1999;14(12):2150-2158. Exclusion code: 6. [pmid: 10620075].
Bougle D, Sabatier JP, Bureau F, et al. Relationship between bone mineralization and aluminium in the healthy infant. Eur J Clin Nutr. 1998;52(6):431-435. Exclusion code: 4. [pmid: 9683396].
Bouillon R, Maes C, Verlinden L, Carmeliet G, Verstuyf A. Vitamin D and Bone. Orwoll E, Bilezikian JP, Vanderschueren D, editors. Osteoporosis in Men: The Effects of Gender on Skeletal Health. 2nd ed. San Diego. Academic Press. 2010:243-253. Exclusion code: 8.
Bouillon R, Van Schoor NM, Gielen E, et al. Optimal vitamin d status: a critical analysis on the basis of evidence-based medicine. J Clin Endocrinol Metab. 2013;98(8):E1283-1304. Exclusion code: 7. [pmid: 23922354].
Boxer RS, Dauser DA, Walsh SJ, Hager WD, Kenny AM. The association between vitamin D and inflammation with the 6-minute walk and frailty in patients with heart failure. J Am Geriatr Soc. 2008;56(3):454-461. Exclusion code: 4. [pmid: 18194227].
Braddy KK, Imam SN, Palla KR, Lee TA. Vitamin d deficiency/insufficiency practice patterns in a veterans health administration long-term care population: a retrospective analysis. J Am Med Dir Assoc. 2009;10(9):653-657. Exclusion code: 2. [pmid: 19883889].
Brändstedt J, Almquist M, Manjer J, Malm J. Vitamin D, PTH, and calcium and the risk of prostate cancer: A prospective nested case-control study. Cancer Causes and Control. 2012;23(8):1377-1385. Exclusion code: 3. [pmid: 22706676].
Braun MM, Helzlsouer KJ, Hollis BW, Comstock GW. Prostate cancer and prediagnostic levels of serum vitamin D metabolites (Maryland, United States). Cancer Causes Control. 1995;6(3):235-239. Exclusion code: 3. [pmid: 7612803].
Braun MM, Helzlsouer KJ, Hollis BW, Comstock GW. Colon cancer and serum vitamin D metabolite levels 10-17 years prior to diagnosis. Am J Epidemiol. 1995;142(6):608-611. Exclusion code: 3. [pmid: 7653469].
Braverman AS. Evidence that high calcium and vitamin D intake decrease the risk of breast cancer in premenopausal women: implications for breast cancer prevention and screening. South Med J. 2007;100(11):1061-1062. Exclusion code: 8. [pmid: 17984726].
Brazerol WF, McPhee AJ, Mimouni F, Specker BL, Tsang RC. Serial ultraviolet B exposure and serum 25 hydroxyvitamin D response in young adult American blacks and whites: no racial differences. J Am Coll Nutr. 1988;7(2):111-118. Exclusion code: 2. [pmid: 3361035].
Brazier M, Kamel S, Lorget F, et al. Biological effects of supplementation with vitamin D and calcium in postmenopausal women with low bone mass receiving alendronate. Clin Drug Invest. 2002;22(12):849-857. Exclusion code: 4.
Brehm JM, Celedon JC, Soto-Quiros ME, et al. Serum vitamin D levels and markers of severity of childhood asthma in Costa Rica. Am J Respir Crit Care Med. 2009;179(9):765-771. Exclusion code: 4. [pmid: 19179486].
Breitling LP, Perna L, Muller H, Raum E, Kliegel M, Brenner H. Vitamin D and cognitive functioning in the elderly population in Germany. Exp Gerontol. 2012;47(1):122-127. Exclusion code: 7. [pmid: 22123431].
Brewer LC, Michos ED, Reis JP. Vitamin D in atherosclerosis, vascular disease, and endothelial function. Curr Drug Targets. 2011;12(1):54-60. Exclusion code: 13. [pmid: 20795937].
Brock K, Huang WY, Fraser DR, et al. Low vitamin D status is associated with physical inactivity, obesity and low vitamin D intake in a large US sample of healthy middle-aged men and women. J Steriod Biochem Mol Biol. 2010;121(1-2):462-466. Exclusion code: 3.
Brodin E, Lerstad G, Grimnes G, et al. Serum levels of vitamin D are not associated with future risk of venous thromboembolism. The Tromso Study. Thromb Haemost. 2013;109(5):885-890. Exclusion code: 3. [pmid: 23446951].
Broe KE, Chen TC, Weinberg J, Bischoff-Ferrari HA, Holick MF, Kiel DP. A higher dose of vitamin d reduces the risk of falls in nursing home residents: a randomized, multiple-dose study. J Am Geriatr Soc. 2007;55(2):234-239. Exclusion code: 15. [pmid: 17302660].
Brondum-Jacobsen P, Benn M, Jensen GB, Nordestgaard BG. 25-hydroxyvitamin d levels and risk of ischemic heart disease, myocardial infarction, and early death: population-based study and meta-analyses of 18 and 17 studies. Arterioscler Thromb Vasc Biol. 2012;32(11):2794-2802. Exclusion code: 3. [pmid: 22936341].
Brøndum-Jacobsen P, Nordestgaard BG, Schnohr P, Benn M. 25-Hydroxyvitamin D and symptomatic ischemic stroke: An original study and meta-analysis. Ann Neurol. 2013;73(1):38-47. Exclusion code: 3. [pmid: 23225498].
Brooke OG, Brown IR, Bone CD, et al. Vitamin D supplements in pregnant Asian women: effects on calcium status and fetal growth. Br Med J. 1980;280(6216):751-754. Exclusion code: 4. [pmid: 6989438].
Brown SJ. The role of vitamin D in multiple sclerosis. Ann Pharmacother. 2006;40(6):1158-1161. Exclusion code: 7. [pmid: 16684809].
Brunner EJ, Jones PJ, Friel S, Bartley M. Fish, human health and marine ecosystem health: policies in collision. Int J Epidemiol. 2009;38(1):93-100. Exclusion code: 8. [pmid: 18676983].
Brunner RL, Cochrane B, Jackson RD, et al. Calcium, vitamin D supplementation, and physical function in the Women's Health Initiative. J Am Diet Assoc. 2008;108(9):1472-1479. Exclusion code: 14. [pmid: 18755319].
Brunner RL, Wactawski-Wende J, Caan BJ, et al. The effect of calcium plus vitamin D on risk for invasive cancer: results of the Women's Health Initiative (WHI) calcium plus vitamin D randomized clinical trial. Nutr Cancer. 2011;63(6):827-841. Exclusion code: 14. [pmid: 21774589].
Brunvand L, Shah SS, Bergstrom S, Haug E. Vitamin D deficiency in pregnancy is not associated with obstructed labor. A study among Pakistani women in Karachi. Acta Obstet Gynecol Scand. 1998;77(3):303-306. Exclusion code: 4. [pmid: 9539276].
Bryson DJ, Nichols JS, Ford AJ, Williams SC. The incidence of vitamin D deficiency amongst patients with a femoral neck fracture: are current bone protection guidelines sufficient ?. Acta Orthop Belg. 2013;79(4):470-473. Exclusion code: 7. [pmid: 24205780].
Buell JS, Dawson-Hughes B, Scott TM, et al. 25-Hydroxyvitamin D, dementia, and cerebrovascular pathology in elders receiving home services. Neurology. 2010;74(1):18-26. Exclusion code: 7. [pmid: 19940273].
Buell JS, Scott TM, Dawson-Hughes B, et al. Vitamin D is associated with cognitive function in elders receiving home health services. J Gerontol A Biol Sci Med Sci. 2009;64(8):888-895. Exclusion code: 5. [pmid: 19377013].
Bunout D, Barrera G, Leiva L, et al. Effects of vitamin D supplementation and exercise training on physical performance in Chilean vitamin D deficient elderly subjects. Exp Gerontol. 2006;41(8):746-752. Exclusion code: 4. [pmid: 16797903].
Burgaz A, Orsini N, Larsson SC, Wolk A. Blood 25-hydroxyvitamin D concentration and hypertension: A meta-analysis. Journal of Hypertension. 2011;29(4):636-645. Exclusion code: 13. [pmid: 21191311].
Burgi AA, Gorham ED, Garland CF, et al. High serum 25-hydroxyvitamin D is associated with a low incidence of stress fractures. J Bone Miner Res. 2011;26(10):2371-2377. Exclusion code: 3. [pmid: 21698667].
Burleigh E, McColl J, Potter J. Does vitamin D stop inpatients falling? A randomised controlled trial. Age Ageing. 2007;36(5):507-513. Exclusion code: 4. [pmid: 17656420].
Burris HH, Rifas-Shiman SL, Camargo CA, et al. Plasma 25-hydroxyvitamin D during pregnancy and small-for-gestational age in black and white infants. Ann Epidemiol. 2012;22(8):581-586. Exclusion code: 4. [pmid: 22658824].
Burton JM, Kimball S, Vieth R, et al. A phase I/II dose-escalation trial of vitamin D3 and calcium in multiple sclerosis. Neurology. 2010;74(23):1852-1859. Exclusion code: 15. [pmid: 20427749].
Byrne PM, Freaney R, McKenna MJ. Vitamin D supplementation in the elderly: review of safety and effectiveness of different regimes. Calcif Tissue Int. 1995;56(6):518-520. Exclusion code: 7. [pmid: 7648477].
Caan B, Neuhouser M, Aragaki A, et al. Calcium plus vitamin D supplementation and the risk of postmenopausal weight gain. Arch Intern Med. 2007;167(9):893-902. Exclusion code: 14. [pmid: 17502530].
Cadranel JL, Garabedian M, Milleron B, et al. Vitamin D metabolism by alveolar immune cells in tuberculosis: correlation with calcium metabolism and clinical manifestations. Eur Respir J. 1994;7(6):1103-1110. Exclusion code: 5. [pmid: 7925880].
Camargo CA Jr, Rifas-Shiman SL, Litonjua AA, et al. Maternal intake of vitamin D during pregnancy and risk of recurrent wheeze in children at 3 y of age. Am J Clin Nutr. 2007;85(3):788-795. Exclusion code: 4. [pmid: 17344501].
Camargo CA Jr, Ingham T, Wickens K, et al. Cord-blood 25-hydroxyvitamin D levels and risk of respiratory infection, wheezing, and asthma. Pediatrics. 2011;127(1):e180-e187. Exclusion code: 4. [pmid: 21187313].
Cameron ID, Gillespie LD, Robertson CM, et al. Interventions for preventing falls in older people in care facilities and hospitals. Cochrane Database Syst Rev. 2012;(12). Exclusion code: 13.
Cameron ID, Gillespie LD, Robertson CM, et al. Interventions for preventing falls in older people in care facilities and hospitals. Cochrane Database Syst Rev. 2013;(3). Exclusion code: 13.
Campbell AJ, Robertson MC, La Grow SJ, et al. Randomised controlled trial of prevention of falls in people aged ≥75 with severe visual impairment: The VIP trial. Br Med J. 2005;331(7520):817-820. Exclusion code: 4. [pmid: 16183652].
Caniggia A, Delling G, Nuti R, Lore F, Vattimo A. Clinical, biochemical and histological results of a double-blind trial with 1,25-dihydroxyvitamin D3, estradiol and placebo in post-menopausal osteoporosis. Acta Vitaminol Enzymol. 1984;6(2):117-128. Exclusion code: 4. [pmid: 6388277].
Cannell JJ, Hollis BW, Zasloff M, Heaney RP. Diagnosis and treatment of vitamin D deficiency. Expert Opin Pharmacother. 2008;9(1):107-118. Exclusion code: 8. [pmid: 18076342].
Carlin AM, Rao DS, Yager KM, Parikh NJ, Kapke A. Treatment of vitamin D depletion after Roux-en-Y gastric bypass: a randomized prospective clinical trial. Surg Obes Relat Dis. 2009;5(4):444-449. Exclusion code: 4. [pmid: 18996761].
Carrillo AE, Flynn MG, Pinkston C, et al. Impact of vitamin D supplementation during a resistance training intervention on body composition, muscle function, and glucose tolerance in overweight and obese adults. Clin Nutr. 2013;32(3):375-381. Exclusion code: 5. [pmid: 23034474].
Cashman KD, Hill TR, Lucey AJ, et al. Estimation of the dietary requirement for vitamin D in healthy adults. Am J Clin Nutr. 2008;88(6):1535-1542. Exclusion code: 15. [pmid: 19064513].
Cashman KD, Wallace JM, Horigan G, et al. Estimation of the dietary requirement for vitamin D in free-living adults >=64 y of age. Am J Clin Nutr. 2009;89(5):1366-1374. Exclusion code: 15. [pmid: 19297462].
Cauley JA, Chlebowski RT, Wactawski-Wende J, et al. Calcium Plus Vitamin D Supplementation and Health Outcomes Five Years After Active Intervention Ended: The Women's Health Initiative. J Womens Health (Larchmt). 2013;22(11):915-929. Exclusion code: 14. [pmid: 24131320].
Cauley JA, Danielson ME, Boudreau R, et al. Serum 25-hydroxyvitamin D and clinical fracture risk in a multiethnic cohort of women: the Women's Health Initiative (WHI). J Bone Miner Res. 2011;26(10):2378-2388. Exclusion code: 3. [pmid: 21710614].
Cauley JA, Lacroix AZ, Wu L, et al. Serum 25-hydroxyvitamin D concentrations and risk for hip fractures. Ann Intern Med. 2008;149(4):242-250. Exclusion code: 2. [pmid: 18711154].
Cauley JA, Parimi N, Ensrud KE, et al. Serum 25-hydroxyvitamin D and the risk of hip and nonspine fractures in older men. J Bone Miner Res. 2010;25(3):545-553. Exclusion code: 3. [pmid: 19775201].
Cavalier E, Delanaye P, Souberbielle JC, Radermecker RP. Vitamin D and type 2 diabetes mellitus: Where do we stand?. Diabetes and Metabolism. 2011;37(4):265-272. Exclusion code: 13. [pmid: 21345709].
Cawthon PM, Parimi N, Barrett-Connor E, et al. Serum 25-hydroxyvitamin D, parathyroid hormone, and mortality in older men. J Clin Endocrinol Metab. 2010;95(10):4625-4634. Exclusion code: 3. [pmid: 20631024].
Ceglia L. Vitamin D and skeletal muscle tissue and function. Mol Aspects Med. 2008;29(6):407-414. Exclusion code: 13. [pmid: 18727936].
Ceglia L, Niramitmahapanya S, Da Silva Morais M, et al. A Randomized study on the effect of vitamin d3 supplementation on skeletal muscle morphology and vitamin d receptor concentration in older women. J Clin Endocrinol Metab. 2013;98(12):E1927-E1935. Exclusion code: 4. [pmid: 24108316].
Chan R, Chan D, Woo J, et al. Not all elderly people benefit from vitamin D supplementation with respect to physical function: results from the Osteoporotic Fractures in Men Study, Hong Kong. J Am Geriatr Soc. 2012;60(2):290-295. Exclusion code: 4. [pmid: 22211795].
Chandler PD, Scott JB, Drake BF, et al. Impact of vitamin D supplementation on inflammatory markers in African Americans: Results of a four-arm, randomized, placebo-controlled trial. Cancer prevention research (Philadelphia, Pa.). 2014;7(2):218-225. Exclusion code: 6.
Chandra RK. Effect of vitamin and trace-element supplementation on cognitive function in elderly subjects. Nutrition. 2001;17(9):709-712. Exclusion code: 5. [pmid: 11527656].
Chao YS, Brunel L, Faris P, Veugelers PJ. The importance of dose, frequency and duration of vitamin D supplementation for plasma 25-hydroxyvitamin D. Nutrients. 2013;5(10):4067-4078. Exclusion code: 7. [pmid: 24152747].
Chapuy M, Schott A, Garnero P, Hans D, Delmas P, Meunier P. Healthy elderly French women living at home have secondary hyperparathyroidism and high bone turnover in winter: E PIDOS S tudy Group. Clin Endocrinol Metab. 1996;81:1129-1133. Exclusion code: 2.
Chapuy MC, Arlot ME, Delmas PD, Meunier PJ. Effect of calcium and cholecalciferol treatment for three years on hip fractures in elderly women. Br Med J. 1994;308(6936):1081-1082. Exclusion code: 14. [pmid: 8173430].
Chapuy MC, Arlot ME, Duboeuf F, et al. Vitamin D3 and calcium to prevent hip fractures in the elderly women. N Engl J Med. 1992;327(23):1637-1642. Exclusion code: 14. [pmid: 1331788].
Chapuy MC, Chapuy P, Meunier PJ. Calcium and vitamin D supplements: Effects on calcium metabolism in elderly people. Am J Clin Nutr. 1987;46(2):324-328. Exclusion code: 6. [pmid: 3497572].
Chen JT, Shiraki M, Hasumi K, et al. 1-alpha-Hydroxyvitamin D3 treatment decreases bone turnover and modulates calcium-regulating hormones in early postmenopausal women. Bone. 1997;20(6):557-562. Exclusion code: 4. [pmid: 9177871].
Chen P, Hu P, Xie D, Qin Y, Wang F, Wang H. Meta-analysis of vitamin D, calcium and the prevention of breast cancer. Breast Cancer Res Treat. 2010;121(2):469-477. Exclusion code: 13. [pmid: 19851861].
Chen TC, Chimeh F, Lu Z, et al. Factors that influence the cutaneous synthesis and dietary sources of vitamin D. Arch Biochem Biophys. 2007;460(2):213-217. Exclusion code: 3. [pmid: 17254541].
Cherniack EP, Florez HJ, Hollis BW, Roos BA, Troen BR, Levis S. The response of elderly veterans to daily vitamin D3 supplementation of 2,000 IU: a pilot efficacy study. J Am Geriatr Soc. 2011;59(2):286-290. Exclusion code: 15. [pmid: 21288233].
Chesney RW. Vitamin D: can an upper limit be defined?. J Nutr. 1989;119(12 Suppl):1825-1828. Exclusion code: 8. [pmid: 2693642].
Chevalley T, Rizzoli R, Nydegger V, et al. Effects of calcium supplements on femoral bone mineral density and vertebral fracture rate in vitamin-D-replete elderly patients. Osteoporos Int. 1994;4(5):245-252. Exclusion code: 5. [pmid: 7812072].
Chiu KC, Chu A, Go VL, Saad MF. Hypovitaminosis D is associated with insulin resistance and beta cell dysfunction. Am J Clin Nutr. 2004;79(5):820-825. Exclusion code: 6. [pmid: 15113720].
Chonchol M, Cigolini M, Targher G. Association between 25-hydroxyvitamin D deficiency and cardiovascular disease in type 2 diabetic patients with mild kidney dysfunction. Nephrol Dial Transplant. 2008;23(1):269-274. Exclusion code: 15. [pmid: 17875570].
Christakos S, DeLuca H. Minireview: Vitamin D: is there a role in extraskeletal health?. Endocrinology. 2011;152(8):2930-2936. Exclusion code: 2. [pmid: 21673104].
Chung M, Balk EM, Brendel M, et al. Vitamin D and Calcium: A Systematic Review of Health Outcomes. 2009. AHRQ Publication No 09-E015. Rockville, MD. Agency for healthcare Research and Quality. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/vitadcal/vitadcal.pdf. January 17, 2014. Exclusion code: 2.
Chung M, Lee J, Terasawa T, Lau J, Trikalinos TA. Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;155(12):827-838. Exclusion code: 2. [pmid: 22184690].
Cigolini M, Iagulli MP, Miconi V, Galiotto M, Lombardi S, Targher G. Serum 25-hydroxyvitamin D3 concentrations and prevalence of cardiovascular disease among type 2 diabetic patients. Diabetes Care. 2006;29(3):722-724. Exclusion code: 7. [pmid: 16505539].
Clemens TL, Zhou XY, Myles M. Serum vitamin D2 and vitamin D3 metabolite concentrations and absorption of vitamin D2 in elderly subjects. J Clin Endocrinol Metab. 1986;63(3):656-660. Exclusion code: 7. [pmid: 3488327].
Colston KW, Lowe LC, Mansi JL, Campbell MJ. Vitamin D status and breast cancer risk. Anticancer Res. 2006;26(4A):2573-2580. Exclusion code: 7. [pmid: 16886666].
Compston JE. The role of vitamin D and calcium supplementation in the prevention of osteoporotic fractures in the elderly. Clin Endocrinol. 1995;43(4):393-405. Exclusion code: 13.
Coney P, Demers LM, Dodson WC, Kunselman AR, Ladson G, Legro RS. Determination of vitamin D in relation to body mass index and race in a defined population of black and white women. Int J Gynaecol Obstet. 2012;119(1):21-25. Exclusion code: 3. [pmid: 22818533].
Cooles FAH, Pratt AG, Wilson G, Isaacs JD, Ng WF. Prevalence and diagnostic outcome relating to vitamin D deficiency in new patients presenting to an early arthritis clinic over 12 months. Clin Rheumatol. 2011;30(8):1137-1138. Exclusion code: 8. [pmid: 21698398].
Cooper C, McIaren M, Wood PJ, Coulton L, Kains JA. Indices of calcium metabolism in women with hip fractures. Bone Miner. 1989;5(2):193-200. Exclusion code: 7. [pmid: 2784069].
Cooper L, Clifton-Bligh PB, Nery ML, et al. Vitamin D supplementation and bone mineral density in early postmenopausal women. Am J Clin Nutr. 2003;77(5):1324-1329. Exclusion code: 15. [pmid: 12716689].
Corder EH, Guess HA, Hulka BS, et al. Vitamin D and prostate cancer: a prediagnostic study with stored sera. Cancer Epidemiol Biomarkers Prev. 1993;2(5):467-472. Exclusion code: 3. [pmid: 8220092].
Corless D, Dawson E, Fraser F, et al. Do vitamin D supplements improve the physical capabilities of elderly hospital patients?. Age Ageing. 1985;14(2):76-84. Exclusion code: 4. [pmid: 4003187].
Correia LCL, Sodre F, Garcia G, et al. Relation of severe deficiency of vitamin D to cardiovascular mortality during acute coronary syndromes. Am J Cardiol. 2013;111(3):324-327. Exclusion code: 4. [pmid: 23174181].
Counts SJ, Baylink DJ, Shen FH, Sherrard DJ, Hickman RO. Vitamin D intoxication in an anephric child. Ann Intern Med. 1975;82(2):196-200. Exclusion code: 4. [pmid: 1115441].
Coussement J, De Paepe L, Schwendimann R, Denhaerynck K, Dejaeger E, Milisen K. Interventions for preventing falls in acute- and chronic-care hospitals: a systematic review and meta-analysis. J Am Geriatr Soc. 2008;56(1):29-36. Exclusion code: 13. [pmid: 18031484].
Cranney A, Guyatt G, Griffith L, Wells G, Tugwell P, Rosen C. Meta-analyses of therapies for postmenopausal osteoporosis. IX: Summary of meta-analyses of therapies for postmenopausal osteoporosis. Endocr Rev. 2002;23(4):570-578. Exclusion code: 8. [pmid: 12202472].
Cranney A, Horsley T, O'Donnell S, et al. Effectiveness and safety of vitamin D in relation to bone health. Evid rep/technol assess. 2007;(158):1-235. Exclusion code: 13.
Crew KD, Gammon MD, Steck SE, et al. Association between plasma 25-hydroxyvitamin D and breast cancer risk. Cancer Prev Res (Phila). 2009;2(6):598-604. Exclusion code: 7. [pmid: 19470790].
Cumming RG, Cummings SR, Nevitt MC, et al. Calcium intake and fracture risk: results from the study of osteoporotic fractures. Am J Epidemiol. 1997;145(10):926-934. Exclusion code: 5. [pmid: 9149664].
Cummings SR, Browner WS, Bauer D, et al. Endogenous hormones and the risk of hip and vertebral fractures among older women. Study of Osteoporotic Fractures Research Group. N Engl J Med. 1998;339(11):733-738. Exclusion code: 3. [pmid: 9731089].
Daly RM, Nowson CA. Long-term effect of calcium-vitamin D3 fortified milk on blood pressure and serum lipid concentrations in healthy older men. Eur J Clin Nutr. 2009;63(8):993-1000. Exclusion code: 9. [pmid: 19156159].
Daly RM, Petrass N, Bass S, Nowson CA. The skeletal benefits of calcium- and vitamin D3-fortified milk are sustained in older men after withdrawal of supplementation: An 18-mo follow-up study. Am J Clin Nutr. 2008;87(3):771-777. Exclusion code: 14. [pmid: 18326617].
Das G, Crocombe S, McGrath M, Berry JL, Mughal MZ. Hypovitaminosis D among healthy adolescent girls attending an inner city school. Arch Dis Child. 2006;91(7):569-572. Exclusion code: 4. [pmid: 16174640].
Davidson MB, Duran P, Lee ML, Friedman TC. High-dose vitamin D supplementation in people with prediabetes and hypovitaminosis D. Diabetes Care. 2013;36(2):260-266. Exclusion code: 4. [pmid: 23033239].
Davies M, Adams PH. The continuing risk of vitamin-D intoxication. Lancet. 1978;2(8090):621-623. Exclusion code: 7. [pmid: 80540].
Dawodu A, Agarwal M, Sankarankutty M, Hardy D, Kochiyil J, Badrinath P. Higher prevalence of vitamin D deficiency in mothers of rachitic than nonrachitic children. J Pediatr. 2005;147(1):109-111. Exclusion code: 4. [pmid: 16027707].
Dawson-Hughes B. Racial/ethnic considerations in making recommendations for vitamin D for adult and elderly men and women. Am J Clin Nutr. 2004;80(6 Suppl):1763S-1766S. Exclusion code: 8. [pmid: 15585802].
Dawson-Hughes B, Dallal GE, Krall EA, Harris S, Sokoll LJ, Falconer G. Effect of vitamin D supplementation on wintertime and overall bone loss in healthy postmenopausal women. Ann Intern Med. 1991;115(7):505-512. Exclusion code: 15. [pmid: 1883119].
Dawson-Hughes B, Harris SS, Krall EA, Dallal GE. Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Eng J Med. 1997;337(10):670-676. Exclusion code: 15.
Dawson-Hughes B, Harris SS, Krall EA, Dallal GE, Falconer G, Green CL. Rates of bone loss in postmenopausal women randomly assigned to one of two dosages of vitamin D. Am J Clin Nutr. 1995;61(5):1140-1145. Exclusion code: 12. [pmid: 7733040].
Dawson-Hughes B, Heaney RP, Holick MF, Lips P, Meunier PJ, Vieth R. Estimates of optimal vitamin D status. Osteoporos Int. 2005;16(7):713-716. Exclusion code: 8. [pmid: 15776217].
Dawson-Hughes B, Mithal A, Bonjour JP, et al. IOF Position Statement: Vitamin D Recommendations for Older Adults. Osteoporos Int. 2010;21(7):1151-1154. Exclusion code: 2. [pmid: 20422154].
de Boer IH, Levin G, Robinson-Cohen C, et al. Serum 25-hydroxyvitamin D concentration and risk for major clinical disease events in a community-based population of older adults a cohort study. Ann Intern Med. 2012;156(9):627-634. Exclusion code: 3. [pmid: 22547472].
Dean AJ, Bellgrove MA, Hall T, et al. Effects of vitamin D supplementation on cognitive and emotional functioning in young adults--a randomised controlled trial. PLoS ONE. [Electronic Resource]. 2011;6(11):e25966. Exclusion code: 15. [pmid: 22073146].
del Puente A, Esposito A, Savastano S, Carpinelli A, Postiglione L, Oriente P. Dietary calcium intake and serum vitamin D are major determinants of bone mass variations in women. A longitudinal study. Aging Clin. 2002;14(5):382-388. Exclusion code: 6.
Delvin EE, Salle BL, Glorieux FH, Adeleine P, David LS. Vitamin D supplementation during pregnancy: effect on neonatal calcium homeostasis. J Pediatr. 1986;109(2):328-334. Exclusion code: 4. [pmid: 3488384].
Deng X, Song Y, Manson JE, et al. Magnesium, vitamin D status and mortality: results from US National Health and Nutrition Examination Survey (NHANES) 2001 to 2006 and NHANES III. BMC Med. 2013;11:187. Exclusion code: 6. [pmid: 23981518].
Dennison E, Eastell R, Fall CH, Kellingray S, Wood PJ, Cooper C. Determinants of bone loss in elderly men and women: a prospective population-based study. Osteoporos Int. 1999;10(5):384-391. Exclusion code: 6. [pmid: 10591836].
Deo R, Katz R, Shlipak MG, et al. Vitamin D, parathyroid hormone, and sudden cardiac death: Results from the cardiovascular health study. Hypertension. 2011;58(6):1021-1028. Exclusion code: 3. [pmid: 22068871].
Derex L, Trouillas P. Reversible parkinsonism, hypophosphoremia, and hypocalcemia under vitamin D therapy. Mov Disord. 1997;12(4):612-613. Exclusion code: 8. [pmid: 9251086].
Deroisy R, Collette J, Albert A, Jupsin I, Reginster JY. Administration of a supplement containing both calcium and vitamin D is more effective than calcium alone to reduce secondary hyperparathyroidism in postmenopausal women with low 25(OH)vitamin D circulating levels. Aging Clin Exp Res. 2002;14(1):13-17. Exclusion code: 6. [pmid: 12027147].
Deschasse G, Chavanne D, Dardaine-Giraud V, Constans T. Effect of a loading dose of vitamin d3 in frail elderly patients with insufficient 25-hydroxyvitamin D serum levels. J Am Geriatr Soc. 2009;57(11):2155-2157. Exclusion code: 8. [pmid: 20121963].
Devereux G, McNeill G, Newman G, et al. Early childhood wheezing symptoms in relation to plasma selenium in pregnant mothers and neonates. Clin Exp Allergy. 2007;37(7):1000-1008. Exclusion code: 4. [pmid: 17581193].
Dhesi JK, Jackson SH, Bearne LM, et al. Vitamin D supplementation improves neuromuscular function in older people who fall. Age Ageing. 2004;33(6):589-595. Exclusion code: 4. [pmid: 15501836].
Di Daniele N, Carbonelli MG, Candeloro N, Iacopino L, De Lorenzo A, Andreoli A. Effect of supplementation of calcium and vitamin D on bone mineral density and bone mineral content in peri- and post-menopause women; a double-blind, randomized, controlled trial. Pharmacol Res. 2004;50(6):637-641. Exclusion code: 14. [pmid: 15501704].
Diamond T, Smerdely P, Kormas N, Sekel R, Vu T, Day P. Hip fracture in elderly men: The importance of subclinical vitamin D deficiency and hypogonadism. Med J Aust. 1998;169(3):138-141. Exclusion code: 7. [pmid: 9734509].
Diamond T, Wong YK, Golombick T. Effect of oral cholecalciferol 2,000 versus 5,000 IU on serum vitamin D, PTH, bone and muscle strength in patients with vitamin D deficiency. Osteoporos Int. 2013;24(3):1101-1105. Exclusion code: 12. [pmid: 22422304].
Dickens AP, Lang IA, Langa KM, Kos K, Llewellyn DJ. Vitamin D, cognitive dysfunction and dementia in older adults. CNS Drugs. 2011;25(8):629-639. Exclusion code: 7. [pmid: 21790207].
Ding C, Cicuttini F, Parameswaran V, Burgess J, Quinn S, Jones G. Serum levels of vitamin D, sunlight exposure, and knee cartilage loss in older adults: the Tasmanian older adult cohort study. Arthritis Rheum. 2009;60(5):1381-1389. Exclusion code: 6. [pmid: 19404958].
Ding EL, Mehta S, Fawzi WW, Giovannucci EL. Interaction of estrogen therapy with calcium and vitamin D supplementation on colorectal cancer risk: reanalysis of Women's Health Initiative randomized trial. Int J Cancer. 2008;122(8):1690-1694. Exclusion code: 6. [pmid: 18092326].
DIPART (Vitamin D Individual Patient Analysis of Randomized Trials) Group. Patient level pooled analysis of 68 500 patients from seven major vitamin D fracture trials in US and Europe. Br Med J (Clin Res Ed). 2010;340. Exclusion code: 13.
Dobnig H, Pilz S, Scharnagl H, et al. Independent association of low serum 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D levels with all-cause and cardiovascular mortality. Arch Intern Med. 2008;168(12):1340-1349. Exclusion code: 4. [pmid: 18574092].
Dong Y, Stallmann-Jorgensen IS, Pollock NK, et al. A 16-week randomized clinical trial of 2000 international units daily vitamin D3 supplementation in black youth: 25-hydroxyvitamin D, adiposity, and arterial stiffness. J Clin Endocrinol Metab. 2010;95(10):4584-4591. Exclusion code: 4. [pmid: 20660028].
Drechsler C, Pilz S, Obermayer-Pietsch B, et al. Vitamin D deficiency is associated with sudden cardiac death, combined cardiovascular events, and mortality in haemodialysis patients. European Heart Journal. 2010;31(18):2253-2261. Exclusion code: 4. [pmid: 20688781].
Drinka P. Vitamin D deficiency in older people. J Am Geriatr Soc. 1996;44(3):333. Exclusion code: 8. [pmid: 8600210].
Dukas L, Bischoff HA, Lindpaintner LS, et al. Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 2004;52(2):230-236. Exclusion code: 15. [pmid: 14728632].
Dukas L, Schacht E, Mazor Z, Stahelin HB. Treatment with alfacalcidol in elderly people significantly decreases the high risk of falls associated with a low creatinine clearance of <65 ml/min. Osteoporos Int. 2005;16(2):198-203. Exclusion code: 14. [pmid: 15221207].
Dumville JC, Miles JN, Porthouse J, Cockayne S, Saxon L, King C. Can vitamin D supplementation prevent winter-time blues? A randomised trial among older women. J Nurt Health Aging. 2006;10(2):151-153. Exclusion code: 14.
Duncan MJ, Mummery WK, Steele RM, Caperchione C, Schofield G. Geographic location, physical activity and perceptions of the environment in Queensland adults. Health Place. 2009;15(1):204-209. Exclusion code: 6. [pmid: 18539518].
Duplessis CA, Harris EB, Watenpaugh DE, Horn WG. Vitamin D supplementation in underway submariners. Aviat Space Environ Med. 2005;76(6):569-575. Exclusion code: 14. [pmid: 15945402].
Durup D, Jorgensen HL, Christensen J, Schwarz P, Heegaard AM, Lind B. A reverse J-shaped association of all-cause mortality with serum 25-hydroxyvitamin D in general practice: the CopD study. J Clin Endocrinol Metab. 2012;97(8):2644-2652. Exclusion code: 3. [pmid: 22573406].
Dyer CA, Taylor GJ, Reed M, Robertson DR, Harrington R. Falls prevention in residential care homes: a randomised controlled trial. Age Ageing. 2004;33(6):596-602. Exclusion code: 5. [pmid: 15381507].
Eaton C. Low vitamin D levels not useful as predictive risk marker for mortality. Cardiol Today. 2010. Exclusion code: 8.
Eaton CB, Young A, Allison MA, et al. Prospective association of vitamin D concentrations with mortality in postmenopausal women: results from the Women's Health Initiative (WHI). Am J Clin Nutr. 2011;94(6):1471-1478. Exclusion code: 6. [pmid: 22030222].
Ebeling PR. Megadose therapy for vitamin D deficiency. Med J Aust. 2005;183(1):4-5. Exclusion code: 8. [pmid: 15992326].
Ebeling PR, Wark JD, Yeung S, et al. Effects of calcitriol or calcium on bone mineral density, bone turnover, and fractures in men with primary osteoporosis: A two-year randomized, double blind, double placebo study. J Clin Endocrinol Metab. 2001;86(9):4098-4103. Exclusion code: 4. [pmid: 11549632].
Effraimidis G, Badenhoop K, Tijssen JGP, Wiersinga WM. Vitamin D deficiency is not associated with early stages of thyroid autoimmunity. Eur J Endocrinol. 2012;167(1):43-48. Exclusion code: 6. [pmid: 22518050].
Elamin MB, Abu Elnour NO, Elamin KB, et al. Vitamin D and cardiovascular outcomes: A systematic review and meta-analysis. J Clin Endocrinol Metab. 2011;96(7):1931-1942. Exclusion code: 13. [pmid: 21677037].
El-Hajj Fuleihan G, Nabulsi M, Choucair M, et al. Hypovitaminosis D in healthy schoolchildren. Pediatrics. 2001;107(4). Exclusion code: 4.
El-Hajj Fuleihan G, Nabulsi M, Tamim H, et al. Effect of vitamin D replacement on musculoskeletal parameters in school children: a randomized controlled trial. J Clin Endocrinol Metab. 2006;91(2):405-412. Exclusion code: 4. [pmid: 16278262].
Eliassen AH, Spiegelman D, Hollis BW, Horst RL, Willett WC, Hankinson SE. Plasma 25-hydroxyvitamin D and risk of breast cancer in the Nurses' Health Study II. Breast Cancer Res. 2011;13(3):R50. Exclusion code: 3. [pmid: 21569367].
Engel P, Fagherazzi G, Boutten A, et al. Serum 25(OH) vitamin D and risk of breast cancer: A nested case-control study from the French E3N cohort. Cancer Epidemiol Biomarkers Prev. 2010;19(9):2341-2350. Exclusion code: 3. [pmid: 20826834].
Ensrud KE, Ewing SK, Fredman L, et al. Circulating 25-hydroxyvitamin D levels and frailty status in older women. J Clin Endocrinol Metab. 2010;95(12):5266-5273. Exclusion code: 3. [pmid: 21131545].
Ensrud KE, Taylor BC, Paudel ML, et al. Serum 25-hydroxyvitamin D levels and rate of hip bone loss in older men. J Clin Endocrinol Metab. 2009;94(8):2773-2780. Exclusion code: 6. [pmid: 19454586].
Erber E, Maskarinec G, Lim U, Kolonel LN. Dietary vitamin D and risk of non-Hodgkin lymphoma: the multiethnic cohort. Br J Nutr. 2010;103(4):581-584. Exclusion code: 6. [pmid: 19781122].
Erem C, Tanakol R, Alagöl F, Ömer B, Çetin Ö. Relationship of bone turnover parameters, endogenous hormones and vit D deficiency to hip fracture in elderly postmenospausal women. Int J Clin Pract. 2002;56(5):333-337. Exclusion code: 7. [pmid: 12137439].
Eskandari F, Martinez PE, Torvik S, et al. Low bone mass in premenopausal women with depression. Arch Intern Med. 2007;167(21):2329-2336. Exclusion code: 7. [pmid: 18039992].
European Food Safety Authority Panel on Dietic Products; Nutrition and Allergies (NDA). Scientific Opinion on the Tolerable Upper Intake Level of vitamin D. European Food Saftey Authority. 2012;10(7). Exclusion code: 2.
Evatt ML, Delong MR, Khazai N, Rosen A, Triche S, Tangpricha V. Prevalence of vitamin d insufficiency in patients with Parkinson disease and Alzheimer disease. Arch Neurol. 2008;65(10):1348-1352. Exclusion code: 15. [pmid: 18852350].
Expert Group on Vitamins and Minerals. Safe Upper Levels for Vitamins and Minerals. Great Britain: Food Standards Agency. 2003. Exclusion code: 8.
Falch JA, Odegaard OR, Finnanger AM, Matheson I. Postmenopausal osteoporosis: no effect of three years treatment with 1,25-dihydroxycholecalciferol. Acta Med Scand. 1987;221(2):199-204. Exclusion code: 4. [pmid: 3035879].
Farrant HJ, Krishnaveni GV, Hill JC, et al. Vitamin D insufficiency is common in Indian mothers but is not associated with gestational diabetes or variation in newborn size. Eur J Clin Nutr. 2009;63(5):646-652. Exclusion code: 4. [pmid: 18285809].
Faulkner KA, Cauley JA, Zmuda JM, et al. Higher 1,25-dihydroxyvitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporos Int. 2006;17(9):1318-1328. Exclusion code: 3. [pmid: 16788853].
Faupel-Badger JM, Diaw L, Albanes D, Virtamo J, Woodson K, Tangrea JA. Lack of association between serum levels of 25-hydroxyvitamin D and the subsequent risk of prostate cancer in Finnish men. Cancer Epidemiol Biomarkers Prev. 2007;16(12):2784-2786. Exclusion code: 6. [pmid: 18086789].
Faurschou A, Beyer DM, Schmedes A, Bogh MK, Philipsen PA, Wulf HC. The relation between sunscreen layer thickness and vitamin D production after ultraviolet B exposure: a randomized clinical trial. Br J Dermatol. 2012;167(2):391-395. Exclusion code: 2. [pmid: 22512875].
Fedirko V, Torres-Mejia G, Ortega-Olvera C, et al. Serum 25-hydroxyvitamin D and risk of breast cancer: results of a large population-based case-control study in Mexican women. Cancer Causes Control. 2012;23(7):1149-1162. Exclusion code: 7. [pmid: 22622862].
Feliciano ES, Ho ML, Specker BL, et al. Seasonal and geographical variations in the growth rate of infants in China receiving increasing dosages of vitamin D supplements. J Trop Pediatr. 1994;40(3):162-165. Exclusion code: 4. [pmid: 8078115].
Fernell E, Gillberg C. Autism spectrum disorder diagnoses in Stockholm preschoolers. Res Dev Disabil. 2010;31(3):680-685. Exclusion code: 4. [pmid: 20149593].
Feskanich D, Ma J, Fuchs CS, et al. Plasma vitamin D metabolites and risk of colorectal cancer in women. Cancer Epidemiol Biomarkers Prev. 2004;13(9):1502-1508. Exclusion code: 3. [pmid: 15342452].
Flicker L, MacInnis RJ, Stein MS, et al. Should older people in residential care receive vitamin D to prevent falls? Results of a randomized trial. J Am Geriatr Soc. 2005;53(11):1881-1888. Exclusion code: 15. [pmid: 16274368].
Flicker L, Mead K, MacInnis RJ, et al. Serum vitamin D and falls in older women in residential care in Australia. J Am Geriatr Soc. 2003;51(11):1533-1538. Exclusion code: 4. [pmid: 14687381].
Fliser D, Stefanski A, Franek E, Fode P, Gudarzi A, Ritz E. No effect of calcitriol on insulin-mediated glucose uptake in healthy subjects. Eur J Clin Invest. 1997;27(7):629-633. Exclusion code: 6. [pmid: 9263752].
Fomon SJ, Younoszai MK, Thomas LN. Influence of vitamin D on linear growth of normal full-term infants. J Nutr. 1966;88(3):345-350. Exclusion code: 4. [pmid: 5952247].
Ford ES, Zhao G, Tsai J, Li C. Vitamin D and all-cause mortality among adults in USA: findings from the National Health and Nutrition Examination Survey Linked Mortality Study. Int J Epidemiol. 2011;40(4):998-1005. Exclusion code: 3. [pmid: 21266455].
Forman JP, Curhan GC, Taylor EN. Plasma 25-hydroxyvitamin D levels and risk of incident hypertension among young women. Hypertension. 2008;52(5):828-832. Exclusion code: 6. [pmid: 18838623].
Forman JP, Giovannucci E, Holmes MD, et al. Plasma 25-hydroxyvitamin D levels and risk of incident hypertension. Hypertension. 2007;49(5):1063-1069. Exclusion code: 6. [pmid: 17372031].
Forman JP, Scott JB, Ng K, et al. Effect of vitamin d supplementation on blood pressure in blacks. Hypertension. 2013;61(4):779-785. Exclusion code: 3. [pmid: 23487599].
Forrest KY, Stuhldreher WL. Prevalence and correlates of vitamin D deficiency in US adults. Nutr Res. 2011;31(1):48-54. Exclusion code: 3. [pmid: 21310306].
Francis RM. The vitamin D paradox. Rheumatology. 2007;46(12):1749-1750. Exclusion code: 8. [pmid: 17998224].
Francis RM, Anderson FH, Patel S, Sahota O, van Staa TP. Calcium and vitamin D in the prevention of osteoporotic fractures. Qjm. 2006;99(6):355-363. Exclusion code: 7. [pmid: 16537574].
Freedman DM, Dosemeci M, McGlynn K. Sunlight and mortality from breast, ovarian, colon, prostate, and non-melanoma skin cancer: a composite death certificate based case-control study. Occup Environ Med. 2002;59(4):257-262. Exclusion code: 5. [pmid: 11934953].
Freedman DM, Looker AC, Abnet CC, Linet MS, Graubard BI. Serum 25-hydroxyvitamin D and cancer mortality in the NHANES III study (1988-2006). Cancer Res. 2010;70(21):8587-8597. Exclusion code: 3. [pmid: 20847342].
Freiberger E, de Vreede P, Schoene D, et al. Performance-based physical function in older community-dwelling persons: a systematic review of instruments. Age Ageing. 2012;41(6):712-721. Exclusion code: 2. [pmid: 22885845].
Frenkel M, Abrams DI, Ladas EJ, et al. Integrating Dietary Supplements Into Cancer Care. Integr Cancer Ther. 2013. Exclusion code: 8.
Frolich A, Rudnicki M, Storm T, Rasmussen N, Hegedus L. Impaired 1,25-dihydroxyvitamin D production in pregnancy-induced hypertension. Eur J Obstet Gynecol Reprod Biol. 1992;47(1):25-29. Exclusion code: 4. [pmid: 1426508].
Fuller KE, Casparian JM. Vitamin D: balancing cutaneous and systemic considerations. South Med J. 2001;94(1):58-64. Exclusion code: 8. [pmid: 11213944].
Gahche J, Bailey R, Burt V, et al. Dietary supplement use among US adults has increased since NHANES III (1988-1994). NCHS Data Brief. 2011;(61):1-8. Exclusion code: 2. [pmid: 21592424].
Gale CR, Robinson SM, Harvey NC, et al. Maternal vitamin D status during pregnancy and child outcomes. Eur J Clin Nutr. 2008;62(1):68-77. Exclusion code: 4. [pmid: 17311057].
Gallagher JC. The effects of calcitriol on falls and fractures and physical performance tests. J Steriod Biochem Mol Biol. 2004;89-90(1-5):497-501. Exclusion code: 15.
Gallagher JC, Fowler SE, Detter JR, Sherman SS. Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001;86(8):3618-3628. Exclusion code: 15. [pmid: 11502787].
Gallagher JC, Goldgar D. Treatment of postmenopausal osteoporosis with high doses of synthetic calcitriol: A randomized controlled study. Ann Intern Med. 1990;113(9):649-655. Exclusion code: 4. [pmid: 2221645].
Gallagher JC, Rapuri PB, Smith LM. An age-related decrease in creatinine clearance is associated with an increase in number of falls in untreated women but not in women receiving calcitriol treatment. J Clin Endocrinol Metab. 2007;92(1):51-58. Exclusion code: 15. [pmid: 17032712].
Gallagher JC, Riggs BL, Recker RR, Goldgar D. The effect of calcitriol on patients with postmenopausal osteoporosis with special reference to fracture frequency. Proc Soc Exp Biol Med. 1989;191(3):287-292. Exclusion code: 4. [pmid: 2740360].
Gallagher JC, Yalamanchili V, Smith LM. The effect of vitamin D on calcium absorption in older women. J Clin Endocrinol Metab. 2012;97(10):3550-3556. Exclusion code: 6. [pmid: 22855333].
Gallagher JC, Yalamanchili V, Smith LM. The effect of vitamin D supplementation on serum 25(OH)D in thin and obese women. J Steroid Biochem Mol Biol. 2013;136:195-200. Exclusion code: 3. [pmid: 23246640].
Gallieni M. High-dose oral vitamin D supplementation and risk of falls in older women. JAMA. 2010;304(8):855. author reply 856-857. Exclusion code: 8. [pmid: 20736466].
Ganji V, Zhang X, Tangpricha V. Serum 25-hydroxyvitamin D concentrations and prevalence estimates of hypovitaminosis D in the U.S. population based on assay-adjusted data. J Nutr. 2012;142(3):498-507. Exclusion code: 2. [pmid: 22323766].
Ganmaa D, Giovannucci E, Bloom BR, et al. Vitamin D, tuberculin skin test conversion, and latent tuberculosis in Mongolian school-age children: a randomized, double-blind, placebo-controlled feasibility trial. Am J Clin Nutr. 2012;96(2):391-396. Exclusion code: 4. [pmid: 22760564].
Garland C, Shekelle RB, Barrett-Connor E, Criqui MH, Rossof AH, Paul O. Dietary vitamin D and calcium and risk of colorectal cancer: a 19-year prospective study in men. Lancet. 1985;1(8424):307-309. Exclusion code: 5. [pmid: 2857364].
Garland CF, Comstock GW, Garland FC, Helsing KJ, Shaw EK, Gorham ED. Serum 25-hydroxyvitamin D and colon cancer: eight-year prospective study. Lancet. 1989;2(8673):1176-1178. Exclusion code: 8. [pmid: 2572900].
Garland CF, Garland FC, Gorham ED. Can colon cancer incidence and death rates be reduced with calcium and vitamin D?. Am J Clin Nutr. 1991;54(1 Suppl):193S-201S. Exclusion code: 8. [pmid: 2053561].
Garland CF, Garland FC, Gorham ED, et al. The role of vitamin D in cancer prevention. Am J Public Health. 2006;96(2):252-261. Exclusion code: 8. [pmid: 16380576].
Garland CF, Gorham ED, Mohr SB, Garland FC. Vitamin D for cancer prevention: Global perspective. Ann Epidemiol. 2009;19(7):468-483. Exclusion code: 7. [pmid: 19523595].
Garland CF, Gorham ED, Mohr SB, et al. Vitamin D and prevention of breast cancer: pooled analysis. J Steriod Biochem Mol Biol. 2007;103(3-5):708-711. Exclusion code: 6.
Garland CF, Grant WB, Mohr SB, Gorham ED, Garland FC. What is the dose-response relationship between vitamin D and cancer risk?. Nutr Rev. 2007;65(8 Pt 2):S91-95. Exclusion code: 8. [pmid: 17867379].
Garland FC, Garland CF, Gorham ED, Young JF. Geographic variation in breast cancer mortality in the United States: a hypothesis involving exposure to solar radiation. Prev Med. 1990;19(6):614-622. Exclusion code: 5. [pmid: 2263572].
George PS, Pearson ER, Witham MD. Effect of vitamin D supplementation on glycaemic control and insulin resistance: a systematic review and meta-analysis. Diabet Med. 2012;29(8):e142-150. Exclusion code: 4. [pmid: 22486204].
Gepner AD, Ramamurthy R, Krueger DC, Korcarz CE, Binkley N, Stein JH. A prospective randomized controlled trial of the effects of vitamin D supplementation on cardiovascular disease risk. PLoS One. 2012;7(5):e36617. Exclusion code: 15. [pmid: 22586483].
Gerdhem P, Ringsberg KA, Obrant KJ, Akesson K. Association between 25-hydroxy vitamin D levels, physical activity, muscle strength and fractures in the prospective population-based OPRA Study of Elderly Women. Osteoporos Int. 2005;16(11):1425-1431. Exclusion code: 3. [pmid: 15744449].
Gernand AD, Simhan HN, Klebanoff MA, Bodnar LM. Maternal serum 25-hydroxyvitamin D and measures of newborn and placental weight in a U.S. multicenter cohort study. J Clin Endocrinol Metab. 2013;98(1):398-404. Exclusion code: 4. [pmid: 23162094].
Gertner JM, Domenech M. 25-Hydroxyvitamin D levels in patients treated with high-dosage ergo- and cholecalciferol. J Clin Pathol. 1977;30(2):144-150. Exclusion code: 7. [pmid: 191473].
Gessner BD, deSchweinitz E, Petersen KM, Lewandowski C. Nutritional rickets among breast-fed black and Alaska Native children. Alaska Med. 1997;39(3):72-74. 87. Exclusion code: 4. [pmid: 9368423].
Geusens P, Dequeker J. Long-term effect of nandrolone decanoate, 1α-hydroxyvitamin D3 or intermittent calcium infusion therapy on bone mineral content, bone remodeling and fracture rate in symptomatic osteoporosis: A double-blind controlled study. Bone Miner. 1986;1(4):347-357. Exclusion code: 4. [pmid: 3333018].
Ghose RR. Vitamin D deficiency and muscle weakness in the elderly. N Z Med J. 2005;118(1219):U1582. Exclusion code: 8. [pmid: 16059404].
Gibney KB, MacGregor L, Leder K, et al. Vitamin D deficiency is associated with tuberculosis and latent tuberculosis infection in immigrants from sub-Saharan Africa. Clin Infect Dis. 2008;46(3):443-446. Exclusion code: 7. [pmid: 18173355].
Gillespie LD, Robertson CM, Gillespie WJ, et al. Interventions for preventing falls in older people living in the community. Cochrane Database Syst Rev. 2012;(11). Exclusion code: 13.
Ginde AA, Liu MC, Camargo CA Jr. Demographic differences and trends of Vitamin D insufficiency in the US population, 1988-2004. Arch Intern Med. 2009;169(6):626-632. Exclusion code: 3. [pmid: 19307527].
Ginde AA, Mansbach JM, Camargo CA Jr. Vitamin D, respiratory infections, and asthma. Curr Allergy Asthma Rep. 2009;9(1):81-87. Exclusion code: 8. [pmid: 19063829].
Ginde AA, Mansbach JM, Camargo CA Jr. Association between serum 25-hydroxyvitamin D level and upper respiratory tract infection in the Third National Health and Nutrition Examination Survey. Arch Intern Med. 2009;169(4):384-390. Exclusion code: 7. [pmid: 19237723].
Ginde AA, Scragg R, Schwartz RS, Camargo CA Jr. Prospective study of serum 25-hydroxyvitamin D level, cardiovascular disease mortality, and all-cause mortality in older U.S. adults. J Am Geriatr Soc. 2009;57(9):1595-1603. Exclusion code: 3. [pmid: 19549021].
Giovannucci E. Can vitamin D reduce total mortality?. Arch Intern Med. 2007;167(16):1709-1710. Exclusion code: 8. [pmid: 17846388].
Giovannucci E. Strengths and limitations of current epidemiologic studies: vitamin D as a modifier of colon and prostate cancer risk. Nutr Rev. 2007;65(8 Pt 2):S77-79. Exclusion code: 8. [pmid: 17867375].
Giovannucci E, Liu Y, Hollis BW, Rimm EB. 25-hydroxyvitamin D and risk of myocardial infarction in men: a prospective study. Arch Intern Med. 2008;168(11):1174-1180. Exclusion code: 3. [pmid: 18541825].
Giovannucci E, Liu Y, Rimm EB, et al. Prospective study of predictors of vitamin D status and cancer incidence and mortality in men. J Natl Cancer Inst. 2006;98(7):451-459. Exclusion code: 7. [pmid: 16595781].
Giovannucci E, Rimm EB, Wolk A, et al. Calcium and fructose intake in relation to risk of prostate cancer. Cancer Res. 1998;58(3):442-447. Exclusion code: 5. [pmid: 9458087].
Glendenning P, Zhu K, Inderjeeth C, Howat P, Lewis JR, Prince RL. Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 2012;27(1):170-176. Exclusion code: 15. [pmid: 21956713].
Glerup H, Mikkelsen K, Poulsen L, et al. Hypovitaminosis D myopathy without biochemical signs of osteomalacic bone involvement. Calcif Tissue Int. 2000;66(6):419-424. Exclusion code: 2. [pmid: 10821877].
Gloth FM 3rd. Vitamin D. Lancet. 1995;345(8958):1185. Exclusion code: 8. [pmid: 7723577].
Gloth FM 3rd, Alam W, Hollis B. Vitamin D vs broad spectrum phototherapy in the treatment of seasonal affective disorder. J Nurt Health Aging. 1999;3(1):5-7. Exclusion code: 12.
Gloth FM 3rd, Smith CE, Hollis BW, Tobin JD. Functional improvement with vitamin D replenishment in a cohort of frail, vitamin D-deficient older people. J Am Geriatr Soc. 1995;43(11):1269-1271. Exclusion code: 4. [pmid: 7594162].
Golombick T, Diamond T. The effect of a combined oral calcium and vitamin D supplement for treating mild to moderate vitamin D deficiency in postmenopausal women. Clin Interv Aging. 2008;3(1):183-186. Exclusion code: 4. [pmid: 18488888].
Gómez-Alonso C, Naves-Díaz ML, Fernández-Martín JL, Díaz-López JB, Fernández-Coto MT, Cannata-Andía JB. Vitamin D status and secondary hyperparathyroidism: The importance of 25-hydroxyvitamin D cut-off levels. Kidney Int Suppl. 2003;63(85):S44-S48. Exclusion code: 13. [pmid: 12753264].
Gorai I, Chaki O, Taguchi Y, et al. Early postmenopausal bone loss is prevented by estrogen and partially by 1alpha-OH-vitamin D3: therapeutic effects of estrogen and/or 1alpha-OH-vitamin D3. Calcif Tissue Int. 1999;65(1):16-22. Exclusion code: 14. [pmid: 10369728].
Gordon CM, DePeter KC, Feldman HA, Grace E, Emans SJ. Prevalence of vitamin D deficiency among healthy adolescents. Arch Pediatr Adolesc Med. 2004;158(6):531-537. Exclusion code: 4. [pmid: 15184215].
Gordon CM, Williams AL, Feldman HA, et al. Treatment of hypovitaminosis D in infants and toddlers. J Clin Endocrinol Metab. 2008;93(7):2716-2721. Exclusion code: 4. [pmid: 18413426].
Gordon NP, Caan BJ, Asgari MM. Variation in vitamin D supplementation among adults in a multi-race/ethnic health plan population, 2008. Nutr J. 2012;11:104. Exclusion code: 2. [pmid: 23231734].
Gorham ED, Garland CF, Garland FC, et al. Vitamin D and prevention of colorectal cancer. J Steriod Biochem Mol Biol. 2005;97(1-2):179-194. Exclusion code: 13.
Gorham ED, Garland CF, Garland FC, et al. Optimal vitamin D status for colorectal cancer prevention: a quantitative meta analysis. Am J Prev Med. 2007;32(3):210-216. Exclusion code: 13. [pmid: 17296473].
Gouni-Berthold I, Krone W, Berthold HK. Vitamin D and cardiovascular disease. Curr Vasc Pharmacol. 2009;7(3):414-422. Exclusion code: 7. [pmid: 19601865].
Graafmans WC, Ooms ME, Hofstee HM, Bezemer PD, Bouter LM, Lips P. Falls in the elderly: a prospective study of risk factors and risk profiles. Am J Epidemiol. 1996;143(11):1129-1136. Exclusion code: 7. [pmid: 8633602].
Grados F, Brazier M, Kamel S, et al. Effects on bone mineral density of calcium and vitamin D supplementation in elderly women with vitamin D deficiency. Joint Bone Spine. 2003;70(3):203-208. Exclusion code: 11. [pmid: 12814763].
Grados F, Brazier M, Kamel S, et al. Prediction of bone mass density variation by bone remodeling markers in postmenopausal women with vitamin D insufficiency treated with calcium and vitamin D supplementation. J Clin Endocrinol Metab. 2003;88(11):5175-5179. Exclusion code: 3. [pmid: 14602746].
Grady D, Halloran B, Cummings S, et al. 1,25-Dihydroxyvitamin D3 and muscle strength in the elderly: a randomized controlled trial. J Clin Endocrinol Metab. 1991;73(5):1111-1117. Exclusion code: 14. [pmid: 1939527].
Grandi NC, Breitling LP, Brenner H. Vitamin D and cardiovascular disease: Systematic review and meta-analysis of prospective studies. Prev Med. 2010;51(3-4):228-233. Exclusion code: 3. [pmid: 20600257].
Grant AM, Avenell A, Campbell MK, et al. Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 2005;365(9471):1621-1628. Exclusion code: 14. [pmid: 15885294].
Grant WB. An estimate of premature cancer mortality in the U.S. due to inadequate doses of solar ultraviolet-B radiation. Cancer. 2002;94(6):1867-1875. Exclusion code: 5. [pmid: 11920550].
Grant WB. Relation between prediagnostic serum 25-hydroxyvitamin D level and incidence of breast, colorectal, and other cancers. J Photochem Photobiol B. 2010;101(2):130-136. Exclusion code: 3. [pmid: 20570169].
Grant WB. An estimate of the global reduction in mortality rates through doubling vitamin D levels. Eur J Clin Nutr. 2011;65(9):1016-1026. Exclusion code: 7. [pmid: 21731036].
Grant WB. Effect of interval between serum draw and follow-up period on relative risk of cancer incidence with respect to 25-hydroxyvitamin D level: Implications for meta-analyses and setting vitamin D guidelines. Dermatoendocrinol. 2011;3(3):199-204. Exclusion code: 6. [pmid: 22110780].
Grant WB. Effect of follow-up time on the relation between prediagnostic serum 25-hydroxyvitamin D and all-cause mortality rate. Dermatoendocrinol. 2012;4(2):198-202. Exclusion code: 6. [pmid: 22928077].
Grant WB, Boucher BJ. Requirements for Vitamin D across the life span. Biol Res Nurs. 2011;13(2):120-133. Exclusion code: 8. [pmid: 21242196].
Grant WB, Garland CF. A critical review of studies on vitamin D in relation to colorectal cancer. Nutr Cancer. 2004;48(2):115-123. Exclusion code: 13. [pmid: 15231446].
Grant WB, Giovannucci E. The possible roles of solar ultraviolet-B radiation and vitamin D in reducing case-fatality rates from the 1918-1919 influenza pandemic in the United States. Dermatoendocrinol. 2009;1(4):215-219. Exclusion code: 5. [pmid: 20592793].
Grant WB, Peiris AN. Differences in vitamin D status may account for unexplained disparities in cancer survival rates between African and white Americans. Dermatoendocrinol. 2012;4(2):85-94. Exclusion code: 7. [pmid: 22928063].
Grau MV, Baron JA, Sandler RS, et al. Vitamin D, calcium supplementation, and colorectal adenomas: results of a randomized trial. J Natl Cancer Inst. 2003;95(23):1765-1771. Exclusion code: 15. [pmid: 14652238].
Green AK, Hankinson SE, Bertone-Johnson ER, Tamimi RM. Mammographic density, plasma vitamin D levels and risk of breast cancer in postmenopausal women. Int J Cancer. 2010;127(3):667-674. Exclusion code: 6. [pmid: 19960434].
Green TJ, Skeaff CM, Rockell JE. Milk fortified with the current adequate intake for vitamin D (5 microg) increases serum 25-hydroxyvitamin D compared to control milk but is not sufficient to prevent a seasonal decline in young women. Asia Pac J Clin Nutr. 2010;19(2):195-199. Exclusion code: 15. [pmid: 20460232].
Greene-Finestone LS, Berger C, de Groh M, et al. 25-Hydroxyvitamin D in Canadian adults: biological, environmental, and behavioral correlates. Osteoporos Int. 2011;22(5):1389-1399. Exclusion code: 7. [pmid: 20730415].
Greenspan SL, Schneider DL, McClung MR, et al. Alendronate improves bone mineral density in elderly women with osteoporosis residing in long-term care facilities: A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2002;136(10):742-746. Exclusion code: 5. [pmid: 12020142].
Greer FR, Marshall S. Bone mineral content, serum vitamin D metabolite concentrations, and ultraviolet B light exposure in infants fed human milk with and without vitamin D2 supplements. J Pediatr. 1989;114(2):204-212. Exclusion code: 4. [pmid: 2783734].
Greer FR, Searcy JE, Levin RS, Steichen JJ, Steichen-Asche PS, Tsang RC. Bone mineral content and serum 25-hydroxyvitamin D concentrations in breast-fed infants with and without supplemental vitamin D: one-year follow-up. J Pediatr. 1982;100(6):919-922. Exclusion code: 4. [pmid: 6979622].
Grieger JA, Nowson CA, Jarman HF, Malon R, Ackland LM. Multivitamin supplementation improves nutritional status and bone quality in aged care residents. Eur J Clin Nutr. 2009;63(4):558-565. Exclusion code: 5. [pmid: 18043700].
Grimnes G, Joakimsen R, Figenschau Y, Torjesen PA, Almas B, Jorde R. The effect of high-dose vitamin D on bone mineral density and bone turnover markers in postmenopausal women with low bone mass--a randomized controlled 1-year trial. Osteoporos Int. 2012;23(1):201-211. Exclusion code: 15. [pmid: 21909730].
Grossmann RE, Zughaier SM, Liu S, Lyles RH, Tangpricha V. Impact of vitamin D supplementation on markers of inflammation in adults with cystic fibrosis hospitalized for a pulmonary exacerbation. Eur J Clin Nutr. 2012;66(9):1072-1074. Exclusion code: 6. [pmid: 22805498].
Guillemant J, Taupin P, Le HT, et al. Vitamin D status during puberty in French healthy male adolescents. Osteoporos Int. 1999;10(3):222-225. Exclusion code: 6. [pmid: 10525714].
Gupta AK, Brashear MM, Johnson WD. Low vitamin D levels, prediabetes and prehypertension in healthy African American adults. Nutr Metab Cardiovasc Dis. 2012;22(10):877-882. Exclusion code: 6. [pmid: 22494807].
Gupta R, Sharma U, Gupta N, et al. Effect of cholecalciferol and calcium supplementation on muscle strength and energy metabolism in vitamin D-deficient Asian Indians: a randomized, controlled trial. Clin Endocrinol. 2010;73(4):445-451. Exclusion code: 3.
Haddock L, Corcino J, Vazquez MD. 25(OH)D serum levels in the normal Puerto Rican population and in subjects with tropical sprue and parathyroid disease. Puerto Rico Health Sci J. 1982;1:85-91. Exclusion code: 6.
Hanley DA, Cranney A, Jones G, et al. Vitamin D in adult health and disease: a review and guideline statement from Osteoporosis Canada. CMAJ. 2010;182(12):E610-618. Exclusion code: 2. [pmid: 20624868].
Hansen K, Jones A, Lindstrom M, Davis L, Engelke J, Shafer M. Vitamin D insufficiency: disease or no disease?. J Bone Miner Res. 2008;23:1052-1060. Exclusion code: 2. [pmid: 18302509].
Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996;15(6):619-629. Exclusion code: 2. [pmid: 8731004].
Harkness LS, Cromer BA. Vitamin D deficiency in adolescent females. J Adolesc Health. 2005;37(1):75.e71-75.e75. Exclusion code: 4. [pmid: 15963911].
Harris RA, Pedersen-White J, Guo DH, et al. Vitamin D3 supplementation for 16 weeks improves flow-mediated dilation in overweight African-American adults. Am J Hypertens. 2011;24(5):557-562. Exclusion code: 6. [pmid: 21311504].
Harris S, Dawson-Hughes B. Seasonal mood changes in 250 normal women. Psychiatry Res. 1993;49(1):77-87. Exclusion code: 15. [pmid: 8140183].
Harris SS. Vitamin D and African Americans. J Nutr. 2006;136(4):1126-1129. Exclusion code: 8. [pmid: 16549493].
Harris SS, Dawson-Hughes B. Seasonal changes in plasma 25-hydroxyvitamin D concentrations of young American black and white women. Am J Clin Nutr. 1998;67(6):1232-1236. Exclusion code: 3. [pmid: 9625098].
Harris SS, Dawson-Hughes B. Plasma vitamin D and 25OHD responses of young and old men to supplementation with vitamin D3. J Am Coll Nutr. 2002;21(4):357-362. Exclusion code: 6. [pmid: 12166534].
Harris SS, Pittas AG, Palermo NJ. A randomized, placebo-controlled trial of vitamin D supplementation to improve glycaemia in overweight and obese African Americans. Diabetes Obes Metab. 2012;14(9):789-794. Exclusion code: 4. [pmid: 22486948].
Harris SS, Soteriades E, Coolidge JA, Mudgal S, Dawson-Hughes B. Vitamin D insufficiency and hyperparathyroidism in a low income, multiracial, elderly population. J Clin Endocrinol Metab. 2000;85(11):4125-4130. Exclusion code: 3. [pmid: 11095443].
Hartman TJ, Albert PS, Snyder K, et al. The association of calcium and vitamin D with risk of colorectal adenomas. J Nutr. 2005;135(2):252-259. Exclusion code: 7. [pmid: 15671222].
Harwood RH, Sahota O, Gaynor K, Masud T, Hosking DJ, Nottingham Neck of Femur S. A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing. 2004;33(1):45-51. Exclusion code: 4. [pmid: 14695863].
Hasling C, Nielsen HE, Melsen F, Mosekilde L. Safety of osteoporosis treatment with sodium fluoride, calcium phosphate and vitamin D. Miner Electrolyte Metab. 1987;13(2):96-103. Exclusion code: 4. [pmid: 3696093].
Hathcock JN, Shao A, Vieth R, Heaney R. Risk assessment for vitamin D. Am J Clin Nutr. 2007;85(1):6-18. Exclusion code: 7. [pmid: 17209171].
Hatse S, Lambrechts D, Verstuyf A, et al. Vitamin D status at breast cancer diagnosis: correlation with tumor characteristics, disease outcome, and genetic determinants of vitamin D insufficiency. Carcinogenesis. 2012;33(7):1319-1326. Exclusion code: 7. [pmid: 22623648].
Haugen M, Brantsaeter AL, Trogstad L, et al. Vitamin D supplementation and reduced risk of preeclampsia in nulliparous women. Epidemiology. 2009;20(5):720-726. Exclusion code: 4. [pmid: 19451820].
Hayward I, Stein MT, Gibson MI. Nutritional rickets in San Diego. Am J Dis Child. 1987;141(10):1060-1062. Exclusion code: 4. [pmid: 3630990].
He JL, Scragg RK. Vitamin D, parathyroid hormone, and blood pressure in the National Health and Nutrition Examination Surveys. Am J Hypertens. 2011;24(8):911-917. Exclusion code: 6. [pmid: 21525968].
Heaney R, Dowell M, Hale C, Bendich A. Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. Am Coll Nutr. 2003;22:142-146. Exclusion code: 2.
Heaney RP. The Vitamin D requirement in health and disease. J Steroid Biochem Mol Biol. 2005;97(1-2):13-19. Exclusion code: 13. [pmid: 16026981].
Heaney RP. Vitamin D--baseline status and effective dose. N Engl J Med. 2012;367(1):77-78. Exclusion code: 8. [pmid: 22762324].
Heaney RP, Davies KM, Chen TC, Holick MF, Janet Barger-Lux M. Human serum 25-hydroxycholecalciferol response to extended oral dosing with cholecalciferol. Am J Clin Nutr. 2003;77(1):204-210. Exclusion code: 15. [pmid: 12499343].
Heaney RP, Holick MF. Why the IOM recommendations for vitamin D are deficient. J Bone Miner Res. 2011;26(3):455-457. Exclusion code: 8. [pmid: 21337617].
Heaney RP, Recker RR, Grote J, Horst RL, Armas LA. Vitamin D(3) is more potent than vitamin D(2) in humans. J Clin Endocrinol Metab. 2011;96(3):E447-452. Exclusion code: 12. [pmid: 21177785].
Heaney RP, Vieth R, Hollis BW. Vitamin D efficacy and safety. Arch Intern Med. 2011;171(3):266. author reply 267. Exclusion code: 8. [pmid: 21325123].
Heikinheimo RJ, Haavisto MV, Harju EJ, et al. Serum vitamin D level after an annual intramuscular injection of ergocalciferol. Calcif Tissue Int. Suppl. 1991;49:S87. Exclusion code: 6. [pmid: 1933611].
Heikinheimo RJ, Inkovaara JA, Harju EJ, et al. Annual injection of vitamin D and fractures of aged bones. Calcif Tissue Int. 1992;51(2):105-110. Exclusion code: 5. [pmid: 1422948].
Heikkinen A, Parviainen MT, Tuppurainen MT, Niskanen L, Komulainen MH, Saarikoski S. Effects of postmenopausal hormone replacement therapy with and without vitamin D3 on circulating levels of 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D. Calcif Tissue Int. 1998;62(1):26-30. Exclusion code: 6. [pmid: 9405729].
Heikkinen AM, Tuppurainen MT, Niskanen L, Komulainen M, Penttila I, Saarikoski S. Long-term vitamin D3 supplementation may have adverse effects on serum lipids during postmenopausal hormone replacement therapy. Eur J Endocrinol. 1997;137(5):495-502. Exclusion code: 14. [pmid: 9405029].
Hernan MA, Olek MJ, Ascherio A. Geographic variation of MS incidence in two prospective studies of US women. Neurology. 1999;53(8):1711-1718. Exclusion code: 5. [pmid: 10563617].
Herndon AC, DiGuiseppi C, Johnson SL, Leiferman J, Reynolds A. Does nutritional intake differ between children with autism spectrum disorders and children with typical development?. J Autism Dev Disord. 2009;39(2):212-222. Exclusion code: 4. [pmid: 18600441].
Herran A, Amado JA, Garcia-Unzueta MT, Vazquez-Barquero JL, Perera L, Gonzalez-Macias J. Increased bone remodeling in first-episode major depressive disorder. Psychosom Med. 2000;62(6):779-782. Exclusion code: 4. [pmid: 11138996].
Heshmat R, Tabatabaei-Malazy O, Abbaszadeh-Ahranjani S, et al. Effect of vitamin D on insulin resistance and anthropometric parameters in Type 2 diabetes; a randomized double-blind clinical trial. Daru. 2012;20(1):10. Exclusion code: 15. [pmid: 23351271].
Hiatt RA, Krieger N, Lobaugh B, Drezner MK, Vogelman JH, Orentreich N. Prediagnostic serum vitamin D and breast cancer. J Natl Cancer Inst. 1998;90(6):461-463. Exclusion code: 5. [pmid: 9521171].
Hii S, Scherer S. Vitamin d deficiency and secondary hyperparathyroidism in older people with low trauma fractures. Aust J Ageing. 2004;23(1):45-47. Exclusion code: 7.
Hill TR, Aspray TJ, Francis RM. Vitamin D and bone health outcomes in older age. Proc Nutr Soc. 2013;72(4):372-380. Exclusion code: 8. [pmid: 24020640].
Hiller JE, Crowther CA, Moore VA, Willson K, Robinson JS. Calcium supplementation in pregnancy and its impact on blood pressure in children and women: follow up of a randomised controlled trial. Aust N Z J Obstet Gynaecol. 2007;47(2):115-121. Exclusion code: 4. [pmid: 17355300].
Himmelstein S, Clemens TL, Rubin A, Lindsay R. Vitamin D supplementation in elderly nursing home residents increases 25(OH)D but not 1,25(OH)2D. Am J Clin Nutr. 1990;52(4):701-706. Exclusion code: 10. [pmid: 2403063].
Hitz MF, Jensen JE, Eskildsen PC. Bone mineral density and bone markers in patients with a recent low-energy fracture: effect of 1 y of treatment with calcium and vitamin D. Am J Clin Nutr. 2007;86(1):251-259. Exclusion code: 4. [pmid: 17616788].
Hofmeyr GJ, Atallah AN, Duley L. Calcium supplementation during pregnancy for preventing hypertensive disorders and related problems. Cochrane Database Syst Rev. 2006;(3). CD001059. Exclusion code: 4.
Hofmeyr GJ, Duley L, Atallah A. Dietary calcium supplementation for prevention of pre-eclampsia and related problems: a systematic review and commentary. BJOG. 2007;114(8):933-943. Exclusion code: 4. [pmid: 17565614].
Hoikka V, Alhava EM, Savolainen K, Parviainen M. Osteomalacia in fractures of the proximal femur. Acta Orthopaedica Scandinavica. 1982;53(2):255-260. Exclusion code: 4. [pmid: 7136573].
Holick M, Siris E, Binkley N, et al. Prevalence of vitamin D inadequacy among postmenopausal North A merican women receiving osteoporosis therapy. J Clin Epidemiol Metab. 2005;90:3215-3224. Exclusion code: 2.
Holick MF. Vitamin D: Importance in the prevention of cancers, type 1 diabetes, heart disease, and osteoporosis. Am J Clin Nutr. 2004;79(3):362-371. Exclusion code: 7. [pmid: 14985208].
Holick MF. Resurrection of vitamin D deficiency and rickets. J Clin Invest. 2006;116(8):2062-2072. Exclusion code: 4. [pmid: 16886050].
Holick MF. Vitamin D deficiency in obesity and health consequences. Curr Opin Endocrinol Diabetes. 2006;13(5):412-418. Exclusion code: 7.
Holick MF. Calcium plus Vitamin D and the Risk of Colorectal Cancer. N Engl J Med. 2006;354(21):2287-2288. Exclusion code: 7. [pmid: 16723623].
Holick MF. Vitamin D deficiency. N Engl J Med. 2007;357(3):266-281. Exclusion code: 7. [pmid: 17634462].
Holick MF. Vitamin D: the other steroid hormone for muscle function and strength. Menopause. 2009;16(6):1077-1078. Exclusion code: 8. [pmid: 19801955].
Holick MF. Vitamin D: evolutionary, physiological and health perspectives. Curr Drug Targets. 2011;12(1):4-18. Exclusion code: 8. [pmid: 20795941].
Holick MF, Biancuzzo RM, Chen TC, et al. Vitamin D2 is as effective as vitamin D3 in maintaining circulating concentrations of 25-hydroxyvitamin D. J Clin Endocrinol Metab. 2008;93(3):677-681. Exclusion code: 15. [pmid: 18089691].
Holick MF, Binkley NC, Bischoff-Ferrari HA, et al. Guidelines for preventing and treating vitamin D deficiency and insufficiency revisited. J Clin Endocrinol Metab. 2012;97(4):1153-1158. Exclusion code: 8. [pmid: 22442274].
Hollis BW. Circulating 25-hydroxyvitamin D levels indicative of vitamin D sufficiency: implications for establishing a new effective dietary intake recommendation for vitamin D. J Nutr. 2005;135(2):317-322. Exclusion code: 8. [pmid: 15671234].
Hollis BW, Johnson D, Hulsey TC, Ebeling M, Wagner CL. Vitamin D supplementation during pregnancy: double-blind, randomized clinical trial of safety and effectiveness. J Bone Miner Res. 2011;26(10):2341-2357. Exclusion code: 4. [pmid: 21706518].
Hollis BW, Wagner CL. Vitamin D requirements during lactation: high-dose maternal supplementation as therapy to prevent hypovitaminosis D for both the mother and the nursing infant. Am J Clin Nutr. 2004;80(6 Suppl):1752S-1758S. Exclusion code: 4. [pmid: 15585800].
Hollis BW, Wagner CL. Assessment of dietary vitamin D requirements during pregnancy and lactation. Am J Clin Nutr. 2004;79(5):717-726. Exclusion code: 4. [pmid: 15113709].
Hollis BW, Wagner CL. Vitamin D requirements and supplementation during pregnancy. Curr Opin Endocrinol Diabetes Obes. 2011;18(6):371-375. Exclusion code: 4. [pmid: 21857221].
Holmlund-Suila E, Viljakainen H, Hytinantti T, Lamberg-Allardt C, Andersson S, Mäkitie O. High-dose vitamin D intervention in infants - Effects on vitamin D status, calcium homeostasis, and bone strength. J Clin Endocrinol Metab. 2012;97(11):4139-4147. Exclusion code: 4. [pmid: 22933541].
Holmoy T, Kampman MT, Smolders J. Vitamin D in multiple sclerosis: implications for assessment and treatment. Expert Rev Neurother. 2012;12(9):1101-1112. Exclusion code: 8. [pmid: 23039389].
Holt PR, Arber N, Halmos B, et al. Colonic epithelial cell proliferation decreases with increasing levels of serum 25-hydroxy vitamin D. Cancer Epidemiol Biomarkers Prev. 2002;11(1):113-119. Exclusion code: 6. [pmid: 11815408].
Holt PR, Bresalier RS, Ma CK, et al. Calcium plus vitamin D alters preneoplastic features of colorectal adenomas and rectal mucosa. Cancer. 2006;106(2):287-296. Exclusion code: 14. [pmid: 16353199].
Holt SK, Kolb S, Fu R, Horst R, Feng Z, Stanford JL. Circulating levels of 25-hydroxyvitamin D and prostate cancer prognosis. Cancer Epidemiology. 2013;37(5):666-670. Exclusion code: 6. [pmid: 23972671].
Holvik K, Ahmed LA, Forsmo S, et al. Low serum levels of 25-hydroxyvitamin D predict hip fracture in the elderly: a NOREPOS study. J Clin Endocrinol Metab. 2013;98(8):3341-3350. Exclusion code: 3. [pmid: 23678033].
Hong SN, Kim JH, Choe WH, et al. Circulating vitamin D and colorectal adenoma in asymptomatic average-risk individuals who underwent first screening colonoscopy: a case-control study. Dig Dis Sci. 2012;57(3):753-763. Exclusion code: 7. [pmid: 21984438].
Hoogendijk WJ, Lips P, Dik MG, Deeg DJ, Beekman AT, Penninx BW. Depression is associated with decreased 25-hydroxyvitamin D and increased parathyroid hormone levels in older adults. Arch Gen Psychiatry. 2008;65(5):508-512. Exclusion code: 7. [pmid: 18458202].
Hopkins MH, Owen J, Ahearn T, et al. Effects of supplemental vitamin D and calcium on biomarkers of inflammation in colorectal adenoma patients: a randomized, controlled clinical trial. Cancer Prev Res. 2011;4(10):1645-1654. Exclusion code: 6.
Hossein-nezhad A, Holick MF. Vitamin D for health: a global perspective. Mayo Clin Proc. 2013;88(7):720-755. Exclusion code: 13. [pmid: 23790560].
Houston DK, Neiberg RH, Tooze JA, et al. Low 25-hydroxyvitamin D predicts the onset of mobility limitation and disability in community-dwelling older adults: the Health ABC Study. J Gerontol A Biol Sci Med Sci. 2013;68(2):181-187. Exclusion code: 3. [pmid: 22573914].
Houston DK, Tooze JA, Davis CC, et al. Serum 25-hydroxyvitamin D and physical function in older adults: the Cardiovascular Health Study All Stars. J Am Geriatr Soc. 2011;59(10):1793-1801. Exclusion code: 7. [pmid: 22091492].
Houston DK, Tooze JA, Neiberg RH, et al. 25-hydroxyvitamin D status and change in physical performance and strength in older adults. Am J Epidemiol. 2012;176(11):1025-1034. Exclusion code: 3. [pmid: 23118104].
Hsia J, Heiss G, Ren H, et al. Calcium/vitamin D supplementation and cardiovascular events. Circulation. 2007;115(7):846-854. Exclusion code: 14. [pmid: 17309935].
Hughes MR, Baylink DJ, Jones PG, Haussler MR. Radioligand receptor assay for 25-hydroxyvitamin D2/D3 and 1 alpha, 25-dihydroxyvitamin D2/D3. J Clin Invest. 1976;58(1):61-70. Exclusion code: 5. [pmid: 1084355].
Huh SY, Gordon CM. Vitamin D deficiency in children and adolescents: Epidemiology, impact and treatment. Rev Endocr metab Disord. 2008;9(2):161-170. Exclusion code: 4. [pmid: 18175220].
Huisman AM, White KP, Algra A, et al. Vitamin D levels in women with systemic lupus erythematosus and fibromyalgia. J Rheumatol. 2001;28(11):2535-2539. Exclusion code: 4. [pmid: 11708429].
Hujoel PP. Vitamin D and dental caries in controlled clinical trials: systematic review and meta-analysis. Nutr Rev. 2013;71(2):88-97. Exclusion code: 4. [pmid: 23356636].
Hull S. Vitamin D deficiency. Br J Gen Pract. 2007;57(543):836-837. Exclusion code: 8. [pmid: 17925145].
Humble MB, Gustafsson S, Bejerot S. Low serum levels of 25-hydroxyvitamin D (25-OHD) among psychiatric out-patients in Sweden: relations with season, age, ethnic origin and psychiatric diagnosis. J Steriod Biochem Mol Biol. 2010;121(1-2):467-470. Exclusion code: 4.
Huncharek M, Muscat J, Kupelnick B. Colorectal cancer risk and dietary intake of calcium, vitamin D, and dairy products: a meta-analysis of 26,335 cases from 60 observational studies. Nutr Cancer. 2009;61(1):47-69. Exclusion code: 5. [pmid: 19116875].
Hunter D, Major P, Arden N, et al. A randomized controlled trial of vitamin D supplementation on preventing postmenopausal bone loss and modifying bone metabolism using identical twin pairs. J Bone Miner Res. 2000;15(11):2276-2283. Exclusion code: 4. [pmid: 11092410].
Huntington MK, Shafer CW, Pudwill R, Boer L, Kendall J. Prevalence of vitamin D deficiency among immigrants to South Dakota. S D Med. 2010;63(2):51-55. Exclusion code: 6. [pmid: 20306571].
Husemoen LLN, Skaaby T, Thuesen BH, Jorgensen T, Fenger RV, Linneberg A. Serum 25(OH)D and incident type 2 diabetes: a cohort study. Eur J Clin Nutr. 2012;66(12):1309-1314. Exclusion code: 3. [pmid: 23031851].
Hutchinson MS, Grimnes G, Joakimsen RM, Figenschau Y, Jorde R. Low serum 25-hydroxyvitamin D levels are associated with increased all-cause mortality risk in a general population: the Tromso study. Eur J Endocrinol. 2010;162(5):935-942. Exclusion code: 7. [pmid: 20185562].
Hypponen E, Boucher BJ, Berry DJ, Power C. 25-hydroxyvitamin D, IGF-1, and metabolic syndrome at 45 years of age: a cross-sectional study in the 1958 British Birth Cohort. Diabetes. 2008;57(2):298-305. Exclusion code: 2. [pmid: 18003755].
Hypponen E, Hartikainen AL, Sovio U, Jarvelin MR, Pouta A. Does vitamin D supplementation in infancy reduce the risk of pre-eclampsia?. Eur J Clin Nutr. 2007;61(9):1136-1139. Exclusion code: 4. [pmid: 17268418].
Hyppönen E, Läärä E, Reunanen A, Järvelin MR, Virtanen SM. Intake of vitamin D and risk of type 1 diabetes: A birth-cohort study. Lancet. 2001;358(9292):1500-1503. Exclusion code: 4. [pmid: 11705562].
Hypponen E, Power C. Hypovitaminosis D in British adults at age 45 y: nationwide cohort study of dietary and lifestyle predictors. Am J Clin Nutr. 2007;85(3):860-868. Exclusion code: 2. [pmid: 17344510].
Hypponen E, Sovio U, Wjst M, et al. Infant vitamin d supplementation and allergic conditions in adulthood: northern Finland birth cohort 1966. Ann N Y Acad Sci. 2004;1037:84-95. Exclusion code: 4. [pmid: 15699498].
Ilahi M, Armas LAG, Heaney RP. Pharmacokinetics of a single, large dose of cholecalciferol. Am J Clin Nutr. 2008;87(3):688-691. Exclusion code: 6. [pmid: 18326608].
Inanir A, Ozoran K, Tutkak H, Mermerci B. The effects of calcitriol therapy on serum interleukin-1, interleukin-6 and tumour necrosis factor-alpha concentrations in post-menopausal patients with osteoporosis. J Int Med Res. 2004;32(6):570-582. Exclusion code: 14. [pmid: 15587751].
Inkovaara J, Gothoni G, Halttula R, Heikinheimo R, Tokola O. Calcium, vitamin D and anabolic steroid in treatment of aged bones: double-blind placebo-controlled long-term clinical trial. Age Ageing. 1983;12(2):124-130. Exclusion code: 14. [pmid: 6346829].
Institute of Medicine. 2011 Dietary reference intakes for calcium and vitamin D. Washington, DC. 2011. Exclusion code: 2.
International Agency for Research on Cancer. Vitamin D and Cancer. Lyon. 25. Nov. 2008. Exclusion code: 2.
International Osteoporosis Foundation (IOF). IOF Statement of New IOM Dietary Reference Intakes for Calcium and Vitamin D. Bone Health. http://www.iofbonehealth.org/iof-statement-new-iom-dietary-reference-intakes-calcium-and-vitamin-d. January 18, 2013. Exclusion code: 2.
Isaia G, Giorgino R, Adami S. High prevalence of hypovitaminosis D in female type 2 diabetic population. Diabetes Care. 2001;24(8):1496. Exclusion code: 7. [pmid: 11473093].
Ishida Y, Kawai S. Comparative efficacy of hormone replacement therapy, etidronate, calcitonin, alfacalcidol, and vitamin K in postmenopausal women with osteoporosis: The Yamaguchi Osteoporosis Prevention Study. Am J Med. 2004;117(8):549-555. Exclusion code: 4. [pmid: 15465502].
Islam MZ, Shamim AA, Viljakainen HT, et al. Effect of vitamin D, calcium and multiple micronutrient supplementation on vitamin D and bone status in Bangladeshi premenopausal garment factory workers with hypovitaminosis D: a double-blinded, randomised, placebo-controlled 1-year intervention. Br J Nutr. 2010;104(2):241-247. Exclusion code: 4. [pmid: 20193095].
Islam T, Peiris P, Copeland RJ, El Zoghby M, Peiris AN. Vitamin D: Lessons from the veterans population. J Am Med Dir Assoc. 2011;12(4):257-262. Exclusion code: 7. [pmid: 21527166].
Ito M, Koyama H, Ohshige A, Maeda T, Yoshimura T, Okamura H. Prevention of preeclampsia with calcium supplementation and vitamin D3 in an antenatal protocol. Int J Gynaecol Obstet. 1994;47(2):115-120. Exclusion code: 4. [pmid: 7843479].
Iuliano-Burns S, Ayton J, Hillam S, et al. Skeletal and hormonal responses to vitamin D supplementation during sunlight deprivation in Antarctic expeditioners. Osteoporos Int. 2012;23(10):2461-2467. Exclusion code: 12. [pmid: 22215183].
Jablonski NG, Chaplin G. The evolution of human skin coloration. J Hum Evol. 2000;39(1):57-106. Exclusion code: 8. [pmid: 10896812].
Jackson C, Gaugris S, Sen SS, Hosking D. The effect of cholecalciferol (vitamin D3) on the risk of fall and fracture: a meta-analysis. Qjm. 2007;100(4):185-192. Exclusion code: 13. [pmid: 17308327].
Jackson RD, LaCroix AZ, Cauley JA, McGowan J. The Women's Health Initiative calcium-vitamin D trial: overview and baseline characteristics of participants. Ann Epidemiol. 2003;13(9 Suppl):S98-106. Exclusion code: 3. [pmid: 14575942].
Jacobs ET, Alberts DS, Benuzillo J, Hollis BW, Thompson PA, Martinez ME. Serum 25(OH)D levels, dietary intake of vitamin D, and colorectal adenoma recurrence. J Steriod Biochem Mol Biol. 2007;103(3-5):752-756. Exclusion code: 6.
Jacobs ET, Alberts DS, Foote JA, et al. Vitamin D insufficiency in southern Arizona. Am J Clin Nutr. 2008;87(3):608-613. Exclusion code: 6. [pmid: 18326598].
Jacobs ET, Giuliano AR, Martinez ME, Hollis BW, Reid ME, Marshall JR. Plasma levels of 25-hydroxyvitamin D, 1,25-dihydroxyvitamin D and the risk of prostate cancer. J Steriod Biochem Mol Biol. 2004;89-90(1-5):533-537. Exclusion code: 3.
Jacques PF, Felson DT, Tucker KL, et al. Plasma 25-hydroxyvitamin D and its determinants in an elderly population sample. Am J Clin Nutr. 1997;66(4):929-936. Exclusion code: 2. [pmid: 9322570].
Jaddou HY, Batieha AM, Khader YS, Kanaan SH, El-Khateeb MS, Ajlouni KM. Depression is associated with low levels of 25-hydroxyvitamin D among Jordanian adults: results from a national population survey. Eur Arch Psychiatry Clin Neurosci. 2012;262(4):321-327. Exclusion code: 4. [pmid: 21993566].
Janet Barger-Lux M, Heaney RP. Effects of above average summer sun exposure on serum 25-hydroxyvitamin D and calcium absorption. J Clin Endocrinol Metab. 2002;87(11):4952-4956. Exclusion code: 6. [pmid: 12414856].
Janowsky EC, Lester GE, Weinberg CR, et al. Association between low levels of 1,25-dihydroxyvitamin D and breast cancer risk. Public Health Nutr. 1999;2(3):283-291. Exclusion code: 7. [pmid: 10512563].
Jassal SK, Chonchol M, Von Mhlen D, Smits G, Barrett-Connor E. Vitamin D, parathyroid hormone, and cardiovascular mortality in older adults: The rancho bernardo study. Am J Med. 2010;123(12):1114-1120. Exclusion code: 3. [pmid: 20870200].
Javaid MK, Crozier SR, Harvey NC, et al. Maternal vitamin D status during pregnancy and childhood bone mass at age 9 years: a longitudinal study. [Erratum appears in Lancet. 2006 May 6;367(9521):1486]. Lancet. 2006;367(9504):36-43. Exclusion code: 4. [pmid: 16399151].
Jeans PC. Vitamin D. J Am Med Assoc. 1950;143(2):177-181. Exclusion code: 8. [pmid: 15415243].
Jenab M, Ferrari P, McKay J, et al. Circulating vitamin d concentration, vitamin d receptor polymorphisms and the risk of colorectal cancer: results from the European Prospective Investigation into Cancer and Nutrition (EPIC). Eur J Cancer. 2008;6(9):190-191. Exclusion code: 5.
Jensen GF, Meinecke B, Boesen J, Transbol I. Does 1,25(OH)2D3 accelerate spinal bone loss? A controlled therapeutic trial in 70-year-old women. Clin Orthop Relat Res. 1985;(192):215-221. Exclusion code: 14. [pmid: 3881203].
John EM, Schwartz GG, Dreon DM, Koo J. Vitamin D and breast cancer risk: The NHANES I epidemiologic follow-up study, 1971-1975 to 1992. Cancer Epidemiol Biomarkers Prev. 1999;8(5):399-406. Exclusion code: 6. [pmid: 10350434].
Johnson KR, Jobber J, Stonawski BJ. Prophylactic vitamin D in the elderly. Age Ageing. 1980;9(2):121-127. Exclusion code: 14. [pmid: 7395656].
Johnson MA, Davey A, Park S, Hausman DB, Poon LW, Georgia Centenarian S. Age, race and season predict vitamin D status in African American and white octogenarians and centenarians. J Nurt Health Aging. 2008;12(10):690-695. Exclusion code: 7.
Jorde R, Bonaa KH. Calcium from dairy products, vitamin D intake, and blood pressure: the Tromso Study. Am J Clin Nutr. 2000;71(6):1530-1535. Exclusion code: 5. [pmid: 10837295].
Jorde R, Figenschau Y. Supplementation with cholecalciferol does not improve glycaemic control in diabetic subjects with normal serum 25-hydroxyvitamin D levels. Eur J Nutr. 2009;48(6):349-354. Exclusion code: 15. [pmid: 19370371].
Jorde R, Sneve M, Figenschau Y, Svartberg J, Waterloo K. Effects of vitamin D supplementation on symptoms of depression in overweight and obese subjects: randomized double blind trial. J Intern Med. 2008;264(6):599-609. Exclusion code: 15. [pmid: 18793245].
Jorde R, Sneve M, Hutchinson M, Emaus N, Figenschau Y, Grimnes G. Tracking of serum 25-hydroxyvitamin D levels during 14 years in a population-based study and during 12 months in an intervention study. Am J Epidemiol. 2010;171(8):903-908. Exclusion code: 7. [pmid: 20219763].
Jorde R, Sneve M, Torjesen P, Figenschau Y. No improvement in cardiovascular risk factors in overweight and obese subjects after supplementation with vitamin D3 for 1 year: Original Article. J Intern Med. 2010;267(5):462-472. Exclusion code: 15. [pmid: 20141565].
Jorde R, Sneve M, Torjesen P, Figenschau Y, Hansen JB. Parameters of the thrombogram are associated with serum 25-hydroxyvitamin D levels at baseline, but not affected during supplementation with vitamin D. Thrombosis Research. 2010;125(5):e210-e213. Exclusion code: 6. [pmid: 20071011].
Jorde R, Sneve M, Torjesen PA, Figenschau Y, Hansen JB, Grimnes G. No significant effect on bone mineral density by high doses of vitamin D3 given to overweight subjects for one year. Nutr J. 2010;9(1). Exclusion code: 15.
Jorde R, Waterloo K, Saleh F, Haug E, Svartberg J. Neuropsychological function in relation to serum parathyroid hormone and serum 25-hydroxyvitamin D levels. The Tromso study. J Neurol. 2006;253(4):464-470. Exclusion code: 7. [pmid: 16283099].
Judd SE, Nanes MS, Ziegler TR, Wilson PWF, Tangpricha V. Optimal vitamin D status attenuates the age-associated increase in systolic blood pressure in white Americans: results from the third National Health and Nutrition Examination Survey. Am J Clin Nutr. 2008;87(1):136-141. Exclusion code: 7. [pmid: 18175747].
Kalyani RR, Stein B, Valiyil R, Manno R, Maynard JW, Crews DC. Vitamin D treatment for the prevention of falls in older adults: systematic review and meta-analysis. J Am Geriatr Soc. 2010;58(7):1299-1310. Exclusion code: 13. [pmid: 20579169].
Kamen DL, Cooper GS, Bouali H, Shaftman SR, Hollis BW, Gilkeson GS. Vitamin D deficiency in systemic lupus erythematosus. Autoimmun Rev. 2006;5(2):114-117. Exclusion code: 7. [pmid: 16431339].
Kampman MT, Steffensen LH, Mellgren SI, Jorgensen L. Effect of vitamin D3 supplementation on relapses, disease progression, and measures of function in persons with multiple sclerosis: exploratory outcomes from a double-blind randomised controlled trial. Mult Scler. 2012;18(8):1144-1151. Exclusion code: 4. [pmid: 22354743].
Kanis JA, Johnell O, Gullberg B, et al. Evidence for efficacy of drugs affecting bone metabolism in preventing hip fracture. BMJ. 1992;305(6862):1124-1128. Exclusion code: 6. [pmid: 1463947].
Karakas M, Thorand B, Zierer A, et al. Low levels of serum 25-hydroxyvitamin D are associated with increased risk of myocardial infarction, especially in women: Results from the MONICA/KORA Augsburg case-cohort study. J Clin Endocrinol Metab. 2013;98(1):272-280. Exclusion code: 3. [pmid: 23150690].
Karhapää P, Pihlajamäki J, Pörsti I, et al. Diverse associations of 25-hydroxyvitamin D and 1,25-dihydroxy-vitamin D with dyslipidaemias. J Intern Med. 2010;268(6):604-610. Exclusion code: 6. [pmid: 20831628].
Ke L, Graubard BI, Albanes D, et al. Hypertension, pulse, and other cardiovascular risk factors and vitamin D status in Finnish men. Am J Hypertens. 2013;26(8):951-956. Exclusion code: 3. [pmid: 23598420].
Keane EM, Healy M, O'Moore R, Coakley D, Walsh JB. Vitamin D-fortified liquid milk: benefits for the elderly community-based population. Calcif Tissue Int. 1998;62(4):300-302. Exclusion code: 6. [pmid: 9504953].
Keane EM, Rochfort A, Cox J, McGovern D, Coakley D, Walsh JB. Vitamin-D-fortified liquid milk--a highly effective method of vitamin D administration for house-bound and institutionalised elderly. Gerontology. 1992;38(5):280-284. Exclusion code: 6. [pmid: 1427127].
Kearney J, Giovannucci E, Rimm EB, et al. Calcium, vitamin D, and dairy foods and the occurrence of colon cancer in men. Am J Epidemiol. 1996;143(9):907-917. Exclusion code: 7. [pmid: 8610704].
Kelly JL, Friedberg JW, Calvi LM, van Wijngaarden E, Fisher SG. Vitamin D and non-Hodgkin lymphoma risk in adults: a review. Cancer Invest. 2009;27(9):942-951. Exclusion code: 7. [pmid: 19832043].
Kelly JL, Friedberg JW, Calvi LM, van Wijngaarden E, Fisher SG. A case-control study of ultraviolet radiation exposure, vitamin D, and lymphoma risk in adults. Cancer Causes Control. 2010;21(8):1265-1275. Exclusion code: 7. [pmid: 20373010].
Kenny AM, Biskup B, Robbins B, Marcella G, Burleson JA. Effects of vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. J Am Geriatr Soc. 2003;51(12):1762-1767. Exclusion code: 15. [pmid: 14687355].
Kerse N, Butler M, Robinson E, Todd M. Fall prevention in residential care: a cluster, randomized, controlled trial. J Am Geriatr Soc. 2004;52(4):524-531. Exclusion code: 5. [pmid: 15066066].
Kesse E, Boutron-Ruault MC, Norat T, Riboli E, Clavel-Chapelon F. Dietary calcium, phosphorus, vitamin D, dairy products and the risk of colorectal adenoma and cancer among French women of the E3N-EPIC prospective study. Int J Cancer. 2005;117(1):137-144. Exclusion code: 5. [pmid: 15880532].
Kestenbaum B, Katz R, de Boer I, et al. Vitamin D, parathyroid hormone, and cardiovascular events among older adults. J Am Coll Cardiol. 2011;58(14):1433-1441. Exclusion code: 3. [pmid: 21939825].
Khadilkar AV, Sayyad MG, Sanwalka NJ, et al. Vitamin D supplementation and bone mass accrual in underprivileged adolescent Indian girls. Asia Pac J Clin Nutr. 2010;19(4):465-472. Exclusion code: 4. [pmid: 21147706].
Khan QJ, Reddy PS, Kimler BF, et al. Effect of vitamin D supplementation on serum 25-hydroxy vitamin D levels, joint pain, and fatigue in women starting adjuvant letrozole treatment for breast cancer. Breast Cancer Res Treat. 2010;119(1):111-118. Exclusion code: 4. [pmid: 19655244].
Khoo AL, Koenen HJPM, Michels M, et al. High-dose vitamin D(3) supplementation is a requisite for modulation of skin-homing markers on regulatory T cells in HIV-infected patients. AIDS Res Hum Retroviruses. 2013;29(2):299-306. Exclusion code: 6. [pmid: 22720723].
Kiebzak GM, Moore NL, Margolis S, Hollis B, Kevorkian CG. Vitamin D status of patients admitted to a hospital rehabilitation unit: Relationship to function and progress. American Journal of Physical Medicine and Rehabilitation. 2007;86(6):435-445. Exclusion code: 4. [pmid: 17515682].
Kienreich K, Tomaschitz A, Verheyen N, et al. Vitamin d and cardiovascular disease. Nutrients. 2013;5(8):3005-3021. Exclusion code: 3. [pmid: 23912328].
Kilpinen-Loisa P, Arvio M, Ilvesmaki V, Makitie O. Vitamin D status and optimal supplementation in institutionalized adults with intellectual disability. J Intellect Disabil Res. 2009;53(12):1014-1023. Exclusion code: 12. [pmid: 19845825].
Kim DH, Sabour S, Sagar UN, Adams S, Whellan DJ. Prevalence of hypovitaminosis D in cardiovascular diseases (from the National Health and Nutrition Examination Survey 2001 to 2004). Am J Cardiol. 2008;102(11):1540-1544. Exclusion code: 2. [pmid: 19026311].
Kim HW, Park CW, Shin YS, et al. Calcitriol regresses cardiac hypertrophy and QT dispersion in secondary hyperparathyroidism on hemodialysis. Nephron Clin Pract. 2006;102(1):c21-29. Exclusion code: 14. [pmid: 16166802].
Kimball S, Vieth R, Dosch HM, et al. Cholecalciferol plus calcium suppresses abnormal PBMC reactivity in patients with multiple sclerosis. J Clin Endocrinol Metab. 2011;96(9):2826-2834. Exclusion code: 6. [pmid: 21697250].
Kimball SM, Ursell MR, O'Connor P, Vieth R. Safety of vitamin D3 in adults with multiple sclerosis. Am J Clin Nutr. 2007;86(3):645-651. Exclusion code: 15. [pmid: 17823429].
Kinyamu HK, Gallagher JC, Balhorn KE, Petranick KM, Rafferty KA. Serum vitamin D metabolites and calcium absorption in normal young and elderly free-living women and in women living in nursing homes. Am J Clin Nutr. 1997;65(3):790-797. Exclusion code: 6. [pmid: 9062531].
Kirii K, Mizoue T, Iso H, et al. Calcium, vitamin D and dairy intake in relation to type 2 diabetes risk in a Japanese cohort. Diabetologia. 2009;52(12):2542-2550. Exclusion code: 5. [pmid: 19823801].
Kolb H, Mandrup-Poulsen T. An immune origin of type 2 diabetes?. Diabetologia. 2005;48(6):1038-1050. Exclusion code: 6. [pmid: 15864529].
Komulainen M, Kroger H, Tuppurainen MT, et al. Prevention of femoral and lumbar bone loss with hormone replacement therapy and vitamin D3 in early postmenopausal women: a population-based 5-year randomized trial. J Clin Endocrinol Metab. 1999;84(2):546-552. Exclusion code: 14. [pmid: 10022414].
Komulainen MH, Kroger H, Tuppurainen MT, et al. HRT and Vit D in prevention of non-vertebral fractures in postmenopausal women; a 5 year randomized trial. Maturitas. 1998;31(1):45-54. Exclusion code: 14. [pmid: 10091204].
Kota SK, Jammula S, Kota SK, Tripathy PR, Panda S, Modi KD. Effect of vitamin D supplementation in type 2 diabetes patients with pulmonary tuberculosis. Diabetes Metab Syndr. 2011;5(2):85-89. Exclusion code: 4. [pmid: 22813409].
Krall EA, Dawson-Hughes B. Relation of fractional 47Ca retention to season and rates of bone loss in healthy postmenopausal women. J Bone Miner Res. 1991;6(12):1323-1329. Exclusion code: 6. [pmid: 1792943].
Krause R, Buhring M, Hopfenmuller W, Holick MF, Sharma AM. Ultraviolet B and blood pressure. Lancet. 1998;352(9129):709-710. Exclusion code: 5. [pmid: 9728997].
Kreiter SR, Schwartz RP, Kirkman HN Jr, Charlton PA, Calikoglu AS, Davenport ML. Nutritional rickets in African American breast-fed infants. J Pediatr. 2000;137(2):153-157. Exclusion code: 4. [pmid: 10931404].
Kristal-Boneh E, Froom P, Harari G, Ribak J. Association of calcitriol and blood pressure in normotensive men. Hypertension. 1997;30(5):1289-1294. Exclusion code: 7. [pmid: 9369290].
Kritchevsky SB, Tooze JA, Neiberg RH, et al. 25-Hydroxyvitamin D, parathyroid hormone, and mortality in black and white older adults: The health ABC study. J Clin Endocrinol Metab. 2012;97(11):4156-4165. Exclusion code: 3. [pmid: 22942386].
Kruger MC, Schollum LM, Kuhn-Sherlock B, et al. The effect of a fortified milk drink on vitamin D status and bone turnover in post-menopausal women from South East Asia. Bone. 2010;46(3):759-767. Exclusion code: 5. [pmid: 19895912].
Kumar A, Devi SG, Batra S, Singh C, Shukla DK. Calcium supplementation for the prevention of pre-eclampsia. Int J Gynaecol Obstet. 2009;104(1):32-36. Exclusion code: 4. [pmid: 18851852].
Kumar J, Muntner P, Kaskel FJ, Hailpern SM, Melamed ML. Prevalence and associations of 25-hydroxyvitamin D deficiency in US children: NHANES 2001-2004. Pediatrics. 2009;124(3):e362-e370. Exclusion code: 4. [pmid: 19661054].
Kumar PR, Fenton TR, Shaheen AA, Raman M. Prevalence of vitamin D deficiency and response to oral vitamin D supplementation in patients receiving home parenteral nutrition. J Parenter Enteral Nutr. 2012;36(4):463-469. Exclusion code: 7.
Kunisaki KM, Niewoehner DE, Connett JE, Network CCR. Vitamin D levels and risk of acute exacerbations of chronic obstructive pulmonary disease: a prospective cohort study. Am J Respir Crit Care Med. 2012;185(3):286-290. Exclusion code: 4. [pmid: 22077070].
Kuroda T, Shiraki M, Tanaka S, Ohta H. Contributions of 25-hydroxyvitamin D, co-morbidities and bone mass to mortality in Japanese postmenopausal women. Bone. 2009;44(1):168-172. Exclusion code: 3. [pmid: 19010116].
Kuwabara A, Tsugawa N, Tanaka K, et al. Improvement of vitamin D status in Japanese institutionalized elderly by supplementation with 800 IU of vitamin D(3). J Nutr Sci Vitaminol. 2009;55(6):453-458. Exclusion code: 6. [pmid: 20086314].
Kyriakidou-Himonas M, Aloia JF, Yeh JK. Vitamin D supplementation in postmenopausal black women. J Clin Endocrinol Metab. 1999;84(11):3988-3990. Exclusion code: 6. [pmid: 10566638].
Laaksi I, Ruohola JP, Mattila V, Auvinen A, Ylikomi T, Pihlajamaki H. Vitamin D supplementation for the prevention of acute respiratory tract infection: a randomized, double-blinded trial among young Finnish men. J Infect Dis. 2010;202(5):809-814. Exclusion code: 15. [pmid: 20632889].
Laaksi I, Ruohola JP, Tuohimaa P, et al. An association of serum vitamin D concentrations < 40 nmol/L with acute respiratory tract infection in young Finnish men. Am J Clin Nutr. 2007;86(3):714-717. Exclusion code: 3. [pmid: 17823437].
Lagari VS, Gomez-Marin O, Levis S. Differences in vitamin D3 dosing regimens in a geriatric community-dwelling population. Endocr Pract. 2012;18(6):847-854. Exclusion code: 6. [pmid: 22784845].
Lagunova Z, Porojnicu AC, Aksnes L, et al. Effect of vitamin D supplementation and ultraviolet B exposure on serum 25-hydroxyvitamin D concentrations in healthy volunteers: A randomized, crossover clinical trial. Br J Dermatol. 2013;169(2):434-440. Exclusion code: 6. [pmid: 23551243].
Lagunova Z, Porojnicu AC, Grant WB, Bruland O, Moan JE. Obesity and increased risk of cancer: does decrease of serum 25-hydroxyvitamin D level with increasing body mass index explain some of the association?. Mol Nutr Food Res. 2010;54(8):1127-1133. Exclusion code: 7. [pmid: 20512788].
Lalau JD, Jans I, el Esper N, Bouillon R, Fournier A. Calcium metabolism, plasma parathyroid hormone, and calcitriol in transient hypertension of pregnancy. Am J Hypertens. 1993;6(6 Pt 1):522-527. Exclusion code: 4. [pmid: 8343236].
Landin-Wilhelmsen K, Wilhelmsen L, Bengtsson BA. Postmenopausal osteoporosis is more related to hormonal aberrations than to lifestyle factors. Clin Endocrinol (Oxf). 1999;51(4):387-394. Exclusion code: 7. [pmid: 10583303].
Lansdowne AT, Provost SC. Vitamin D3 enhances mood in healthy subjects during winter. Psychopharmacology (Berl). 1998;135(4):319-323. Exclusion code: 14. [pmid: 9539254].
Lapid MI, Cha SS, Takahashi PY. Vitamin D and depression in geriatric primary care patients. Clin Interv Aging. 2013;8:509-514. Exclusion code: 7. [pmid: 23667311].
Lappe J, Cullen D, Haynatzki G, Recker R, Ahlf R, Thompson K. Calcium and vitamin d supplementation decreases incidence of stress fractures in female navy recruits. J Bone Miner Res. 2008;23(5):741-749. Exclusion code: 4. [pmid: 18433305].
Lappe JM, Heaney RP. Why randomized controlled trials of calcium and vitamin D sometimes fail. Dermatoendocrinol. 2012;4(2):95-100. Exclusion code: 2. [pmid: 22928064].
Lappe JM, Travers-Gustafson D, Davies KM, Recker RR, Heaney RP. Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. 2007;85(6):1586-1591. Exclusion code: 15. [pmid: 17556697].
Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents osteoporotic fractures in elderly community dwelling residents: A pragmatic population-based 3-year intervention study. J Bone Miner Res. 2004;19(3):370-378. Exclusion code: 14. [pmid: 15040824].
Larsen ER, Mosekilde L, Foldspang A. Vitamin D and calcium supplementation prevents severe falls in elderly community-dwelling women: a pragmatic population-based 3-year intervention study. Aging Clin. 2005;17(2):125-132. Exclusion code: 14.
Larsen T, Mose FH, Bech JN, Hansen AB, Pedersen EB. Effect of cholecalciferol supplementation during winter months in patients with hypertension: a randomized, placebo-controlled trial. Am J Hypertens. 2012;25(11):1215-1222. Exclusion code: 15. [pmid: 22854639].
Laslett LL, Quinn S, Burgess JR, et al. Moderate vitamin D deficiency is associated with changes in knee and hip pain in older adults: a 5-year longitudinal study. Ann Rheum Dis. 2014;73(4):697-703. Exclusion code: 7. [pmid: 23595144].
Latham NK, Anderson CS, Lee A, Bennett DA, Moseley A, Cameron ID. A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc. 2003;51(3):291-299. Exclusion code: 4. [pmid: 12588571].
Latham NK, Anderson CS, Reid IR. Effects of vitamin D supplementation on strength, physical performance, and falls in older persons: a systematic review. J Am Geriatr Soc. 2003;51(9):1219-1226. Exclusion code: 13. [pmid: 12919233].
Lau EMC, Woo J, Swaminathan R, MacDonald D, Donnan SPB. Plasma 25-hydroxyvitamin D concentration in patients with hip fracture in Hong Kong. Gerontology. 1989;35(4):198-204. Exclusion code: 4. [pmid: 2583533].
Launoy G, Milan C, Day NE, Pienkowski MP, Gignoux M, Faivre J. Diet and squamous-cell cancer of the oesophagus: a French multicentre case-control study. Int J Cancer. 1998;76(1):7-12. Exclusion code: 7. [pmid: 9533754].
Law M, Withers H, Morris J, Anderson F. Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age Ageing. 2006;35(5):482-486. Exclusion code: 14. [pmid: 16641143].
LeBoff MS, Kohlmeier L, Hurwitz S, Franklin J, Wright J, Glowacki J. Occult vitamin D deficiency in postmenopausal US women with acute hip fracture. JAMA. 1999;281(16):1505-1511. Exclusion code: 7. [pmid: 10227320].
Lee DM, Tajar A, Ulubaev A, et al. Association between 25-hydroxyvitamin D levels and cognitive performance in middle-aged and older European men. J Neurol Neurosurg Psychiatry. 2009;80(7):722-729. Exclusion code: 7. [pmid: 19460797].
Lee JE, Li H, Chan AT, et al. Circulating levels of vitamin D and colon and rectal cancer: the Physicians' Health Study and a meta-analysis of prospective studies. Cancer Prev Res. 2011;4(5):735-743. Exclusion code: 3.
Lee JM, Smith JR, Philipp BL, Chen TC, Mathieu J, Holick MF. Vitamin D deficiency in a healthy group of mothers and newborn infants. Clin Pediatr (Phila). 2007;46(1):42-44. Exclusion code: 4. [pmid: 17164508].
Lee L, Kang SA, Lee HO, et al. Relationships between dietary intake and cognitive function level in Korean elderly people. Public Health. 2001;115(2):133-138. Exclusion code: 5. [pmid: 11406779].
Leffelaar ER, Vrijkotte TG, van Eijsden M. Maternal early pregnancy vitamin D status in relation to fetal and neonatal growth: results of the multi-ethnic Amsterdam Born Children and their Development cohort. Br J Nutr. 2010;104(1):108-117. Exclusion code: 4. [pmid: 20193097].
Lehtonen-Veromaa MK, Mottonen TT, Nuotio IO, Irjala KM, Leino AE, Viikari JS. Vitamin D and attainment of peak bone mass among peripubertal Finnish girls: a 3-y prospective study. Am J Clin Nutr. 2002;76(6):1446-1453. Exclusion code: 4. [pmid: 12450915].
Lemmila S, Saha H, Virtanen V, Ala-Houhala I, Pasternack A. Effect of intravenous calcitriol on cardiac systolic and diastolic function in patients on hemodialysis. Am J Nephrol. 1998;18(5):404-410. Exclusion code: 5. [pmid: 9730564].
Leu M, Giovannucci E. Vitamin D: epidemiology of cardiovascular risks and events. Best Pract Res Clin Endocrinol Metab. 2011;25(4):633-646. Exclusion code: 3. [pmid: 21872804].
Leventis P, Kiely PDW. The tolerability and biochemical effects of high-dose bolus vitamin D2 and D3 supplementation in patients with vitamin D insufficiency. Scand J Rheumatol. 2009;38(2):149-153. Exclusion code: 12. [pmid: 18991184].
Levi F, Pasche C, Lucchini F, La Vecchia C. Dietary intake of selected micronutrients and breast-cancer risk. Int J Cancer. 2001;91(2):260-263. Exclusion code: 7. [pmid: 11146455].
Levi J, Vinter S, Richardson L, Laurent R, Segal LM. F as in Fat: How Obesity Policies Are Failing in America, 2009. Washington, DC. Trust For America's Health. 2009. Exclusion code: 8.
Levine AJ, Harper JM, Ervin CM, et al. Serum 25-hydroxyvitamin D, dietary calcium intake, and distal colorectal adenoma risk. Nutr Cancer. 2001;39(1):35-41. Exclusion code: 7. [pmid: 11588900].
Levitan EB, Judd SE. Can vitamin D supplementation improve physical function and quality of life in older patients with heart failure?. Circ Heart Fail. 2010;3(2):183-184. Exclusion code: 8. [pmid: 20233991].
Lewis RM, Redzic M, Thomas DT. The effects of season-long vitamin D supplementation on collegiate swimmers and divers. International journal of sport nutrition and exercise metabolism. 2013;23(5):431-440. Exclusion code: 15.
Li H, Stampfer MJ, Hollis JB, et al. A prospective study of plasma vitamin D metabolites, vitamin D receptor polymorphisms, and prostate cancer. PLoS Med. 2007;4(3):e103. Exclusion code: 6. [pmid: 17388667].
Lieben L, Masuyama R, Torrekens S, et al. Normocalcemia is maintained in mice under conditions of calcium malabsorption by vitamin D-induced inhibition of bone mineralization. J Clin Invest. 2012;122(5):1803-1815. Exclusion code: 4. [pmid: 22523068].
Lim S, Kim MJ, Choi SH, et al. Association of vitamin D deficiency with incidence of type 2 diabetes in high-risk Asian subjects. Am J Clin Nutr. 2013;97(3):524-530. Exclusion code: 7. [pmid: 23364011].
Lim U, Freedman DM, Hollis BW, et al. A prospective investigation of serum 25-hydroxyvitamin D and risk of lymphoid cancers. Int J Cancer. 2009;124(4):979-986. Exclusion code: 6. [pmid: 19035445].
Lin J, Manson JE, Lee IM, Cook NR, Buring JE, Zhang SM. Intakes of calcium and vitamin D and breast cancer risk in women. Arch Intern Med. 2007;167(10):1050-1059. Exclusion code: 5. [pmid: 17533208].
Lin SW, Chen W, Fan JH, et al. Prospective study of serum 25-hydroxyvitamin d concentration and mortality in a chinese population. Am J Epidemiol. 2012;176(11):1043-1050. Exclusion code: 3. [pmid: 23139250].
Lind L, Wengle B, Wide L, Ljunghall S. Reduction of blood pressure during long-term treatment with active vitamin D (alphacalcidol) is dependent on plasma renin activity and calcium status. A double-blind, placebo-controlled study. Am J Hypertens. 1989;2(1):20-25. Exclusion code: 14. [pmid: 2643969].
Linday LA, Shindledecker RD, Dolitsky JN, Chen TC, Holick MF. Plasma 25-hydroxyvitamin D levels in young children undergoing placement of tympanostomy tubes. Ann Otol Rhinol Laryngol. 2008;117(10):740-744. Exclusion code: 4. [pmid: 18998501].
Linden V. Vitamin D and myocardial infarction. Br Med J. 1974;3(5932):647-650. Exclusion code: 5. [pmid: 4425790].
Li-Ng M, Aloia JF, Pollack S, et al. A randomized controlled trial of vitamin D3 supplementation for the prevention of symptomatic upper respiratory tract infections. Epidemiol Infect. 2009;137(10):1396-1404. Exclusion code: 15. [pmid: 19296870].
Linos E, Keiser E, Kanzler M, et al. Sun protective behaviors and vitamin D levels in the US population: NHANES 2003-2006. Cancer Causes Control. 2012;23(1):133-140. Exclusion code: 2. [pmid: 22045154].
Lippi G, Montagnana M, Meschi T, Borghi L. Vitamin D concentration and deficiency across different ages and genders. Aging Clin. 2012;24(5):548-551. Exclusion code: 6.
Lippi G, Montagnana M, Targher G, Guidi GC. Relationship between serum vitamin D and inflammatory markers in the general population: comment on the article by Patel et al. Arthritis Rheum. 2008;58(3):913-914. Exclusion code: 7. [pmid: 18311799].
Lips P. Vitamin D deficiency and osteoporosis: the role of vitamin D deficiency and treatment with vitamin D and analogues in the prevention of osteoporosis-related fractures. Eur J Clin Invest. 1996;26(6):436-442. Exclusion code: 7. [pmid: 8817154].
Lips P. Vitamin D deficiency and secondary hyperparathyroidism in the elderly: consequences for bone loss and fractures and therapeutic implications. Endocr Rev. 2001;22(4):477-501. Exclusion code: 8. [pmid: 11493580].
Lips P. Which circulating level of 25-hydroxyvitamin D is appropriate?. J Steriod Biochem Mol Biol. 2004;89-90(1-5):611-614. Exclusion code: 8.
Lips P. Vitamin D physiology. Prog Biophys Mol Biol. 2006;92(1):4-8. Exclusion code: 13. [pmid: 16563471].
Lips P, Bouillon R, van Schoor NM, et al. Reducing fracture risk with calcium and vitamin D. Clin Endocrinol (Oxf). 2010;73(3):277-285. Exclusion code: 7. [pmid: 20796001].
Lips P, Duong T, Oleksik A, et al. A global study of vitamin D status and parathyroid function in postmenopausal women with osteoporosis: Baseline data from the multiple outcomes of raloxifene evaluation clinical trial. J Clin Endocrinol Metab. 2001;86(3):1212-1221. Exclusion code: 4. [pmid: 11238511].
Lips P, Hackeng WHL, Jongen MJM, van Ginkel FC, Netelenbos JC. Seasonal variation in serum concentrations of parathyroid hormone in elderly people. J Clin Endocrinol Metab. 1983;57(1):204-206. Exclusion code: 6. [pmid: 6853678].
Lips P, Van Ginkel FC, Jongen MJM, Rubertus F, Van der Vijgh WJF, Netelenbos JC. Determinants of vitamin D status in patients with hip fracture and in elderly control subjects. Am J Clin Nutr. 1987;46(6):1005-1010. Exclusion code: 7. [pmid: 3687818].
Lips P, Wiersinga A, van Ginkel FC, et al. The effect of vitamin D supplementation on vitamin D status and parathyroid function in elderly subjects. J Clin Endocrinol Metab. 1988;67(4):644-650. Exclusion code: 6. [pmid: 3417845].
Lister T. Should long-term care residents be supplemented with vitamin D?. Can J Diet Pract Res. 2008;69(1):28-31. Exclusion code: 7. [pmid: 18334051].
Liu E, McKeown NM, Pittas AG, et al. Predicted 25-hydroxyvitamin D score and change in fasting plasma glucose in the Framingham offspring study. Eur J Clin Nutr. 2012;66(1):139-141. Exclusion code: 7. [pmid: 22009071].
Liu E, Meigs JB, Pittas AG, et al. Predicted 25-hydroxyvitamin D score and incident type 2 diabetes in the Framingham Offspring Study. Am J Clin Nutr. 2010;91(6):1627-1633. Exclusion code: 7. [pmid: 20392893].
Liu PT, Stenger S, Li H, et al. Toll-like receptor triggering of a vitamin D-mediated human antimicrobial response. Science. 2006;311(5768):1770-1773. Exclusion code: 4. [pmid: 16497887].
Liu S, Song Y, Ford ES, Manson JE, Buring JE, Ridker PM. Dietary calcium, vitamin D, and the prevalence of metabolic syndrome in middle-aged and older U.S. women. Diabetes Care. 2005;28(12):2926-2932. Exclusion code: 5. [pmid: 16306556].
Llewellyn DJ, Langa KM, Lang IA. Serum 25-hydroxyvitamin D concentration and cognitive impairment. J Geriatr Psychiatry Neurol. 2009;22(3):188-195. Exclusion code: 7. [pmid: 19073839].
Logan VF, Gray AR, Peddie MC, Harper MJ, Houghton LA. Long-term vitamin D3 supplementation is more effective than vitamin D2 in maintaining serum 25-hydroxyvitamin D status over the winter months. Br J Nutr. 2013;109(6):1082-1088. Exclusion code: 6. [pmid: 23168298].
Løken-Amsrud KH T, Bakke SJ, Beiske AG, Bjerve KS, Bjørnarå BT, Hovdal H, Lilleås F, Midgard R, Pedersen T, Benth JS, Sandvik L, Torkildsen O, Wergeland S, Myhr KM. Vitamin D and disease activity in multiple sclerosis before and during interferon-β treatment. Neurology. 2012;79(3):261-266. Exclusion code: 6. [pmid: 22700811].
Longenecker CT, Hileman CO, Carman TL, et al. Vitamin D supplementation and endothelial function in vitamin D deficient HIV-infected patients: a randomized placebo-controlled trial. Antivir Ther. 2012;17(4):613-621. Exclusion code: 6. [pmid: 22293363].
Looker AC, Dawson-Hughes B, Calvo MS, Gunter EW, Sahyoun NR. Serum 25-hydroxyvitamin D status of adolescents and adults in two seasonal subpopulations from NHANES III. Bone. 2002;30(5):771-777. Exclusion code: 2. [pmid: 11996918].
Looker AC, Johnson CL, Lacher DA, Pfeiffer CM, Schleicher RL, Sempos CT. Vitamin D Status: United States, 2001-2006. Hyattsville, MD. 2011. Exclusion code: 2.
Lowe LC, Guy M, Mansi JL, et al. Plasma 25-hydroxy vitamin D concentrations, vitamin D receptor genotype and breast cancer risk in a UK Caucasian population. Eur J Cancer. 2005;41(8):1164-1169. Exclusion code: 7. [pmid: 15911240].
Luczynska A, Kaaks R, Rohrmann S, et al. Plasma 25-hydroxyvitamin D concentration and lymphoma risk: results of the European Prospective Investigation into Cancer and Nutrition. Am J Clin Nutr. 2013;98(3):827-838. Exclusion code: 3. [pmid: 23885049].
Lund B, Badskjaer J, Soerensen OH. Vitamin D and ischaemic heart disease. Horm Metab Res. 1978;10(6):553-556. Exclusion code: 7. [pmid: 744575].
Lund B, Sorensen OH, Christensen AB. 25-Hydroxycholecaliferol and fractures of the proximal. Lancet. 1975;2(7929):300-302. Exclusion code: 4. [pmid: 50509].
Lyons RA, Johansen A, Brophy S, et al. Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int. 2007;18(6):811-818. Exclusion code: 14. [pmid: 17473911].
Maalouf J, Nabulsi M, Vieth R, et al. Short- and long-term safety of weekly high-dose vitamin D3 supplementation in school children. J Clin Endocrinol Metab. 2008;93(7):2693-2701. Exclusion code: 4. [pmid: 18445674].
MacDonald D, Lau E, Chan ELP, et al. Serum intact parathyroid hormone levels in elderly Chinese females with hip fracture. Calcif Tissue Int. 1992;51(6):412-414. Exclusion code: 7. [pmid: 1451007].
MacLaughlin J, Holick MF. Aging decreases the capacity of human skin to produce vitamin D3. J Clin Invest. 1985;76(4):1536-1538. Exclusion code: 4. [pmid: 2997282].
Mai XM, Langhammer A, Camargo CA, Chen Y. Serum 25-hydroxyvitamin D levels and incident asthma in adults. Am J Epidemiol. 2012;176(12):1169-1176. Exclusion code: 3. [pmid: 23204497].
Majak P, Jerzynska J, Smejda K, Stelmach I, Timler D, Stelmach W. Correlation of vitamin D with Foxp3 induction and steroid-sparing effect of immunotherapy in asthmatic children. Ann Allergy Asthma Immunol. 2012;109(5):329-335. Exclusion code: 4. [pmid: 23062388].
Major GC, Alarie F, Dore J, Phouttama S, Tremblay A. Supplementation with calcium + vitamin D enhances the beneficial effect of weight loss on plasma lipid and lipoprotein concentrations. Am J Clin Nutr. 2007;85(1):54-59. Exclusion code: 14. [pmid: 17209177].
Maki KC, Rubin MR, Wong LG, McManus JF, Jensen CD, Lawless A. Effects of vitamin D supplementation on 25-hydroxyvitamin D, high-density lipoprotein cholesterol, and other cardiovascular disease risk markers in subjects with elevated waist circumference. Int J Food Sci Nutr. 2011;62(4):318-327. Exclusion code: 15. [pmid: 21250901].
Malabanan A, Veronikis I, Holick M. Redefining Vitamin D Insufficiency. Lancet. 1998;351(9105):805-806. Exclusion code: 2. [pmid: 9519960].
Mallet E, Gugi B, Brunelle P, Henocq A, Basuyau JP, Lemeur H. Vitamin D supplementation in pregnancy: a controlled trial of two methods. Obstet Gynecol. 1986;68(3):300-304. Exclusion code: 4. [pmid: 3755517].
Manders M, De Groot LC, Hoefnagels WH, et al. The effect of a nutrient dense drink on mental and physical function in institutionalized elderly people. J Nurt Health Aging. 2009;13(9):760-767. Exclusion code: 5.
Manson JE, Allison MA, Carr JJ, et al. Calcium/vitamin D supplementation and coronary artery calcification in the Women's Health Initiative. Menopause. 2010;17(4):683-691. Exclusion code: 14. [pmid: 20551849].
Manson JE, Mayne ST, Clinton SK. Vitamin D and prevention of cancer--ready for prime time?. N Engl J Med. 2011;364(15):1385-1387. Exclusion code: 8. [pmid: 21428761].
Margolis KL, Ray RM, Van Horn L, et al. Effect of calcium and vitamin D supplementation on blood pressure: the Women's Health Initiative Randomized Trial. Hypertension. 2008;52(5):847-855. Exclusion code: 3. [pmid: 18824662].
Vitamin D deficiency rickets in northern Europe and Libya. Raven Press. 1991. Exclusion code: 4.
Marniemi J, Alanen E, Impivaara O, et al. Dietary and serum vitamins and minerals as predictors of myocardial infarction and stroke in elderly subjects. Nutr Metab Cardiovasc Dis. 2005;15(3):188-197. Exclusion code: 3. [pmid: 15955467].
Martineau AR, Timms PM, Bothamley GH, et al. High-dose vitamin D(3) during intensive-phase antimicrobial treatment of pulmonary tuberculosis: a double-blind randomised controlled trial. Lancet. 2011;377(9761):242-250. Exclusion code: 4. [pmid: 21215445].
Martins D, Wolf M, Pan D, et al. Prevalence of cardiovascular risk factors and the serum levels of 25-hydroxyvitamin D in the United States: data from the Third National Health and Nutrition Examination Survey. Arch Intern Med. 2007;167(11):1159-1165. Exclusion code: 6. [pmid: 17563024].
Marwaha RK, Tandon N, Reddy DR, et al. Vitamin D and bone mineral density status of healthy schoolchildren in northern India. Am J Clin Nutr. 2005;82(2):477-482. Exclusion code: 4. [pmid: 16087996].
Marya RK, Rathee S, Dua V, Sangwan K. Effect of vitamin D supplementation during pregnancy on foetal growth. Indian J Med Res. 1988;88:488-492. Exclusion code: 4. [pmid: 3243609].
Marya RK, Rathee S, Manrow M. Effect of calcium and vitamin D supplementation on toxaemia of pregnancy. Gynecol Obstet Invest. 1987;24(1):38-42. Exclusion code: 4. [pmid: 3623260].
Mason RS, Lissner D, Grunstein HS, Posen S. A simplified assay for dihydroxylated vitamin D metabolites in human serum: application to hyper- and hypovitaminosis D. Clin Chem. 1980;26(3):444-450. Exclusion code: 5. [pmid: 6892691].
Mastaglia SR, Mautalen CA, Parisi MS, Oliveri B. Vitamin D2 dose required to rapidly increase 25OHD levels in osteoporotic women. Eur J Clin Nutr. 2006;60(5):681-687. Exclusion code: 4. [pmid: 16391587].
Matsuoka LY, Ide L, Wortsman J, MacLaughlin JA, Holick MF. Sunscreens suppress cutaneous vitamin D3 synthesis. J Clin Endocrinol Metab. 1987;64(6):1165-1168. Exclusion code: 2. [pmid: 3033008].
Mattila C, Knekt P, Mannisto S, et al. Serum 25-hydroxyvitamin D concentration and subsequent risk of type 2 diabetes. Diabetes Care. 2007;30(10):2569-2570. Exclusion code: 3. [pmid: 17626891].
Mawer EB, Hann JT, Berry JL, Davies M. Vitamin D metabolism in patients intoxicated with ergocalciferol. Clin Sci (Lond). 1985;68(2):135-141. Exclusion code: 7. [pmid: 3871380].
Maxwell JD, Ang L, Brooke OG, Brown IR. Vitamin D supplements enhance weight gain and nutritional status in pregnant Asians. Br J Obstet Gynaecol. 1981;88(10):987-991. Exclusion code: 4. [pmid: 6793058].
May HT, Bair TL, Lappe DL, et al. Association of vitamin D levels with incident depression among a general cardiovascular population. Am Heart J. 2010;159(6):1037-1043. Exclusion code: 4. [pmid: 20569717].
McAlindon TE, Felson DT, Zhang Y, et al. Relation of dietary intake and serum levels of vitamin D to progression of osteoarthritis of the knee among participants in the Framingham Study. Ann Intern Med. 1996;125(5):353-359. Exclusion code: 6. [pmid: 8702085].
McCullough ML, Bostick RM, Daniel CR, et al. Vitamin D status and impact of vitamin D3 and/or calcium supplementation in a randomized pilot study in the Southeastern United States. J Am Coll Nutr. 2009;28(6):678-686. Exclusion code: 15. [pmid: 20516268].
McCullough ML, Robertson AS, Rodriguez C, et al. Calcium, vitamin D, dairy products, and risk of colorectal cancer in the Cancer Prevention Study II Nutrition Cohort (United States). Cancer Causes Control. 2003;14(1):1-12. Exclusion code: 5. [pmid: 12708719].
McCullough ML, Rodriguez C, Diver WR, et al. Dairy, calcium, and vitamin D intake and postmenopausal breast cancer risk in the Cancer Prevention Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev. 2005;14(12):2898-2904. Exclusion code: 5. [pmid: 16365007].
McCullough ML, Stevens VL, Patel R, et al. Serum 25-hydroxyvitamin D concentrations and postmenopausal breast cancer risk: a nested case control study in the Cancer Prevention Study-II Nutrition Cohort. Breast Cancer Res. 2009;11(4):R64. Exclusion code: 3. [pmid: 19715600].
McGill AT, Stewart JM, Lithander FE, Strik CM, Poppitt SD. Relationships of low serum vitamin D3 with anthropometry and markers of the metabolic syndrome and diabetes in overweight and obesity. Nutr J. 2008;7(1). Exclusion code: 6.
McGrath J, Scragg R, Chant D, Eyles D, Burne T, Obradovic D. No association between serum 25-hydroxyvitamin D3 level and performance on psychometric tests in NHANES III. Neuroepidemiology. 2007;29(1-2):49-54. Exclusion code: 7. [pmid: 17898524].
McGrath JJ, Eyles DW, Pedersen CB, et al. Neonatal vitamin D status and risk of schizophrenia: a population-based case-control study. Arch Gen Psychiatry. 2010;67(9):889-894. Exclusion code: 4. [pmid: 20819982].
McKee J. Studies find patients have low levels of Vitamin D. AAOS Now. 2012. http://www.aaos.org/news/aaosnow/mar12/clinical2.asp. January 15, 2014. Exclusion code: 2.
McKiernan FE, Wiley C. Vitamin D2, vitamin D3, and the tolerable upper intake level. J Bone Miner Res. 2008;23(12):2060-2061. Exclusion code: 8. [pmid: 18684090].
McKinney JD, Bailey BA, Garrett LH, Peiris P, Manning T, Peiris AN. Relationship between vitamin D status and ICU outcomes in veterans. J Am Med Dir Assoc. 2011;12(3):208-211. Exclusion code: 7. [pmid: 21333923].
McMurdo ME, Millar AM, Daly F. A randomized controlled trial of fall prevention strategies in old peoples' homes. Gerontology. 2000;46(2):83-87. Exclusion code: 5. [pmid: 10671804].
Meier C, Woitge HW, Witte K, Lemmer B, Seibel MJ. Supplementation with oral vitamin D3 and calcium during winter prevents seasonal bone loss: a randomized controlled open-label prospective trial. J Bone Miner Res. 2004;19(8):1221-1230. Exclusion code: 15. [pmid: 15231008].
Meier DE, Luckey MM, Wallenstein S, Clemens TL, Orwoll ES, Waslien CI. Calcium, vitamin D, and parathyroid hormone status in young white and black women: Association with racial differences in bone mass. J Clin Endocrinol Metab. 1991;72(3):703-710. Exclusion code: 7. [pmid: 1997523].
Melamed ML, Muntner P, Michos ED, et al. Serum 25-hydroxyvitamin D levels and the prevalence of peripheral arterial disease: results from NHANES 2001 to 2004. Arterioscler Thromb Vasc Biol. 2008;28(6):1179-1185. Exclusion code: 7. [pmid: 18417640].
Melhus H, Snellman G, Gedeborg R, et al. Plasma 25-hydroxyvitamin D levels and fracture risk in a community-based cohort of elderly men in Sweden. J Clin Endocrinol Metab. 2010;95(6):2637-2645. Exclusion code: 3. [pmid: 20332246].
Melin A, Wilske J, Ringertz H, Saaf M. Seasonal variations in serum levels of 25-hydroxyvitamin D and parathyroid hormone but no detectable change in femoral neck bone density in an older population with regular outdoor exposure. J Am Geriatr Soc. 2001;49(9):1190-1196. Exclusion code: 5. [pmid: 11559378].
Menczel J, Foldes J, Steinberg R, et al. Alfacalcidol (alpha D3) and calcium in osteoporosis. Clin Orthop Relat Res. 1994;(300):241-247. Exclusion code: 4. [pmid: 8131343].
Merewood A, Mehta SD, Chen TC, Bauchner H, Holick MF. Association between vitamin D deficiency and primary cesarean section. J Clin Endocrinol Metab. 2009;94(3):940-945. Exclusion code: 4. [pmid: 19106272].
Merlino LA, Curtis J, Mikuls TR, Cerhan JR, Criswell LA, Saag KG. Vitamin D intake is inversely associated with rheumatoid arthritis: results from the Iowa Women's Health Study. Arthritis Rheum. 2004;50(1):72-77. Exclusion code: 5. [pmid: 14730601].
Messenger W, Nielson CM, Li H, et al. Serum and dietary vitamin D and cardiovascular disease risk in elderly men: A prospective cohort study. Nutr Metab Cardiovasc Dis. 2012;22(10):856-863. Exclusion code: 3. [pmid: 21466949].
Meunier PJ. Prevention of hip fractures. Am J Med. 1993;95(5 A):75S-78S. Exclusion code: 8. [pmid: 8256801].
Meunier PJ, Chapuy MC, Arlot ME, Delmas PD, Duboeuf F. Can we stop bone loss and prevent hip fractures in the elderly?. Osteoporos Int. 1994;4(SUPPL. 1):S71-S76. Exclusion code: 8.
Meyer G, Warnke A, Bender R, Muhlhauser I. Effect on hip fractures of increased use of hip protectors in nursing homes: cluster randomised controlled trial. BMJ. 2003;326(7380):76. Exclusion code: 5. [pmid: 12521969].
Meyer HE, Robsahm TE, Bjørge T, Brustad M, Blomhoff R. Vitamin D, season, and risk of prostate cancer: A nested case-control study within Norwegian health studies. Am J Clin Nutr. 2013;97(1):147-154. Exclusion code: 3. [pmid: 23193007].
Meyer HE, Smedshaug GB, Kvaavik E, Falch JA, Tverdal A, Pedersen JI. Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res. 2002;17(4):709-715. Exclusion code: 15. [pmid: 11918228].
Michael YL, Smit E, Seguin R, Curb JD, Phillips LS, Manson JE. Serum 25-hydroxyvitamin D and physical performance in postmenopausal women. J Womens Health. 2011;20(11):1603-1608. Exclusion code: 3.
Michael YL, Whitlock EP, Lin JS, Fu R, O'Connor EA, Gold R. Primary care-relevant interventions to prevent falling in older adults: A systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(12):815-825. Exclusion code: 2. [pmid: 21173416].
Michelson D, Stratakis C, Hill L, et al. Bone mineral density in women with depression. N Engl J Med. 1996;335(16):1176-1181. Exclusion code: 7. [pmid: 8815939].
Michos E. Vitamin-D deficiency linked to fatal stroke in whites but not blacks. Risk of Fatal Stroke Associated with Vitamin-D Deficiency (25[OH]D <15 Ng/mL) in White Vs Black Participants. 2010. Exclusion code: 8.
Michos ED, Melamed ML. Vitamin D and cardiovascular disease risk. Curr Opin Clin Nutr Metab Care. 2008;11(1):7-12. Exclusion code: 7. [pmid: 18090651].
Mikhak B, Hunter DJ, Spiegelman D, Platz EA, Hollis BW, Giovannucci E. Vitamin D receptor (VDR) gene polymorphisms and haplotypes, interactions with plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D, and prostate cancer risk. Prostate. 2007;67(9):911-923. Exclusion code: 5. [pmid: 17440943].
Miller EA, Keku TO, Satia JA, Martin CF, Galanko JA, Sandler RS. Calcium, dietary, and lifestyle factors in the prevention of colorectal adenomas. Cancer. 2007;109(3):510-517. Exclusion code: 7. [pmid: 17200965].
Miller PD. Vitamin D, calcium, and cardiovascular mortality: a perspective from a plenary lecture given at the annual meeting of the American Association of Clinical Endocrinologists. Endocr Pract. 2011;17(5):798-806. Exclusion code: 8. [pmid: 21856593].
Mitchell DM, Henao MP, Finkelstein JS, Burnett-Bowie S-AM. Prevalence and predictors of vitamin D deficiency in healthy adults. Endocr Pract. 2012;18(6):914-923. Exclusion code: 7. [pmid: 22982792].
Mithal A, Wahl DA, Bonjour JP, et al. Global vitamin D status and determinants of hypovitaminosis D. Osteoporos Int. 2009;20(11):1807-1820. Exclusion code: 2. [pmid: 19543765].
Mitri J, Dawson-Hughes B, Hu FB, Pittas AG. Effects of vitamin D and calcium supplementation on pancreatic cell function, insulin sensitivity, and glycemia in adults at high risk of diabetes: the Calcium and Vitamin D for Diabetes Mellitus (CaDDM) randomized controlled trial. Am J Clin Nutr. 2011;94(2):486-494. Exclusion code: 4. [pmid: 21715514].
Mocanu V, Stitt PA, Costan AR, et al. Long-term effects of giving nursing home residents bread fortified with 125 microg (5000 IU) vitamin D(3) per daily serving. Am J Clin Nutr. 2009;89(4):1132-1137. Exclusion code: 6. [pmid: 19244376].
Mølgaard C, Larnkjær A, Cashman KD, Lamberg-Allardt C, Jakobsen J, Michaelsen KF. Does vitamin D supplementation of healthy Danish Caucasian girls affect bone turnover and bone mineralization?. Bone. 2010;46(2):432-439. Exclusion code: 4. [pmid: 19735754].
Moncrieff MW, Chance GW. Nephrotoxic effect of vitamin D therapy in vitamin D refractory rickets. Arch Dis Child. 1969;44(237):571-579. Exclusion code: 4. [pmid: 5350034].
Morales E, Romieu I, Guerra S, et al. Maternal vitamin D status in pregnancy and risk of lower respiratory tract infections, wheezing, and asthma in offspring. Epidemiology. 2012;23(1):64-71. Exclusion code: 4. [pmid: 22082994].
Moreira-Pfrimer LDF, Pedrosa MAC, Teixeira L, Lazaretti-Castro M. Treatment of vitamin D deficiency increases lower limb muscle strength in institutionalized older people independently of regular physical activity: a randomized double-blind controlled trial. Ann Nutr Metab. 2009;54(4):291-300. Exclusion code: 4. [pmid: 19729890].
Moreno LA, Valtueña J, Pérez-López F, González-Gross M. Health effects related to low vitamin D concentrations: Beyond bone metabolism. Ann Nutr Metab. 2011;59(1):22-27. Exclusion code: 8. [pmid: 22123633].
Morley R, Carlin JB, Pasco JA, Wark JD. Maternal 25-hydroxyvitamin D and parathyroid hormone concentrations and offspring birth size. J Clin Endocrinol Metab. 2006;91(3):906-912. Exclusion code: 4. [pmid: 16352684].
Moschonis G, Katsaroli I, Lyritis GP, Manios Y. The effects of a 30-month dietary intervention on bone mineral density: the Postmenopausal Health Study. Br J Nutr. 2010;104(1):100-107. Exclusion code: 15. [pmid: 20370938].
Moschonis G, Manios Y. Skeletal site-dependent response of bone mineral density and quantitative ultrasound parameters following a 12-month dietary intervention using dairy products fortified with calcium and vitamin D: the Postmenopausal Health Study. Br J Nutr. 2006;96(6):1140-1148. Exclusion code: 14. [pmid: 17181890].
Mowe M, Haug E, Bohmer T. Low serum calcidiol concentration in older adults with reduced muscular function. J Am Geriatr Soc. 1999;47(2):220-226. Exclusion code: 4. [pmid: 9988294].
Moyer VA. Prevention of falls in community-dwelling older adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(3):197-204. Exclusion code: 2. [pmid: 22868837].
Moyer VA. Vitamin D and calcium supplementation to prevent fractures in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;158(9):691-696. Exclusion code: 2. [pmid: 23440163].
Mozaffari-Khosravi H, Nabizade L, Yassini-Ardakani SM, Hadinedoushan H, Barzegar K. The effect of 2 different single injections of high dose of vitamin D on improving the depression in depressed patients with vitamin D deficiency: a randomized clinical trial. J Clin Psychopharmacol. 2013;33(3):378-385. Exclusion code: 4. [pmid: 23609390].
Muldowney S, Lucey AJ, Hill TR, et al. Incremental cholecalciferol supplementation up to 15 mug/d throughout winter at 51-55 degrees N has no effect on biomarkers of cardiovascular risk in healthy young and older adults. J Nutr. 2012;142(8):1519-1525. Exclusion code: 15. [pmid: 22739371].
Mulrow CD, Gerety MB, Kanten D, et al. A randomized trial of physical rehabilitation for very frail nursing home residents. JAMA. 1994;271(7):519-524. Exclusion code: 4. [pmid: 8301766].
Munger KL, Levin LI, Hollis BW, Howard NS, Ascherio A. Serum 25-hydroxyvitamin D levels and risk of multiple sclerosis. JAMA. 2006;296(23):2832-2838. Exclusion code: 3. [pmid: 17179460].
Munger KL, Levin LI, Massa J, Horst R, Orban T, Ascherio A. Preclinical serum 25-hydroxyvitamin D levels and risk of type 1 diabetes in a cohort of US military personnel. Am J Epidemiol. 2013;177(5):411-419. Exclusion code: 3. [pmid: 23380046].
Munger KL, Zhang SM, O'Reilly E, et al. Vitamin D intake and incidence of multiple sclerosis. Neurology. 2004;62(1):60-65. Exclusion code: 7. [pmid: 14718698].
Murad MH, Elamin KB, Abu Elnour NO, et al. Clinical review: The effect of vitamin D on falls: a systematic review and meta-analysis. J Clin Endocrinol Metab. 2011;96(10):2997-3006. Exclusion code: 13. [pmid: 21795448].
Murdoch DR, Slow S, Chambers ST, et al. Effect of vitamin D3 supplementation on upper respiratory tract infections in healthy adults: the VIDARIS randomized controlled trial. JAMA. 2012;308(13):1333-1339. Exclusion code: 15. [pmid: 23032549].
Murphy AB, Kelley B, Nyame YA, et al. Predictors of serum vitamin D levels in African American and European American men in Chicago. Am J Mens Health. 2012;6(5):420-426. Exclusion code: 7. [pmid: 22398989].
Myrup B, Jensen GF, McNair P. Cardiovascular risk factors during estrogen-norethindrone and cholecalciferol treatment. Arch Intern Med. 1992;152(11):2265-2268. Exclusion code: 14. [pmid: 1332634].
Nagant de Deuxchaisnes C, Devogelaer JP. Vitamin D deficiency in elderly people. BMJ. 1991;303(6804):718. Exclusion code: 8. [pmid: 1912930].
Nagpal J, Pande JN, Bhartia A. A double-blind, randomized, placebo-controlled trial of the short-term effect of vitamin D3 supplementation on insulin sensitivity in apparently healthy, middle-aged, centrally obese men. Diabet Med. 2009;26(1):19-27. Exclusion code: 10. [pmid: 19125756].
Namgung R, Tsang RC, Lee C, Han DG, Ho ML, Sierra RI. Low total body bone mineral content and high bone resorption in Korean winter-born versus summer-born newborn infants. J Pediatr. 1998;132(3 Pt 1):421-425. Exclusion code: 4. [pmid: 9544894].
Narang NK, Gupta RC, Jain MK. Role of vitamin D in pulmonary tuberculosis. J Assoc Physicians India. 1984;32(2):185-188. Exclusion code: 6. [pmid: 6746514].
National Institutes of Health Office of Dietary Supplements. Dietary supplement fact sheet: Vitamin D. National Institutes of Health, editor. Bethesda, MD. 2011. Exclusion code: 8.
National Osteoporosis Foundation. Clinician Guideline. 2010. http://nof.org/files/nof/public/content/file/344/upload/159.pdf. February 12, 2014. Exclusion code: 2.
Neelemaat F, Lips P, Bosmans JE, Thijs A, Seidell JC, van Bokhorst-de van der Schueren MA. Short-term oral nutritional intervention with protein and vitamin D decreases falls in malnourished older adults. J Am Geriatr Soc. 2012;60(4):691-699. Exclusion code: 5. [pmid: 22316322].
Nelson ML, Blum JM, Hollis BW, Rosen C, Sullivan SS. Supplements of 20 microg/d cholecalciferol optimized serum 25-hydroxyvitamin D concentrations in 80% of premenopausal women in winter. J Nutr. 2009;139(3):540-546. Exclusion code: 15. [pmid: 19158226].
Nemerovski CW, Dorsch MP, Simpson RU, Bone HG, Aaronson KD, Bleske BE. Vitamin D and cardiovascular disease. Pharmacotherapy. 2009;29(6):691-708. Exclusion code: 8. [pmid: 19476421].
Nesby-O'Dell S, Scanlon KS, Cogswell ME, et al. Hypovitaminosis D prevalence and determinants among African American and white women of reproductive age: third National Health and Nutrition Examination Survey, 1988-1994. Am J Clin Nutr. 2002;76(1):187-192. Exclusion code: 4. [pmid: 12081833].
Neuhouser ML, Manson JE, Millen A, et al. The influence of health and lifestyle characteristics on the relation of serum 25-hydroxyvitamin D with risk of colorectal and breast cancer in postmenopausal women. Am J Epidemiol. 2012;175(7):673-684. Exclusion code: 3. [pmid: 22362582].
Neuhouser ML, Wassertheil-Smoller S, Thomson C, et al. Multivitamin use and risk of cancer and cardiovascular disease in the Women's Health Initiative cohorts. Arch Intern Med. 2009;169(3):294-304. Exclusion code: 5. [pmid: 19204221].
Newmark HL, Lipkin M. Calcium, vitamin D, and colon cancer. Cancer Res. 1992;52(7 Suppl):2067s-2070s. Exclusion code: 8. [pmid: 1544142].
Neyens JC, van Haastregt JC, Dijcks BP, et al. Effectiveness and implementation aspects of interventions for preventing falls in elderly people in long-term care facilities: a systematic review of RCTs. J Am Med Dir Assoc. 2011;12(6):410-425. Exclusion code: 13. [pmid: 21450201].
Ng K, Meyerhardt JA, Wu K, et al. Circulating 25-hydroxyvitamin d levels and survival in patients with colorectal cancer. J Clin Oncol. 2008;26(18):2984-2991. Exclusion code: 4. [pmid: 18565885].
Ng K, Scott JB, Drake BF, et al. Dose response to vitamin D supplementation in African Americans: results of a 4-arm, randomized, placebo-controlled trial. Am J Clin Nutr. 2014;99(3):587-598. Exclusion code: 4. [pmid: 24368437].
Nieves JW, Cosman F, Grubert E, Ambrose B, Ralston SH, Lindsay R. Skeletal effects of vitamin D supplementation in postmenopausal black women. Calcif Tissue Int. 2012;91(5):316-324. Exclusion code: 2. [pmid: 22923289].
Nilas L, Christiansen C. Treatment with vitamin D or its analogues does not change body weight or blood glucose level in postmenopausal women. Int J Obes (Lond). 1984;8(5):407-411. Exclusion code: 14.
Nnoaham KE, Clarke A. Low serum vitamin D levels and tuberculosis: a systematic review and meta-analysis. Int J Epidemiol. 2008;37(1):113-119. Exclusion code: 4. [pmid: 18245055].
Nordin BE, Baker MR, Horsman A, Peacock M. A prospective trial of the effect of vitamin D supplementation on metacarpal bone loss in elderly women. Am J Clin Nutr. 1985;42(3):470-474. Exclusion code: 6. [pmid: 4036849].
Norenstedt S, Pernow Y, Brismar K, et al. Primary hyperparathyroidism and metabolic risk factors, impact of parathyroidectomy and vitamin D supplementation, and results of a randomized double-blind study. Eur J Endocrinol. 2013;169(6):795-804. Exclusion code: 4. [pmid: 24026893].
Norval M, Wulf HC. Does chronic sunscreen use reduce vitamin D production to insufficient levels?. Br J Dermatol. 2009;161(4):732-736. Exclusion code: 2. [pmid: 19663879].
Nurmi-Luthje I, Sund R, Juntunen M, Luthje P. Post-hip fracture use of prescribed calcium plus vitamin D or vitamin D supplements and antiosteoporotic drugs is associated with lower mortality: a nationwide study in Finland. J Bone Miner Res. 2011;26(8):1845-1853. Exclusion code: 14. [pmid: 21351147].
Nursyam EW, Amin Z, Rumende CM. The effect of vitamin D as supplementary treatment in patients with moderately advanced pulmonary tuberculous lesion. Acta Med Indones. 2006;38(1):3-5. Exclusion code: 14. [pmid: 16479024].
Nuti R, Bianchi G, Brandi ML, et al. Superiority of alfacalcidol compared to vitamin D plus calcium in lumbar bone mineral density in postmenopausal osteoporosis. Rheumatol Int. 2006;26(5):445-453. Exclusion code: 4. [pmid: 16283320].
O'Donnell S, Moher D, Thomas K, Hanley DA, Cranney A. Systematic review of the benefits and harms of calcitriol and alfacalcidol for fractures and falls. J Bone Miner Metab. 2008;26(6):531-542. Exclusion code: 13. [pmid: 18979152].
Okonofua F, Menon RK, Houlder S, et al. Parathyroid hormone and neonatal calcium homeostasis: evidence for secondary hyperparathyroidism in the Asian neonate. Metabolisim. 1986;35(9):803-806. Exclusion code: 4.
Orimo H, Shiraki M, Hayashi Y, et al. Effects of 1 alpha-hydroxyvitamin D3 on lumbar bone mineral density and vertebral fractures in patients with postmenopausal osteoporosis. Calcif Tissue Int. 1994;54(5):370-376. Exclusion code: 15. [pmid: 8062152].
Orwoll E, Nielson CM, Marshall LM, et al. Vitamin D deficiency in older men. J Clin Endocrinol Metab. 2009;94(4):1214-1222. Exclusion code: 3. [pmid: 19174492].
Orwoll ES, McClung MR, Oviatt SK, Recker RR, Weigel RM. Histomorphometric effects of calcium or calcium plus 25-hydroxyvitamin D3 therapy in senile osteoporosis. J Bone Miner Res. 1989;4(1):81-88. Exclusion code: 4. [pmid: 2718782].
Orwoll ES, Oviatt S. Relationship of mineral metabolism and long-term calcium and cholecalciferol supplementation to blood pressure in normotensive men. Am J Clin Nutr. 1990;52(4):717-721. Exclusion code: 14. [pmid: 2169703].
Orwoll ES, Oviatt SK, McClung MR, Deftos LJ, Sexton G. The rate of bone mineral loss in normal men and the effects of calcium and cholecalciferol supplementation. Ann Intern Med. 1990;112(1):29-34. Exclusion code: 3. [pmid: 2152844].
Otani T, Iwasaki M, Sasazuki S, Inoue M, Tsugane S. Plasma vitamin D and risk of colorectal cancer: the Japan Public Health Center-Based Prospective Study. Br J Cancer. 2007;97(3):446-451. Exclusion code: 3. [pmid: 17622244].
Ott SM, Chesnut CH 3rd. Calcitriol treatment is not effective in postmenopausal osteoporosis. Ann Intern Med. 1989;110(4):267-274. Exclusion code: 4. [pmid: 2913914].
Pacifico L, Anania C, Osborn JF, et al. Low 25(OH)D3 levels are associated with total adiposity, metabolic syndrome, and hypertension in Caucasian children and adolescents. Eur J Endocrinol. 2011;165(4):603-611. Exclusion code: 4. [pmid: 21753070].
Pan A, Lu L, Franco OH, Yu Z, Li H, Lin X. Association between depressive symptoms and 25-hydroxyvitamin D in middle-aged and elderly Chinese. J Affect Disord. 2009;118(1-3):240-243. Exclusion code: 7. [pmid: 19249103].
Panunzio MF, Pisano A, Telesforob P, Tomaiuolo P. Diet can increase 25-hydroxyvitamin-D3 plasma levels in the elderly: A dietary intervention trial. Nutr Res. 2003;23(9):1177-1181. Exclusion code: 6.
Papadimitropoulos E, Wells G, Shea B, et al. Meta-analyses of therapies for postmenopausal osteoporosis. VIII: Meta-analysis of the efficacy of vitamin D treatment in preventing osteoporosis in postmenopausal women. Endocr Rev. 2002;23(4):560-569. Exclusion code: 14. [pmid: 12202471].
Pappa HM, Gordon CM, Saslowsky TM, et al. Vitamin D status in children and young adults with inflammatory bowel disease. Pediatrics. 2006;118(5):1950-1961. Exclusion code: 4. [pmid: 17079566].
Parfitt AM, Gallagher JC, Heaney RP, Johnston CC, Neer R, Whedon GD. Vitamin D and bone health in the elderly. Am J Clin Nutr. 1982;36(5 Suppl):1014-1031. Exclusion code: 8. [pmid: 6765068].
Park MJ, Namgung R, Kim DH, Tsang RC. Bone mineral content is not reduced despite low vitamin D status in breast milk-fed infants versus cow's milk based formula-fed infants. J Pediatr. 1998;132(4):641-645. Exclusion code: 4. [pmid: 9580763].
Park SY, Cooney RV, Wilkens LR, Murphy SP, Henderson BE, Kolonel LN. Plasma 25-hydroxyvitamin D and prostate cancer risk: the multiethnic cohort. Eur J Cancer. 2010;46(5):932-936. Exclusion code: 7. [pmid: 20064705].
Park SY, Murphy SP, Wilkens LR, Nomura AM, Henderson BE, Kolonel LN. Calcium and vitamin D intake and risk of colorectal cancer: the Multiethnic Cohort Study. Am J Epidemiol. 2007;165(7):784-793. Exclusion code: 5. [pmid: 17215380].
Park Y, Leitzmann MF, Subar AF, Hollenbeck A, Schatzkin A. Dairy food, calcium, and risk of cancer in the NIH-AARP Diet and Health Study. Arch Intern Med. 2009;169(4):391-401. Exclusion code: 5. [pmid: 19237724].
Parker J, Hashmi O, Dutton D, et al. Levels of vitamin D and cardiometabolic disorders: systematic review and meta-analysis. Maturitas. 2010;65(3):225-236. Exclusion code: 13. [pmid: 20031348].
Partonen T, Vakkuri O, Lamberg-Allardt C, Lonnqvist J. Effects of bright light on sleepiness, melatonin, and 25-hydroxyvitamin D(3) in winter seasonal affective disorder. Biol Psychiatry. 1996;39(10):865-872. Exclusion code: 5. [pmid: 9172707].
Pasco JA, Henry MJ, Kotowicz MA, et al. Seasonal periodicity of serum vitamin D and parathyroid hormone, bone resorption, and fractures: the Geelong Osteoporosis Study. J Bone Miner Res. 2004;19(5):752-758. Exclusion code: 6. [pmid: 15068498].
Patel P, Poretsky L, Liao E. Lack of effect of subtherapeutic vitamin D treatment on glycemic and lipid parameters in Type 2 diabetes: A pilot prospective randomized trial. J Diabetes. 2010;2(1):36-40. Exclusion code: 4. [pmid: 20923473].
Patel R, Collins D, Bullock S, Swaminathan R, Blake GM, Fogelman I. The effect of season and vitamin D supplementation on bone mineral density in healthy women: a double-masked crossover study. Osteoporos Int. 2001;12(4):319-325. Exclusion code: 15. [pmid: 11420782].
Pathak K, Soares MJ, Calton EK, Zhao Y, Hallett J. Vitamin D supplementation and body weight status: a systematic review and meta-analysis of randomized controlled trials. Obes Rev. 2014;15(6):528-537. Exclusion code: 13. [pmid: 24528624].
Pazdiora P, Svobodova S, Fuchsova R, et al. Vitamin D in colorectal, breast, prostate and lung cancer: a pilot study. Anticancer Res. 2011;31(10):3619-3621. Exclusion code: 6. [pmid: 21965787].
Peacock M, Liu G, Carey M, et al. Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60. J Clin Endocrinol Metab. 2000;85(9):3011-3019. Exclusion code: 15. [pmid: 10999778].
Peechakara SV, Pittas AG. Vitamin D as a potential modifier of diabetes risk. Nat Clin Pract Endocrinol Metab. 2008;4(4):182-183. Exclusion code: 8. [pmid: 18283325].
Peichl P, Rintelen B, Kumpan W, Broll H. Increase of axial and appendicular trabecular and cortical bone density in established osteoporosis with intermittent nasal salmon calcitonin therapy. Gynecol Endocrinol. 1999;13(1):7-14. Exclusion code: 14. [pmid: 10368793].
Peiris AN, Bailey B, Manning T, Kuriacose R, Copeland R, Garrett L. Testing for vitamin D deficiency in veterans-is there a seasonal bias?. J Am Med Dir Assoc. 2010;11(2):128-131. Exclusion code: 6. [pmid: 20142068].
Peiris AN, Bailey BA, Manning T. The relationship of vitamin D deficiency to health care costs in veterans. Mil Med. 2008;173(12):1214-1218. Exclusion code: 6. [pmid: 19149342].
Peiris AN, Bailey BA, Manning T. Relationship of vitamin D monitoring and status to bladder cancer survival in veterans. South Med J. 2013;106(2):126-130. Exclusion code: 4. [pmid: 23380747].
Peiris AN, Bailey BA, Manning T, Adebonojo L. Are 25-hydroxyvitamin D levels adequately monitored following evidence of vitamin D insufficiency in veterans?. Mil Med. 2010;175(6):453-456. Exclusion code: 6. [pmid: 20572480].
Peiris AN, Bailey BA, Peiris P, Copeland RJ, Manning T. Race and vitamin D status and monitoring in male veterans. J Natl Med Assoc. 2011;103(6):492-497. Exclusion code: 3. [pmid: 21830632].
Perez-Lopez FR. Sunlight, the vitamin D endocrine system, and their relationships with gynaecologic cancer. Maturitas. 2008;59(2):101-113. Exclusion code: 7. [pmid: 18289805].
Perez-Lopez FR, Brincat M, Erel CT, et al. EMAS position statement: Vitamin D and postmenopausal health. Maturitas. 2012;71(1):83-88. Exclusion code: 8. [pmid: 22100145].
Peters U, Hayes RB, Chatterjee N, et al. Circulating vitamin D metabolites, polymorphism in vitamin D receptor, and colorectal adenoma risk. Cancer Epidemiol Biomarkers Prev. 2004;13(4):546-552. Exclusion code: 6. [pmid: 15066918].
Peters U, McGlynn KA, Chatterjee N, et al. Vitamin D, calcium, and vitamin D receptor polymorphism in colorectal adenomas. Cancer Epidemiol Biomarkers Prev. 2001;10(12):1267-1274. Exclusion code: 7. [pmid: 11751444].
Peterson A, Mattek N, Clemons A, et al. Serum vitamin D concentrations are associated with falling and cognitive function in older adults. J Nurt Health Aging. 2012;16(10):898-901. Exclusion code: 15.
Petrella RJ, Jones TJ. Do patients receive recommended treatment of osteoporosis following hip fracture in primary care?. BMC Fam Pract. 2006;7. Exclusion code: 4.
Pettifor JM, Ross FP, Moodley G, Wang J, Margo G, Skjolde C. Serum calcium, magnesium, phosphorus, alkaline phosphatase and 25-hydroxyvitamin D concentrations in children. S Afr Med J. 1978;53(19):751-754. Exclusion code: 4. [pmid: 694614].
Pfeifer M, Begerow B, Minne HW, Nachtigall D, Hansen C. Effects of a short-term vitamin D(3) and calcium supplementation on blood pressure and parathyroid hormone levels in elderly women. J Clin Endocrinol Metab. 2001;86(4):1633-1637. Exclusion code: 3. [pmid: 11297596].
Pfeifer M, Dobnig H, Begerow B, Suppan K. Effects of vitamin D and calcium supplementation on falls and parameters of muscle function - a prospective, randomized, double-blind, multi-center study. J Bone Miner Res. 2004;19(SUPPL. 1). Exclusion code: 14.
Pietras SM, Obayan BK, Cai MH, Holick MF. Vitamin D2 treatment for vitamin D deficiency and insufficiency for up to 6 years. Arch Intern Med. 2009;169(19):1806-1808. Exclusion code: 7. [pmid: 19858440].
Pike KC, Inskip HM, Robinson S, et al. Maternal late-pregnancy serum 25-hydroxyvitamin D in relation to childhood wheeze and atopic outcomes. Thorax. 2012;67(11):950-956. Exclusion code: 4. [pmid: 22707522].
Pilz S, Dobnig H, Fischer JE, et al. Low vitamin d levels predict stroke in patients referred to coronary angiography. Stroke. 2008;39(9):2611-2613. Exclusion code: 4. [pmid: 18635847].
Pilz S, Dobnig H, Winklhofer-Roob B, et al. Low serum levels of 25-hydroxyvitamin D predict fatal cancer in patients referred to coronary angiography. Cancer Epidemiol Biomarkers Prev. 2008;17(5):1228-1233. Exclusion code: 4. [pmid: 18463400].
Pilz S, Marz W, Wellnitz B, et al. Association of vitamin D deficiency with heart failure and sudden cardiac death in a large cross-sectional study of patients referred for coronary angiography. J Clin Endocrinol Metab. 2008;93(10):3927-3935. Exclusion code: 7. [pmid: 18682515].
Pilz S, Tomaschitz A, Drechsler C, Zittermann A, Dekker JM, März W. Vitamin d supplementation: A promising approach for the prevention and treatment of strokes. Curr Drug Targets. 2011;12(1):88-96. Exclusion code: 13. [pmid: 20795935].
Pilz S, Tomaschitz A, Obermayer-Pietsch B, Dobnig H, Pieber TR. Epidemiology of vitamin D insufficiency and cancer mortality. Anticancer Res. 2009;29(9):3699-3704. Exclusion code: 7. [pmid: 19667167].
Pilz S, Tomaschitz A, Ritz E, Pieber TR. Vitamin D status and arterial hypertension: a systematic review. Nat Rev Cardiol. 2009;6(10):621-630. Exclusion code: 7. [pmid: 19687790].
Pimlott NJ, Evans MF. Regular vitamin D supplementation for housebound, frail elderly people. Can Fam Physician. 1997;43:2127-2128. Exclusion code: 7. [pmid: 9426931].
Pittas AG, Chung M, Trikalinos T, et al. Systematic review: Vitamin D and cardiometabolic outcomes. Ann Intern Med. 2010;152(5):307-314. Exclusion code: 3. [pmid: 20194237].
Pittas AG, Dawson-Hughes B, Li T, et al. Vitamin D and calcium intake in relation to type 2 diabetes in women. Diabetes Care. 2006;29(3):650-656. Exclusion code: 7. [pmid: 16505521].
Pittas AG, Harris SS, Stark PC, Dawson-Hughes B. The effects of calcium and vitamin D supplementation on blood glucose and markers of inflammation in nondiabetic adults. Diabetes Care. 2007;30(4):980-986. Exclusion code: 15. [pmid: 17277040].
Pittas AG, Lau J, Hu FB, Dawson-Hughes B. The role of vitamin D and calcium in type 2 diabetes. A systematic review and meta-analysis. J Clin Endocrinol Metab. 2007;92(6):2017-2029. Exclusion code: 3. [pmid: 17389701].
Pittas AG, Nelson J, Mitri J, et al. Plasma 25-hydroxyvitamin D and progression to diabetes in patients at risk for diabetes: an ancillary analysis in the Diabetes Prevention Program. Diabetes Care. 2012;35(3):565-573. Exclusion code: 7. [pmid: 22323410].
Pittas AG, Sun Q, Manson JE, Dawson-Hughes B, Hu FB. Plasma 25-hydroxyvitamin D concentration and risk of incident type 2 diabetes in women. Diabetes Care. 2010;33(9):2021-2023. Exclusion code: 3. [pmid: 20805275].
Platz EA, Hankinson SE, Hollis BW, et al. Plasma 1,25-dihydroxy- and 25-hydroxyvitamin D and adenomatous polyps of the distal colorectum. Cancer Epidemiol Biomarkers Prev. 2000;9(10):1059-1065. Exclusion code: 15. [pmid: 11045788].
Platz EA, Leitzmann MF, Hollis BW, Willett WC, Giovannucci E. Plasma 1,25-dihydroxy- and 25-hydroxyvitamin D and subsequent risk of prostate cancer. Cancer Causes Control. 2004;15(3):255-265. Exclusion code: 3. [pmid: 15090720].
Platz EA, Rimm EB, Willett WC, Kantoff PW, Giovannucci E. Racial variation in prostate cancer incidence and in hormonal system markers among male health professionals. J Natl Cancer Inst. 2000;92(24):2009-2017. Exclusion code: 6. [pmid: 11121463].
Ponda MP, Dowd K, Finkielstein D, Holt PR, Breslow JL. The short-term effects of vitamin D repletion on cholesterol: a randomized, placebo-controlled trial. Arterioscler Thromb Vasc Biol. 2012;32(10):2510-2515. Exclusion code: 4. [pmid: 22947589].
Ponsonby AL, McMichael A, van der Mei I. Ultraviolet radiation and autoimmune disease: insights from epidemiological research. Toxicology. 2002;181-182:71-78. Exclusion code: 5. [pmid: 12505287].
Poole KE, Loveridge N, Barker PJ, et al. Reduced vitamin D in acute stroke. Stroke. 2006;37(1):243-245. Exclusion code: 6. [pmid: 16322500].
Porthouse J, Cockayne S, King C, et al. Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 2005;330(7498):1003. Exclusion code: 14. [pmid: 15860827].
Powe CE, Evans MK, Wenger J, et al. Vitamin D-binding protein and vitamin D status of black Americans and white Americans. N Engl J Med. 2013;369(21):1991-2000. Exclusion code: 3. [pmid: 24256378].
Prentice RL, Anderson GL. The women's health initiative: Lessons learned. 2008;29:131-150. Exclusion code: 8.
Prentice RL, Pettinger MB, Jackson RD, et al. Health risks and benefits from calcium and vitamin D supplementation: Women's Health Initiative clinical trial and cohort study. Osteoporos Int. 2013;24(2):567-580. Exclusion code: 14. [pmid: 23208074].
Priemel M, von Domarus C, Klatte TO, et al. Bone mineralization defects and vitamin D deficiency: histomorphometric analysis of iliac crest bone biopsies and circulating 25-hydroxyvitamin D in 675 patients. J Bone Miner Res. 2010;25(2):305-312. Exclusion code: 6. [pmid: 19594303].
Prince RL, Austin N, Devine A, Dick IM, Bruce D, Zhu K. Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 2008;168(1):103-108. Exclusion code: 4. [pmid: 18195202].
Principi N, Bianchini S, Baggi E, Esposito S. Implications of maternal vitamin D deficiency for the fetus, the neonate and the young infant. Eur J Nutr. 2013;52(3):859-867. Exclusion code: 4. [pmid: 23224056].
Przybelski R, Agrawal S, Krueger D, Engelke JA, Walbrun F, Binkley N. Rapid correction of low vitamin D status in nursing home residents. Osteoporos Int. 2008;19(11):1621-1628. Exclusion code: 12. [pmid: 18421544].
Pun KK, Wong FHW, Wang C, et al. Vitamin D status among patients with fractured neck of femur in Hong Kong. Bone. 1990;11(5):365-368. Exclusion code: 7. [pmid: 2252813].
Punnonen R, Salmi J, Tuimala R, Järvinen M, Pystynen P. Vitamin D deficiency in women with femoral neck fracture. Maturitas. 1986;8(4):291-295. Exclusion code: 4. [pmid: 3494904].
Quint JK, Donaldson GC, Wassef N, Hurst JR, Thomas M, Wedzicha JA. 25-hydroxyvitamin D deficiency, exacerbation frequency and human rhinovirus exacerbations in chronic obstructive pulmonary disease. BMC polm. 2012;12:28. Exclusion code: 6.
Racovan M, Walitt B, Collins CE, et al. Calcium and vitamin D supplementation and incident rheumatoid arthritis: The Women's Health Initiative Calcium plus Vitamin D trial. Rheumatol Int. 2012;32(12):3823-3830. Exclusion code: 14. [pmid: 22190273].
Rajakumar K, Fernstrom JD, Janosky JE, Greenspan SL. Vitamin D insufficiency in preadolescent African-American children. Clin Pediatr (Phila). 2005;44(8):683-692. Exclusion code: 4. [pmid: 16211192].
Rajakumar K, Greenspan SL, Thomas SB, Holick MF. Solar ultraviolet radiation and vitamin D: A historical perspective. Am J Public Health. 2007;97(10):1746-1754. Exclusion code: 8. [pmid: 17761571].
Ranstam J, Kanis JA. Influence of age and body mass on the effects of vitamin D on hip fracture risk. Osteoporos Int. 1995;5(6):450-454. Exclusion code: 6. [pmid: 8695967].
Ray JA, Meikle AW. D-light: vitamin D and good health. MLO Med Lab Obs. 2010;42(5):32. Exclusion code: 8. [pmid: 20521518].
Ray WA, Taylor JA, Brown AK, et al. Prevention of fall-related injuries in long-term care: a randomized controlled trial of staff education. Arch Intern Med. 2005;165(19):2293-2298. Exclusion code: 5. [pmid: 16246997].
Recker R, Lips P, Felsenberg D, et al. Alendronate with and without cholecalciferol for osteoporosis: results of a 15-week randomized controlled trial. Curr Med Res Opin. 2006;22(9):1745-1755. Exclusion code: 4. [pmid: 16968578].
Reginster JY. The high prevalence of inadequate serum vitamin D levels and implications for bone health. Curr Med Res Opin. 2005;21(4):579-585. Exclusion code: 13. [pmid: 15899107].
Reid IR, Ames R, Mason B, et al. Randomized controlled trial of calcium supplementation in healthy, nonosteoporotic, older men. Arch Intern Med. 2008;168(20):2276-2282. Exclusion code: 5. [pmid: 19001206].
Reid IR, Bolland MJ, Grey A. Effects of vitamin D supplements on bone mineral density: a systematic review and meta-analysis. Lancet. 2013. Exclusion code: 3.
Rejnmark L, Avenell A, Masud T, et al. Vitamin D with calcium reduces mortality: patient level pooled analysis of 70,528 patients from eight major vitamin D trials. J Clin Endocrinol Metab. 2012;97(8):2670-2681. Exclusion code: 13. [pmid: 22605432].
Remmelts HHF, van de Garde EMW, Meijvis SCA, et al. Addition of vitamin D status to prognostic scores improves the prediction of outcome in community-acquired pneumonia. Clin Infect Dis. 2012;55(11):1488-1494. Exclusion code: 7. [pmid: 22942205].
Riek AE, Oh J, Sprague JE, et al. Vitamin D suppression of endoplasmic reticulum stress promotes an antiatherogenic monocyte/macrophage phenotype in type 2 diabetic patients. J Biol Chem. 2012;287(46):38482-38494. Exclusion code: 4. [pmid: 23012375].
Riis B, Christiansen C, Rodbro P. The effect of different vitamin D treatments on serum vitamin D levels in early postmenopausal women. Acta Vitaminol Enzymol. 1984;6(2):77-82. Exclusion code: 4. [pmid: 6093487].
Riis BJ, Thomsen K, Christiansen C. Does 24R,25(OH)2-vitamin D3 prevent postmenopausal bone loss?. Calcif Tissue Int. 1986;39(3):128-132. Exclusion code: 14. [pmid: 3093022].
Ringe JD, Fardellone P, Kruse HP, Amling M, Van Der Geest SAP, Mller G. Value of a new fixed-combination pack of bisphosphonate, calcium and vitamin d in the therapy of osteoporosis: Results of two quantitative patient research studies. Drugs Aging. 2009;26(3):241-253. Exclusion code: 5. [pmid: 19358619].
Rizzole R, Eisman JA, Norquist J, et al. Risk factors for vitamin D inadequacy among women with osteoporosis: An international epidemiological study. Int J Clin Pract. 2006;60(8):1013-1019. Exclusion code: 4. [pmid: 16893446].
Rizzoli R, Boonen S, Brandi ML, Burlet N, Delmas P, Reginster JY. The role of calcium and vitamin D in the management of osteoporosis. Bone. 2008;42(2):246-249. Exclusion code: 6. [pmid: 18055288].
Rizzoli R, Bruyere O, Cannata-Andia JB, et al. Management of osteoporosis in the elderly. Curr Med Res Opin. 2009;25(10):2373-2387. Exclusion code: 13. [pmid: 19650751].
Rizzoli R, Stoermann C, Ammann P, Bonjour JP. Hypercalcemia and hyperosteolysis in vitamin D intoxication: effects of clodronate therapy. Bone. 1994;15(2):193-198. Exclusion code: 7. [pmid: 8086237].
Robien K, Cutler GJ, Lazovich D. Vitamin D intake and breast cancer risk in postmenopausal women: the Iowa Women's Health Study. Cancer Causes Control. 2007;18(7):775-782. Exclusion code: 5. [pmid: 17549593].
Rohan TE, Negassa A, Chlebowski RT, et al. A randomized controlled trial of calcium plus vitamin D supplementation and risk of benign proliferative breast disease. Breast Cancer Res Treat. 2009;116(2):339-350. Exclusion code: 14. [pmid: 18853250].
Rolland Y, de Souto Barreto P, Abellan Van Kan G, et al. Vitamin D supplementation in older adults: searching for specific guidelines in nursing homes. J Nurt Health Aging. 2013;17(4):402-412. Exclusion code: 7.
Rollins G. Vitamin D Testing—What's the Right Answer? Labs Grapple with Confusing Analytics, Evidence. Clinical Laboratory News. 2009;35(7). Exclusion code: 2.
Romagnoli E, Mascia ML, Cipriani C, et al. Short and long-term variations in serum calciotropic hormones after a single very large dose of ergocalciferol (vitamin D2) or cholecalciferol (vitamin D3) in the elderly. J Clin Endocrinol Metab. 2008;93(8):3015-3020. Exclusion code: 7. [pmid: 18492750].
Rosen CJ, Adams JS, Bikle DD, et al. The nonskeletal effects of vitamin D: an Endocrine Society scientific statement. Endrocr Rev. 2012;33(3):456-492. Exclusion code: 3.
Rosen CJ, Morrison A, Zhou H, et al. Elderly women in northern New England exhibit seasonal changes in bone mineral density and calciotropic hormones. Bone Miner. 1994;25(2):83-92. Exclusion code: 6. [pmid: 8086854].
Rossi M, McLaughlin JK, Lagiou P, et al. Vitamin D intake and breast cancer risk: a case-control study in Italy. Ann Oncol. 2009;20(2):374-378. Exclusion code: 5. [pmid: 18711029].
Rossini M, Alberti V, Flor L, et al. Effect of oral vitamin D2 yearly bolus on hip fracture risk in elderly women: a community primary prevention study. Aging Clin. 2004;16(6):432-436. Exclusion code: 7.
Rossini M, Bianchi G, Di Munno O, et al. Determinants of adherence to osteoporosis treatment in clinical practice. Osteoporos Int. 2006;17(6):914-921. Exclusion code: 6. [pmid: 16538553].
Rossom RC, Espeland MA, Manson JE, et al. Calcium and vitamin D supplementation and cognitive impairment in the women's health initiative. J Am Geriatr Soc. 2012;60(12):2197-2205. Exclusion code: 14. [pmid: 23176129].
Rossouw JE, Anderson GL, Prentice RL, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women's Health Initiative randomized controlled trial. JAMA. 2002;288(3):321-333. Exclusion code: 5. [pmid: 12117397].
Roth DE, Al Mahmud A, Raqib R, et al. Randomized placebo-controlled trial of high-dose prenatal third-trimester vitamin D3 supplementation in Bangladesh: The AViDD trial. Nutr J. 2013;12(1). Exclusion code: 4.
Rouzi AA, Al-Sibiani SA, Al-Senani NS, Radaddi RM, Ardawi MSM. Independent predictors of all osteoporosis-related fractures among healthy Saudi postmenopausal women: The CEOR Study. Bone. 2012;50(3):713-722. Exclusion code: 3. [pmid: 22178778].
Ruiz-Irastorza G, Egurbide MV, Olivares N, Martinez-Berriotxoa A, Aguirre C. Vitamin D deficiency in systemic lupus erythematosus: prevalence, predictors and clinical consequences. Rheumatology. 2008;47(6):920-923. Exclusion code: 7. [pmid: 18411213].
Runia TF, Hop WCJ, de Rijke YB, Buljevac D, Hintzen RQ. Lower serum vitamin D levels are associated with a higher relapse risk in multiple sclerosis. Neurology. 2012;79(3):261-266. Exclusion code: 6. [pmid: 22700811].
Ruohola JP, Laaksi I, Ylikomi T, et al. Association between serum 25(OH)D concentrations and bone stress fractures in Finnish young men. J Bone Miner Res. 2006;21(9):1483-1488. Exclusion code: 3. [pmid: 16939407].
Russell R, Chung M, Balk EM, et al. Issues and Challenges in Conducting Systematic Reviews to Support Development of Nutrient Reference Values: Workshop Summary: Nutrition Research Series. Rockville, MD. 2009;2. Exclusion code: 2.
Sabetta JR, DePetrillo P, Cipriani RJ, Smardin J, Burns LA, Landry ML. Serum 25-hydroxyvitamin d and the incidence of acute viral respiratory tract infections in healthy adults. PLoS ONE. 2010;5(6):e11088. Exclusion code: 3. [pmid: 20559424].
Sai AJ, Walters RW, Fang X, Gallagher JC. Relationship between vitamin D, parathyroid hormone, and bone health. J Clin Endocrinol Metab. 2011;96(3):E436-446. Exclusion code: 6. [pmid: 21159838].
Sakalli H, Arslan D, Yucel AE. The effect of oral and parenteral vitamin D supplementation in the elderly: a prospective, double-blinded, randomized, placebo-controlled study. Rheumatol Int. 2012;32(8):2279-2283. Exclusion code: 10. [pmid: 21556746].
Salesi M, Farajzadegan Z. Efficacy of vitamin D in patients with active rheumatoid arthritis receiving methotrexate therapy. Rheumatol Int. 2012;32(7):2129-2133. Exclusion code: 15. [pmid: 21523344].
Salovaara K, Tuppurainen M, Karkkainen M, et al. Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res. 2010;25(7):1487-1495. Exclusion code: 15. [pmid: 20200964].
Salzer J, Hallmans G, Nyström M, Stenlund H, Wadell G, Sundström P. VitaminDas a protective factor in multiple sclerosis. Neurology. 2012;79(21):2140-2145. Exclusion code: 3. [pmid: 23170011].
Sambrook PN, Chen CJ, March L, et al. High bone turnover is an independent predictor of mortality in the frail elderly. J Bone Miner Res. 2006;21(4):549-555. Exclusion code: 3. [pmid: 16598375].
Sambrook PN, Chen JS, March LM, et al. Serum parathyroid hormone predicts time to fall independent of vitamin D status in a frail elderly population. J Clin Endocrinol Metab. 2004;89(4):1572-1576. Exclusion code: 6. [pmid: 15070914].
Samefors M, Ostgren CJ, Molstad S, Lannering C, Midlov P, Tengblad A. Vitamin D deficiency in elderly people in Swedish nursing homes is associated with increased mortality. Eur J Endocrinol. 2014;170(5):667-675. Exclusion code: 3. [pmid: 24520134].
Samuel L, Borrell LN. The effect of body mass index on optimal vitamin D status in U.S. adults: the National Health and Nutrition Examination Survey 2001-2006. Ann Epidemiol. 2013;23(7):409-414. Exclusion code: 2. [pmid: 23790345].
Sanders KM, Stuart AL, Merriman EN, et al. Trials and tribulations of recruiting 2,000 older women onto a clinical trial investigating falls and fractures: Vital D study. BMC Med Res Methodol. 2009;9:78. Exclusion code: 6. [pmid: 19930724].
Sanders KM, Stuart AL, Williamson EJ, et al. Annual high-dose vitamin D3 and mental well-being: randomised controlled trial. Br J Psychiatry. 2011;198(5):357-364. Exclusion code: 4. [pmid: 21525520].
Sanders KM, Stuart AL, Williamson EJ, et al. Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. [Erratum appears in JAMA. 2010 Jun 16;303(23):2357]. JAMA. 2010;303(18):1815-1822. Exclusion code: 14. [pmid: 20460620].
Sarkis KS, Salvador MB, Pinheiro MM, Silva RG, Zerbini CA, Martini LA. Association between osteoporosis and rheumatoid arthritis in women: a cross-sectional study. Sao Paulo Med J. 2009;127(4):216-222. Exclusion code: 7. [pmid: 20011927].
Sato Y, Honda Y, Hayashida N, Iwamoto J, Kanoko T, Satoh K. Vitamin K deficiency and osteopenia in elderly women with Alzheimer's disease. Arch Phys Med Rehabil. 2005;86(3):576-581. Exclusion code: 5. [pmid: 15759247].
Sato Y, Iwamoto J, Kanoko T, Satoh K. Low-dose vitamin D prevents muscular atrophy and reduces falls and hip fractures in women after stroke: a randomized controlled trial. Cerebrovasc Dis. 2005;20(3):187-192. Exclusion code: 4. [pmid: 16088114].
Sato Y, Iwamoto J, Kanoko T, Satoh K. Amelioration of osteoporosis and hypovitaminosis D by sunlight exposure in hospitalized, elderly women with Alzheimer's disease: A randomized controlled trial. J Bone Miner Res. 2005;20(8):1327-1333. Exclusion code: 4. [pmid: 16007329].
Sato Y, Maruoka H, Oizumi K. Amelioration of hemiplegia-associated osteopenia more than 4 years after stroke by 1 alpha-hydroxyvitamin D3 and calcium supplementation. Stroke. 1997;28(4):736-739. Exclusion code: 14. [pmid: 9099188].
Sato Y, Metoki N, Iwamoto J, Satoh K. Amelioration of osteoporosis and hypovitaminosis D by sunlight exposure in stroke patients. Neurology. 2003;61(3):338-342. Exclusion code: 4. [pmid: 12913194].
Schaafsma A, Muskiet FA, Storm H, Hofstede GJ, Pakan I, Van der Veer E. Vitamin D(3) and vitamin K(1) supplementation of Dutch postmenopausal women with normal and low bone mineral densities: effects on serum 25-hydroxyvitamin D and carboxylated osteocalcin. Eur J Clin Nutr. 2000;54(8):626-631. Exclusion code: 6. [pmid: 10951511].
Schaafsma A, van Doormaal JJ, Muskiet FA, Hofstede GJ, Pakan I, van der Veer E. Positive effects of a chicken eggshell powder-enriched vitamin-mineral supplement on femoral neck bone mineral density in healthy late post-menopausal Dutch women. Br J Nutr. 2002;87(3):267-275. Exclusion code: 5. [pmid: 12064336].
Schleithoff SS, Zittermann A, Tenderich G, Berthold HK, Stehle P, Koerfer R. Vitamin D supplementation improves cytokine profiles in patients with congestive heart failure: a double-blind, randomized, placebo-controlled trial. Am J Clin Nutr. 2006;83(4):754-759. Exclusion code: 4. [pmid: 16600924].
Schneider B, Weber B, Frensch A, Stein J, Fritz J. Vitamin D in schizophrenia, major depression and alcoholism. J Neural Transm. 2000;107(7):839-842. Exclusion code: 7. [pmid: 11005548].
Schnelle JF, Kapur K, Alessi C, et al. Does an exercise and incontinence intervention save healthcare costs in a nursing home population?. J Am Geriatr Soc. 2003;51(2):161-168. Exclusion code: 5. [pmid: 12558711].
Scholl TO, Chen X. Vitamin D intake during pregnancy: association with maternal characteristics and infant birth weight. Early Hum Dev. 2009;85(4):231-234. Exclusion code: 4. [pmid: 19008055].
Schott GD, Wills MR. Muscle weakness in osteomalacia. Lancet. 1976;1(7960):626-629. Exclusion code: 8. [pmid: 55903].
Schottker B, Ball D, Gellert C, Brenner H. Serum 25-hydroxyvitamin D levels and overall mortality. A systematic review and meta-analysis of prospective cohort studies. Ageing Res Rev. 2012. Exclusion code: 13.
Schottker B, Haug U, Schomburg L, et al. Strong associations of 25-hydroxyvitamin D concentrations with all-cause, cardiovascular, cancer, and respiratory disease mortality in a large cohort study. Am J Clin Nutr. 2013;97(4):782-793. Exclusion code: 3. [pmid: 23446902].
Schottker B, Herder C, Rothenbacher D, Perna L, Muller H, Brenner H. Serum 25-hydroxyvitamin D levels and incident diabetes mellitus type 2: a competing risk analysis in a large population-based cohort of older adults. Eur J Epidemiol. 2013;28(3):267-275. Exclusion code: 3. [pmid: 23354985].
Schroth RJ, Jeal NS, Kliewer E, Sellers EA. The relationship between vitamin D and severe early childhood caries: a pilot study. Int J Vitam Nutr Res. 2012;82(1):53-62. Exclusion code: 4. [pmid: 22811377].
Schwalfenberg G. Vitamin D and diabetes: improvement of glycemic control with vitamin D3 repletion. Can Fam Physician. 2008;54(6):864-866. Exclusion code: 7. [pmid: 18556494].
Schwalfenberg GK, Genuis SJ. Vitamin D supplementation in a nursing home population. Mol Nutr Food Res. 2010;54(8):1072-1076. Exclusion code: 7. [pmid: 20440692].
Schwartz GG, Hulka BS. Is vitamin D deficiency a risk factor for prostate cancer? (Hypothesis). Anticancer Res. 1990;10(5A):1307-1311. Exclusion code: 8. [pmid: 2241107].
Scientific Committee on Food. Opinion of the Scientific Committee on Food on the Tolerable Upper Intake Level of Vitamin D. Commission E. 2002. Exclusion code: 8.
Scott D, Blizzard L, Fell J, Ding C, Winzenberg T, Jones G. A prospective study of the associations between 25-hydroxy-vitamin D, sarcopenia progression and physical activity in older adults. Clin Endocrinol. 2010;73(5):581-587. Exclusion code: 6.
Scragg KRR, Kenealy T, Bryant JL, Camargo CA Jr. Vitamin D for preventing cardiovascular disease. Cochrane Database Syst Rev. 2011;(1). Exclusion code: 8.
Scragg R, Holdaway I, Singh V, Metcalf P, Baker J, Dryson E. Serum 25-hydroxyvitamin D3 levels decreased in impaired glucose tolerance and diabetes mellitus. Diabetes Res Clin Pract. 1995;27(3):181-188. Exclusion code: 6. [pmid: 7555599].
Scragg R, Jackson R, Holdaway IM, Lim T, Beaglehole R. Myocardial infarction is inversely associated with plasma 25-hydroxyvitamin D3 levels: a community-based study. Int J Epidemiol. 1990;19(3):559-563. Exclusion code: 7. [pmid: 2262248].
Scragg R, Khaw KT, Murphy S. Effect of winter oral vitamin D3 supplementation on cardiovascular risk factors in elderly adults. Eur J Clin Nutr. 1995;49(9):640-646. Exclusion code: 10. [pmid: 7498100].
Scragg R, Sowers M, Bell C. Serum 25-hydroxyvitamin D, Ethnicity, and Blood Pressure in the Third National Health and Nutrition Examination Survey. Am J Hypertens. 2007;20(7):713-719. Exclusion code: 6. [pmid: 17586404].
Seely EW, Wood RJ, Brown EM, Graves SW. Lower serum ionized calcium and abnormal calciotropic hormone levels in preeclampsia. J Clin Endocrinol Metab. 1992;74(6):1436-1440. Exclusion code: 4. [pmid: 1592891].
Segal E, Zinman C, Raz B, Ish-Shalom S. Low patient compliance-A major negative factor in achieving vitamin D adequacy in elderly hip fracture patients supplemented with 800 IU of vitamin D3 daily. Archives of Gerontology and Geriatrics. 2009;49(3):364-367. Exclusion code: 4. [pmid: 19147237].
Semba RD, Houston DK, Ferrucci L, et al. Low serum 25-hydroxyvitamin D concentrations are associated with greater all-cause mortality in older community-dwelling women. Nutr Res. 2009;29(8):525-530. Exclusion code: 4. [pmid: 19761886].
Shah M, Salhab N, Patterson D, Seikaly MG. Nutritional rickets still afflict children in north Texas. Tex Med. 2000;96(6):64-68. Exclusion code: 4. [pmid: 10876374].
Shaikh U, Alpert PT. Nutritional rickets in Las Vegas, Nevada. J Pediatr Endocrinol Metab. 2006;19(3):209-212. Exclusion code: 4. [pmid: 16607920].
Shea MK, Booth SL, Massaro JM, et al. Vitamin K and vitamin D status: associations with inflammatory markers in the Framingham Offspring Study. Am J Epidemiol. 2008;167(3):313-320. Exclusion code: 6. [pmid: 18006902].
Shea MK, Houston DK, Tooze JA, et al. Correlates and prevalence of insufficient 25-hydroxyvitamin D status in black and white older adults: the health, aging and body composition study. J Am Geriatr Soc. 2011;59(7):1165-1174. Exclusion code: 2. [pmid: 21668915].
Shin M, Minden C. Evaluation of the effectiveness of cholecalciferol in long-term care elderly patients with hypovitaminosis D. Consult Pharm. 2011;26(2):101-107. Exclusion code: 7. [pmid: 21310707].
Shin MH, Holmes MD, Hankinson SE, Wu K, Colditz GA, Willett WC. Intake of dairy products, calcium, and vitamin d and risk of breast cancer. J Natl Cancer Inst. 2002;94(17):1301-1311. Exclusion code: 5. [pmid: 12208895].
Shipowick CD, Moore CB, Corbett C, Bindler R. Vitamin D and depressive symptoms in women during the winter: a pilot study. Appl Nurs Res. 2009;22(3):221-225. Exclusion code: 7. [pmid: 19616172].
Shiraki M, Kushida K, Yamazaki K, Nagai T, Inoue T, Orimo H. Effects of 2 years' treatment of osteoporosis with 1 alpha-hydroxy vitamin D3 on bone mineral density and incidence of fracture: a placebo-controlled, double-blind prospective study. Endocr J. 1996;43(2):211-220. Exclusion code: 4. [pmid: 9026268].
Shiraki M, Orimo H, Ito H, et al. Long-term treatment of postmenopausal osteoporosis with active vitamin D3, 1-alpha-hydroxycholecalciferol (1 alpha-OHD3) and 1, 24 Dihydroxycholecalciferol (1, 24(OH)2D3). Endocrinol Jpn. 1985;32(2):305-315. Exclusion code: 4. [pmid: 2995014].
Shirazi L, Almquist M, Malm J, Wirfalt E, Manjer J. Determinants of serum levels of vitamin D: a study of life-style, menopausal status, dietary intake, serum calcium, and PTH. BMC Womens Health. 2013;13(1):33. Exclusion code: 3. [pmid: 23945218].
Shui IM, Mucci LA, Kraft P, et al. Vitamin D-related genetic variation, plasma vitamin D, and risk of lethal prostate cancer: A prospective nested case-control study. J Natl Cancer Inst. 2012;104(9):690-699. Exclusion code: 3. [pmid: 22499501].
Signorello LB, Han X, Cai Q, et al. A prospective study of serum 25-hydroxyvitamin d levels and mortality among African Americans and non-African Americans. Am J Epidemiol. 2013;177(2):171-179. Exclusion code: 3. [pmid: 23125439].
Simpson M, Brady H, Yin X, et al. No association of vitamin D intake or 25-hydroxyvitamin D levels in childhood with risk of islet autoimmunity and type 1 diabetes: The Diabetes Autoimmunity Study in the Young (DAISY). Diabetologia. 2011;54(11):2779-2788. Exclusion code: 4. [pmid: 21858504].
Sita-Lumsden A, Lapthorn G, Swaminathan R, Milburn HJ. Reactivation of tuberculosis and vitamin D deficiency: the contribution of diet and exposure to sunlight. Thorax. 2007;62(11):1003-1007. Exclusion code: 7. [pmid: 17526677].
Skaaby T, Husemoen LLN, Pisinger C, et al. Vitamin D status and cause-specific mortality: a general population study. PLoS ONE. [Electronic Resource]. 2012;7(12):e52423. Exclusion code: 3. [pmid: 23285034].
Skaaby T, Husemoen LLN, Pisinger C, et al. Vitamin D status and changes in cardiovascular risk factors: a prospective study of a general population. Cardiology. 2012;123(1):62-70. Exclusion code: 6. [pmid: 22986625].
Skaaby T, Husemoen LLN, Pisinger C, et al. Vitamin D status and incident cardiovascular disease and all-cause mortality: a general population study. Endocrine. 2013;43(3):618-625. Exclusion code: 3. [pmid: 23015273].
Skinner HG, Michaud DS, Giovannucci E, Willett WC, Colditz GA, Fuchs CS. Vitamin D intake and the risk for pancreatic cancer in two cohort studies. Cancer Epidemiol Biomarkers Prev. 2006;15(9):1688-1695. Exclusion code: 5. [pmid: 16985031].
Slinin Y, Paudel M, Taylor BC, et al. Association between serum 25(OH) vitamin D and the risk of cognitive decline in older women. J Gerontol A Biol Sci Med Sci. 2012;67(10):1092-1098. Exclusion code: 3. [pmid: 22454371].
Slinin Y, Paudel ML, Taylor BC, et al. 25-Hydroxyvitamin D levels and cognitive performance and decline in elderly men. Neurology. 2010;74(1):33-41. Exclusion code: 3. [pmid: 19940271].
Smedshaug GB, Pedersen JI, Meyer HE. Can vitamin D supplementation improve grip strength in elderly nursing home residents? A double-blinded controlled trial. Scand J Food Nutr. 2007;51(2):74-78. Exclusion code: 15.
Smit E, Crespo CJ, Michael Y, et al. The effect of vitamin D and frailty on mortality among non-institutionalized US older adults. Eur J Clin Nutr. 2012;66(9):1024-1028. Exclusion code: 3. [pmid: 22692022].
Smith H, Anderson F, Raphael H, Crozier S, Cooper C. Effect of annual intramuscular vitamin D supplementation on fracture risk: Population-based, randomised, double-blind, placebo-controlled trial. Rheumatology. 2007;46(12):1852-1857. Exclusion code: 14. [pmid: 17998225].
Smith SM, Gardner KK, Locke J, Zwart SR. Vitamin D supplementation during Antarctic winter. Am J Clin Nutr. 2009;89(4):1092-1098. Exclusion code: 12. [pmid: 19225122].
Smolders J, Menheere P, Kessels A, Damoiseaux J, Hupperts R. Association of vitamin D metabolite levels with relapse rate and disability in multiple sclerosis. Mult Scler. 2008;14(9):1220-1224. Exclusion code: 4. [pmid: 18653736].
Sneve M, Figenschau Y, Jorde R. Supplementation with cholecalciferol does not result in weight reduction in overweight and obese subjects. Eur J Endocrinol. 2008;159(6):675-684. Exclusion code: 15. [pmid: 19056900].
Snijder MB, van Schoor NM, Pluijm SMF, van Dam RM, Visser M, Lips P. Vitamin D status in relation to one-year risk of recurrent falling in older men and women. J Clin Endocrinol Metab. 2006;91(8):2980-2985. Exclusion code: 6. [pmid: 16684818].
Sohl E, Heymans MW, de Jongh RT, et al. Prediction of vitamin D deficiency by simple patient characteristics. Am J Clin Nutr. 2014;99(5):1089-1095. Exclusion code: 7. [pmid: 24552751].
Sohl E, van Schoor NM, de Jongh RT, Visser M, Deeg DJH, Lips P. Vitamin D Status Is Associated With Functional Limitations and Functional Decline in Older Individuals. J Clin Endocrinol Metab. 2013;98(9):E1483-E1490. Exclusion code: 3. [pmid: 23864700].
Soilu-Hanninen M, Aivo J, Lindstrom BM, et al. A randomised, double blind, placebo controlled trial with vitamin D3 as an add on treatment to interferon beta-1b in patients with multiple sclerosis. J Neurol Neurosurg Psychiatry. 2012;83(5):565-571. Exclusion code: 6. [pmid: 22362918].
Soilu-Hanninen M, Laaksonen M, Laitinen I, Eralinna JP, Lilius EM, Mononen I. A longitudinal study of serum 25-hydroxyvitamin D and intact parathyroid hormone levels indicate the importance of vitamin D and calcium homeostasis regulation in multiple sclerosis. J Neurol Neurosurg Psychiatry. 2008;79(2):152-157. Exclusion code: 7. [pmid: 17578859].
Sokol SI, Srinivas V, Crandall JP, et al. The effects of vitamin D repletion on endothelial function and inflammation in patients with coronary artery disease. Vasc Med. 2012;17(6):394-404. Exclusion code: 4. [pmid: 23184900].
Sonderman JS, Munro HM, Blot WJ, Signorello LB. Reproducibility of serum 25-hydroxyvitamin d and vitamin D-binding protein levels over time in a prospective cohort study of black and white adults. Am J Epidemiol. 2012;176(7):615-621. Exclusion code: 2. [pmid: 22975199].
Songpatanasilp T, Chailurkit LO, Nichachotsalid A, Chantarasorn M. Combination of alfacalcidol with calcium can improve quadriceps muscle strength in elderly ambulatory Thai women who have hypovitaminosis D: a randomized controlled trial. J Med Assoc Thai. Suppl5. 2009;92:S30-41. Exclusion code: 15. [pmid: 19894330].
Soni M, Kos K, Lang IA, Jones K, Melzer D, Llewellyn DJ. Vitamin D and cognitive function. Scand J Clin Lab Invest. 2012;243:79-82. Exclusion code: 8.
Sørensen OH, Lund B, Saltin B, et al. Myopathy in bone loss of ageing: Improvement by treatment with 1α-hydroxycholecalciferol and calcium. Clin Sci (Lond). 1979;56(2):157-161. Exclusion code: 15. [pmid: 477197].
Sorva A, Risteli J, Risteli L, Valimaki M, Tilvis R. Effects of vitamin D and calcium on markers of bone metabolism in geriatric patients with low serum 25-hydroxyvitamin D levels. Calcif Tissue Int. Suppl. 1991;49:S88-89. Exclusion code: 6. [pmid: 1933612].
Souberbielle JC, Friedlander G, Cormier C. Practical considerations in PTH testing. Clin Chim Acta. 2006;366(1-2):81-89. Exclusion code: 6. [pmid: 16310759].
Specker BL, Ho ML, Oestreich A, et al. Prospective study of vitamin D supplementation and rickets in China. J Pediatr. 1992;120(5):733-739. Exclusion code: 4. [pmid: 1578308].
Specker BL, Tsang RC. Cyclical serum 25-hydroxyvitamin D concentrations paralleling sunshine exposure in exclusively breast-fed infants. J Pediatr. 1987;110(5):744-747. Exclusion code: 4. [pmid: 3494833].
Specker BL, Valanis B, Hertzberg V, Edwards N, Tsang RC. Sunshine exposure and serum 25-hydroxyvitamin D concentrations in exclusively breast-fed infants. J Pediatr. 1985;107(3):372-376. Exclusion code: 4. [pmid: 3839846].
Standing Committee on the Scientific Evaluation of Dietary Reference Intakes. Dietary Reference Intakes for Calcium, Phosphorus, Magnesium, Vitamin D, and Fluoride. Washington, D.C. National Academy Press. 1999. Exclusion code: 8.
Stein MS, Liu Y, Gray OM, et al. A randomized trial of high-dose vitamin D2 in relapsing-remitting multiple sclerosis. Neurology. 2011;77(17):1611-1618. Exclusion code: 6. [pmid: 22025459].
Stern PH, Taylor AB, Bell NH, Epstein S. Demonstration that circulating 1 alpha, 25-dihydroxyvitamin D is loosely regulated in normal children. J Clin Invest. 1981;68(5):1374-1377. Exclusion code: 4. [pmid: 6975284].
Stewart JW, Alekel DL, Ritland LM, Van Loan M, Gertz E, Genschel U. Serum 25-hydroxyvitamin D is related to indicators of overall physical fitness in healthy postmenopausal women. Menopause. 2009;16(6):1093-1101. Exclusion code: 6. [pmid: 19512949].
Stockton KA, Mengersen K, Paratz JD, Kandiah D, Bennell KL. Effect of vitamin D supplementation on muscle strength: a systematic review and meta-analysis. Osteoporos Int. 2011;22(3):859-871. Exclusion code: 3. [pmid: 20924748].
Stolzenberg-Solomon RZ, Jacobs EJ, Arslan AA, et al. Circulating 25-hydroxyvitamin D and risk of pancreatic cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):81-93. Exclusion code: 6. [pmid: 20562185].
Stone K, Bauer DC, Black DM, Sklarin P, Ensrud KE, Cummings SR. Hormonal predictors of bone loss in elderly women: a prospective study. The Study of Osteoporotic Fractures Research Group. J Bone Miner Res. 1998;13(7):1167-1174. Exclusion code: 6. [pmid: 9661081].
Storm D, Eslin R, Porter ES, et al. Calcium supplementation prevents seasonal bone loss and changes in biochemical markers of bone turnover in elderly New England women: a randomized placebo-controlled trial. J Clin Endocrinol Metab. 1998;83(11):3817-3825. Exclusion code: 5. [pmid: 9814452].
Strachan DP, Powell KJ, Thaker A, Millard FJ, Maxwell JD. Vegetarian diet as a risk factor for tuberculosis in immigrant south London Asians. Thorax. 1995;50(2):175-180. Exclusion code: 5. [pmid: 7701458].
Stratton-Loeffler M, Lo J, Hui R, Coates A, Minkoff J, Budayr A. Treatment of Vitamin D Deficiency Within a Large Integrated Health Care Delivery System. J Manag Care Pharm. 2012;18(7):497-505. Exclusion code: 2. [pmid: 22971203].
Straube S, Andrew Moore R, Derry S, McQuay HJ. Vitamin D and chronic pain. Pain. 2009;141(1-2):10-13. Exclusion code: 4. [pmid: 19084336].
Straube S, Derry S, Moore RA, McQuay HJ. Vitamin D for the treatment of chronic painful conditions in adults. Cochrane Database Syst Rev. 2010;(1). CD007771. Exclusion code: 4.
Streck WF, Waterhouse C, Haddad JG. Glucocorticoid effects in vitamin D intoxication. Arch Intern Med. 1979;139(9):974-977. Exclusion code: 6. [pmid: 224830].
Stubbs JR, Idiculla A, Slusser J, Menard R, Quarles LD. Cholecalciferol supplementation alters calcitriol-responsive monocyte proteins and decreases inflammatory cytokines in ESRD. J Am Soc Nephrol. 2010;21(2):353-361. Exclusion code: 4. [pmid: 20007751].
Sugden JA, Davies JI, Witham MD, Morris AD, Struthers AD. Vitamin D improves endothelial function in patients with Type 2 diabetes mellitus and low vitamin D levels. Diabet Med. 2008;25(3):320-325. Exclusion code: 4. [pmid: 18279409].
Sullivan SS, Rosen CJ, Halteman WA, Chen TC, Holick MF. Adolescent girls in maine are at risk for vitamin D insufficiency. J Am Diet Assoc. 2005;105(6):971-974. Exclusion code: 4. [pmid: 15942551].
Sun Q, Pan A, Hu FB, Manson JE, Rexrode KM. 25-Hydroxyvitamin D levels and the risk of stroke: a prospective study and meta-analysis. Stroke. 2012;43(6):1470-1477. Exclusion code: 3. [pmid: 22442173].
Suzuki T, Kwon J, Kim H, et al. Low serum 25-hydroxyvitamin D levels associated with falls among Japanese community-dwelling elderly. J Bone Miner Res. 2008;23(8):1309-1317. Exclusion code: 2. [pmid: 18410227].
Swanenburg J, de Bruin ED, Stauffacher M, Mulder T, Uebelhart D. Effects of exercise and nutrition on postural balance and risk of falling in elderly people with decreased bone mineral density: randomized controlled trial pilot study. Clin Rehabil. 2007;21(6):523-534. Exclusion code: 5. [pmid: 17613583].
Syroney L, Franjesevic A. Vitamin D deficiency: screening and treatment in primary care. Adv Nurse Pract. 2010;18(5):37-38. Exclusion code: 8. [pmid: 20491192].
Szulc P, Claustrat B, Delmas PD. Serum concentrations of 17beta-E2 and 25-hydroxycholecalciferol (25OHD) in relation to all-cause mortality in older men--the MINOS study. Clin Endocrinol (Oxf). 2009;71(4):594-602. Exclusion code: 15. [pmid: 19207314].
Szulc P, Maurice C, Marchand F, Delmas PD. Increased bone resorption is associated with higher mortality in community-dwelling men ≥50 years of age: The MINOS study. J Bone Miner Res. 2009;24(6):1116-1124. Exclusion code: 5. [pmid: 19113925].
Tai K, Need AG, Horowitz M, Chapman IM. Glucose tolerance and vitamin D: effects of treating vitamin D deficiency. Nutrition. 2008;24(10):950-956. Exclusion code: 10. [pmid: 18653316].
Tang BM, Eslick GD, Nowson C, Smith C, Bensoussan A. Use of calcium or calcium in combination with vitamin D supplementation to prevent fractures and bone loss in people aged 50 years and older: a meta-analysis. Lancet. 2007;370(9588):657-666. Exclusion code: 13. [pmid: 17720017].
Tang JY, Fu T, Leblanc E, et al. Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer: post hoc analyses of the women's health initiative randomized controlled trial. J Clin Oncol. 2011;29(22):3078-3084. Exclusion code: 14. [pmid: 21709199].
Tangpricha V, Pearce EN, Chen TC, Holick MF. Vitamin D insufficiency among free-living healthy young adults. Am J Med. 2002;112(8):659-662. Exclusion code: 6. [pmid: 12034416].
Tangrea J, Helzlsouer K, Pietinen P, et al. Serum levels of vitamin D metabolites and the subsequent risk of colon and rectal cancer in Finnish men. Cancer Causes Control. 1997;8(4):615-625. Exclusion code: 6. [pmid: 9242478].
Tarcin O, Yavuz DG, Ozben B, et al. Effect of vitamin D deficiency and replacement on endothelial function in asymptomatic subjects. J Clin Endocrinol Metab. 2009;94(10):4023-4030. Exclusion code: 5. [pmid: 19584181].
Targher G, Bertolini L, Padovani R, et al. Serum 25-hydroxyvitamin D3 concentrations and carotid artery intima-media thickness among type 2 diabetic patients. Clin Endocrinol (Oxf). 2006;65(5):593-597. Exclusion code: 5. [pmid: 17054459].
Taussig HB. Possible injury to the cardiovascular system from vitamin D. Ann Intern Med. 1966;65(6):1195-1200. Exclusion code: 8. [pmid: 5333232].
Taylor CB, Hass GM, Ho KJ, Liu LB. Risk factors in the pathogenesis of atherosclerotic heart disease and generalized atherosclerosis. Ann Clin Lab Sci. 1972;2(3):239-243. Exclusion code: 8. [pmid: 4628363].
Taylor CL, Carriquiry AL, Bailey RL, Sempos CT, Yetley EA. Appropriateness of the probability approach with a nutrient status biomarker to assess population inadequacy: a study using vitamin D. Am J Clin Nutr. 2013;97(1):72-78. Exclusion code: 2. [pmid: 23097269].
Taylor EN, Stampfer MJ, Curhan GC. Dietary factors and the risk of incident kidney stones in men: new insights after 14 years of follow-up. J Am Soc Nephrol. 2004;15(12):3225-3232. Exclusion code: 5. [pmid: 15579526].
Tellioglu A, Basaran S, Guzel R, Seydaoglu G. Efficacy and safety of high dose intramuscular or oral cholecalciferol in vitamin D deficient/insufficient elderly. Maturitas. 2012;72(4):332-338. Exclusion code: 12. [pmid: 22613271].
Thiebaud D, Burckhardt P, Costanza M, et al. Importance of albumin, 25(OH)-vitamin D and IGFBP-3 as risk factors in elderly women and men with hip fracture. Osteoporos Int. 1997;7(5):457-462. Exclusion code: 5. [pmid: 9425504].
Thomas GN, o Hartaigh B, Bosch JA, et al. Vitamin D levels predict all-cause and cardiovascular disease mortality in subjects with the metabolic syndrome: the Ludwigshafen Risk and Cardiovascular Health (LURIC) Study. Diabetes Care. 2012;35(5):1158-1164. Exclusion code: 4. [pmid: 22399697].
Thomas M, Lloyd-Jones D, Thadhani R, et al. Hypovitaminosis D in medical inpatients. N Engl J Med. 1998;338(12):777-783. Exclusion code: 2. [pmid: 9504937].
Thys-Jacobs S, Starkey P, Bernstein D, Tian J. Calcium carbonate and the premenstrual syndrome: effects on premenstrual and menstrual symptoms. Premenstrual Syndrome Study Group. Am J Obstet Gynecol. 1998;179(2):444-452. Exclusion code: 5. [pmid: 9731851].
Tilyard MW, Spears GFS, Thomson J, Dovey S. Treatment of postmenopausal osteoporosis with calcitriol or calcium. N Engl J Med. 1992;326(6):357-362. Exclusion code: 4. [pmid: 1729617].
Timms PM, Mannan N, Hitman GA, et al. Circulating MMP9, vitamin D and variation in the TIMP-1 response with VDR genotype: mechanisms for inflammatory damage in chronic disorders?. Qjm. 2002;95(12):787-796. Exclusion code: 6. [pmid: 12454321].
Tjellesen L, Hummer L, Christiansen C, Rodbro P. Serum concentration of vitamin D metabolites during treatment with vitamin D2 and D3 in normal premenopausal women. Bone Miner. 1986;1(5):407-413. Exclusion code: 12. [pmid: 2849489].
Tolppanen AM, Sayers A, Granell R, Fraser WD, Henderson J, Lawlor DA. Prospective association of 25-hydroxyvitamin D3 and D2 with childhood lung function, asthma, wheezing, and flexural dermatitis. Epidemiology. 2013;24(2):310-319. Exclusion code: 4. [pmid: 23377091].
Toner CD, Davis CD, Milner JA. The vitamin D and cancer conundrum: aiming at a moving target. J Am Diet Assoc. 2010;110(10):1492-1500. Exclusion code: 8. [pmid: 20869488].
Toriola AT, Surcel HM, Calypse A, et al. Independent and joint effects of serum 25-hydroxyvitamin D and calcium on ovarian cancer risk: a prospective nested case-control study. Eur J Cancer. 2010;46(15):2799-2805. Exclusion code: 6. [pmid: 20601305].
Toss G, Andersson R, Diffey BL, Fall PA, Larko O, Larsson L. Oral vitamin D and ultraviolet radiation for the prevention of vitamin D deficiency in the elderly. Acta Med Scand. 1982;212(3):157-161. Exclusion code: 6. [pmid: 6983207].
Tran B, Armstrong BK, McGeechan K, et al. Predicting vitamin D deficiency in older Australian adults. Clin Endocrinol (Oxf). 2013. Exclusion code: 7.
Trang HM, Cole DEC, Rubin LA, Pierratos A, Siu S, Vieth R. Evidence that vitamin D3 increases serum 25-hydroxyvitamin D more efficiently than does vitamin D2. Am J Clin Nutr. 1998;68(4):854-858. Exclusion code: 6. [pmid: 9771862].
Travis RC, Crowe FL, Allen NE, et al. Serum vitamin D and risk of prostate cancer in a case-control analysis nested within the European Prospective Investigation into Cancer and Nutrition (EPIC). Am J Epidemiol. 2009;169(10):1223-1232. Exclusion code: 3. [pmid: 19359375].
Tretli S, Hernes E, Berg JP, Hestvik UE, Robsahm TE. Association between serum 25(OH)D and death from prostate cancer. Br J Cancer. 2009;100(3):450-454. Exclusion code: 7. [pmid: 19156140].
Tretli S, Schwartz GG, Torjesen PA, Robsahm TE. Serum levels of 25-hydroxyvitamin D and survival in Norwegian patients with cancer of breast, colon, lung, and lymphoma: a population-based study. Cancer Causes Control. 2012;23(2):363-370. Exclusion code: 4. [pmid: 22193397].
Tripkovic L, Lambert H, Hart K, et al. Comparison of vitamin D2 and vitamin D3 supplementation in raising serum 25-hydroxyvitamin D status: a systematic review and meta-analysis. Am J Clin Nutr. 2012;95(6):1357-1364. Exclusion code: 2. [pmid: 22552031].
Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. Br Med J (Clin Res Ed). 2003;326(7387):469. Exclusion code: 14.
Tsagari A, Toulis KA, Makras P, Skagias K, Galanos A, Lyritis G. Performance of the mini nutritional assessment score in the detection of vitamin D status in an elderly Greek population. Horm Metab Res. 2012;44(12):896-899. Exclusion code: 6. [pmid: 22692927].
Tseng M, Giri V, Bruner DW, Giovannucci E. Prevalence and correlates of vitamin D status in African American men. BMC Public Health. 2009;9:191. Exclusion code: 6. [pmid: 19534831].
Tsur A, Feldman BS, Feldhammer I, Hoshen MB, Leibowitz G, Balicer RD. Decreased serum concentrations of 25-hydroxycholecalciferol are associated with increased risk of progression to impaired fasting glucose and diabetes. Diabetes Care. 2013;36(5):1361-1367. Exclusion code: 3. [pmid: 23393216].
Tuppurainen M, Heikkinen AM, Penttila I, Saarikoski S. Does vitamin D3 have negative effects on serum levels of lipids? A follow-up study with a sequential combination of estradiol valerate and cyproterone acetate and/or vitamin D3. Maturitas. 1995;22(1):55-61. Exclusion code: 14. [pmid: 7666817].
U.S. Preventive Services Task Force. Procedure Manual. 2011. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. April 3 2013. Exclusion code: 2.
U.S. Preventive Services Task Force. Vitamin D and Calcium Supplementation to Prevent Cancer and Osteoporotic Fractures in Adults: Draft Recommendation Statement. 2012. AHRQ Publication 12-05163-EF-2. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.uspreventiveservicestaskforce.org/uspstf12/vitamind/draftrecvitd.htm. January 17, 2014. Exclusion code: 2.
U.S. Preventive Services Task Force. Vitamin D and Calcium Supplementation to Prevent Fractures in Adults: U.S. Preventive Services Task Force Recommendation Statement. 2013. AHRQ Publication 12-05163-EF-2. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.uspreventiveservicestaskforce.org/uspstf12/vitamind/finalrecvitd.htm. January 17, 2014. Exclusion code: 2.
U.S. Preventive Services Task Force. Vitamin, Mineral, and Multivitamin Supplements for the Primary Prevention of Cardiovascular Disease and Cancer: Draft Recommendation Statement. 2013. AHRQ Publication 14-05199-EF-2. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.uspreventiveservicestaskforce.org/draftrec2.htm. January 17, 2014. Exclusion code: 2.
Urashima M, Segawa T, Okazaki M, Kurihara M, Wada Y, Ida H. Randomized trial of vitamin D supplementation to prevent seasonal influenza A in schoolchildren. Am J Clin Nutr. 2010;91(5):1255-1260. Exclusion code: 4. [pmid: 20219962].
Ushiroyama T, Ikeda A, Sakai M, Higashiyama T, Ueki M. Effects of the combined use of calcitonin and 1 alpha-hydroxycholecalciferol on vertebral bone loss and bone turnover in women with postmenopausal osteopenia and osteoporosis: a prospective study of long-term and continuous administration with low dose calcitonin. Maturitas. 2001;40(3):229-238. Exclusion code: 14. [pmid: 11731184].
Vacek JL, Vanga SR, Good M, Lai SM, Lakkireddy D, Howard PA. Vitamin D deficiency and supplementation and relation to cardiovascular health. Am J Cardiol. 2012;109(3):359-363. Exclusion code: 7. [pmid: 22071212].
Van den Berghe G, Van Roosbroeck D, Vanhove P, Wouters PJ, De Pourcq L, Bouillon R. Bone turnover in prolonged critical illness: effect of vitamin D. J Clin Endocrinol Metab. 2003;88(10):4623-4632. Exclusion code: 4. [pmid: 14557432].
van der Mei IA, Ponsonby AL, Dwyer T, et al. Past exposure to sun, skin phenotype, and risk of multiple sclerosis: case-control study. BMJ. 2003;327(7410):316. Exclusion code: 5. [pmid: 12907484].
van der Mei IAF, Ponsonby AL, Dwyer T, et al. Vitamin D levels in people with multiple sclerosis and community controls in Tasmania, Australia. J Neurol. 2007;254(5):581-590. Exclusion code: 7. [pmid: 17426912].
van der Pols JC, Russell A, Bauer U, Neale RE, Kimlin MG, Green AC. Vitamin D status and skin cancer risk independent of time outdoors: 11-year prospective study in an Australian community. J Invest Dermatol. 2013;133(3):637-641. Exclusion code: 3. [pmid: 23076499].
van Oeffelen AAM, Bekkers MBM, Smit HA, et al. Serum micronutrient concentrations and childhood asthma: The PIAMA birth cohort study. Pediatric Allergy and Immunology. 2011;22(8):784-793. Exclusion code: 4. [pmid: 21929603].
van Schoor NM, Visser M, Pluijm SM, Kuchuk N, Smit JH, Lips P. Vitamin D deficiency as a risk factor for osteoporotic fractures. Bone. 2008;42(2):260-266. Exclusion code: 3. [pmid: 18289505].
Veldhuis S, Wolbers F, Brouckaert O, Vermes I, Franke HR. Cancer prevalence in osteoporotic women with low serum vitamin D levels. Menopause. 2011;18(3):319-322. Exclusion code: 7. [pmid: 21178642].
Velho S, Marques-Vidal P, Baptista F, Camilo ME. Dietary intake adequacy and cognitive function in free-living active elderly: a cross-sectional and short-term prospective study. Clin Nutr. 2008;27(1):77-86. Exclusion code: 5. [pmid: 18082291].
Venning G. Recent developments in vitamin D deficiency and muscle weakness among elderly people. BMJ. 2005;330(7490):524-526. Exclusion code: 8. [pmid: 15746134].
Verhaar HJ, Samson MM, Jansen PA, de Vreede PL, Manten JW, Duursma SA. Muscle strength, functional mobility and vitamin D in older women. Aging Clin. 2000;12(6):455-460. Exclusion code: 7.
Verreault R, Semba RD, Volpato S, Ferrucci L, Fried LP, Guralnik JM. Low serum vitamin D does not predict new disability or loss of muscle strength in older women. J Am Geriatr Soc. 2002;50(5):912-917. Exclusion code: 4. [pmid: 12028180].
Vieth R. Why the optimal requirement for Vitamin D3 is probably much higher than what is officially recommended for adults. J Steriod Biochem Mol Biol. 2004;89-90(1-5):575-579. Exclusion code: 8.
Vieth R. What is the optimal vitamin D status for health?. Prog Biophys Mol Biol. 2006;(92):26. Exclusion code: 2. [pmid: 16766239].
Vieth R, Chan PC, MacFarlane GD. Efficacy and safety of vitamin D3 intake exceeding the lowest observed adverse effect level. Am J Clin Nutr. 2001;73(2):288-294. Exclusion code: 12. [pmid: 11157326].
Vieth R, Kimball S, Hu A, Walfish PG. Randomized comparison of the effects of the vitamin D3 adequate intake versus 100 mcg (4000 IU) per day on biochemical responses and the wellbeing of patients. Nutr J. 2004;3:8. Exclusion code: 5. [pmid: 15260882].
Vik B, Try K, Thelle DS, Forde OH. Tromso Heart Study: vitamin D metabolism and myocardial infarction. Br Med J. 1979;2(6183):176. Exclusion code: 6. [pmid: 466339].
Viljakainen HT, Palssa A, Karkkainen M, Jakobsen J, Lamberg-Allardt C. How much vitamin D3 do the elderly need?. J Am Coll Nutr. 2006;25(5):429-435. Exclusion code: 6. [pmid: 17031013].
Villar J, Abdel-Aleem H, Merialdi M, et al. World Health Organization randomized trial of calcium supplementation among low calcium intake pregnant women. Am J Obstet Gynecol. 2006;194(3):639-649. Exclusion code: 4. [pmid: 16522392].
Villareal DT, Civitelli R, Chines A, Avioli LV. Subclinical vitamin D deficiency in postmenopausal women with low vertebral bone mass. J Clin Endocrinol Metab. 1991;72(3):628-634. Exclusion code: 6. [pmid: 1997517].
Vimaleswaran KS, Berry DJ, Lu C, et al. Causal relationship between obesity and vitamin D status: bi-directional Mendelian randomization analysis of multiple cohorts. PLoS Medicine / Public Library of Science. 2013;10(2):e1001383. Exclusion code: 7.
Virtanen JK, Nurmi T, Voutilainen S, Mursu J, Tuomainen TP. Association of serum 25-hydroxyvitamin D with the risk of death in a general older population in Finland. Eur J Nutr. 2011;50(5):305-312. Exclusion code: 3. [pmid: 20976461].
Visser M, Deeg DJ, Lips P. Low vitamin D and high parathyroid hormone levels as determinants of loss of muscle strength and muscle mass (sarcopenia): the Longitudinal Aging Study Amsterdam. J Clin Endocrinol Metab. 2003;88(12):5766-5772. Exclusion code: 2. [pmid: 14671166].
von Hurst PR, Stonehouse W, Coad J. Vitamin D supplementation reduces insulin resistance in South Asian women living in New Zealand who are insulin resistant and vitamin D deficient - a randomised, placebo-controlled trial. Br J Nutr. 2010;103(4):549-555. Exclusion code: 4. [pmid: 19781131].
von Hurst PR, Stonehouse W, Kruger MC, Coad J. Vitamin D supplementation suppresses age-induced bone turnover in older women who are vitamin D deficient. J Steroid Biochem Mol Biol. 2010;121(1-2):293-296. Exclusion code: 6. [pmid: 20304051].
von Hurst PR, Stonehouse W, Matthys C, Conlon C, Kruger MC, Coad J. Study protocol--metabolic syndrome, vitamin D and bone status in South Asian women living in Auckland, New Zealand: a randomised, placebo-controlled, double-blind vitamin D intervention. BMC Public Health. 2008;8:267. Exclusion code: 8. [pmid: 18667086].
von Muhlen DG, Greendale GA, Garland CF, Wan L, Barrett-Connor E. Vitamin D, parathyroid hormone levels and bone mineral density in community-dwelling older women: the Rancho Bernardo Study. Osteoporos Int. 2005;16(12):1721-1726. Exclusion code: 6. [pmid: 15928802].
von Restorff C, Bischoff-Ferrari HA, Theiler R. High-dose oral vitamin D3 supplementation in rheumatology patients with severe vitamin D3 deficiency. Bone. 2009;45(4):747-749. Exclusion code: 12. [pmid: 19539796].
Wagner CL, Greer FR. Prevention of rickets and vitamin D deficiency in infants, children, and adolescents. Pediatrics. 2008;122(5):1142-1152. Exclusion code: 4. [pmid: 18977996].
Wallace RB, Wactawski-Wende J, O'Sullivan MJ, et al. Urinary tract stone occurrence in the Women's Health Initiative (WHI) randomized clinical trial of calcium and vitamin D supplements. Am J Clin Nutr. 2011;94(1):270-277. Exclusion code: 14. [pmid: 21525191].
Wang L, Manson JE, Buring JE, Lee IM, Sesso HD. Dietary intake of dairy products, calcium, and vitamin D and the risk of hypertension in middle-aged and older women. Hypertension. 2008;51(4):1073-1079. Exclusion code: 5. [pmid: 18259007].
Wang L, Manson JE, Song Y, Sesso HD. Systematic review: Vitamin D and calcium supplementation in prevention of cardiovascular events. Ann Intern Med. 2010;152(5):315-323. Exclusion code: 13. [pmid: 20194238].
Wang L, Song Y, Manson JE, et al. Circulating 25-hydroxy-vitamin D and risk of cardiovascular disease: a meta-analysis of prospective studies. Circ Cardiovasc Qual Outcomes. 2012;5(6):819-829. Exclusion code: 3. [pmid: 23149428].
Wang TJ, Zhang F, Richards JB, et al. Common genetic determinants of vitamin D insufficiency: a genome-wide association study. Lancet. 2010;376(9736):180-188. Exclusion code: 6. [pmid: 20541252].
Ward KA, Das G, Roberts SA, et al. A randomized, controlled trial of vitamin D supplementation upon musculoskeletal health in postmenarchal females. J Clin Endocrinol Metab. 2010;95(10):4643-4651. Exclusion code: 4. [pmid: 20631020].
Wasson LT, Shimbo D, Rubin MR, Shaffer JA, Schwartz JE, Davidson KW. Is vitamin D deficiency a risk factor for ischemic heart disease in patients with established cardiovascular disease? 10-year follow-up of the Nova Scotia Health Survey. Int J Cardiol. 2011;148(3):387-389. Exclusion code: 6. [pmid: 21396725].
Watson KE, Abrolat ML, Malone LL, et al. Active serum vitamin D levels are inversely correlated with coronary calcification. Circulation. 1997;96(6):1755-1760. Exclusion code: 6. [pmid: 9323058].
Weatherall M. A meta-analysis of 25 hydroxyvitamin D in older people with fracture of the proximal femur. N Z Med J. 2000;113(1108):137-140. Exclusion code: 13. [pmid: 10872433].
Webb AR, Kline L, Holick MF. Influence of season and latitude on the cutaneous synthesis of vitamin D3: exposure to winter sunlight in Boston and Edmonton will not promote vitamin D3 synthesis in human skin. J Clin Endocrinol Metab. 1988;67(2):373-378. Exclusion code: 6. [pmid: 2839537].
Wei MY, Garland CF, Gorham ED, Mohr SB, Giovannucci E. Vitamin D and prevention of colorectal adenoma: a meta-analysis. Cancer Epidemiol Biomarkers Prev. 2008;17(11):2958-2969. Exclusion code: 13. [pmid: 18990737].
Wei MY, Giovannucci EL. Vitamin D and multiple health outcomes in the Harvard cohorts. Mol Nutr Food Res. 2010;54(8):1114-1126. Exclusion code: 7. [pmid: 20486209].
Weingarten MA, Zalmanovici A, Yaphe J. Dietary calcium supplementation for preventing colorectal cancer and adenomatous polyps. Cochrane Database Syst Rev. 2008;(1). CD003548. Exclusion code: 5.
Wejse C, Gomes VF, Rabna P, et al. Vitamin D as supplementary treatment for tuberculosis: a double-blind, randomized, placebo-controlled trial. Am J Respir Crit Care Med. 2009;179(9):843-850. Exclusion code: 15. [pmid: 19179490].
Welsh P, Doolin O, McConnachie A, et al. Circulating 25OHD, dietary vitamin D, PTH, and calcium associations with incident cardiovascular disease and mortality: the MIDSPAN Family Study. J Clin Endocrinol Metab. 2012;97(12):4578-4587. Exclusion code: 3. [pmid: 23071162].
Weng FL, Shults J, Leonard MB, Stallings VA, Zemel BS. Risk factors for low serum 25-hydroxyvitamin D concentrations in otherwise healthy children and adolescents. Am J Clin Nutr. 2007;86(1):150-158. Exclusion code: 4. [pmid: 17616775].
White JH. Vitamin D metabolism and signaling in the immune system. Rev Endocr Metab Disord. 2012;13(1):21-29. Exclusion code: 8. [pmid: 21845364].
Whitehouse AJO, Holt BJ, Serralha M, Holt PG, Kusel MMH, Hart PH. Maternal serum vitamin D levels during pregnancy and offspring neurocognitive development. Pediatrics. 2012;129(3):485-493. Exclusion code: 4. [pmid: 22331333].
Wicherts IS, van Schoor NM, Boeke AJ, et al. Vitamin D status predicts physical performance and its decline in older persons. J Clin Endocrinol Metab. 2007;92(6):2058-2065. Exclusion code: 2. [pmid: 17341569].
Wilhelm-Leen ER, Hall YN, Deboer IH, Chertow GM. Vitamin D deficiency and frailty in older Americans. J Intern Med. 2010;268(2):171-180. Exclusion code: 7. [pmid: 20528970].
Wilkins CH, Birge SJ. Prevention of osteoporotic fractures in the elderly. Am J Med. 2005;118(11):1190-1195. Exclusion code: 7. [pmid: 16271899].
Williams DA, Arnold LM. Measures of fibromyalgia: Fibromyalgia Impact Questionnaire (FIQ), Brief Pain Inventory (BPI), Multidimensional Fatigue Inventory (MFI-20), Medical Outcomes Study (MOS) Sleep Scale, and Multiple Ability Self-Report Questionnaire (MASQ). Arthrisis Care Res. 2011;63(S11):S86-S97. Exclusion code: 2.
Witham MD, Crighton LJ, Gillespie ND, Struthers AD, McMurdo MET. The effects of vitamin D supplementation on physical function and quality of life in older patients with heart failure: a randomized controlled trial. Circ Heart Fail. 2010;3(2):195-201. Exclusion code: 4. [pmid: 20103775].
Witham MD, Nadir MA, Struthers AD. Effect of vitamin D on blood pressure: a systematic review and meta-analysis. J Hypertens. 2009;27(10):1948-1954. Exclusion code: 13. [pmid: 19587609].
Wjst M, Hypponen E. Vitamin D serum levels and allergic rhinitis. Allergy. 2007;62(9):1085-1086. Exclusion code: 7. [pmid: 17686112].
Wong YYE, Flicker L, Yeap BB, McCaul KA, Hankey GJ, Norman PE. Is hypovitaminosis D associated with abdominal aortic aneurysm, and is there a dose-response relationship?. Eur J Vasc Endovasc Surg. 2013;45(6):657-664. Exclusion code: 7. [pmid: 23602862].
Woo J, Lau E, Swaminathan R, Pang CP, MacDonald D. Biochemical predictors for osteoporotic fractures in elderly Chinese - A longitudinal study. Gerontology. 1990;36(1):55-58. Exclusion code: 3. [pmid: 2384226].
World Cancer Research Fund / American Institute for Cancer Research. Food, Nutrition, Physical Activity, and the Prevention of Cancer: A Global Perspective. Washington, DC. 2007. Exclusion code: 8.
Wortsman J, Matsuoka LY, Chen TC, Lu Z, Holick MF. Decreased bioavailability of vitamin D in obesity. Am J Clin Nutr. 2000;72(3):690-693. Exclusion code: 5. [pmid: 10966885].
Wu SH, Ho SC, Zhong L. Effects of vitamin D supplementation on blood pressure. South Med J. 2010;103(8):729-737. Exclusion code: 13. [pmid: 20622727].
Yamshchikov AV, Desai NS, Blumberg HM, Ziegler TR, Tangpricha V. Vitamin D for treatment and prevention of infectious diseases: a systematic review of randomized controlled trials. Endocr Pract. 2009;15(5):438-449. Exclusion code: 4. [pmid: 19491064].
Yan L, Zhou B, Wang X, et al. Older people in China and the United Kingdom differ in the relationships among parathyroid hormone, vitamin D, and bone mineral status. Bone. 2003;33(4):620-627. Exclusion code: 6. [pmid: 14555267].
Yanoff LB, Parikh SJ, Spitalnik A, et al. The prevalence of hypovitaminosis D and secondary hyperparathyroidism in obese Black Americans. Clin Endocrinol. 2006;64(5):523-529. Exclusion code: 6.
Yaylim-Eraltan I, Arzu Ergen H, Arikan S, et al. Investigation of the VDR gene polymorphisms association with susceptibility to colorectal cancer. Cell Biochem Funct. 2007;25(6):731-737. Exclusion code: 7. [pmid: 17243190].
Yesudian PD, Berry JL, Wiles S, et al. The effect of ultraviolet B-induced vitamin D levels on host resistance to Mycobacterium tuberculosis: a pilot study in immigrant Asian adults living in the United Kingdom. Photodermatol Photoimmunol Photomed. 2008;24(2):97-98. Exclusion code: 5. [pmid: 18353091].
Yetley E. Assessing the vitamin D status of the US population. Am J Clin Nutr. 2008;88(558S). Exclusion code: 3.
Yin L, Grandi N, Raum E, Haug U, Arndt V, Brenner H. Meta-analysis: longitudinal studies of serum vitamin D and colorectal cancer risk. Aliment Pharmacol Ther. 2009;30(2):113-125. Exclusion code: 3. [pmid: 19392870].
Yin L, Grandi N, Raum E, Haug U, Arndt V, Brenner H. Meta-analysis: serum vitamin D and breast cancer risk. Eur J Cancer. 2010;46(12):2196-2205. Exclusion code: 3. [pmid: 20456946].
Yin L, Raum E, Haug U, Arndt V, Brenner H. Meta-analysis of longitudinal studies: Serum vitamin D and prostate cancer risk. Cancer Epidemiol. 2009;33(6):435-445. Exclusion code: 3. [pmid: 19939760].
Yiu YF, Yiu KH, Siu CW, et al. Randomized controlled trial of vitamin D supplement on endothelial function in patients with type 2 diabetes. Atherosclerosis. 2013;227(1):140-146. Exclusion code: 6. [pmid: 23298824].
Yu CKH, Sykes L, Sethi M, Teoh TG, Robinson S. Vitamin D deficiency and supplementation during pregnancy. Clin Endocrinol. 2009;70(5):685-690. Exclusion code: 4.
Yusupov EL-N M, Pollack S, Yeh JK, Mikhail M, Aloia JF. Vitamin d and serum cytokines in a randomized clinical trial. Int J Endocrinol. 2010. Exclusion code: 15.
Zabihiyeganeh M, Jahed A, Nojomi M. Treatment of hypovitaminosis D with pharmacologic doses of cholecalciferol, oral vs intramuscular; an open labeled RCT. Clin Endocrinol. 2013;78(2):210-216. Exclusion code: 12.
Zamora SA, Rizzoli R, Belli DC, Slosman DO, Bonjour JP. Vitamin D supplementation during infancy is associated with higher bone mineral mass in prepubertal girls. J Clin Endocrinol Metab. 1999;84(12):4541-4544. Exclusion code: 4. [pmid: 10599715].
Zeghoud F, Vervel C, Guillozo H, Walrant-Debray O, Boutignon H, Garabedian M. Subclinical vitamin D deficiency in neonates: definition and response to vitamin D supplements. Am J Clin Nutr. 1997;65(3):771-778. Exclusion code: 4. [pmid: 9062528].
Zermansky AG, Alldred DP, Petty DR, et al. Clinical medication review by a pharmacist of elderly people living in care homes--randomised controlled trial. Age Ageing. 2006;35(6):586-591. Exclusion code: 5. [pmid: 16905764].
Zhao G, Ford ES, Li C, Croft JB. Serum 25-hydroxyvitamin D levels and all-cause and cardiovascular disease mortality among US adults with hypertension: the NHANES linked mortality study. Journal of Hypertension. 2012;30(2):284-289. Exclusion code: 4. [pmid: 22179077].
Zhou C, Assem M, Tay JC, et al. Steroid and xenobiotic receptor and vitamin D receptor crosstalk mediates CYP24 expression and drug-induced osteomalacia. J Clin Invest. 2006;116(6):1703-1712. Exclusion code: 6. [pmid: 16691293].
Zhou G, Stoitzfus J, Swan BA. Optimizing vitamin D status to reduce colorectal cancer risk: an evidentiary review. Clin J Oncol Nurs. 2009;13(4):E3-E17. Exclusion code: 13. [pmid: 19648087].
Zhou W, Heist RS, Liu G, et al. Circulating 25-hydroxyvitamin D levels predict survival in early-stage non-small-cell lung cancer patients. J Clin Oncol. 2007;25(5):479-485. Exclusion code: 4. [pmid: 17290055].
Zhu K, Austin N, Devine A, Bruce D, Prince RL. A randomized controlled trial of the effects of vitamin D on muscle strength and mobility in older women with vitamin D insufficiency. J Am Geriatr Soc. 2010;58(11):2063-2068. Exclusion code: 3. [pmid: 21054285].
Zhu K, Bruce D, Austin N, Devine A, Ebeling PR, Prince RL. Randomized controlled trial of the effects of calcium with or without vitamin D on bone structure and bone-related chemistry in elderly women with vitamin D insufficiency. J Bone Miner Res. 2008;23(8):1343-1348. Exclusion code: 4. [pmid: 18410225].
Zhu K, Devine A, Dick IM, Wilson SG, Prince RL. Effects of calcium and vitamin D supplementation on hip bone mineral density and calcium-related analytes in elderly ambulatory Australian women: A five-year randomized controlled trial. J Clin Endocrinol Metab. 2008;93(3):743-749. Exclusion code: 15. [pmid: 18089701].
Zhu W, Cai D, Wang Y, et al. Calcium plus vitamin D3 supplementation facilitated Fat loss in overweight and obese college students with very-low calcium consumption: A randomized controlled trial. Nutr J. 2013:8. Exclusion code: 6. [pmid: 23297844].
Ziambaras K, Dagogo-Jack S. Reversible muscle weakness in patients with vitamin D deficiency. West J Med. 1997;167(6):435-439. Exclusion code: 8. [pmid: 9426489].
Ziegler EE, Hollis BW, Nelson SE, Jeter JM. Vitamin D deficiency in breastfed infants in Iowa. Pediatrics. 2006;118(2):603-610. Exclusion code: 4. [pmid: 16882813].
Zipitis CS, Akobeng AK. Vitamin D supplementation in early childhood and risk of type 1 diabetes: a systematic review and meta-analysis. Arch Dis Child. 2008;93(6):512-517. Exclusion code: 4. [pmid: 18339654].
Zittermann A, Frisch S, Berthold HK, et al. Vitamin D supplementation enhances the beneficial effects of weight loss on cardiovascular disease risk markers. Am J Clin Nutr. 2009;89(5):1321-1327. Exclusion code: 5. [pmid: 19321573].
Zittermann A, Gummert JF, Borgermann J. Vitamin D deficiency and mortality. Curr Opin Clin Nutr Metab Care. 2009;12(6):634-639. Exclusion code: 7. [pmid: 19710612].
Zittermann A, Iodice S, Pilz S, Grant WB, Bagnardi V, Gandini S. Vitamin D deficiency and mortality risk in the general population: a meta-analysis of prospective cohort studies. Am J Clin Nutr. 2012;95(1):91-100. Exclusion code: 3. [pmid: 22170374].
Zittermann A, Schleithoff SS, Frisch S, et al. Circulating calcitriol concentrations and total mortality. Clin Chem. 2009;55(6):1163-1170. Exclusion code: 4. [pmid: 19359534].
Zittermann A, Schleithoff SS, Koerfer R. Vitamin D insufficiency in congestive heart failure: why and what to do about it?. Heart Fail Rev. 2006;11(1):25-33. Exclusion code: 8. [pmid: 16819575].
Zittermann A, Schleithoff SS, Tenderich G, Berthold HK, Korfer R, Stehle P. Low vitamin D status: a contributing factor in the pathogenesis of congestive heart failure?. J Am Coll Cardiol. 2003;41(1):105-112. Exclusion code: 7. [pmid: 12570952].
Zwart SR, Parsons H, Kimlin M, Innis SM, Locke JP, Smith SM. A 250 mug/week dose of vitamin D was as effective as a 50 mug/d dose in healthy adults, but a regimen of four weekly followed by monthly doses of 1250 mug raised the risk of hypercalciuria. Br J Nutr. 2013;110(10):1866-1872. Exclusion code: 15. [pmid: 23595003].
Dissemination CfRa. Vitamin D and dental caries in controlled clinical trials: systematic review and meta-analysis. (Structured abstract). DARE. 2013;(4). Exclusion code: 4.
Dissemination CfRa. Optimizing vitamin D status to reduce colorectal cancer risk: an evidentiary review. (Structured abstract). DARE. 2013;(4). Exclusion code: 13.
Dissemination CfRa. Interventions for preventing falls in acute- and chronic-care hospitals: a systematic review and meta-analysis. (Structured abstract). DARE. 2013;(4). Exclusion code: 13.
Dissemination CfRa. Effectiveness and implementation aspects of interventions for preventing falls in elderly people in long-term care facilities: a systematic review of RCTs. DARE. 2013;(4). Exclusion code: 13.
Study shows monthly vitamin D supplement effective in older women. Mayo Clin Womens Healthsource. 2009;13(5):3. Exclusion code: 8.
Aloia JF. Clinical Review: The 2011 report on dietary reference intake for vitamin D: where do we go from here?. J Clin Endocrinol Metab. 2011;96(10):2987-2996. Exclusion code: 8. [pmid: 21795456].
Ameri P, Bovio M, Murialdo G. Treatment for vitamin D deficiency: here and there do not mean everywhere. Eur J Nutr. 2012;51(2):257-259. author reply 255-256. Exclusion code: 8. [pmid: 22302617].
Anagnostis P, Athyros VG, Adamidou F, Florentin M, Karagiannis A. Vitamin D and cardiovascular disease: a novel agent for reducing cardiovascular risk?. Curr Vasc Pharmacol. 2010;8(5):720-730. Exclusion code: 7. [pmid: 20180765].
Annweiler C, Beauchet O. Vitamin D-mentia: randomized clinical trials should be the next step. Neuroepidemiology. 2011;37(3-4):249-258. Exclusion code: 7. [pmid: 22156654].
Aspray TJ, Francis RM. Vitamin D and fractures: where are we now?. Maturitas. 2010;66(3):221-222. Exclusion code: 8. [pmid: 20378289].
Babu US, Calvo MS. Modern India and the vitamin D dilemma: evidence for the need of a national food fortification program. Mol Nutr Food Res. 2010;54(8):1134-1147. Exclusion code: 7. [pmid: 20440690].
Bedner M, Lippa KA, Tai SS. An assessment of 25-hydroxyvitamin D measurements in comparability studies conducted by the Vitamin D Metabolites Quality Assurance Program. Clin Chim Acta. 2013;426:6-11. Exclusion code: 2. [pmid: 23978484].
Bell DSH. Protean manifestations of vitamin D deficiency, part 1: the epidemic of deficiency. South Med J. 2011;104(5):331-334. Exclusion code: 7. [pmid: 21606711].
Bertone-Johnson ER. Vitamin D and the occurrence of depression: causal association or circumstantial evidence?. Nutr Rev. 2009;67(8):481-492. Exclusion code: 8. [pmid: 19674344].
Binkley N, Krueger DC, Morgan S, Wiebe D. Current status of clinical 25-hydroxyvitamin D measurement: an assessment of between-laboratory agreement. Clin Chim Acta. 2010;411(23-24):1976-1982. Exclusion code: 2. [pmid: 20713030].
Bischoff-Ferrari HA. Vitamin D and fracture prevention. Endocrinol Metab Clin North Am. 2010;39(2):347-353. Exclusion code: 8. [pmid: 20511056].
Bischoff-Ferrari HA. “Vitamin D - why does it matter?” - defining vitamin D deficiency and its prevalence. Scand J Clin Lab Invest. 2012;243:3-6. Exclusion code: 7.
Bischoff-Ferrari HA, Staehelin HB. Importance of vitamin D and calcium at older age. Int J Vitam Nutr Res. 2008;78(6):286-292. Exclusion code: 7. [pmid: 19685438].
Boonen S, Bischoff-Ferrari HA, Cooper C, et al. Addressing the musculoskeletal components of fracture risk with calcium and vitamin D: a review of the evidence. Calcif Tissue Int. 2006;78(5):257-270. Exclusion code: 7. [pmid: 16622587].
Bosomworth NJ. Mitigating epidemic vitamin D deficiency: the agony of evidence. Can Fam Physician. 2011;57(1):16-20. Exclusion code: 8. [pmid: 21252124].
Bouillon R. Why modest but widespread improvement of the vitamin D status is the best strategy?. Baillieres Best Pract Res Clin Endocrinol Metab. 2011;25(4):693-702. Exclusion code: 8.
Carrozza C, Persichilli S, Canu G, et al. Measurement of 25-hydroxyvitamin vitamin D by liquid chromatography tandem-mass spectrometry with comparison to automated immunoassays. Clin Chem Lab Med. 2012;50(11):2033-2035. Exclusion code: 2. [pmid: 22740579].
Carter GD, Berry JL, Gunter E, et al. Proficiency testing of 25-hydroxyvitamin D (25-OHD) assays. J Steriod Biochem Mol Biol. 2010;121(1-2):176-179. Exclusion code: 2.
Carter GD, Jones JC. Use of a common standard improves the performance of liquid chromatography-tandem mass spectrometry methods for serum 25-hydroxyvitamin-D. Ann Clin Biochem. 2009;46(Pt 1):79-81. Exclusion code: 2. [pmid: 19103962].
Cashman KD, Kiely M, Kinsella M, et al. Evaluation of Vitamin D Standardization Program protocols for standardizing serum 25-hydroxyvitamin D data: a case study of the program's potential for national nutrition and health surveys. Am J Clin Nutr. 2013;97(6):1235-1242. Exclusion code: 2. [pmid: 23615829].
Cava RC, Javier AND. Vitamin D deficiency. N Engl J Med. 2007;357(19):1981. author reply 1981-1982. Exclusion code: 8. [pmid: 17992733].
Centre for Reviews and Dissemination. Effectiveness and implementation aspects of interventions for preventing falls in elderly people in long-term care facilities: a systematic review of RCTs. (Structured abstract). DARE. 2012;(4). Exclusion code: 8.
Chapuy MC, Preziosi P, Maamer M, et al. Prevalence of vitamin D insufficiency in an adult normal population. Osteoporos Int. 1997;7(5):439-443. Exclusion code: 6. [pmid: 9425501].
Cherniack EP, Levis S, Troen BR. Hypovitaminosis D: a widespread epidemic. Geriatrics. 2008;63(4):24-30. Exclusion code: 8. [pmid: 18376898].
Cherniack EP, Troen BR, Florez HJ, Roos BA, Levis S. Some new food for thought: the role of vitamin D in the mental health of older adults. Curr Psychiatry Rep. 2009;11(1):12-19. Exclusion code: 7. [pmid: 19187703].
Christakos S, Hewison M, Gardner DG, et al. Vitamin D: beyond bone. Ann N Y Acad Sci. 2013;1287:45-58. Exclusion code: 2. [pmid: 23682710].
Compston JE. Vitamin D deficiency: time for action. Evidence supports routine supplementation for elderly people and others at risk. BMJ. 1998;317(7171):1466-1467. Exclusion code: 8. [pmid: 9831568].
Cornell JE, Mulrow CD, Localio R, et al. Random-Effects Meta-analysis of Inconsistent Effects: A Time for Change. Ann Intern Med. 2014;160(4):267-270. Exclusion code: 2. [pmid: 24727843].
Dawson-Hughes B. Serum 25-hydroxyvitamin D and muscle atrophy in the elderly. Proc Nutr Soc. 2012;71(1):46-49. Exclusion code: 7. [pmid: 22040926].
Dror Y, Giveon SM, Hoshen M, Feldhamer I, Balicer RD, Feldman BS. Vitamin D levels for preventing acute coronary syndrome and mortality: evidence of a nonlinear association. J Clin Endocrinol Metab. 2013;98(5):2160-2167. Exclusion code: 2. [pmid: 23533239].
Fortmann SP, Burda BU, Senger CA, Lin JS, Whitlock EP. Vitamin and Mineral Supplements in the Primary Prevention of Cardiovascular Disease and Cancer: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013. Exclusion code: 2.
Francis RM. What do we currently know about nutrition and bone health in relation to United Kingdom public health policy with particular reference to calcium and vitamin D?. Br J Nutr. 2008;99(1):155-159. Exclusion code: 7. [pmid: 17640420].
Fraser WD, Milan AM. Vitamin D assays: past and present debates, difficulties, and developments. Calcif Tissue Int. 2013;92(2):118-127. Exclusion code: 2. [pmid: 23314742].
Gaugris S, Heaney RP, Boonen S, Kurth H, Bentkover JD, Sen SS. Vitamin D inadequacy among post-menopausal women: a systematic review. Qjm. 2005;98(9):667-676. Exclusion code: 3. [pmid: 16006498].
Gennari C. Calcium and vitamin D nutrition and bone disease of the elderly. Public Health Nutr. 2001;4(2B):547-559. Exclusion code: 7. [pmid: 11683549].
Granado Lorencio F, Blanco-Navarro I, Perez-Sacrsitan B. Critical evaluation of assays for vitamin D status. Curr Opin Clin Nutr Metab Care. 2013;16(6):734-740. Exclusion code: 2. [pmid: 24100666].
Grant WB, Schwalfenberg GK, Genuis SJ, Whiting SJ. An estimate of the economic burden and premature deaths due to vitamin D deficiency in Canada. Mol Nutr Food Res. 2010;54(8):1172-1181. Exclusion code: 7. [pmid: 20352622].
Hanley DA, Cranney A, Jones G, Whiting SJ, Leslie WD. Guidelines Committee of the Scientific Advisory Council of Osteoporosis C. Vitamin D in adult health and disease: a review and guideline statement from Osteoporosis Canada (summary). CMAJ Canadian Medical Association Journal. 2010;182(12):1315-1319. Exclusion code: 8.
Hart W. Recommendations for calcium and vitamin D in the report ‘Nutritional standards’ of the Netherlands Health Council. Ned Tijdschr Geneeskd. 2000;144(42):1991-1994. Exclusion code: 8. [pmid: 11072516].
Heaney RP. Vitamin D: how much do we need, and how much is too much?. Osteoporos Int. 2000;11(7):553-555. Exclusion code: 8. [pmid: 11069187].
Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-560. Exclusion code: 2. [pmid: 12958120].
Holick MF. Vitamin D requirements for humans of all ages: new increased requirements for women and men 50 years and older. Osteoporos Int. 1998;8(Suppl 2):S24-29. Exclusion code: 8. [pmid: 10197179].
Holick MF. High prevalence of vitamin D inadequacy and implications for health. Mayo Clin Proc. 2006;81(3):353-373. Exclusion code: 7. [pmid: 16529140].
Holick MF. Vitamin D: a d-lightful solution for health. J Investig Med. 2011;59(6):872-880. Exclusion code: 2.
Holick MF, Binkley NC, Bischoff-Ferrari HA, et al. Evaluation, treatment, and prevention of vitamin D deficiency: an Endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2011;96(7):1911-1930. Exclusion code: 2. [pmid: 21646368].
Holmes EW, Garbincius J, McKenna KM. Analytical variability among methods for the measurement of 25-hydroxyvitamin D: still adding to the noise. Am J Clin Pathol. 2013;140(4):550-560. Exclusion code: 2. [pmid: 24045553].
Holmes RP, Kummerow FA. The relationship of adequate and excessive intake of vitamin D to health and disease. J Am Coll Nutr. 1983;2(2):173-199. Exclusion code: 8. [pmid: 6350405].
Jones G. Pharmacokinetics of Vitamin D toxicity. Am J Clin Nutr. 2008;88(2):582S-586S. Exclusion code: 8. [pmid: 18689406].
Kallas M, Green F, Hewison M, White C, Kline G. Rare causes of calcitriol-mediated hypercalcemia: a case report and literature review. J Clin Endocrinol Metab. 2010;95(7):3111-3117. Exclusion code: 7. [pmid: 20427501].
Kennel KA, Drake MT, Hurley DL. Vitamin D deficiency in adults: when to test and how to treat. Mayo Clin Proc. 2010;85(8):752-757. quiz 757-758. Exclusion code: 7. [pmid: 20675513].
Laaksi IT. Vitamin D and respiratory infection in adults. Proc Nutr Soc. 2012;71(1):90-97. Exclusion code: 7. [pmid: 22115013].
Lai JK, Lucas RM, Banks E, Ponsonby AL. Variability in vitamin D assays impairs clinical assessment of vitamin D status. Intern Med J. 2012;42(1):43-50. Exclusion code: 2. [pmid: 21395958].
Lambert J. Vitamin D deficiency. Br J Gen Pract. 2007;57(541):669. author reply 669-670. Exclusion code: 8. [pmid: 17688766].
Larrosa M, Casado E, Vazquez I, Navarro N, Gratacos J. Comment on Przybelski et al.: Rapid correction of low vitamin D status in nursing home residents. Osteoporos Int. 2009;20(8):1455-1456. Exclusion code: 8. [pmid: 19219478].
Lawless S, White P, Murdoch P, Leitch S. (Preventing) two birds with one stone: improving vitamin D levels in the elderly. J Prim Health Care. 2011;3(2):150-152. Exclusion code: 6. [pmid: 21625664].
Lips P. Worldwide status of vitamin D nutrition. J Steriod Biochem Mol Biol. 2010;121(1-2):297-300. Exclusion code: 8.
Lopez-Torres Hidalgo J, Group A. Prevention of falls and fractures in old people by administration of calcium and vitamin D, randomized clinical trial. BMC Public Health. 2011;11:910. Exclusion code: 8. [pmid: 22151975].
Manson JE, Bassuk SS, Lee IM, et al. The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 2012;33(1):159-171. Exclusion code: 2. [pmid: 21986389].
Meunier P. Prevention of hip fractures by correcting calcium and vitamin D insufficiencies in elderly people. Scand J Rheumatol Suppl. 1996;103:75-78. discussion 79-80. Exclusion code: 8. [pmid: 8966494].
Mitri J, Pittas AG. Diabetes: Shining a light: the role of vitamin D in diabetes mellitus. Nat Rev Endocrinol. 2010;6(9):478-480. Exclusion code: 8. [pmid: 20720588].
Moon HW, Cho JH, Hur M, et al. Comparison of four current 25-hydroxyvitamin D assays. Clin Biochem. 2012;45(4-5):326-330. Exclusion code: 2. [pmid: 22244986].
Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(02):138-144. Exclusion code: 2. [pmid: 22559755].
Mosekilde L. Vitamin D and the elderly. Clin Endocrinol. 2005;62(3):265-281. Exclusion code: 7.
Norman AW, Bouillon R. Vitamin D nutritional policy needs a vision for the future. Exp Biol Med (Maywood). 2010;235(9):1034-1045. Exclusion code: 7. [pmid: 20667908].
Nowson CA. Prevention of fractures in older people with calcium and vitamin D. Nutrients. 2010;2(9):975-984. Exclusion code: 7. [pmid: 22254066].
Nowson CA, McGrath JJ, Ebeling PR, et al. Vitamin D and health in adults in Australia and New Zealand: a position statement. Med J Aust. 2012;196(11):686-687. Exclusion code: 8. [pmid: 22708765].
Panou N, Georgopoulos S, Panou M, Sergentanis TN, Maropoulos G, Papalambros E. Sun exposure and vitamin D. Perspect Public Health. 2012;132(1):7. discussion 7. Exclusion code: 8. [pmid: 22458138].
Pearce SHS, Cheetham TD. Diagnosis and management of vitamin D deficiency. BMJ. 2010;340:b5664. Exclusion code: 7. [pmid: 20064851].
Perez-Lopez FR, Chedraui P, Fernandez-Alonso AM. Vitamin D and aging: beyond calcium and bone metabolism. Maturitas. 2011;69(1):27-36. Exclusion code: 7. [pmid: 21429678].
Pfeifer M, Begerow B, Minne HW. Vitamin D and muscle function. Osteoporos Int. 2002;13(3):187-194. Exclusion code: 7. [pmid: 11991436].
Pham B, Klassen TP, Lawson ML, Moher D. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005;58(8):769-776. Exclusion code: 2. [pmid: 16086467].
Planton J, Meyer JO, Edlund BJ. Vitamin D. J Gerontol Nurs. 2011;37(1):9-13. Exclusion code: 8. [pmid: 21175109].
Pogge E. Vitamin D and Alzheimer's disease: is there a link?. Consult Pharm. 2010;25(7):440-450. Exclusion code: 7. [pmid: 20601349].
Premaor MO, Scalco R, da Silva MJS, Froehlich PE, Furlanetto TW. The effect of a single dose versus a daily dose of cholecalciferol on the serum 25-hydroxycholecalciferol and parathyroid hormone levels in the elderly with secondary hyperparathyroidism living in a low-income housing unit. J Bone Miner Metab. 2008;26(6):603-608. Exclusion code: 12. [pmid: 18979160].
Rao DS, Alqurashi S. Management of vitamin d depletion in postmenopausal women. Curr. 2003;1(3):110-115. Exclusion code: 8.
Reid IR, Avenell A. Evidence-based policy on dietary calcium and vitamin D. J Bone Miner Res. 2011;26(3):452-454. Exclusion code: 8. [pmid: 21337616].
Reis JP, von Muhlen D, Miller ER 3rd, Michos ED, Appel LJ. Vitamin D status and cardiometabolic risk factors in the United States adolescent population. Pediatrics. 2009;124(3):e371-379. Exclusion code: 4. [pmid: 19661053].
Rizzoli R, Boonen S, Brandi ML, et al. Vitamin D supplementation in elderly or postmenopausal women: a 2013 update of the 2008 recommendations from the European Society for Clinical and Economic Aspects of Osteoporosis and Osteoarthritis (ESCEO). Curr Med Res Opin. 2013;29(4):305-313. Exclusion code: 2. [pmid: 23320612].
Rosen CJ. Clinical practice. Vitamin D insufficiency. N Engl J Med. 2011;364(3):248-254. Exclusion code: 8. [pmid: 21247315].
Rosen CJ, Abrams SA, Aloia JF, et al. IOM Committee Members Respond to Endocrine Society Vitamin D Guideline. J Clin Endocrinol Metab. 2012;97(4):1146-1152. Exclusion code: 2. [pmid: 22442278].
Ross AC, Manson JE, Abrams SA, et al. The 2011 report on dietary reference intakes for calcium and vitamin d from the Institute of Medicine: what clinicians need to know. J Clin Endocrinol Metab. 2011;96(1):53-58. Exclusion code: 8. [pmid: 21118827].
Sahota O. Calcium and vitamin d reduces falls and fractures--confusion and controversy. J Nurt Health Aging. 2007;11(2):176-178. Exclusion code: 7.
Sempos CT, Durazo-Arvizu RA, Dawson-Hughes B, et al. Is there a reverse J-shaped association between 25-hydroxyvitamin D and all-cause mortality? Results from the U.S. nationally representative NHANES. J Clin Endocrinol Metab. 2013;98(7):3001-3009. Exclusion code: 2. [pmid: 23666975].
Sempos CT, Vesper HW, Phinney KW, Thienpont LM, Coates PM. Vitamin D status as an international issue: national surveys and the problem of standardization. Scand J Clin Lab Invest. 2012;243:32-40. Exclusion code: 2.
Siffledeen JS, Siminoski K, Steinhart H, Greenberg G, Fedorak RN. The frequency of vitamin D deficiency in adults with Crohn's disease. Can J Gastroenterol. 2003;17(8):473-478. Exclusion code: 2. [pmid: 12945007].
Souberbielle JC, Body JJ, Lappe JM, et al. Vitamin D and musculoskeletal health, cardiovascular disease, autoimmunity and cancer: Recommendations for clinical practice. Autoimmun Rev. 2010;9(11):709-715. Exclusion code: 8. [pmid: 20601202].
Straube S, Derry S, Moore AR, McQuay HJ. Vitamin D for the treatment of chronic painful conditions in adults. Cochrane Database Syst Rev. 2012;(8). Exclusion code: 4.
Thuesen B, Husemoen L, Fenger M, et al. Determinants of vitamin D status in a general population of Danish adults. Bone. 2012;50(3):605-610. Exclusion code: 7. [pmid: 22227435].
Tomson J, Emberson J, Hill M, et al. Vitamin D and risk of death from vascular and non-vascular causes in the Whitehall study and meta-analyses of 12,000 deaths. Eur Heart J. 2013;34(18):1365-1374. Exclusion code: 2. [pmid: 23257953].
Troesch B, Hoeft B, McBurney M, Eggersdorfer M, Weber P. Dietary surveys indicate vitamin intakes below recommendations are common in representative Western countries. Br J Nutr. 2012;108(4):692-698. Exclusion code: 7. [pmid: 22691229].
van Groningen L, Opdenoordt S, van Sorge A, Telting D, Giesen A, de Boer H. Cholecalciferol loading dose guideline for vitamin D-deficient adults. Eur J Endocrinol. 2010;162(4):805-811. Exclusion code: 12. [pmid: 20139241].
van Schoor NM, Lips P. Worldwide vitamin D status. Baillieres Best Pract Res Clin Endocrinol Metab. 2011;25(4):671-680. Exclusion code: 2.
Vanlint SJ. Vitamin D and adult bone health in Australia and New Zealand: a position statement. Med J Aust. 2005;183(1):52. author reply 53-54. Exclusion code: 8. [pmid: 15992344].
Vieth R. Vitamin D supplementation, 25-hydroxyvitamin D concentrations, and safety. Am J Clin Nutr. 1999;69(5):842-856. Exclusion code: 8. [pmid: 10232622].
Vieth R. Critique of the considerations for establishing the tolerable upper intake level for vitamin D: critical need for revision upwards. J Nutr. 2006;136(4):1117-1122. Exclusion code: 8. [pmid: 16549491].
Vieth R. Why the minimum desirable serum 25-hydroxyvitamin D level should be 75nmol/L (30ng/ml). Baillieres Best Pract Res Clin Endocrinol Metab. 2011;25(4):681-691. Exclusion code: 2.
Wagner D, Hanwell HE, Vieth R. An evaluation of automated methods for measurement of serum 25-hydroxyvitamin D. Clin Biochem. 2009;42(15):1549-1556. Exclusion code: 2. [pmid: 19631201].
Weggemans RM, Schaafsma G, Kromhout D. Towards an adequate intake of vitamin D. An advisory report of the Health Council of the Netherlands. Eur J Clin Nutr. 2009;63(12):1455-1457. Exclusion code: 8. [pmid: 19623202].
Winzenberg T, van der Mei I, Mason RS, Nowson C, Jones G. Vitamin D and the musculoskeletal health of older adults. Aust Fam Physician. 2012;41(3):92-99. Exclusion code: 8. [pmid: 22396920].
Wong YY, McCaul KA, Yeap BB, Hankey GJ, Flicker L. Low vitamin D status is an independent predictor of increased frailty and all-cause mortality in older men: the Health in Men Study. J Clin Endocrinol Metab. 2013;98(9):3821-3828. Exclusion code: 2. [pmid: 23788685].
Working Group of the Australian and New Zealand Bone and Mineral Society Endocrine Society of Australia and Osteoporosis Australia. Vitamin D and adult bone health in Australia and New Zealand: a position statement. Med J Aust. 2005;182(6):281-285. Exclusion code: 8. [pmid: 15777143].
Youssef DA, El Abbassi AM, Cutchins DC, Chhabra S, Peiris AN. Vitamin D deficiency: implications for acute care in the elderly and in patients with chronic illness. Geriatr Gerontol Int. 2011;11(4):395-407. Exclusion code: 8. [pmid: 21605301].
Zgaga L, Theodoratou E, Farrington SM, et al. Diet, environmental factors, and lifestyle underlie the high prevalence of vitamin D deficiency in healthy adults in Scotland, and supplementation reduces the proportion that are severely deficient. J Nutr. 2011;141(8):1535-1542. Exclusion code: 7. [pmid: 21697298].
Zittermann A, Gummert JF. Nonclassical vitamin D action. Nutrients. 2010;2(4):408-425. Exclusion code: 8. [pmid: 22254030].
Annweiler C, Rolland Y, Schott AM, Blain H, Vellas B, Beauchet O. Serum vitamin D deficiency as a predictor of incident non-Alzheimer dementias: a 7-year longitudinal study. Dement Geriatr Cogn Disord. 2011;32(4):273-278. Exclusion code: 7. [pmid: 22261995].
Benjamin A, Moriakova A, Akhter N, et al. Determinants of 25-hydroxyvitamin D levels in African-American and Caucasian male veterans. Osteoporos Int. 2009;20(10):1795-1803. Exclusion code: 3. [pmid: 19280273].
Bock G, Prietl B, Mader JK, et al. The effect of vitamin D supplementation on peripheral regulatory T cells and [beta] cell function in healthy humans: a randomized controlled trial. Diabetes/metabolism research and reviews. 2011;27(8):942-945. Exclusion code: 15. [pmid: 22069289].
Bolland MJ, Bacon CJ, Horne AM, et al. Vitamin D insufficiency and health outcomes over 5 y in older women. Am J Clin Nutr. 2010;91(1):82-89. Exclusion code: 7. [pmid: 19906799].
Centre for Reviews and Dissemination. Prognostic role of vitamin D status and efficacy of vitamin D supplementation in cancer patients: a systematic review. (Provisional abstract). DARE. 2012;(4). Exclusion code: 4.
Chan R, Chan D, Woo J, et al. Association between serum 25-hydroxyvitamin D and psychological health in older Chinese men in a cohort study. J Affect Disord. 2011;130(1-2):251-259. Exclusion code: 4. [pmid: 21056909].
Chen W, Dawsey SM, Qiao YL, et al. Prospective study of serum 25(OH)-vitamin D concentration and risk of oesophageal and gastric cancers. Br J Cancer. 2007;97(1):123-128. Exclusion code: 6. [pmid: 17551495].
Chlebowski RT, Pettinger M, Johnson KC, et al. Calcium plus vitamin D supplementation and joint symptoms in postmenopausal women in the women's health initiative randomized trial. J Acad Nutr Diet. 2013;113(10):1302-1310. Exclusion code: 14. [pmid: 23954097].
Chowdhury R, Kunutsor S, Vitezova A, et al. Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014:348. Exclusion code: 2.
Close GL, Russell J, Cobley JN, et al. Assessment of vitamin D concentration in non-supplemented professional athletes and healthy adults during the winter months in the UK: implications for skeletal muscle function. J Sports Sci. 2013;31(4):344-353. Exclusion code: 3. [pmid: 23083379].
Dam TTL, von Muhlen D, Barrett-Connor EL. Sex-specific association of serum 25-Hydroxyvitamin D levels with physical function in older adults. Osteoporos Int. 2009;20(5):751-760. Exclusion code: 3. [pmid: 18802657].
Dawson-Hughes B. Serum 25-hydroxyvitamin D and functional outcomes in the elderly. Am J Clin Nutr. 2008;88(2):537S-540S. Exclusion code: 3. [pmid: 18689397].
de Boer IH, Kestenbaum B, Shoben AB, Michos ED, Sarnak MJ, Siscovick DS. 25-hydroxyvitamin D levels inversely associate with risk for developing coronary artery calcification. J Am Soc Nephrol. 2009;20(8):1805-1812. Exclusion code: 4. [pmid: 19443637].
Ding H, Dhima K, Lockhart KC, et al. Unrecognized vitamin D3 deficiency is common in Parkinson disease: Harvard Biomarker Study. Neurology. 2013;81(17):1531-1537. Exclusion code: 7. [pmid: 24068787].
Fiscella K, Franks P. Vitamin D, race, and cardiovascular mortality: findings from a national US sample. Ann Fam Med. 2010;8(1):11-18. Exclusion code: 3. [pmid: 20065273].
Ford ES, Ajani UA, McGuire LC, Liu S. Concentrations of serum Vitamin D and the metabolic syndrome among U.S. adults. Diabetes Care. 2005;28(5):1228-1230. Exclusion code: 7. [pmid: 15855599].
Freedman DM, Chang SC, Falk RT, et al. Serum levels of vitamin D metabolites and breast cancer risk in the prostate, lung, colorectal, and ovarian cancer screening trial. Cancer Epidemiol Biomarkers Prev. 2008;17(4):889-894. Exclusion code: 3. [pmid: 18381472].
Freedman DM, Looker AC, Chang SC, Graubard BI. Prospective study of serum vitamin D and cancer mortality in the United States. J Natl Cancer Inst. 2007;99(21):1594-1602. Exclusion code: 3. [pmid: 17971526].
Gallicchio L, Helzlsouer KJ, Chow WH, et al. Circulating 25-hydroxyvitamin D and the risk of rarer cancers: Design and methods of the Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):10-20. Exclusion code: 8. [pmid: 20562188].
Gallicchio L, Moore LE, Stevens VL, et al. Circulating 25-hydroxyvitamin D and risk of kidney cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):47-57. Exclusion code: 6. [pmid: 20562187].
Gandini S, Boniol M, Haukka J, et al. Meta-analysis of observational studies of serum 25-hydroxyvitamin D levels and colorectal, breast and prostate cancer and colorectal adenoma. Int J Cancer. 2011;128(6):1414-1424. Exclusion code: 3. [pmid: 20473927].
Gann PH, Ma J, Hennekens CH, Hollis BW, Haddad JG, Stampfer MJ. Circulating vitamin D metabolites in relation to subsequent development of prostate cancer. Cancer Epidemiol Biomarkers Prev. 1996;5(2):121-126. Exclusion code: 6. [pmid: 8850273].
Gilbert R, Metcalfe C, Fraser WD, et al. Associations of circulating 25-hydroxyvitamin D with prostate cancer diagnosis, stage and grade. Int J Cancer. 2012;131(5):1187-1196. Exclusion code: 7. [pmid: 22033893].
Gonzalez-Molero I, Rojo-Martinez G, Morcillo S, et al. Vitamin D and incidence of diabetes: a prospective cohort study. Clin Nutr. 2012;31(4):571-573. Exclusion code: 3. [pmid: 22204964].
Griffin FC, Gadegbeku CA, Sowers MR. Vitamin D and subsequent systolic hypertension among women. Am J Hypertens. 2011;24(3):316-321. Exclusion code: 6. [pmid: 21088670].
Helzlsouer KJ, Committee VS. Overview of the Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):4-9. Exclusion code: 8. [pmid: 20562193].
Hosseinpanah F, Yarjanli M, Sheikholeslami F, Heibatollahi M, Eskandary PS, Azizi F. Associations between vitamin D and cardiovascular outcomes; Tehran Lipid and Glucose Study. Atherosclerosis. 2011;218(1):238-242. Exclusion code: 4. [pmid: 21676397].
Husemoen LLN, Thuesen BH, Fenger M, et al. Serum 25(OH)D and type 2 diabetes association in a general population: a prospective study. Diabetes Care. 2012;35(8):1695-1700. Exclusion code: 6. [pmid: 22688545].
Jacobs ET, Hibler EA, Lance P, Sardo CL, Jurutka PW. Association between circulating concentrations of 25(OH)D and colorectal adenoma: a pooled analysis. Int J Cancer. 2013;133(12):2980-2988. Exclusion code: 7. [pmid: 23754630].
Jenab M, Bueno-de-Mesquita HB, Ferrari P, et al. Association between pre-diagnostic circulating vitamin D concentration and risk of colorectal cancer in European populations:A nested case-control study. BMJ. 2010;340:b5500. Exclusion code: 3. [pmid: 20093284].
Jia X, Aucott LS, McNeill G. Nutritional status and subsequent all-cause mortality in men and women aged 75 years or over living in the community. Br J Nutr. 2007;98(3):593-599. Exclusion code: 3. [pmid: 17442130].
Johansson H, Oden A, Kanis J, et al. Low serum vitamin D is associated with increased mortality in elderly men: MrOS Sweden. Osteoporos Int. 2012;23(3):991-999. Exclusion code: 3. [pmid: 22008880].
Kaloostian CL, Shil AB. Effects of vitamin D on muscle strength and mobility in older women. J Am Geriatr Soc. 2011;59(4):771. author reply 771-772. Exclusion code: 2. [pmid: 21492116].
Kalra P, Das V, Agarwal A, et al. Effect of vitamin D supplementation during pregnancy on neonatal mineral homeostasis and anthropometry of the newborn and infant. Br J Nutr. 2012;108(6):1052-1058. Exclusion code: 4. [pmid: 22212646].
Kayaniyil S, Retnakaran R, Harris SB, et al. Prospective associations of vitamin D with -cell function and glycemia: the PROspective Metabolism and ISlet cell Evaluation (PROMISE) cohort study. Diabetes. 2011;60(11):2947-2953. Exclusion code: 4. [pmid: 21911752].
Kilkkinen A, Knekt P, Aro A, et al. Vitamin D status and the risk of cardiovascular disease death. Am J Epidemiol. 2009;170(8):1032-1039. Exclusion code: 2. [pmid: 19762371].
Knekt P, Kilkkinen A, Rissanen H, Marniemi J, Saaksjarvi K, Heliovaara M. Serum vitamin D and the risk of Parkinson disease. Arch Neurol. 2010;67(7):808-811. Exclusion code: 3. [pmid: 20625085].
Knekt P, Laaksonen M, Mattila C, et al. Serum vitamin D and subsequent occurrence of type 2 diabetes. Epidemiology. 2008;19(5):666-671. Exclusion code: 3. [pmid: 18496468].
Lane NE, Gore LR, Cummings SR, et al. Serum vitamin D levels and incident changes of radiographic hip osteoarthritis: a longitudinal study. Study of Osteoporotic Fractures Research Group. Arthritis Rheum. 1999;42(5):854-860. Exclusion code: 3. [pmid: 10323440].
LeBlanc ES, Rizzo JH, Pedula KL, et al. Associations between 25-hydroxyvitamin D and weight gain in elderly women. J Womens Health Gend Based Med. 2012;21(10):1066-1073. Exclusion code: 6.
Liang G, Nan H, Qureshi AA, Han J. Pre-diagnostic plasma 25-hydroxyvitamin D levels and risk of non-melanoma skin cancer in women. PLoS ONE. [Electronic Resource]. 2012;7(4):e35211. Exclusion code: 6. [pmid: 22493740].
Llewellyn DJ, Lang IA, Langa KM, et al. Vitamin D and risk of cognitive decline in elderly persons. Arch Intern Med. 2010;170(13):1135-1141. Exclusion code: 3. [pmid: 20625021].
Looker AC, Mussolino ME. Serum 25-hydroxyvitamin D and hip fracture risk in older U.S. white adults. J Bone Miner Res. 2008;23(1):143-150. Exclusion code: 3. [pmid: 17907920].
Looker AC, Pfeiffer CM, Lacher DA, Schleicher RL, Picciano MF, Yetley EA. Serum 25-hydroxyvitamin D status of the US population: 1988-1994 compared with 2000-2004. Am J Clin Nutr. 2008;88(6):1519-1527. Exclusion code: 3. [pmid: 19064511].
McCullough ML, Weinstein SJ, Freedman DM, et al. Correlates of circulating 25-hydroxyvitamin D: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):21-35. Exclusion code: 3. [pmid: 20562191].
Melamed ML, Michos ED, Post W, Astor B. 25-hydroxyvitamin D levels and the risk of mortality in the general population. Arch Intern Med. 2008;168(15):1629-1637. Exclusion code: 3. [pmid: 18695076].
Menant JC, Close JCT, Delbaere K, et al. Relationships between serum vitamin D levels, neuromuscular and neuropsychological function and falls in older men and women. Osteoporos Int. 2012;23(3):981-989. Exclusion code: 3. [pmid: 21523392].
Michaelsson K, Baron JA, Snellman G, et al. Plasma vitamin D and mortality in older men: a community-based prospective cohort study. Am J Clin Nutr. 2010;92(4):841-848. Exclusion code: 3. [pmid: 20720256].
Michos ED, Reis JP, Post WS, et al. 25-Hydroxyvitamin D deficiency is associated with fatal stroke among whites but not blacks: The NHANES-III linked mortality files. Nutrition. 2012;28(4):367-371. Exclusion code: 3. [pmid: 22261577].
Milaneschi Y, Shardell M, Corsi AM, et al. Serum 25-hydroxyvitamin D and depressive symptoms in older women and men. J Clin Endocrinol Metab. 2010;95(7):3225-3233. Exclusion code: 3. [pmid: 20444911].
Millen AE, Wactawski-Wende J, Pettinger M, et al. Predictors of serum 25-hydroxyvitamin D concentrations among postmenopausal women: the Women's Health Initiative Calcium plus Vitamin D clinical trial. Am J Clin Nutr. 2010;91(5):1324-1335. Exclusion code: 3. [pmid: 20219959].
Mondul AM, Weinstein SJ, Horst RL, Purdue M, Albanes D. Serum vitamin D and risk of bladder cancer in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening trial. Cancer Epidemiol Biomarkers Prev. 2012;21(7):1222-1225. Exclusion code: 6. [pmid: 22623707].
Mondul AM, Weinstein SJ, Mannisto S, et al. Serum vitamin D and risk of bladder cancer. Cancer Res. 2010;70(22):9218-9223. Exclusion code: 3. [pmid: 20978193].
Nomura AM, Stemmermann GN, Lee J, et al. Serum vitamin D metabolite levels and the subsequent development of prostate cancer (Hawaii, United States). Cancer Causes Control. 1998;9(4):425-432. Exclusion code: 3. [pmid: 9794175].
Pan WH, Wang CY, Li LA, Kao LS, Yeh SH. No significant effect of calcium and vitamin D supplementation on blood pressure and calcium metabolism in elderly Chinese. Chin J Physiol. 1993;36(2):85-94. Exclusion code: 15. [pmid: 8198625].
Peiris AN, Bailey BA, Guha BN, Copeland R, Manning T. Can a model predictive of vitamin D status be developed from common laboratory tests and demographic parameters?. South Med J. 2011;104(9):636-639. Exclusion code: 3. [pmid: 21886082].
Pilz S, Dobnig H, Nijpels G, et al. Vitamin D and mortality in older men and women. Clin Endocrinol. 2009;71(5):666-672. Exclusion code: 6.
Purdue MP, Freedman DM, Gapstur SM, et al. Circulating 25-hydroxyvitamin D and risk of non-hodgkin lymphoma: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):58-69. Exclusion code: 6. [pmid: 20562184].
Rejnmark L, Tietze A, Vestergaard P, et al. Reduced prediagnostic 25-hydroxyvitamin D levels in women with breast cancer: a nested case-control study. Cancer Epidemiol Biomarkers Prev. 2009;18(10):2655-2660. Exclusion code: 7. [pmid: 19789365].
Rienstra M, Cheng S, Larson MG, et al. Vitamin D status is not related to development of atrial fibrillation in the community. Am Heart J. 2011;162(3):538-541. Exclusion code: 6. [pmid: 21884873].
Robinson-Cohen C, Hoofnagle AN, Ix JH, et al. Racial differences in the association of serum 25-hydroxyvitamin d concentration with coronary heart disease eventsrace and chd events associated with vitamin drace and chd events associated with vitamin d. JAMA. 2013;310(2):179-188. Exclusion code: 3. [pmid: 23839752].
Salehpour A, Shidfar F, Hosseinpanah F, et al. Vitamin D3 and the risk of CVD in overweight and obese women: a randomised controlled trial. Br J Nutr. 2012;108(10):1866-1873. Exclusion code: 3. [pmid: 22317756].
Schierbeck LL, Rejnmark L, Tofteng CL, et al. Vitamin D deficiency in postmenopausal, healthy women predicts increased cardiovascular events: a 16-year follow-up study. Eur J Endocrinol. 2012;167(4):553-560. Exclusion code: 3. [pmid: 22875588].
Semba RD, Garrett E, Johnson BA, Guralnik JM, Fried LP. Vitamin D deficiency among older women with and without disability. Am J Clin Nutr. 2000;72(6):1529-1534. Exclusion code: 3. [pmid: 11101482].
Semba RD, Houston DK, Bandinelli S, et al. Relationship of 25-hydroxyvitamin D with all-cause and cardiovascular disease mortality in older community-dwelling adults. Eur J Clin Nutr. 2010;64(2):203-209. Exclusion code: 3. [pmid: 19953106].
Simha V, Mahmood M, Ansari M, Spellman CW, Shah P. Effect of vitamin D replacement on insulin sensitivity in subjects with vitamin D deficiency. J Investig Med. 2012;60(8):1214-1218. Exclusion code: 3.
Sohl E, de Jongh RT, Heijboer AC, et al. Vitamin D status is associated with physical performance: the results of three independent cohorts. Osteoporos Int. 2013;24(1):187-196. Exclusion code: 3. [pmid: 22961566].
Stolzenberg-Solomon RZ, Hayes RB, Horst RL, Anderson KE, Hollis BW, Silverman DT. Serum vitamin D and risk of pancreatic cancer in the prostate, lung, colorectal, and ovarian screening trial. Cancer Res. 2009;69(4):1439-1447. Exclusion code: 6. [pmid: 19208842].
Stolzenberg-Solomon RZ, Vieth R, Azad A, et al. A prospective nested case-control study of vitamin D status and pancreatic cancer risk in male smokers. Cancer Res. 2006;66(20):10213-10219. Exclusion code: 6. [pmid: 17047087].
Sun Q, Shi L, Rimm EB, et al. Vitamin D intake and risk of cardiovascular disease in US men and women. Am J Clin Nutr. 2011;94(2):534-542. Exclusion code: 6. [pmid: 21653796].
Theodoratou E, Tzoulaki I, Zgaga L, Ioannidis JPA. Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014:348. Exclusion code: 2.
Tuohimaa P, Tenkanen L, Ahonen M, et al. Both high and low levels of blood vitamin D are associated with a higher prostate cancer risk: a longitudinal, nested case-control study in the Nordic countries. Int J Cancer. 2004;108(1):104-108. Exclusion code: 3. [pmid: 14618623].
Tuohimaa P, Tenkanen L, Syvala H, et al. Interaction of factors related to the metabolic syndrome and vitamin D on risk of prostate cancer. Cancer Epidemiol Biomarkers Prev. 2007;16(2):302-307. Exclusion code: 6. [pmid: 17301263].
Tworoger SS, Lee IM, Buring JE, Rosner B, Hollis BW, Hankinson SE. Plasma 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D and risk of incident ovarian cancer. Cancer Epidemiol Biomarkers Prev. 2007;16(4):783-788. Exclusion code: 6. [pmid: 17416771].
Visser M, Deeg DJH, Puts MTE, Seidell JC, Lips P. Low serum concentrations of 25-hydroxyvitamin D in older persons and the risk of nursing home admission. Am J Clin Nutr. 2006;84(3):616-622. quiz 671-612. Exclusion code: 3. [pmid: 16960177].
Wang H, Xia N, Yang Y, Peng DQ. Influence of vitamin D supplementation on plasma lipid profiles: a meta-analysis of randomized controlled trials. Lipids health dis. 2012;11:42. Exclusion code: 3. [pmid: 22433171].
Wang TJ, Pencina MJ, Booth SL, et al. Vitamin D deficiency and risk of cardiovascular disease. Circulation. 2008;117(4):503-511. Exclusion code: 3. [pmid: 18180395].
Weinstein SJ, Yu K, Horst RL, Ashby J, Virtamo J, Albanes D. Serum 25-hydroxyvitamin D and risks of colon and rectal cancer in Finnish men. Am J Epidemiol. 2011;173(5):499-508. Exclusion code: 6. [pmid: 21248311].
Woolcott CG, Wilkens LR, Nomura AMY, et al. Plasma 25-hydroxyvitamin D levels and the risk of colorectal cancer: the multiethnic cohort study. Cancer Epidemiol Biomarkers Prev. 2010;19(1):130-134. Exclusion code: 3. [pmid: 20056631].
Wu K, Feskanich D, Fuchs CS, Willett WC, Hollis BW, Giovannucci EL. A nested case control study of plasma 25-hydroxyvitamin D concentrations and risk of colorectal cancer. J Natl Cancer Inst. 2007;99(14):1120-1129. Exclusion code: 3. [pmid: 17623801].
Zeleniuch-Jacquotte A, Gallicchio L, Hartmuller V, et al. Circulating 25-hydroxyvitamin D and risk of endometrial cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):36-46. Exclusion code: 6. [pmid: 20562189].
Zheng W, Danforth KN, Tworoger SS, et al. Circulating 25-hydroxyvitamin D and risk of epithelial ovarian cancer: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):70-80. Exclusion code: 6. [pmid: 20562186].

## Appendix B5 Quality Rating Criteria

### Randomized, Controlled Trials (RCTs) and Cohort Studies

Criteria
- Initial assembly of comparable groups:
  ○ for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs

Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below. Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some, but not all, important outcomes are considered; and, some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat is lacking.
Source: | USPSTF Procedure Manual149

## Appendix B6 List of Reviewers

### Expert Reviewers

- John F. Aloia, MD, Director, Winthrop Bone Mineral Research Center, Mineola, NY; Chief Academic Officer, Winthrop University Hospital, Mineola, NY; Associate Dean, Professor of Medicine, State University of New York at Stony Brook
- Michael F. Holick, MD, PhD, Professor of Medicine, Physiology, and Biophysics at Boston University School of Medicine
- Elina Hypponen, MPH, PhD, Reader in Epidemiology and Public Health, Department of Population Health Sciences, MRC Center of Epidemiology for Child Health
- JoAnn E. Manson, MD, MPH, DrPH, Professor, Department of Epidemiology, Brigham and Women's Hospital, Boston, MA; Professor of Medicine, Harvard Medical School, Boston, MA; Chief, Division of Preventive Medicine, Department of Medicine, Brigham and Women's Hospital
- Clifford Rosen, MD, Director of Clinical and Translational Research, Main Medical Center, Scarborough, ME; Senior Scientist, Maine Medical Center Research Institute, Scarborough, ME; Adjunct Staff Scientist, The Jackson Laboratory, Bar Harbor, ME; Professor of Medicine, Tufts University School of Medicine, Boston, MA; National Institute of Arthritis and Musculoskeletal and Skin Diseases Scientific Advisory Board; Food and Drug Administration Advisory Board on Endocrinologic and Metabolic Drugs
- Elizabeth Yetley, PhD, MS, Scientific Consultant, Office of Dietary Supplements at the National Institutes of Health

### Federal Reviewers

- Margaret Brewinski Issacs, MD, MPH, Medical Officer, National Institutes of Health, Office of Research on Women's Health
- Rosemarie Filart, MD, MPH, Medical Officer, Department of Health and Human Services, National Institutes of Health
- Linda S. Kisinger, MD, MPH, Chief Consultant for Preventive Medicine, National Center for Health Promotion and Disease Prevention, Office of Patient Care Services, Veterans Health Administration
- Amy C. Lossie, PhD, Health Scientist, National Institutes of Health
- Harold Seifried, PhD, DABT, Chief, Nutritional Science Group, Division of Cancer Prevention, National Cancer Institute
- Catherine Witkop, MD, MPH, Chief, Preventive Medicine, Air Force, Military Health Service