# Contextual Questions

## Appendix A1 Association Between 25(OH)D Levels and Health Outcomes

### Contextual Question 1 What Is the Association Between Serum 25(OH)D Levels and Health Outcomes?

The association between serum 25(OH)D levels and health outcomes has been evaluated in several studies (Table 1). For this contextual question, we included prospective cohort and nested case-control studies or systematic reviews that examined the association between predisease-state 25(OH)D levels and health outcomes, to avoid the problem of reverse causation or the health outcome influencing the 25(OH)D level (e.g., through changes in sun exposure or diet). We included studies that reported on the following health outcomes: mortality, cancer, fractures, falls, cardiovascular disease, diabetes, depression, cognitive function, and functional status.

#### Mortality

A 2009 AHRQ review (not for the USPSTF) included four cohort studies on the association between 25(OH)D levels and subsequent mortality. The highest quality study found a significant trend for lower odds of death with increasing 25(OH)D concentrations, although there was a suggestion of a U-shaped relationship; the three other cohort studies did not find any association between 25(OH)D level and mortality risk.

A 2012 meta-analysis of 11 prospective cohort studies concluded that as 25(OH)D levels increased, there was a nonlinear decline in mortality risk, with levels between 30 and 35 ng/mL being most clearly associated with a decreased mortality risk.1 Similarly, three studies published soon after the review concluded that both low and high 25(OH)D levels were associated with an increased risk for mortality,2-4 with optimal 25(OH)D level ranging from 20 to 40 ng/mL.2-5 However, two 2014 systematic reviews of 31 to 73 studies concluded that lower 25(OH)D levels were associated with a significantly increased risk for death but did not describe a U-shaped association.6,7 A 2014 umbrella review of 107 systematic reviews and 74 meta-analyses of observational studies stated that there was not enough evidence to make conclusions about the association between vitamin D levels and mortality.8

In two studies that had a large enough nonwhite population to examine the association by race, lower 25(OH)D levels were associated with increased mortality risk in blacks.5,9

#### Cancer

We examined the 2011 systematic review and meta-analysis conducted for the USPSTF that included studies through July 2011 on the association between 25(OH)D levels and colorectal, breast, and prostate cancer.10 We also reviewed other meta-analyses and research conducted since 2011.

##### Colorectal Cancer

The 2011 USPSTF review reported an association between higher 25(OH)D concentrations and decreased risk for colorectal cancer in a meta-analysis of eight fair-quality nested case-control studies.10 For each 4 ng/mL increase in blood 25(OH)D concentration, there was a 6 percent (95% CI, 3% to 9%) reduced risk for colorectal cancer. The direction of the association is consistent with other systematic evidence reviews, including two 2014 evidence reviews 6,8 and one conducted by the International Agency for Research on Cancer (IARC), although the magnitude of the effect was smaller; other meta-analyses have noted that an increase of 10 to 20 ng/mL in 25(OH)D levels decreased the risk for colorectal cancer by 15 to 50 percent, respectively.11,12 When evaluated by 25(OH)D level, meta-analyses have shown that individuals in the highest quartile or quintile of 25(OH)D have about one third to one half the risk of developing colorectal cancer as those in the lowest group.6,13-15 In its 2008 report on vitamin D and cancer, the IARC working group concluded that the dose–response was fairly linear up to a 25(OH)D level of 35 to 40 ng/mL. Some, but not all,8 studies suggest that the association might be stronger in rectal rather than colon cancer, but the numbers have been too small to draw any firm conclusions.15

##### Breast Cancer

Four meta-analyses, including the 2011 USPSTF review, have not found evidence of an association between 25(OH)D level and breast cancer risk in prospective studies.6,8,10,16,17 Similarly, a nested case-control study, not included in these meta-analyses, did not find an association between 25(OH)D level and breast cancer in predominantly premenopausal women.18

##### Prostate Cancer

No association was reported between 25(OH)D level and risk for prostate cancer in systematic reviews and meta-analyses of prospective studies, including the 2011 USPSTF review.6,8,10,11,16

##### Pancreatic Cancer

No association between 25(OH)D level and pancreatic cancer risk was noted in two meta-analyses of prospective studies.11,16 Both meta-analyses noted that several individual studies had observed a U-shaped association between 25(OH)D level and pancreatic cancer, with both low and high 25(OH)D levels increasing risk for pancreatic cancer. One 2014 evidence review concluded that higher 25(OH)D levels were associated with a 24-percent increased risk for pancreatic cancer,6 but a different systematic review concluded that data were inconsistent about whether high 25(OH)D levels were associated with an increased risk for pancreatic cancer.8

##### Other Cancers

Two 2014 systematic reviews did not conclude that 25(OH)D level was associated with risk for other cancers, including esophageal and gastric, ovarian, endometrial, bladder, and kidney cancer, or non-Hodgkin lymphoma.6,8

#### Fractures

A 2009 AHRQ review examined the association between 25(OH)D level and fracture risk.19 Citing a 2007 evidence review conducted by the Ottawa Evidence-based Practice Center (EPC), the 2009 review concluded that the evidence for an association between serum 25(OH)D concentrations and fracture risk was inconsistent.

While prospective studies published since the 2009 review have generally shown that lower 25(OH)D levels were associated with increased fracture risk, a recent 2014 umbrella study of systematic reviews and meta-analyses of observational studies concluded that the evidence was suggestive only for nonvertebral fractures and that no conclusions could be reached about other fractures.8 Prospective studies finding an association have generally reported that risk increases at 25(OH)D levels less than 20 ng/mL in persons of Caucasian or European descent. The largest and most recent study, a prospective case-cohort study of more than 21,774 persons from Norway (1,175 hip fractures), reported an inverse association between 25(OH)D level and hip fracture; those in the lowest quartile (<17 ng/mL) had a 38-percent increased risk for fracture compared with those with 25(OH)D levels greater than 27 ng/mL.20 Similarly, two smaller Scandinavian studies found increased risk for any fracture when 25(OH)D level was below 13 to 16 ng/mL.21,22

In the United States, studies that have found associations between 25(OH)D and fracture risk have been done in older white men and women. In these studies, an increased risk for hip fracture occurred when 25(OH)D levels dropped below 18 to 24 ng/mL.23-25 A 25(OH)D level of 30 ng/mL or greater was associated with a decreased risk for fracture in the WHI trial,26 but not in NHANES data.24 An association between 25(OH)D level and fracture may not exist in nonwhite races. In the WHI trial, black women actually had a higher fracture risk at 25(OH)D levels greater than 20 ng/mL and Asians had higher risk when levels exceeded 30 ng/mL. In Hispanic and Native American women, there was no association between 25(OH)D level and fracture risk.26 In the Health ABC study, in which more than 40 percent of participants were black, there was no clear association between 25(OH)D and fracture risk, although the number of fractures in the study was low.27

Based on these data as well as the optimal level of 25(OH)D necessary to maximally suppress parathyroid hormone28-32 and maximize calcium absorption,33,34 experts generally agree that levels lower than 20 ng/mL are suboptimal for skeletal health. However, there is not general consensus about whether goal 25(OH)D levels should be higher than 20 ng/mL to protect the skeleton. The IOM contends that 25(OH)D concentrations above 20 ng/mL are sufficient for optimal bone health.35 Other expert bodies such as the Endocrine Society, National Osteoporosis Foundation, and International Osteoporosis Foundation suggest that 25(OH)D levels should be higher, at least 30 ng/mL, particularly in older adults.36-40

#### Falls

A 2009 AHRQ review cited a 2007 Ottawa EPC review that found there was fair evidence of an association between lower serum 25(OH)D concentrations and an increased risk for falls in institutionalized elderly persons.19,41 One study suggested a serum 25(OH)D concentration below 16 ng/mL was associated with an increased risk for falls. We identified one additional study published on this association since 2007. In that study of community-dwelling persons, 25(OH)D levels less than 20 ng/mL were associated with increased falls in men, but not in women.42 Of note, the one study in the 2007 Ottawa EPC review that did not find an association between 25(OH)D level and fall risk was conducted among community-dwelling women.43 A recent 2014 umbrella analysis of systematic reviews and meta-analysis stated that the evidence was inconsistent and no conclusions could be reached about the association between lower 25(OH)D levels and fall risk; instead, the evidence was suggestive that high 25(OH)D levels are actually linked to an increased rate of falls.8

#### Cardiovascular Disease

A 2009 AHRQ review identified four prospective studies on the association between serum 25(OH)D concentrations and cardiovascular outcomes (cardiovascular events, nonfatal myocardial infarction or fatal coronary heart disease, cardiovascular death, myocardial infarction, and stroke). Results were mixed; two studies noted that levels less than 15 ng/mL were generally associated with increased cardiovascular risk, but the other two studies did not report an association.19

Since the 2009 AHRQ review, multiple studies on this association have been published. Recent evidence reviews and meta-analyses have concluded that among largely white or entirely white participants with 25(OH)D levels less than 24 ng/mL, lower levels may be associated with an increased risk for incident cardiovascular disease.6,8,44-46 The association between 25(OH)D levels greater than 24 ng/mL and cardiovascular disease is not clear. Meta-analyses of seven prospective studies found that lower levels (<12 ng/mL) of 25(OH)D were associated with an increased risk for developing stroke compared with higher levels (>19 ng/mL).6,8,47

These associations may differ by race/ethnicity; in a recent study, lower 25(OH)D levels were not associated with a greater risk for incident coronary heart disease among blacks, although it was associated with cardiovascular risk among white and Chinese participants.48 Similarly, a recent cohort study did not find that 25(OH)D levels were associated with stroke risk in blacks.49

#### Diabetes

A 2014 umbrella analysis of systematic reviews and meta-analyses concluded that the evidence was suggestive for an association between 25(OH)D level and diabetes risk.8 A 2013 meta-analysis concluded that each 4-ng/mL increment in 25(OH)D level was associated with a 4-percent decreased risk for diabetes.50 Individual studies generally found that risk for diabetes increased in the lowest (generally <10 to 20 ng/mL) versus highest quartile or quintile of 25(OH)D level. 51-58

#### Depression

Two 2014 systematic reviews concluded that the evidence was suggestive of a decreased risk for depression and mood disorders with high 25(OH)D concentrations.6,8 In two prospective studies, optimal 25(OH)D levels were between 21 and 34 ng/mL.59,60

#### Cognitive Functioning

Two large 2014 systematic evidence reviews concluded that the evidence was suggestive of an association between high 25(OH)D levels and a decreased risk for cognitive decline.6,8 A study conducted in Italian men and women found that levels less than 10 ng/mL were associated with an increased risk for cognitive decline on the Mini Mental State Examination (MMSE) versus those with a level greater than 30 ng/mL.61 The association may vary by sex. In older American women, 25(OH)D levels less than 20 ng/mL were associated with a higher risk for incident global cognitive decline as measured by the MMSE compared with women with levels greater than 30 ng/mL.62 However, the association was not seen in older American men.63

#### Functional Status

Results from prospective studies of community-dwelling older persons from a range of racial backgrounds (100% European to 50% black) are mixed.6 Baseline 25(OH)D levels less than 20 ng/mL were associated with greater decreases in physical functioning measures after 3 to 6 years in some,64-66 but not other, 67,68 studies. Vitamin D deficiency was not associated with a greater risk for developing activities of daily living disability over 3 years.65

### References

1 Zittermann A, Iodice S, Pilz S, et al. Vitamin D deficiency and mortality risk in the general population: a meta-analysis of prospective cohort studies. Am J Clin Nutr. 2012;95(1):91-100. [pmid: 22170374].
2 Dror Y, Giveon SM, Hoshen M, et al. Vitamin D levels for preventing acute coronary syndrome and mortality: evidence of a nonlinear association. J Clin Endocrinol Metab. 2013;98(5):2160-7. [pmid: 23533239].
3 Durup D, Jorgensen HL, Christensen J, et al. A reverse J-shaped association of all-cause mortality with serum 25-hydroxyvitamin D in general practice: the CopD study. J Clin Endocrinol Metab. 2012;97(8):2644-52. [pmid: 22573406].
4 Sempos CT, Durazo-Arvizu RA, Dawson-Hughes B, et al. Is there a reverse J-shaped association between 25-hydroxyvitamin D and all-cause mortality? Results from the U.S. nationally representative NHANES. J Clin Endocrinol Metab. 2013;98(7):3001-9. [pmid: 23666975].
5 Signorello LB, Han X, Cai Q, et al. A prospective study of serum 25-hydroxyvitamin d levels and mortality among African Americans and non-African Americans. Am J Epidemiol. 2013;177(2):171-9. [pmid: 23125439].
6 Autier P, Boniol M, Pizot C, et al. Vitamin D status and ill health: a systematic review. Lancet Diabetes Endocrinol. 2014;2(1):76-89. [pmid: 24622671].
7 Chowdhury R, Kunutsor S, Vitezova A, et al. Vitamin D and risk for cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014;348.
8 Theodoratou E, Tzoulaki I, Zgaga L, et al. Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014;348.
9 Kritchevsky SB, Tooze JA, Neiberg RH, et al. 25-Hydroxyvitamin D, parathyroid hormone, and mortality in black and white older adults: The health ABC study. J Clin Endocrinol Metab. 2012;97(11):4156-65. [pmid: 22942386].
10 Chung M, Lee J, Terasawa T, et al. Vitamin D with or without calcium supplementation for prevention of cancer and fractures: an updated meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;155(12):827-38. [pmid: 22184690].
11 Yin L, Raum E, Haug U, et al. Meta-analysis of longitudinal studies: Serum vitamin D and prostate cancer risk. Cancer Epidemiol. 2009;33(6):435-45. [pmid: 19939760].
12 Grant WB. Relation between prediagnostic serum 25-hydroxyvitamin D level and incidence of breast, colorectal, and other cancers. J Photochem Photobiol B. 2010;101(2):130-6. [pmid: 20570169].
13 Lee JE, Li H, Chan AT, et al. Circulating levels of vitamin D and colon and rectal cancer: the Physicians' Health Study and a meta-analysis of prospective studies. Cancer Prev Res. 2011;4(5):735-43.
14 Gorham ED, Garland CF, Garland FC, et al. Optimal vitamin D status for colorectal cancer prevention: a quantitative meta analysis. Am J Prev Med. 2007;32(3):210-6. [pmid: 17296473].
15 International Agency for Research on Cancer. Vitamin D and Cancer. Lyon. 25. Nov. 2008. Availible at:.
16 Gandini S, Boniol M, Haukka J, et al. Meta-analysis of observational studies of serum 25-hydroxyvitamin D levels and colorectal, breast and prostate cancer and colorectal adenoma. Int J Cancer. 2011;128(6):1414-24. [pmid: 20473927].
17 Yin L, Grandi N, Raum E, et al. Meta-analysis: serum vitamin D and breast cancer risk. Eur J Cancer. 2010;46(12):2196-205. [pmid: 20456946].
18 Eliassen AH, Spiegelman D, Hollis BW, et al. Plasma 25-hydroxyvitamin D and risk for breast cancer in the Nurses' Health Study II. Breast Cancer Res. 2011;13(3):R50. [pmid: 21569367].
19 Chung M, Balk EM, Brendel M, et al. Vitamin D and Calcium: A Systematic Review of Health Outcomes. AHRQ Publication No. 09-E015. Rockville, MD. Agency for healthcare Research and Quality. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/vitadcal/vitadcal.pdf. January 17, 2014.
20 Holvik K, Ahmed LA, Forsmo S, et al. Low serum levels of 25-hydroxyvitamin D predict hip fracture in the elderly: a NOREPOS study. J Clin Endocrinol Metab. 2013;98(8):3341-50. [pmid: 23678033].
21 Melhus H, Snellman G, Gedeborg R, et al. Plasma 25-hydroxyvitamin D levels and fracture risk in a community-based cohort of elderly men in Sweden. J Clin Endocrinol Metab. 2010;95(6):2637-45. [pmid: 20332246].
22 van Schoor NM, Visser M, Pluijm SM, et al. Vitamin D deficiency as a risk factor for osteoporotic fractures. Bone. 2008;42(2):260-6. [pmid: 18289505].
23 Cauley JA, Parimi N, Ensrud KE, et al. Serum 25-hydroxyvitamin D and the risk for hip and nonspine fractures in older men. J Bone Miner Res. 2010;25(3):545-53. [pmid: 19775201].
24 Looker AC, Mussolino ME. Serum 25-hydroxyvitamin D and hip fracture risk in older U.S. white adults. J Bone Miner Res. 2008;23(1):143-50. [pmid: 17907920].
25 Cauley JA, Lacroix AZ, Wu L, et al. Serum 25-hydroxyvitamin D concentrations and risk for hip fractures. Ann Intern Med. 2008;149(4):242-50. [pmid: 18711154].
26 Cauley JA, Danielson ME, Boudreau R, et al. Serum 25-hydroxyvitamin D and clinical fracture risk in a multiethnic cohort of women: the Women's Health Initiative (WHI). J Bone Miner Res. 2011;26(10):2378-88. [pmid: 21710614].
27 Barbour KE, Houston DK, Cummings SR, et al. Calciotropic hormones and the risk for hip and nonspine fractures in older adults: The health ABC study. J Bone Miner Res. 2012;27(5):1177-85. [pmid: 22228250].
28 Malabanan A, Veronikis I, Holick M. Redefining Vitamin D Insufficiency. Lancet. 1998;351(9105):805-6. [pmid: 9519960].
29 Institute of Medicine. 2011 Dietary reference intakes for calcium and vitamin D. Washington, DC. The national Academies Press. 2011. Availible at:.
30 Chapuy M, Schott A, Garnero P, et al. Healthy elderly French women living at home have secondary hyperparathyroidism and high bone turnover in winter: E PIDOS S tudy Group. Clin Endocrinol Metab. 1996;81:1129-33.
31 Holick M, Siris E, Binkley N, et al. Prevalence of vitamin D inadequacy among postmenopausal North A merican women receiving osteoporosis therapy. J Clin Epidemiol Metab. 2005;90:3215-24.
32 Thomas M, Lloyd-Jones D, Thadhani R, et al. Hypovitaminosis D in medical inpatients. N Engl J Med. 1998;338(12):777-83. [pmid: 9504937].
33 Heaney R, Dowell M, Hale C, et al. Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. Am Coll Nutr. 2003;22:142-6.
34 Hansen K, Jones A, Lindstrom M, et al. Vitamin D insufficiency: disease or no disease?. J Bone Miner Res. 2008;23:1052-60. [pmid: 18302509].
35 Ross AC, Manson JE, Abrams SA, et al. The 2011 report on dietary reference intakes for calcium and vitamin d from the Institute of Medicine: what clinicians need to know. J Clin Endocrinol Metab. 2011;96(1):53-8. [pmid: 21118827].
36 Holick MF, Binkley NC, Bischoff-Ferrari HA, et al. Evaluation, treatment, and prevention of vitamin D deficiency: an Endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2011;96(7):1911-30. [pmid: 21646368].
37 National Osteoporosis Foundation. Clinician Guideline. http://nof.org/files/nof/public/content/file/344/upload/159.pdf. February 12, 2014.
38 International Osteoporosis Foundation (IOF). IOF Statement of New IOM Dietary Reference Intakes for Calcium and Vitamin D. http://www.iofbonehealth.org/iof-statement-new-iom-dietary-reference-intakes-calcium-and-vitamin-d. January 18, 2013.
39 Dawson-Hughes B, Mithal A, Bonjour JP, et al. IOF Position Statement: Vitamin D Recommendations for Older Adults. Osteoporos Int. 2010;21(7):1151-4. [pmid: 20422154].
40 Vieth R. What is the optimal vitamin D status for health?. Prog Biophys Mol Biol. 2006;(92):26. [pmid: 16766239].
41 Cranney A, Horsley T, O'Donnell S, et al. Effectiveness and safety of vitamin D in relation to bone health. Evid rep/technol assess. 2007;(158):1-235.
42 Menant JC, Close JCT, Delbaere K, et al. Relationships between serum vitamin D levels, neuromuscular and neuropsychological function and falls in older men and women. Osteoporos Int. 2012;23(3):981-9. [pmid: 21523392].
43 Faulkner KA, Cauley JA, Zmuda JM, et al. Higher 1,25-dihydroxyvitamin D3 concentrations associated with lower fall rates in older community-dwelling women. Osteoporos Int. 2006;17(9):1318-28. [pmid: 16788853].
44 Pittas AG, Chung M, Trikalinos T, et al. Systematic review: Vitamin D and cardiometabolic outcomes. Ann Intern Med. 2010;152(5):307-14. [pmid: 20194237].
45 Wang L, Song Y, Manson JE, et al. Circulating 25-hydroxy-vitamin D and risk for cardiovascular disease: a meta-analysis of prospective studies. Circ Cardiovasc Qual Outcomes. 2012;5(6):819-29. [pmid: 23149428].
46 Brondum-Jacobsen P, Benn M, Jensen GB, et al. 25-hydroxyvitamin d levels and risk for ischemic heart disease, myocardial infarction, and early death: population-based study and meta-analyses of 18 and 17 studies. Arterioscler Thromb Vasc Biol. 2012;32(11):2794-802. [pmid: 22936341].
47 Sun Q, Pan A, Hu FB, et al. 25-Hydroxyvitamin D levels and the risk for stroke: a prospective study and meta-analysis. Stroke. 2012;43(6):1470-7. [pmid: 22442173].
48 Robinson-Cohen C, Hoofnagle AN, Ix JH, et al. Racial differences in the association of serum 25-hydroxyvitamin d concentration with coronary heart disease eventsrace and chd events associated with vitamin drace and chd events associated with vitamin d. JAMA. 2013;310(2):179-88. [pmid: 23839752].
49 Michos ED, Reis JP, Post WS, et al. 25-Hydroxyvitamin D deficiency is associated with fatal stroke among whites but not blacks: The NHANES-III linked mortality files. Nutrition. 2012;28(4):367-71. [pmid: 22261577].
50 Song Y, Wang L, Pittas AG, et al. Blood 25-hydroxy vitamin D levels and incident type 2 diabetes: A meta-analysis of prospective studies. Diabetes Care. 2013;36(5):1422-8. [pmid: 23613602].
51 Mattila C, Knekt P, Mannisto S, et al. Serum 25-hydroxyvitamin D concentration and subsequent risk for type 2 diabetes. Diabetes Care. 2007;30(10):2569-70. [pmid: 17626891].
52 Knekt P, Laaksonen M, Mattila C, et al. Serum vitamin D and subsequent occurrence of type 2 diabetes. Epidemiology. 2008;19(5):666-71. [pmid: 18496468].
53 Gonzalez-Molero I, Rojo-Martinez G, Morcillo S, et al. Vitamin D and incidence of diabetes: a prospective cohort study. Clin Nutr. 2012;31(4):571-3. [pmid: 22204964].
54 Pittas AG, Sun Q, Manson JE, et al. Plasma 25-hydroxyvitamin D concentration and risk for incident type 2 diabetes in women. Diabetes Care. 2010;33(9):2021-3. [pmid: 20805275].
55 Tsur A, Feldman BS, Feldhammer I, et al. Decreased serum concentrations of 25-hydroxycholecalciferol are associated with increased risk for progression to impaired fasting glucose and diabetes. Diabetes Care. 2013;36(5):1361-7. [pmid: 23393216].
56 Schottker B, Herder C, Rothenbacher D, et al. Serum 25-hydroxyvitamin D levels and incident diabetes mellitus type 2: a competing risk analysis in a large population-based cohort of older adults. Eur J Epidemiol. 2013;28(3):267-75. [pmid: 23354985].
57 Husemoen LLN, Skaaby T, Thuesen BH, et al. Serum 25(OH)D and incident type 2 diabetes: a cohort study. Eur J Clin Nutr. 2012;66(12):1309-14. [pmid: 23031851].
58 Forouhi NG, Ye Z, Rickard AP, et al. Circulating 25-hydroxyvitamin D concentration and the risk for type 2 diabetes: Results from the European Prospective Investigation into Cancer (EPIC)-Norfolk cohort and updated meta-analysis of Prospective studies. Diabetologia. 2012;55(8):2173-82. [pmid: 22526608].
59 Milaneschi Y, Shardell M, Corsi AM, et al. Serum 25-hydroxyvitamin D and depressive symptoms in older women and men. J Clin Endocrinol Metab. 2010;95(7):3225-33. [pmid: 20444911].
60 Maddock J, Berry DJ, Geoffroy MC, et al. Vitamin D and common mental disorders in mid-life: Cross-sectional and prospective findings. Clin Nutr. 2013;32(5):758-64. [pmid: 23395104].
61 Llewellyn DJ, Lang IA, Langa KM, et al. Vitamin D and risk for cognitive decline in elderly persons. Arch Intern Med. 2010;170(13):1135-41. [pmid: 20625021].
62 Slinin Y, Paudel M, Taylor BC, et al. Association between serum 25(OH) vitamin D and the risk for cognitive decline in older women. J Gerontol A Biol Sci Med Sci. 2012;67(10):1092-8. [pmid: 22454371].
63 Slinin Y, Paudel ML, Taylor BC, et al. 25-Hydroxyvitamin D levels and cognitive performance and decline in elderly men. Neurology. 2010;74(1):33-41. [pmid: 19940271].
64 Sohl E, van Schoor NM, de Jongh RT, et al. Vitamin D Status Is Associated With Functional Limitations and Functional Decline in Older Individuals. J Clin Endocrinol Metab. 2013;98(9):E1483-E90. [pmid: 23864700].
65 Houston DK, Tooze JA, Davis CC, et al. Serum 25-hydroxyvitamin D and physical function in older adults: the Cardiovascular Health Study All Stars. J Am Geriatr Soc. 2011;59(10):1793-801. [pmid: 22091492].
66 Houston DK, Neiberg RH, Tooze JA, et al. Low 25-hydroxyvitamin D predicts the onset of mobility limitation and disability in community-dwelling older adults: the Health ABC Study. J Gerontol A Biol Sci Med Sci. 2013;68(2):181-7. [pmid: 22573914].
67 Houston DK, Tooze JA, Neiberg RH, et al. 25-hydroxyvitamin D status and change in physical performance and strength in older adults. Am J Epidemiol. 2012;176(11):1025-34. [pmid: 23118104].
68 Sohl E, de Jongh RT, Heijboer AC, et al. Vitamin D status is associated with physical performance: the results of three independent cohorts. Osteoporos Int. 2013;24(1):187-96. [pmid: 22961566].

## Appendix A2 Risk Factors Associated With Vitamin D Deficiency

### Contextual Question 2 What Are the Risk Factors Associated With Vitamin D Deficiency?

In the United States, the main dietary sources of vitamin D are fortified foods such as milk, milk products, and cereals, as well as supplements; naturally occurring foods that contain vitamin D include fatty fish, egg yolk, and mushrooms. In large (>750 persons) population-based cross-sectional studies in predominantly American populations,1-4 low dietary vitamin D intake and/or lack of vitamin D supplements are associated with a two- to five-fold increased risk for vitamin D deficiency (defined as a 25(OH)D level <20 ng/mL).1-3

Vitamin D is also obtained through synthesis in the skin in response to UVB radiation. Large population-based studies confirm that low UVB exposure is associated with an increased risk for vitamin D deficiency.2,4-6 Persons who have blood drawn for a 25(OH)D level in winter have a 2 to 3 times greater risk for being vitamin D deficient than those whose level is evaluated in the fall or summer.1,2 Avoiding sunlight by staying in the shade/indoors or wearing long sleeves is associated with increased risk for vitamin D deficiency.5 Higher latitude of residence has been modestly associated with vitamin D deficiency.2,4,5 Although sunscreen reduces the skin's ability to produce vitamin D in response to UVB in controlled research settings,7 it is not associated with vitamin D deficiency in population-based studies.6,8 This discrepancy is likely due to incomplete application of sunscreen9 and/or subjects who use sunscreen being in the sun for extended periods.10

Increased skin pigmentation reduces the skin's ability to produce vitamin D in response to UVB.10 When total 25(OH)D levels are used to define deficiency, blacks have a two- to nine-fold greater risk and Hispanics a two- to three-fold greater risk for vitamin D deficiency compared with whites.1-3 However, a recent study found that compared with white Americans, black Americans had not only lower total 25(OH)D levels but lower vitamin D–binding protein,11 resulting in similar concentrations of estimated bioavailable 25(OH)D. This recent study has called into question previous reports of higher rates of vitamin D deficiency in blacks.

Aging also reduces the skin's ability to synthesize vitamin D, and older adults may also have poor dairy and vitamin D intake and decreased sun exposure. However, studies are inconsistent about whether older age is associated with increased risk for vitamin D deficiency. In a cohort of older men (>65 years), the oldest participants (>85 years) had a two-fold increased risk for vitamin D deficiency compared with younger men.2 In cohorts with a smaller percentage of participants older than age 70 years, the results are mixed, with some showing significant associations between risk for vitamin D deficiency and older age,4,5 and others not.1,3

Since vitamin D is stored in adipose tissue, it has been hypothesized that higher adiposity leads to greater sequestration of vitamin D. Also, obese and overweight persons may have lower physical activity levels and lower dietary vitamin D intake.12 Obesity does appear to confer an almost two-fold increased risk for vitamin D deficiency.1-3,13 In addition, since women have a higher percentage of body fat compared with men, they may be at greater risk than men. In two large cohort studies, women were at increased risk for vitamin D deficiency than men.1,5 However, in the most recent NHANES analysis, sex did not influence risk for deficiency.3

Other factors have been modestly associated with vitamin D deficiency in some studies, but diet, supplement use, and UV exposure may be mediating factors. For example, low levels of physical activity was modestly associated with vitamin D deficiency in three studies.1,2,4 In NHANES, lower education level was associated with an increased risk for deficiency, but this was not true in a cohort of older men who had an overall high educational background (75% had college and/or graduate education).2 Lower health status has also been associated with an increased risk for deficiency in NHANES.3,6

However, these risk factors appear to account for a small percentage of the variation in 25(OH)D levels. In the WHI trial, a predictive model consisting of latitude of residence, total vitamin D intake from foods and supplements, waist circumference, recreational physical activity, and race/ethnicity could only explain 21 percent of the variation in 25(OH)D level.4 Similarly, in a cohort study of male health professionals, geographic region of residence, skin pigmentation, dietary and supplement intake, BMI, and physical activity accounted for only 28 percent of the variation in 25(OH)D level.14

### References

1 McCullough ML, Weinstein SJ, Freedman DM, et al. Correlates of circulating 25-hydroxyvitamin D: Cohort Consortium Vitamin D Pooling Project of Rarer Cancers. Am J Epidemiol. 2010;172(1):21-35. [pmid: 20562191].
2 Orwoll E, Nielson CM, Marshall LM, et al. Vitamin D deficiency in older men. J Clin Endocrinol Metab. 2009;94(4):1214-22. [pmid: 19174492].
3 Forrest KY, Stuhldreher WL. Prevalence and correlates of vitamin D deficiency in US adults. Nutr Res. 2011;31(1):48-54. [pmid: 21310306].
4 Millen AE, Wactawski-Wende J, Pettinger M, et al. Predictors of serum 25-hydroxyvitamin D concentrations among postmenopausal women: the Women's Health Initiative Calcium plus Vitamin D clinical trial. Am J Clin Nutr. 2010;91(5):1324-35. [pmid: 20219959].
5 Jacques PF, Felson DT, Tucker KL, et al. Plasma 25-hydroxyvitamin D and its determinants in an elderly population sample. Am J Clin Nutr. 1997;66(4):929-36. [pmid: 9322570].
6 Linos E, Keiser E, Kanzler M, et al. Sun protective behaviors and vitamin D levels in the US population: NHANES 2003-2006. Cancer Causes Control. 2012;23(1):133-40. [pmid: 22045154].
7 Matsuoka LY, Ide L, Wortsman J, et al. Sunscreens suppress cutaneous vitamin D3 synthesis. J Clin Endocrinol Metab. 1987;64(6):1165-8. [pmid: 3033008].
8 Norval M, Wulf HC. Does chronic sunscreen use reduce vitamin D production to insufficient levels?. Br J Dermatol. 2009;161(4):732-6. [pmid: 19663879].
9 Faurschou A, Beyer DM, Schmedes A, et al. The relation between sunscreen layer thickness and vitamin D production after ultraviolet B exposure: a randomized clinical trial. Br J Dermatol. 2012;167(2):391-5. [pmid: 22512875].
10 International Agency for Research on Cancer. Vitamin D and Cancer. Lyon. 25. Nov. 2008. Availible at:.
11 Powe CE, Evans MK, Wenger J, et al. Vitamin D-binding protein and vitamin D status of black Americans and white Americans. N Engl J Med. 2013;369(21):1991-2000. [pmid: 24256378].
12 Ross AC, Manson JE, Abrams SA, et al. The 2011 report on dietary reference intakes for calcium and vitamin d from the Institute of Medicine: what clinicians need to know. J Clin Endocrinol Metab. 2011;96(1):53-8. [pmid: 21118827].
13 Samuel L, Borrell LN. The effect of body mass index on optimal vitamin D status in U.S. adults: the National Health and Nutrition Examination Survey 2001-2006. Annals of Epidemiology. 2013;23(7):409-14. [pmid: 23790345].
14 Giovannucci E, Liu Y, Rimm EB, et al. Prospective study of predictors of vitamin D status and cancer incidence and mortality in men. J Natl Cancer Inst. 2006;98(7):451-9. [pmid: 16595781].

## Appendix A3 Effects of Vitamin D Treatment on Intermediate Outcomes

### Contextual Question 3 What Is the Effect of Vitamin D (With or Without Calcium) on Intermediate Outcomes?

We examined RCTs of vitamin D (with or without calcium) versus placebo on the intermediate outcomes of lipids, glucose, blood pressure, bone mineral density, and physical functioning or balance in persons with vitamin D deficiency (at least 90% <30 ng/mL).

#### Lipids

Four studies examining the effects of 400 to 5,700 IU per day of vitamin D treatment on lipid levels in persons with vitamin D insufficiency (most <23 ng/mL) found that vitamin D had no effect on lipid levels compared with placebo.1-4

#### Glucose

Three studies that examined the effects of 400 to 7,143 IU per day of vitamin D treatment found that vitamin D had no effect on glucose levels, insulin levels, insulin sensitivity, or insulin resistance in persons without diabetes.1,4,5

#### Blood Pressure

We reviewed three studies examining the effect of vitamin D treatment on blood pressure in patients with vitamin D deficiency.3,6,7 Two studies, one of elderly (age ≥70 years) women and the other of blacks ages 30 to 80 years, found that 800 to 4,000 IU per day of vitamin D resulted in decreases in systolic but not diastolic blood pressure compared with placebo.3,7 However, in the WHI trial, women with vitamin D deficiency who were randomized to 1,000 mg per day of calcium and 400 IU per day of vitamin D did not have a decreased risk for incident hypertension.7

#### Bone Mineral Density

We identified seven studies that examined the effect of vitamin D treatment on bone mineral density in persons with vitamin D deficiency.1,2,8-13 In three European studies of older women with severe deficiency (<12 ng/mL), 400 to 800 IU per day of vitamin D (with and without calcium) had mixed results on hip bone mineral density;8-10 two9,10 of three studies found less decline at the femoral neck and one9 of two9,10 found less decline at the trochanter while the other did not.8 No study found that vitamin D treatment led to less decline at the distal radius compared with placebo.8,10 Postmenopausal black women randomized to 1,000 IU per day of vitamin D for 2 years did not have improved bone mineral density compared with those given placebo.13 In elderly men, 1,000 IU per day of vitamin D_3_ and 1,000 mg per day of calcium did not result in less loss of bone mineral content at the radius or vertebra over 3 years.11 Results in younger, mixed-sex populations given 400 to 7,000 IU per day of vitamin D for 26 to 52 weeks did not find significant effects of vitamin D on spine or hip bone mineral density.1,12 In a recent 2014 meta-analysis of eight studies with populations whose mean 25(OH)D level was less than 20 ng/mL, there was little evidence of an overall benefit of vitamin D supplementation on bone density.14

#### Physical Functioning/Balance

We reviewed four studies that evaluated the effect of vitamin D treatment on strength15-18 and one study that examined balance.19 Among elderly women, 400 to 1,800 IU per day of vitamin D did not improve hand strength,15,17 leg strength,15 or balance19 compared with placebo. In two studies of younger (mean age, 18 to 33 years) deficient (<30 ng/mL) persons, large (25,000 to >60,000 IU per week) doses of vitamin D improved several strength measures more in the vitamin D versus the placebo group.16,18 However, in a Norwegian trial using smaller dosages of vitamin D (400 to 1,000 IU per day) in deficient immigrants with mean ages of 35 to 40 years, strength measures were not improved in the intervention versus control group after 16 weeks.20

### References

1 Wamberg L, Kampmann U, Stodkilde-Jorgensen H, et al. Effects of vitamin D supplementation on body fat accumulation, inflammation, and metabolic risk factors in obese adults with low vitamin D levels - Results from a randomized trial. Eur J Intern Med. 2013.
2 Andersen R, Brot C, Mejborn H, et al. Vitamin D supplementation does not affect serum lipids and lipoproteins in Pakistani immigrants. Eur J Clin Nutr. 2009;63(9):1150-3. [pmid: 19352377].
3 Pfeifer M, Begerow B, Minne HW, et al. Effects of a short-term vitamin D(3) and calcium supplementation on blood pressure and parathyroid hormone levels in elderly women. J Clin Endocrinol Metab. 2001;86(4):1633-7. [pmid: 11297596].
4 Wood AD, Secombes KR, Thies F, et al. Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab. 2012;97(10):3557-68. [pmid: 22865902].
5 Simha V, Mahmood M, Ansari M, et al. Effect of vitamin D replacement on insulin sensitivity in subjects with vitamin D deficiency. J Investig Med. 2012;60(8):1214-8.
6 Forman JP, Scott JB, Ng K, et al. Effect of vitamin d supplementation on blood pressure in blacks. Hypertension. 2013;61(4):779-85. [pmid: 23487599].
7 Margolis KL, Ray RM, Van Horn L, et al. Effect of calcium and vitamin D supplementation on blood pressure: the Women's Health Initiative Randomized Trial. Hypertension. 2008;52(5):847-55. [pmid: 18824662].
8 Chapuy MC, Pamphile R, Paris E, et al. Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. 2002;13(3):257-64. [pmid: 11991447].
9 Grados F, Brazier M, Kamel S, et al. Prediction of bone mass density variation by bone remodeling markers in postmenopausal women with vitamin D insufficiency treated with calcium and vitamin D supplementation. J Clin Endocrinol Metab. 2003;88(11):5175-9. [pmid: 14602746].
10 Ooms ME, Roos JC, Bezemer PD, et al. Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. 1995;80(4):1052-8. [pmid: 7714065].
11 Orwoll ES, Oviatt SK, McClung MR, et al. The rate of bone mineral loss in normal men and the effects of calcium and cholecalciferol supplementation. Ann Intern Med. 1990;112(1):29-34. [pmid: 2152844].
12 Wamberg L, Pedersen SB, Richelsen B, et al. The Effect of High-Dose Vitamin D Supplementation on Calciotropic Hormones and Bone Mineral Density in Obese Subjects with Low Levels of Circulating 25-Hydroxyvitamin D: Results from a Randomized Controlled Study. Calcif Tissue Int. 2013.
13 Nieves JW, Cosman F, Grubert E, et al. Skeletal effects of vitamin D supplementation in postmenopausal black women. Calcif Tissue Int. 2012;91(5):316-24. [pmid: 22923289].
14 Reid IR, Bolland MJ, Grey A. Effects of vitamin D supplements on bone mineral density: a systematic review and meta-analysis. Lancet. 2014;383(9912):146-55. [pmid: 24119980].
15 Janssen HCJP, Samson MM, Verhaar HJJ. Muscle strength and mobility in vitamin D-insufficient female geriatric patients: a randomized controlled trial on vitamin D and calcium supplementation. Aging Clin. 2010;22(1):78-84.
16 Gupta R, Sharma U, Gupta N, et al. Effect of cholecalciferol and calcium supplementation on muscle strength and energy metabolism in vitamin D-deficient Asian Indians: a randomized, controlled trial. Clin Endocrinol. 2010;73(4):445-51.
17 Honkanen R, Alhava E, Parviainen M, et al. The necessity and safety of calcium and vitamin D in the elderly. J Am Geriatr Soc. 1990;38(8):862-6. [pmid: 2387950].
18 Close GL, Russell J, Cobley JN, et al. Assessment of vitamin D concentration in non-supplemented professional athletes and healthy adults during the winter months in the UK: implications for skeletal muscle function. J Sports Sci. 2013;31(4):344-53. [pmid: 23083379].
19 Bischoff-Ferrari HA, Conzelmann M, Stahelin HB, et al. Is fall prevention by vitamin D mediated by a change in postural or dynamic balance?. Osteoporos Int. 2006;17(5):656-63. [pmid: 16508700].
20 Knutsen KV, Madar AA, Lagerlov P, et al. Does vitamin D improve muscle strength in adults? A randomized, double-blind, placebo-controlled trial among ethnic minorities in Norway. J Clin Endocrinol Metab. 2014;99(1):194-202. [pmid: 24248184].