# Discussion

## Summary of Review Findings

The findings of this review are summarized in Table 8.

Table 8 Summary of Evidence

Prior Report Findings | Studies Identified in Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality
KQ 1. Does screening for thyroid dysfunction reduce morbidity or mortality?
No studies | No studies | - | - | - | - | -
KQ 2. What are the harms of screening for thyroid dysfunction?
No studies | No studies | - | - | - | - | -
KQ 3a. Does treatment of screen-detected overt or subclinical thyroid dysfunction improve morbidity or mortality?
Subclinical hypothyroidism
Cardiovascular events, coronary artery disease, and heart failure
No studies | 1 retrospective cohort study | Did not adjust for use of aspirin, lipid-lowering therapy, or cardiovascular medications | NA | Study population in United Kingdom | 1 fair-quality retrospective cohort study found that treatment of subclinical hypothyroidism was associated with decreased risk for cardiac events, cancer, and all-cause mortality in adults ages 40–70 years, but not in those age >70 years. However, this study had methodological limitations, including failure to adjust for some important confounders. The findings could represent a true effect or a spurious association as a result of residual confounding | Poor
Overall quality of life
Only 1 of 5 trials found improvement in quality of life; most studies evaluated patients previously treated for Graves' disease | 5 RCTs | Trials were small and of short duration | Consistent | Study populations in Norway and United Kingdom | Thyroxine was associated with no effect on quality of life using various measures | Fair
Changes in cognition
1 of 2 trials found a statistically significant improvement in memory in patients older than age 55 years that the authors described as “small and of questionable clinical importance” | 2 RCTs | Trials were small and of short duration | Consistent | Study populations in Norway and United Kingdom | Thyroxine was associated with no effect on cognitive function using various measures | Poor
Subclinical hyperthyroidism
No studies | No studies | - | - | - | - | -
Overt thyroid disease^a^
Not assessed | No studies | - | - | - | - | -
KQ 3b. Does treatment of screen-detected overt or subclinical thyroid dysfunction improve intermediate outcomes?
Subclinical hypothyroidism
Changes in blood pressure
No studies | 3 RCTs | Studies were small, of limited duration, used different cutoffs for TSH, and used different dosing protocols | Consistent | Study populations in Italy, Japan, and United Kingdom | Thyroxine was associated with no effect on systolic blood pressure (difference ranged from −3 to −2 mm Hg) or diastolic blood pressure (difference ranged from −3 to 0 mm Hg) | Poor
Changes in lipid levels
1 of 7 studies found a slight improvement in LDL cholesterol with treatment of 50 μg/d of levothyroxine vs. 25 μg/d | 9 RCTs | See above | Inconsistent | Study populations in United Kingdom, Brazil, Italy, Turkey, Norway, Kuwait, and Japan | 3 of 8 good- and fair-quality trials found that treatment was associated with lower total and LDL cholesterol, and other trials also reported a slight trend toward beneficial effects for total cholesterol, although nonsignificant. However, differences were small (−28 to 0 mg/dL for total cholesterol and −22 to 2 mg/dL for LDL). Treatment of subclinical hypothyroidism was not associated with beneficial effects on HDL (−4 to 4 mg/dL) or triglyceride (−32 to 11 mg/dL) levels | Fair
Changes in BMI or weight
No studies | 6 RCTs | See above | Consistent | | Thyroxine was associated with no effect on BMI (difference ranged from −1 to 1 kg/m^2^) or weight (difference of −1 kg in one study) | Fair
Subclinical hyperthyroidism
Changes in blood pressure
No studies | 2 RCTs | Studies were very small, of limited duration, and used different treatment protocols | Consistent | Study populations in Italy and Turkey | Thyroxine was associated with no effect on systolic blood pressure (difference ranged from −2 to 10 mm Hg) or diastolic blood pressure (difference ranged from −3 to 0 mm Hg) | Poor
Changes in bone density
No studies | 1 RCT | See above | NA | Study populations in Turkey | Thyroxine was associated with no effect on femur neck (difference was −0.042 g/cm^2^) or lumbar vertebra BMD (difference was 0.03 g/cm^2^) | Poor
Changes in lipid levels
No studies | 1 RCT | See above | NA | Study populations in Turkey | Thyroxine was associated with no effect on total (difference was 26 mg/dL), LDL (difference was 15 mg/dL), or HDL cholesterol (difference was 0 mg/dL), or triglycerides (difference was −36 mg/dL) | Poor
Changes in BMI
No studies | 1 RCT | See above | NA | Study population in Italy | Thyroxine was associated with no effect on BMI (difference was 0 kg/m^2^) | Poor
Overt thyroid disease^a^
Not assessed | No studies | - | - | - | - | -
KQ 4. What are the harms of treatment of screen-detected thyroid dysfunction?
Incidental findings included low percentage of nervousness, anxiety, palpitations, and withdrawals due to complications | 5 RCTs for subclinical hypothyroidism; 1 RCT for subclinical hyperthyroidism | Only 1 trial directly compared harms between treated and not treated adults; all other reported ad hoc adverse effects | Not able to assess | Study populations in United Kingdom, Japan, Brazil, and Italy | Only 1 trial in patients with subclinical hypothyroidism directly compared harms between treated and not treated adults and found no difference in withdrawals due to side effects; all other trials reported ad hoc adverse effects | Poor

a Asymptomatic or mildly symptomatic patients with biochemically overt thyroid disease.

Abbreviations: BMD=bone mineral density; BMI=body mass index; HDL=high-density lipoprotein; KQ=key question; LDL=low-density lipoprotein; NA=not applicable; TSH=thyroid- stimulating hormone; RCT=randomized, controlled trial.

As in the 2004 USPSTF report, we found no direct evidence on effects of thyroid screening compared with no screening on clinical outcomes. The scope of this update was expanded to include detection and treatment of screen-detected, undiagnosed overt thyroid disease, but we found no studies of treatment versus no treatment.

Evidence on benefits and harms of treatment was largely restricted to patients with subclinical hypothyroidism. Despite the potential association between subclinical hypothyroidism and cardiovascular disease and congestive heart failure4-6 there is no clear evidence that treatment improves clinical outcomes. Although one fair-quality retrospective cohort study found that treatment of subclinical hypothyroidism associated with decreased risk for cardiac events, cancer, and all-cause mortality in adults ages 40 to 70 years,49 it was an observational study with potential methodological limitations, including failure to adjust for some important confounders

As in the 2004 USPSTF review, evidence from newer trials found no clear improvement in quality of life or measures of cognitive function, but they were few in number, enrolled small samples, and may have been underpowered.37,41,42,47,48

Findings regarding intermediate outcomes were also consistent with the 2004 USPSTF review. Trials found no clear benefits of treatment of subclinical hypothyroidism on blood pressure, bone mineral density, or body mass index. Although treatment of subclinical hypothyroidism might have some beneficial effects on total and LDL cholesterol levels, differences were small and of uncertain clinical significance (range, -28 to 0 mg/dL for total cholesterol and -22 to 2 mg/dL for LDL cholesterol) and were not statistically significant in most studies.38-40,42-46,48,50,51 No studies evaluated treatment of subclinical hypothyroidism with higher TSH levels, which may be associated with increased risk for adverse clinical outcomes.

Only two poor-quality studies evaluated treatment of subclinical hyperthyroidism, precluding reliable conclusions.52,53 While a recent systematic review of observational studies found that subclinical hyperthyroidism might be associated with an increased risk for fractures, it only found trends, not statistically significant effects.9

The harms of screening remain poorly studied and sparsely reported. Potential harms of screening for subclinical hypothyroidism include false-positive test results, anxiety related to test results, and harms of treatment (including overreplacement or overtreatment), but evidence is too limited to estimate effects on any of these outcomes. Two prospective cohort studies suggest that approximately 40 percent of persons with subclinical hypothyroidism were biochemically euthyroid after 3 years of watchful waiting, and subsequent overtreatment could be a potential issue.11,13

## Limitations

Our review has several limitations. We did not include non-English–language articles. However, some studies have found that excluding non-English–language articles does not lead to biased estimates for noncomplementary interventions,64 and a number of the studies included in our review were published in non-English–speaking countries. We were also unable to assess for publication bias using graphical or statistical methods because of the small numbers of studies for different outcomes.65 We included poor-quality studies, but focused on results from higher-quality studies and performed sensitivity analyses in which poor-quality studies were excluded. Inclusion of poor-quality studies did not change any conclusions.

The evidence on thyroid screening was also limited. Direct evidence on benefits and harms of screening remains unavailable. In addition, the applicability of the evidence on benefits and harms of treatment of subclinical thyroid dysfunction to screening is uncertain. Few trials evaluated screen-detected populations.37,40,41,47 Other trials did not clearly describe methods for identifying patients, except to report that they were recruited from outpatient clinics. In addition, no treatment study was conducted in the U.S., most trials were small (n<120), criteria for abnormal TSH and free T4 varied, treatment regimens varied, and followup in most studies was relatively brief (4 to 12 months).

We identified no trials of treatment versus no treatment of biochemically overt thyroid disease. This may be because treatment is recommended in clinical practice guidelines10,30,31 and considered the standard of care. Although some trials have evaluated treatment of clinically overt thyroid disease (e.g., Graves' disease), such studies are not directly relevant for screening and were outside the scope of this report.

## Emerging Issues and Future Research

Trials of thyroid screening versus no screening would provide the most direct evidence on benefits and harms of screening. Prior to conducting trials of screening, however, it may be prudent to conduct well-designed trials of treatment versus placebo or no treatment, as effective treatments are a necessary prerequisite for effective screening interventions. For treatment trials to be most informative, they should enroll clearly defined samples of patients, clearly describe treatment protocols (e.g., doses and target TSH levels), and be designed to evaluate important clinical outcomes, including both benefits and harms and short- and long-term outcomes. Trials that enroll screen-detected asymptomatic patients would be the most directly applicable for informing screening decisions.

Research is also needed on the prevalence of unrecognized overt thyroid disease and on the effects of treatment in such patients in order to better understand the potential impact of screening. Observational studies could help provide important information on effects of screening and treatment, but should be conducted in well-defined populations and account for important confounders (e.g., patient demographics, medical and psychiatric comorbidities, risk factors for cardiovascular disease, and concomitant medication use) in their design and analysis. More research is needed to understand potential effects of treatment of subclinical hypothyroidism on cancer risk.49

Another emerging area with implications for screening is research suggesting that subclinical hypothyroidism might be protective in older persons13,20,21 and that the reference ranges for TSH should be adjusted upward in older adults.22,66 Additional research to clarify criteria for abnormal thyroid function would obviously have implications for defining the target populations and impact of screening.

## Conclusion

Although screening can identify patients with subclinical hypothyroidism, subclinical hyperthyroidism, or unrecognized or undiagnosed overt thyroid disease, direct evidence on benefits and harms of screening versus no screening remains unavailable. Trials of treatment of subclinical hypothyroidism suggest a possible beneficial effect on total and LDL cholesterol levels, but the magnitude of effect appears small and of uncertain clinical significance. The only study showing a beneficial effect of treatment on cardiovascular events was observational and susceptible to residual confounding. Trials on the effects of treatment of subclinical hypothyroidism on other clinical and intermediate outcomes showed no clear beneficial effects, and data on harms were poor. More research is needed to understand effects of treatment of subclinical thyroid dysfunction and screen-detected, undiagnosed overt thyroid disease.