# Results

Fourteen studies (13 randomized, controlled trials and one cohort study) published since the prior USPSTF review1,15 met inclusion criteria for this update. Twelve studies (in 15 publications) addressed treatment of subclinical hypothyroidism37-51 and two studies addressed treatment of subclinical hyperthyroidism52,53 (Tables 3-7; Appendix B1). No studies examined benefits or harms of screening and no studies addressed treatment versus no treatment of screen-detected, undiagnosed overt thyroid disease.

Table 3 Subclinical Hypothyroidism Cardiovascular Events and Mortality

Study, Year Study Design Study Duration | Country Age TSH Level | Intervention, n | Outcome | Treated vs. Nontreated | | | | | | Quality
Study, Year Study Design Study Duration | Country Age TSH Level | Intervention, n | Outcome | Ages 40–70 Years | | | Age >70 Years | | | Quality
Study, Year Study Design Study Duration | Country Age TSH Level | Intervention, n | Outcome | Events in Treated vs. Nontreated Groups (%) | HR (95% CI)^a^ | Age- and Sex- Adjusted HR (95% CI) | Events in Treated vs. Nontreated Groups (%) | HR (95% CI)^a^ | Age- and Sex- Adjusted HR (95% CI) | Quality
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | Fatal and nonfatal ischemic heart disease events | 4.2% vs. 6.6% | 0.61 (0.39–0.95) | 0.64 (0.41–0.89) | 12.7% vs. 10.7% | 0.99 (0.59–1.33) | 1.03 (0.98–1.83) | Fair
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | All-cause mortality | 3.4% vs. 6.4% | 0.36 (0.19–0.66) | 0.43 (0.30–0.78) | 35.2% vs. 40.5% | 0.71 (0.56–1.08) | 0.91 (0.65–1.14) | Fair
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | Death due to circulatory diseases^b^ | 1.4% vs. 2.4% | 0.54 (0.37–0.92) | 0.61 (0.37–0.91) | 17.1% vs. 18.3% | 0.91 (0.56–1.46) | 0.87 (0.43–1.37) | Fair
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | Death due to ischemic heart disease events | 1.0% vs. 1.7% | 0.43 (0.19–2.05) | 0.55 (0.38–1.19) | 5.5% vs. 6.3% | 1.04 (0.56–1.93) | 1.12 (0.66–2.05) | Fair
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | Death due to malignant neoplasms | 1.2% vs. 2.2% | 0.59 (0.21–0.88) | 0.61 (0.36–0.95) | 4.6% vs. 6.5% | 0.51 (0.24–1.09) | 0.73 (0.34–1.16) | Fair
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | Fatal and nonfatal cerebrovascular accident | 3.4% vs. 3.0% | 1.03 (0.51–2.13) | 1.09 (0.75–1.89) | 17.7% vs. 17.9% | 0.81 (0.31–2.12) | 1.11 (0.45–2.01) | Fair
Razvi 2012^49^ Retrospective cohort study (database analysis) Median for 40–70 age group: 7.6 years Median for >70 age group: 5.2 years | United Kingdom Age ≥40 years TSH: 5.01 to 10.00 mIU/L | Ages 40-70 years LT4, 75 μg/d (median): 1634 Not treated: 1459 Age >70 years LT4, 75 μg/d (median): 819 Not treated: 832 | Atrial fibrillation | 2.0% vs. 2.3% | 0.76 (0.26–1.73) | 0.87 (0.59–1.44) | 8.1% vs. 7.7% | 0.98 (0.54–1.76) | 1.23 (0.69–1.58) | Fair

a Multivariate adjusted for age, sex, body mass index, socioeconomic deprivation score, total cholesterol, TSH level, smoking status, history of diabetes mellitus, systolic and diastolic blood pressure, and levothyroxine use as a time-dependent covariate.

b Circulatory events include ischemic heart disease, cerebrovascular accident, and peripheral vascular disease.

Bold=significant difference.

Abbreviations: HR=hazard ratio; CI=confidence interval; LT4=levothyroxine; TSH=thyroid-stimulating hormone.

Table 4 Subclinical Hypothyroidism Quality of Life and Cognitive Function

Study, Year Study Design Study Duration Country | Mean Age Mean TSH Level (LT4 vs. Placebo) | Intervention and Duration, n | Results, LT4 vs. Placebo | Quality
Quality of life
Abu-Helalah 2010^37^ RCT crossover (at 2 months) 4 months United Kingdom | 58 years overall (NR by group) 4.1 to 9.0 mIU/L (mean NR) | LT4 72 μg (mean) for 2 months: 33 Placebo: 31 | QOL: odds of feeling better after taking thyroxine than placebo TSH >4.0 mIU/L: 21 vs.16 patients; odds, 1.3 TSH >4.5 mIU/L: 17 vs. 7 patients; odds, 2.4 TSH >5.0 mIU/L: 12 vs. 5 patients; odds, 2.4 TSH >5.5 mIU/L: 11 vs. 4 patients; odds, 2.8 TSH >6.0 mIU/L: 8 vs. 2 patients; odds, 4.0 | Poor
Jorde 2006^41^ RCT 12 months Norway | 62 vs. 63 years 5.8 vs. 5.3 mIU/L | LT4 109.7 μg for 12 months (mean): 36 Placebo: 33 | GHQ-30: 1.9 ± 3.3 vs. 1.2 ± 2.0; p=NS BDI: 4.3 ± 3.6 vs. 3.3 ± 4.0; p=NS | Fair
Kong 2002^42^ RCT 6 months United Kingdom | 53 vs. 45 years 8.0 vs. 7.3 mIU/L | LT4 (mean NR) for 6 months: 23 Placebo: 17 | Mean change in thyroxine group minus mean change in placebo group: HADS–anxiety: 1 (95% CI, −1 to 3); p=NS HADS–depression: −1 (95% CI, −3 to 1); p=NS GHQ-30: 2 (95% CI, −5 to 7); p=NS | Good
Parle 2010^47^ RCT 12 months United Kingdom | 73.5 vs. 74.2 years 6.6 vs. 6.6 mIU/L | LT4 50 μg (median) for 12 months: 52 Placebo: 42 | HADS–depression: 3.55 (0.27) vs. 3.37 (0.31); p=0.82 | Good
Razvi 2007^48^ RCT crossover (at 2.8 months) 5.5 months United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4100 μg for 12 weeks: 50 Placebo: 50 | ThyDQoL: −1.1 ± 1 vs. −1.2 ± 0.9; p=0.24 SF-36–sex: −2.3 ± 2.7 vs. −2.7 ± 2.8; p=0.18 SF-36–motivation: −3.6 ± 2.7 vs. −3.7 ± 2.7; p=0.16 SF-36–worries: −2.5 ± 3 vs. −2.8 ± 2.9; p=0.23 Average weighted impact of all 18 QOL domains: −2.7 ± 2.4 vs. −2.8 ± 2.3; p=0.45 | Good
Cognitive function
Jorde 2006^41^ RCT 12 months Norway | 62 vs. 63 years 5.8 vs. 5.3 mIU/L | LT4 109.7 μg for 12 months (mean): 36 Placebo: 33 | Composite cognitive function score: 1.5 ± 3.7 vs. −0.9 ± 4.8; p=NS Trail Making A–psychomotor test of executive function: 39.0 ± 14.8 vs. 44.1 ± 17.7; p=NS Trail Making B–psychomotor test of executive function: 94 ± 62 vs. 103 ± 49; p=NS | Fair
Parle 2010^47^ RCT 12 months United Kingdom | 73.5 vs. 74.2 years 6.6 vs. 6.6 mIU/L | LT4 50 μg (median) for 12 months: 52 Placebo: 42 | MEAMS–cognitive skills and performance: 11.67 (0.09) vs. 11.60 (0.11); p=0.57 MMSE–cognitive status: 28.24 (0.38) vs. 28.22 (0.43); p=0.18 SCOLP–speed of cognitive processing and accounting: 1.29 (0.30) vs. 0.84 (0.35); p=0.59 Trail Making A–psychomotor test of executive function: 45.33 (2.63) vs. 46.78 (3.05); p=0.52 Trail Making B–psychomotor test of executive function: 100.65 (7.75) vs. 114.11 (9.07); p=0.95 Trail Making B-A–psychomotor test of executive function: 54.55 (6.80) vs. 67.27 (7.97); p=0.86 | Good

Abbreviations: BDI=Beck Depression Inventory; CI=confidence interval; GHQ-30=General Health Questionnaire; HADS=Hospital Anxiety and Depression Scale; LT4=levothyroxine; MEAMS=Middlesex Elderly Assessment on Mental State; MMSE=Mini-Mental State Examination; NR=not reported; NS=not significant; QOL=quality of life; RCT=randomized, controlled trial; SCOLP=Speed and Capacity of Language Processing; SF-36=36-Item Short-Form Health Survey; TSH=thyroid-stimulating hormone.

Table 5 Subclinical Hypothyroidism Intermediate Outcomes

Study, Year Study Design Study Duration Country | Mean Age Mean TSH Level (LT4 vs. Placebo) | Intervention and Duration, n | Results, LT4 vs. Placebo | Difference in Means (Treatment vs. Control)^a^ | Quality
Blood pressure
Monzani 2004^44^ RCT 10.5 months Italy | 37 years (NR by group) 6.03 vs. 5.68 mIU/L | LT4 70 μg (mean) for 6 months: 23 Placebo: 22 | SBP: 112 ± 15 vs. 114 ± 13 mm Hg; p=NS DBP: 69 ± 9 vs. 72 ± 8 mm Hg; p=NS | SBP: −2 mm Hg DBP: −3 mm Hg | Fair
Nagasaki 2009^46^ RCT 5 months Japan | 64 vs. 66 years 7.3 vs. 7.3 mIU/L | LT4 25.8 μg (average) for 5 months: 48/NR Placebo: 47/NR | SBP: 129 ± 4 vs. 132 ± 4 mm H; p=NS DBP: 73 ± 2 vs. 73 ± 2 mm Hg; p=NS | SBP: −3 mm Hg DBP: 0 mm Hg | Fair
Razvi 2007^48^ RCT crossover (at 12 weeks) 24 weeks United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4 100 μg for 12 weeks: 50/50 Placebo: 50/49 | SBP: 133 ± 23 vs. 135 ± 23 mm Hg; p=0.21 DBP: 79 ± 10 vs. 80 ± 10 mm Hg; p=0.16 | SBP: −2 mm Hg DBP: −1 mm Hg | Good
Total cholesterol
Cabral 2011^38^ RCT 12 months Brazil | 43 vs. 47 years 6.79 vs. 6.77 mIU/L | LT4 (median, 44.23 μg) for 12 months: 14 No treatment: 18 | TC: 208 ± 37 vs. 228 ± 37 mg/dL; p=NS | TC: −20 mg/dL | Fair
Duman 2007^39^ RCT 8 months Turkey | 36 vs. 35 years 10.9 vs. 11.0 mIU/L | LT4 (all patients reached dose of 100 μg [mean NR] for 8 months): 22 No treatment: 19 | TC: 202 ± 28 vs. 202 ± 28 mg/dL; p=NS | TC: 0 mg/dL | Fair
Iqbal, 2006^40^ RCT 12 months Norway | 63 vs. 61 years 5.8 vs. 5.4 mIU/L | LT4 96 to 97 μg (mean) for 12 months: 32/32 Placebo: 32/32 | TC: 220 ± 43 vs. 224 ± 35 mg/dL; p=NS | TC: −4 mg/dL | Fair
Kong 2002^42^ RCT 6 months United Kingdom | 53 vs. 45 years 8.0 vs. 7.3 mIU/L | LT4 (mean NR) for 6 months: 23 Placebo: 17 | NR | Mean change in thyroxine group minus mean change in placebo group, TC: −8 mg/dL (95% CI, −28 to 20); p=NS | Good
Mikhail 2008^43^ RCT 12 months Kuwait | 32 vs. 32 years 6.4 vs. 6.3 mIU/L | LT4 72 μg (mean) for 12 months: 60 Placebo: 60 | TC: 183 ± 34 vs. 195 ± 26 mg/dL; p<0.029 | TC: −12 mg/dL | Fair
Monzani 2004^44^ RCT 10.5 months Italy | 37 years (NR by group) 6.03 vs. 5.68 mIU/L | LT4 70 μg (mean) for 6 months: 23 Placebo: 22 | TC: 192 ± 33 vs. 220 ± 49 mg/dL; p=0.03 | TC: −28 mg/dL | Fair
Nagasaki 2009^46^ RCT 5 months Japan | 64 vs. 66 years 7.3 vs. 7.3 mIU/L | LT4 25.8 μg (average) for 5 months: 48/NR Placebo: 47/NR | TC: 201 ± 6 vs. 206 ± 9 mg/dL; p=NS | TC: −5 mg/dL | Fair
Razvi 2007^48^ RCT crossover (at 12 weeks) 24 weeks United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4 100 μg for 12 weeks: 50/50 Placebo: 50/49 | TC: 220 ± 39 vs. 232 ± 39 mg/dL; p<0.001 | TC: −12 mg/dL | Good
Teixeira 2008^50^.51 RCT 12 months Brazil | 48.9 vs. 47.5 years 7.5 vs. 7.7 mIU/mL | LT4 (mean NR) for 12 months: 35 Placebo: 25 | TC: 197 ± 29 vs. 203 ± 41 mg/dL; p=0.032 | TC: −6 mg/dL | Poor
Low-density lipoprotein
Cabral 2011^38^ RCT 12 months Brazil | 43 vs. 47 years 6.79 vs. 6.77 mIU/L | LT4 (median, 44.23 μg) for 12 months: 14 No treatment: 18 | LDL: 133 ± 38 vs. 151 ± 35 mg/dL; p=NS | LDL: −18 mg/dL | Fair
Duman 2007^39^ RCT 8 months Turkey | 36 vs. 35 years 10.9 vs. 11.0 mIU/L | LT4 (all patients reached dose of 100 μg [mean NR] for 8 months): 22 No treatment: 19 | LDL: 130 ± 32 vs. 128 ± 25 mg/dL; p=NS | LDL: 2 mg/dL | Fair
Iqbal 2006^40^ RCT 12 months Norway | 63 vs. 61 years 5.8 vs. 5.4 mIU/L | LT4 96 to 97 μg (mean) for 12 months: 32/32 Placebo: 32/32 | LDL: 139 ± 35 vs. 139 +/0 39 mg/dL; p=NS | LDL: 0 mg/dL | Fair
Kong 2002^42^ RCT 6 months United Kingdom | 53 vs. 45 years 8.0 vs. 7.3 mIU/L | LT4 (mean NR) for 6 months: 23 Placebo: 17 | NR | Mean change in thyroxine group minus mean change in placebo group, LDL: −4 mg/dL (95% CI, −23 to 15); p=NS | Good
Mikhail 2008^43^ RCT 12 months Kuwait | 32 vs. 32 years 6.4 vs. 6.3 mIU/L | LT4 72 μg (mean) for 12 months: 60 Placebo: 60 | LDL: 112 ± 23 vs. 120 ± 30 mg/dL; p<0.001 | LDL: −8 mg/dL | Fair
Monzani 2004^44^ RCT 10.5 months Italy | 37 years (NR by group) 6.03 vs. 5.68 mIU/L | LT4 70 μg (mean) for 6 months: 23 Placebo: 22 | LDL: 119 ± 28 vs. 141 ± 39 mg/dL; p=0.03 | LDL: −22 mg/dL | Fair
Nagasaki 2009^46^ RCT 5 months Japan | 64 vs. 66 years 7.3 vs. 7.3 mIU/L | LT4 25.8 μg (average) for 5 months: 48/NR Placebo: 47/NR | LDL: 121 ± 11 vs. 130 ± 7 mg/dL; p=NS | LDL: −9 mg/dL | Fair
Razvi 2007^48^ RCT crossover (at 12 weeks) 24 weeks United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4 100 μg for 12 weeks: 50/50 Placebo: 50/49 | LDL: 131 ± 31 vs. 143 ± 35 mg/dL; p<0.001 | LDL: −12 mg/dL | Good
Teixeira 2008^50, 51^ RCT 12 months Brazil | 48.9 vs. 47.5 years 7.5 vs. 7.7 mIU/mL | LT4 (mean NR) for 12 months: 35 Placebo: 25 | LDL: 118 ± 24 vs. 130 ± 35 mg/dL; p=0.024 | LDL: −12 mg/dL | Poor
High-density lipoprotein
Cabral 2011^38^ RCT 12 months Brazil | 43 vs. 47 years 6.79 vs. 6.77 mIU/L | LT4 (median, 44.23 μg) for 12 months: 14 No treatment: 18 | HDL: 54 ± 12 vs. 50 ± 10 mg/dL; p=NS | HDL: 4 mg/dL | Fair
Duman 2007^39^ RCT 8 months Turkey | 36 vs. 35 years 10.9 vs. 11.0 mIU/L | LT4 (all patients reached dose of 100 μg [mean NR] for 8 months): 22 No treatment: 19 | HDL: 53 ± 16 vs. 53 ± 9 mg/dL; p=NS | HDL: 0 mg/dL | Fair
Iqbal 2006^40^ RCT 12 months Norway | 63 vs. 61 years 5.8 vs. 5.4 mIU/L | LT4 96 to 97 μg (mean) for 12 months: 32/32 Placebo: 32/32 | HDL: 58 ± 16 vs. 58 ± 19 mg/dL; p=NS | HDL: 0 mg/dL | Fair
Kong 2002^42^ RCT 6 months United Kingdom | 53 vs. 45 years 8.0 vs. 7.3 mIU/L | LT4 (mean NR) for 6 months: 23 Placebo: 17 | NR | Mean change in thyroxine group minus mean change in placebo group, HDL: −1 mg/dL (95% CI, −8 to 4); p=NS | Good
Mikhail 2008^43^ RCT 12 months Kuwait | 32 vs. 32 years 6.4 vs. 6.3 mIU/L | LT4 72 μg (mean) for 12 months: 60 Placebo: 60 | HDL: 46 ± 12 vs. 43 ± 10 mg/dL; p=NS | HDL: 3 mg/dL | Fair
Monzani 2004^44^ RCT 10.5 months Italy | 37 years (NR by group) 6.03 vs. 5.68 mIU/L | LT4 70 μg (mean) for 6 months: 23 Placebo: 22 | HDL: 55 ± 7 vs. 58 ± 12 mg/dL; p=NS | HDL: −3 mg/dL | Fair
Nagasaki 2009^46^ RCT 5 months Japan | 64 vs. 66 years 7.3 vs. 7.3 mIU/L | LT4 25.8 μg (average) for 5 months: 48/NR Placebo: 47/NR | HDL: 55 ± 3 vs. 54 ± 2 mg/dL; p=NS | HDL: 1 mg/dL | Fair
Razvi 2007^48^ RCT cross-over (at 12 weeks) 24 weeks United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4 100 μg for 12 weeks: 50/50 Placebo: 50/49 | HDL: 62 ± 19 vs. 66 ± 19 mg/dL; p=0.12 | HDL: −4 mg/dL | Good
Teixeira 2008^50, 51^ RCT 12 months Brazil | 48.9 vs. 47.5 years 7.5 vs. 7.7 mIU/mL | LT4 (mean NR) for 12 months: 35 Placebo: 25 | HDL: 55 ± 18 vs. 49 ± 10 mg/dL; p=0.180 | HDL: 6 mg/dL | Poor
Triglycerides
Cabral 2011^38^ RCT 12 months Brazil | 43 vs. 47 years 6.79 vs. 6.77 mIU/L | LT4 (median, 44.23 μg/d) for 12 months: 14 No treatment: 18 | TG: 106 ± 37 vs. 137 ± 56 mg/dL;, p=NS | TG: −31 mg/dL | Fair
Duman 2007^39^ RCT 8 months Turkey | 36 vs. 35 years 10.9 vs. 11.0 mIU/L | LT4 (all patients reached dose of 100 μg [mean NR] for 8 months): 22 No treatment: 19 | TG: 96 ± 37 vs. 128 ± 58 mg/dL; p=NS | TG: −32 mg/dL | Fair
Iqbal 2006^40^ RCT 12 months Norway | 63 vs. 61 years 5.8 vs. 5.4 mIU/L | LT4 96 to 97 μg (mean) for 12 months: 32/32 Placebo: 32/32 | TG: 133 ± 89 vs. 142 ± 62 mg/dL; p=NS | TG: −9 mg/dL | Fair
Kong 2002^42^ RCT 6 months United Kingdom | 53 vs. 45 years 8.0 vs. 7.3 mIU/L | LT4 (mean NR) for 6 months: 23 Placebo: 17 | NR | Mean change in thyroxine group minus mean change in placebo group, TG: 9 mg/dL (95% CI, −26 to 44); p=NS | Good
Mikhail 2008^43^ RCT 12 months Kuwait | 32 vs. 32 years 6.4 vs. 6.3 mIU/L | LT4 72 μg (mean) for 12 months: 60 Placebo: 60 | TG: 84 ± 47 vs. 94 ± 52 mg/dL; p=NS | TG: −10 mg/dL | Fair
Monzani 2004^44^ RCT 10.5 months Italy | 37 years (NR by group) 6.03 vs. 5.68 mIU/L | LT4 70 μg (mean) for 6 months: 23 Placebo: 22 | TG: 88 ± 30 vs. 103 ± 53 mg/dL; p=NS | TG: −15 mg/dL | Fair
Nagasaki 2009^49^ RCT 5 months Japan | 64 vs. 66 years 7.3 vs. 7.3 mIU/L | LT4 25.8 μg (average) for 5 months: 48/NR Placebo: 47/NR | TG: 133 ± 14 vs. 122 ± 12 mg/dL; p=NS | TG: 11 mg/dL | Fair
Razvi 2007^46^ RCT cross-over (at 12 weeks) 24 weeks United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4 100 μg for 12 weeks: 50/50 Placebo: 50/49 | TG: 115 (44 to 363) vs. 115 (35 to 452) mg/dL; p=0.26 | TG: 0 mg/dL | Good
Teixeira 2008^50, 51^ RCT 12 months Brazil | 48.9 vs. 47.5 years 7.5 vs. 7.7 mIU/mL | LT4 (mean NR) for 12 months: 35 Placebo: 25 | TG: 105 ± 59 vs. 123 ± 59 mg/dL; p=0.384 | TG: −18 mg/dL | Poor
Body mass index or weight
Duman 2007^39^ RCT 8 months Turkey | 36 vs. 35 years 10.9 vs. 11.0 mIU/L | LT4 (all patients reached dose of 100 μg [mean NR] for 8 months: 22 No treatment: 19 | BMI: 25 ± 3 vs. 26 ± 9 kg/m^2^; p=NS | BMI: −1 kg/m^2^ | Fair
Iqbal 2006^40^ RCT 12 months Norway | 63 vs. 61 years 5.8 vs. 5.4 mIU/L | LT4 96 to 97 μg (mean) for 12 months: 32/32 Placebo: 32/32 | BMI: 28 ± 6 vs. 27 ± 4 kg/m^2^; p=NS | BMI: 1 kg/m^2^ | Fair
Kong 2002^42^ RCT 6 months United Kingdom | 53 vs. 45 years 8.0 vs. 7.3 mIU/L | LT4 (mean NR) for 6 months: 23 Placebo: 17 | NR | Mean change in thyroxine group minus mean change in placebo group: BMI: −0.3 kg/m^2^ (95% CI, 0.9 to 0.4); p=NS % lean body weight: 0.1 (95% CI, 1.6 to 1.7); p=NS | Good
Monzani 2004^44^ RCT 10.5 months Italy | 37 years (NR by group) 6.03 vs. 5.68 mIU/L | LT4 70 μg (mean) for 6 months: 23 Placebo: 22 | BMI: 24 ± 4 vs. 25 ± 4 kg/m^2^; p=NS | BMI: −1 kg/m^2^ | Fair
Nagasaki 2009^46^ RCT 5 months Japan | 64 vs. 66 years 7.3 vs. 7.3 mIU/L | LT4 25.8 μg (average) for 5 months: 48/NR Placebo: 47/NR | BMI: 22 ± 0.5 vs. 22 ± 0.5 kg/m^2^; p=NS | BMI: 0 kg/m^2^ | Fair
Razvi 2007^48^ RCT crossover (at 12 weeks) 24 weeks United Kingdom | 53.5 vs. 54.2 years 5.4 vs. 5.3 mIU/L | LT4 100 μg for 12 weeks: 50/50 Placebo: 50/49 | Weight: 76 ± 17 vs. 77 ± 17 kg; p=0.12 | Weight: −1 kg | Good

a Negative values favor treatment for BMI, SBP, DBP, total cholesterol, LDL, and triglycerides; positive values favor treatment for HDL.

Abbreviations: BMI=body mass index; CI=confidence interval; DBP=diastolic blood pressure; HDL=high-density lipoprotein; LDL=low-density lipoprotein; LT4=levothyroxine; NR=not reported; NS=not significant; RCT=randomized, controlled trial; SBP=systolic blood pressure; TC= total cholesterol; TG=triglycerides; TSH=thyroid-stimulating hormone.

Table 6 Subclinical Hyperthyroidism Intermediate Outcomes

Study, Year Study Design Study Duration Country | Mean Age Mean TSH Level (Intervention vs. No Treatment) | Intervention, n | Results, Intervention vs. No Treatment | Difference in Means (Treatment vs. Control)^a^ | Quality
Blood pressure
Buscemi 2007^52^ RCT 12 months Italy | 59 vs. 57 years 0.06 vs. 0.06 mIU/L | Methimazole 10 to 15 mg for 12 months: 7 No treatment: 7 | SBP: 136 ± 4 vs. 126 ± 11 mm Hg; p=NS DBP: 78 ± 3 vs. 80 ± 3 mm Hg; p=NS | SBP: 10 mm Hg DBP: −2 mm Hg | Poor
Yonem 2002^53^ RCT 6 months Turkey | 38.7 vs. 33.5 years 0.23 vs. 0.21 mIU/L | Propylthiouracil 150 mg for 6 months: 9 Radioactive iodine for 6 months: 1 No treatment: 10 | SBP day: 112 ± 3 vs. 114 ± 3 mm Hg; p=NS DBP day: 69 ± 2 vs. 72 ± 2 mm Hg; p=NS SBP night : 100 ± 2 vs. 102 ± 2 mm Hg; p=NS DBP night: 62 ± 1 vs. 62 ± 3 mm Hg; p=NS | SBP day: −2 mm Hg DBP day: −3 mm Hg SBP night: −2 mm Hg DBP night: 0 mm Hg | Poor
Body mass index
Buscemi 2007^52^ RCT 12 months Italy | 59 vs. 57 years 0.06 vs. 0.06 mIU/L | Methimazole 10 to 15 mg for 12 months: 7 No treatment: 7 | BMI: 28 ± 1 vs. 28 ± 1 kg/m^2^; p=NS | BMI: 0 kg/m^2^ | Poor
Bone mineral density
Yonem 2002^53^ RCT 6 months Turkey | 38.7 vs. 33.5 years 0.23 vs. 0.21 mIU/L | Propylthiouracil 150 mg for 6 months: 9 Radioactive iodine for 6 months: 1 No treatment: 10 | BMD femur neck: 0.826 ± 0.042 vs. 0.868 ± 0.019 g/cm^2^; p=NS BMD lumbar vertebra: 0.998 ± 0.048 vs. 0.968 ± 0.030 g/cm^2^; p=NS | BMD femur neck: −0.042 g/cm^2^ BMD lumbar vertebra: 0.03 g/cm^2^ | Poor
Lipid levels
Yonem 2002^53^ RCT 6 months Turkey | 38.7 vs. 33.5 years 0.23 vs. 0.21 mIU/L | Propylthiouracil 150 mg for 6 months: 9 Radioactive iodine for 6 months: 1 No treatment: 10 | TG: 40 ± 24 vs. 76 ± 14 mg/dL; p=NS TC: 183 ± 9 vs. 157 ± 7 mg/dL; p=NS LDL: 106 ± 7 vs. 91 ± 6 mg/dL; p=NS HDL: 48 ± 4 vs. 48 ± 4 mg/dL; p=NS | TG: −36 mg/dL TC: 26 mg/dL LDL: 15 mg/dL HDL: 0 mg/dL | Poor

a Negative values favor treatment for BMD, BMI, SBP, DBP, TC, LDL, and TG; positive values favor treatment for HDL.

Abbreviations: BMD=bone mineral density; BMI=body mass index; DBP=diastolic blood pressure; HDL=high-density lipoprotein; LDL=low-density lipoprotein; NS=not significant; RCT=randomized, controlled trial; SBP=systolic blood pressure; TC=total cholesterol; TG=triglycerides; TSH=thyroid-stimulating hormone.

Table 7 Adverse Effects of Treatment

Study, Year | Duration | Adverse Effects Reported | Quality
Subclinical hypothyroidism
Abu-Helalah 2010^37^ | 4 months | “No indication of harms” | Poor
Nagasaki 2009^46^ | 5 months | None of the patients required withdrawal of treatment due to side effects | Fair
Parle 2010^47^ | 12 months | Withdrawal due to side effects: 9.6% (5/52) intervention vs. 14.3% (6/42) placebo; p=0.49 | Good
Razvi 2007^48^ | 5.5 months | 1 person in the placebo group discontinued because of “perceived side effects and personal problems” | Good
Teixeira 2008^50,51^ | 12 months | Levothyroxine group: 1 patient withdrew because of Hashitoxicosis, 1 patient withdrew because of symptomatic tachycardia | Poor
Subclinical hyperthyroidism
Buscemi 2007^52^ | 12 months | “No adverse effect” was observed in the treatment group | Poor

Three trials were rated as good quality,42,47,48 six trials (reported in seven publications) were rated as fair quality38-41,43,44,46 and four trials (in five publications) were rated as poor quality37,50-53 (Appendix B2); the one retrospective cohort study was rated as fair quality (Appendix B3).49 Most of the poor-quality studies were characterized by poor reporting of methods (e.g., methods of randomization, allocation concealment, blinding, and reporting of attrition) rather than clearly inadequate methods.

None of the trials were conducted in the United States. Twelve were conducted in Europe (the United Kingdom, Italy, Turkey, or Norway), two in Brazil, one in Kuwait, and one in Japan. The TSH values used to diagnose subclinical thyroid dysfunction at baseline varied among the studies; the threshold ranged from 4.1 to 11.0 mIU/L for subclinical hypothyroidism and from 0.06 to 0.23 mIU/L for subclinical hyperthyroidism. Mean patient age ranged from 32 to older than 70 years. Treatment of subclinical hypothyroidism was levothyroxine using different dosages and dosing regimens, and for subclinical hyperthyroidism was methimazole, propylthiouracil, or radioactive iodine. Study duration ranged from 4 to 12 months except for the cohort study, which analyzed data retrospectively, with up to 7.6 years of followup.49 Sample sizes in the trials ranged from 14 to 120 patients; the cohort study analyzed 4,744 patients.49 Two publications from the Tromsø Study reported different outcomes from the same population.40,41 While most studies evaluated a placebo comparator, five used a no treatment comparison.38,39,49, 52,53

Three trials (in four publications) evaluated screen-detected populations.37,40,41,47 Most other trials did not clearly report how patients were identified, other than that they were recruited from outpatient clinics. Most trials reported that patients were newly diagnosed and excluded those with previous thyroid dysfunction or those previously taking antithyroid medications.

## Key Question 1 Does Screening for Thyroid Dysfunction Reduce Morbidity or Mortality?

As in the previous USPSTF report,1,15 we found no studies of screening for subclinical dysfunction or biochemically overt thyroid disease versus no screening that reported clinical outcomes.

## Key Question 2 What Are the Harms of Screening for Thyroid Dysfunction?

No studies reported harms of thyroid screening versus no screening.

## Key Question 3a Does Treatment of Screen-Detected Overt or Subclinical Thyroid Dysfunction Improve Morbidity or Mortality?

### Summary

The previous USPSTF review included no studies on effects of treatment of subclinical hypothyroidism on cardiovascular events. In one fair-quality retrospective cohort study of subclinical hypothyroid patients in the U.K. General Practice Research Database published since the prior USPSTF review, levothyroxine use was associated with lower risk for fatal or nonfatal ischemic heart disease events (4.2% vs. 6.6%; hazard ratio [HR], 0.61 [95% CI, 0.39 to 0.95]), all-cause mortality (3.4% vs. 6.4%; HR, 0.36 [95%, CI, 0.19 to 0.66]), death due to circulatory diseases (1.4% vs. 2.4%; HR, 0.54 [95% CI, 0.37 to 0.92]), and cancer mortality (1.2% vs. 2.2%; HR, 0.59 [95% CI, 0.21 to 0.88]) compared with no treatment among subjects ages 40 to 70 years, but there was no association among those older than age 70 years.49

Results regarding effects of treatment of subclinical hypothyroidism on clinical outcomes were consistent with findings from the prior USPSTF review in showing no clear effects on measures of quality of life or cognitive function. Five small randomized trials (N=40 to 100) published since the prior USPSTF review found no effect of treatment of subclinical hypothyroidism on various self-reported quality of life measures, and two trials (N=69 and 94) found no effect on measures of cognitive function.

No study of overt thyroid disease or subclinical hyperthyroidism reported clinical outcomes.

### Evidence

#### Subclinical Hypothyroidism

We identified five trials (three good-quality,42,47,48 one fair-quality,41 and one poor-quality37) and one fair-quality retrospective cohort study49 published since the prior USPSTF review that evaluated effects of treatment of subclinical hypothyroidism on clinical outcomes (Tables 3 and 4; Appendixes B1, B2, and B3).

Cardiovascular events and mortality. The previous USPSTF review1,15 included no studies on the association between treatment of subclinical hypothyroidism and risk for cardiac events.

We identified one fair-quality retrospective cohort study conducted in 2001 that evaluated the effects of treatment on risk for cardiac events49 in 4,744 adults age 40 years or older with subclinical hypothyroidism (based on a single TSH level of >5.00 to 10.00 mIU/L; mean followup, 7.6 years) (Table 3). Analyses were stratified, based on an a priori categorization, by ages 40 to 70 years and older than age 70 years. The authors did not report analyses based on the whole cohort. The primary outcome was a composite of first incident fatal and nonfatal ischemic heart disease event. Secondary outcomes were first fatal and nonfatal cerebrovascular disease events and all-cause and cause-specific mortality identified during the study period. About half of the participants were treated with levothyroxine (average dose, 75 μg).

After adjustment for age, sex, body mass index, socioeconomic status, total cholesterol level, smoking status, history of diabetes mellitus, index serum thyrotropin level, levothyroxine use, and blood pressure, levothyroxine use was associated with lower risk for fatal or nonfatal ischemic heart disease events (4.2% vs. 6.6%; HR, 0.61 [95% CI, 0.39 to 0.95]), all-cause mortality (3.4% vs. 6.4%; HR. 0.36 [95% CI, 0.19 to 0.66]), death due to circulatory diseases (1.4% vs. 2.4%; HR, 0.54 [95% CI, 0.37 to 0.92]), and cancer mortality (1.2% vs. 2.2%; HR, 0.59 [95% CI, 0.21 to 0.88]) compared with no treatment in subjects ages 40 to 70 years.49 In subjects older than age 70 years, there was no association between use of levothyroxine and ischemic heart disease events (HR, 0.99 [95% CI, 0.59 to 1.33]), all-cause mortality (35.2% vs. 40.5%; HR, 0.71 [95% CI, 0.56 to 1.08]), or cancer mortality (4.6% vs. 6.5%; HR, 0.51 [95% CI, 0.24 to 1.09]). Potential limitations include the lack of adjustment for medications that reduce risk for cardiovascular disease, though baseline data suggested no differences between treatment groups.

Quality of life. The prior USPSTF review1,15 included five trials that evaluated the association between treatment of subclinical thyroid dysfunction and quality of life.42,54-57 One of the trials found that treatment of subclinical hypothyroidism was associated with better quality of life in patients with recent Graves' disease.54 The other four trials found no effect of treatment.42,55-57 However, the applicability of these studies to screening appears limited, and three would have been excluded from this update because patients had previously been treated for thyroid dysfunction,54,56 or because they included mostly enrolled euthyroid patients.57

We identified five trials (three good-quality,42,47,48 one fair-quality,41 and one poor-quality37) published since the prior USPSTF review on treatment of subclinical hypothyroidism (TSH thresholds varied from >3.5 to >5.5) using various doses of levothyroxine (mean, 50 to 109.7 μg/day) and effects on various measures of quality of life (36-Item Short-Form Health Survey [SF-36], General Health Questionnaire-30 [GHQ-30], Beck Depression Inventory, Hospital Anxiety and Depression Scale [HADS], and Underactive Thyroid-Dependent Quality of Life Questionnaire) in adults with mean ages ranging from 45 to 74 years (Table 4). Sample sizes were less than 100 in all trials, mean age ranged from 45 to 74 years, and followup ranged from 4 to 12 months. No differences were found between those receiving treatment and placebo in any study. Three of these treatment trials evaluated screen-detected populations.37,41,47

Of the three good-quality trials, one (N=40) found no difference in the mean change in the thyroxine group minus the mean change in the placebo group on the HADS anxiety score (1 [95% CI, -1 to 3]; p=not significant [NS]), the HADS depression score (-1 [95% CI, -3 to 1]; p=NS), or the GHQ-30 (2 [95% CI, -5 to 7]; p=NS) after 6 months.42 One trial (N=94) found no difference in HADS depression scores in the thyroxine versus placebo groups (mean score, 3.55 vs. 3.37; p=0.82) after 12 months,47 and one crossover trial (N=100) found no differences in the Underactive Thyroid-Dependent Quality of Life Questionnaire (-1.1 vs. -1.2; p=0.24), the SF-36 sex component (-2.3 vs. -2.7; p=0.18), the SF-36 motivation component (-3.6 vs. -3.7; p=0.16), the SF-36 worries component (-2.5 vs. -2.8; p=0.23), or the average weighted effect of all 18 quality of life domains (-2.7 vs. -2.8; p=045) after 12 weeks.48 The fair-quality study found no effects of treatment versus placebo on the GHQ-30 (1.9 vs. 1.2; p=NS) or the Beck Depression Inventory (4.3 vs. 3.3; p=NS).41

Cognitive function. Two trials included in the previous USPSTF review evaluated effects of treatment of subclinical hypothyroidism on cognitive function.55,57 One trial that included euthyroid patients57 found no effect, and the second trial found a statistically significant improvement in memory using a composite outcome in adults older than age 55 years that the authors described as “small and of questionable clinical importance.”55

We identified one good-quality47 and one fair-quality trial41 published since the last USPSTF review that found no association between treatment with levothyroxine for subclinical hypothyroidism (defined as TSH >3.5 and <10^41^ or TSH > 5.5^47^) versus placebo and various measures of cognitive function after 12 months (Table 4). Both studies appeared to evaluate screen-detected populations. Mean age was 62 to 63 years in one study (N=69),41 and 74 years in the other (N=94).47 The good-quality study47 found no effects on cognitive skills and performance (Middlesex Elderly Assessment of Mental State, 11.67 vs. 11.60; p=0.57), cognitive status (Mini-Mental State Examination, 28.24 vs. 28.22; p=0.18), speed of cognitive processing and accounting (Speed and Capacity of Language Processing test, 1.29 vs. 0.84; p=0.59), psychomotor test of executive function (Trail Making A, 45.33 vs. 46.78; p=0.52), psychomotor test of executive function (Trail Making B, 100.65 vs. 114.11; p=0.95), or psychomotor test of executive function (Trail Making B-A, 54.55 vs. 67.27; p=0.86).

#### Subclinical Hyperthyroidism

No studies evaluated benefits of treatments for subclinical hyperthyroidism on clinical outcomes.

#### Overt Thyroid Disease

No studies reported effects of treatment of overt thyroid disease.

## Key Question 3b Does Treatment of Screen-Detected Overt or Subclinical Thyroid Dysfunction Improve Intermediate Outcomes?

### Summary

We identified nine trials published since the prior USPSTF review on effects of treatment of subclinical hypothyroidism on intermediate outcomes. Like the prior USPSTF review, we found some evidence that treatment is associated with lower total and low-density lipoprotein (LDL) cholesterol than placebo or no treatment. Across eight good- and fair-quality trials, mean differences between treatment and placebo or no treatment ranged from -28 to 0 mg/dL for total cholesterol and from -22 to 2 mg/dL for LDL cholesterol, with a statistically significant difference in three trials. Treatment was not associated with beneficial effects on blood pressure, high-density lipoprotein (HDL) cholesterol, triglyceride levels, or body mass index/weight.

Two small, poor-quality trials found no differences between treatment of subclinical hyperthyroidism and no treatment on blood pressure, body mass index, bone mineral density, or lipid levels.

No studies examined the effect of treatment of overt thyroid disease on intermediate outcomes.

### Evidence

#### Subclinical Hypothyroidism

We identified nine trials (reported in 11 publications) published since the prior USPSTF review on the effects of treatment of subclinical hypothyroidism on blood pressure; total, LDL, and HDL cholesterol, triglycerides, and body mass index or weight (Table 5; Appendices B1 and B2).38-40,42-46,48,50,51 Two trials were rated as good quality,42,48 six trials as fair quality,38-40,43,44,46 and one trial as poor quality.50,51

Blood pressure. The 2004 USPSTF review1,15 included no studies on the effect of treatment of subclinical hypothyroidism on blood pressure.

We identified one good-quality48 and two fair-quality44,46 trials on the effects of treatment of subclinical hypothyroidism (defined as TSH > 3.6 44 or >4.0^48^ or TSH above the normal limit46) on blood pressure. None found a significant difference between groups. Across all three trials, differences in means between treatment and placebo groups in ranged from -3 to -2 mm Hg for systolic blood pressure and from -3 to 0 mm Hg for diastolic blood pressure (Table 5). In the good-quality trial (n=100), which was a crossover trial, the difference in means was -2 mm Hg (p=0.21) for systolic blood pressure and -1 mm Hg (p=0.16) for diastolic blood pressure after 12 weeks.48

Lipids. The prior USPSTF review included seven trials on the effect of treatment of subclinical hypothyroidism and effects on lipid profiles.42,45,54-56,58,59 Six trials found no improvement in lipid parameters,42,45,54-56,59 while one poor-quality trial in euthyroid patients found about a 5 percent improvement in LDL cholesterol with 50 μg/day of levothyroxine versus 25 μg/day.58

Total cholesterol. We identified two good-quality,42,49 six fair-quality38,39,43,44,46 and one poor-quality50,51 trials published since the prior USPSTF review on the effects of treatment of subclinical hypothyroidism on total cholesterol (Table 5). TSH thresholds varied from >3.6 to >5, or “greater than the upper limit of normal”.46 In the eight good- and fair-quality trials, differences between treatment and no treatment in mean total cholesterol ranged from -28 to 0 mg/dL. Three of the trials (N=45, 100, and 120) reported statistically significant differences in mean total cholesterol values of -12 mg/dL (p<0.03),43 -28 mg/dL (p=0.03),44 and -12 mg/dL (p<0001).48 The poor-quality trial found that treatment was associated with slightly lower total cholesterol values (difference in means, -6 mg/dL; p=0.03).50,51

LDL cholesterol. Two good-quality,42,48 six fair-quality,38-40,43,44,46 and one poor-quality50,51 trials published since the prior USPSTF review evaluated the effect of treatment of subclinical hypothyroidism on LDL values. In the eight good- and fair-quality trials, differences between treatment and no treatment in mean LDL cholesterol ranged from -22 to 2 mg/dL. Three of the trials (N=45, 100, and 120) reported statistically significant differences in mean LDL values of -8 mg/dL (p<0.001),43 -22 mg/dL (p=0.03),44 and -12 mg/dL (p<0.001).48 The poor-quality trial found that treatment was associated with slightly lower LDL values (difference in means, -12 mg/dL; p=0.02).50,51

HDL cholesterol. We identified two good-quality,42,48 six fair-quality,38-40,43,44,46 and one poor-quality50,51 trials published since the prior USPSTF review on the effect of treatment of subclinical hypothyroidism on HDL values (Table 5). In the eight good- and fair-quality trials, differences between treatment and no treatment in mean HDL cholesterol ranged from -4 to 4 mg/dL. None of the trials found a significant difference between treatment and control groups in HDL values. The two good-quality trials (N=40 and 100) reported differences in mean HDL values of -1 mg/dL (p=NS) after 6 months42 and -4 mg/dL (p=NS) after 12 weeks.48

Triglycerides. We identified two good-quality,42,48 six fair-quality,38-40,43,44,46 and one poor-quality50,51 trials on the effect of treatment of subclinical hypothyroidism on triglyceride values (Table 5). In the eight good- and fair-quality trials, differences in means ranged from -32 to 11 mg/dL. None of the trials found a significant difference between treatment and control groups in triglyceride values. The two good-quality trials (N=40 and 100) had differences in mean triglyceride values of 9 mg/dL (p=NS) after 6 months42 and 0 mg/dL (p=NS) after 12 weeks.48

Body mass index or weight. None of the trials included in the previous USPSTF review assessed effects of treatment of subclinical thyroid dysfunction on body mass index or weight.

We identified two good-quality42,48 and four fair-quality39,40,44,46 trials published since the prior USPSTF review on the effect of treatment of subclinical hypothyroidism (TSH thresholds varied from >3.5 to >5, or “greater than the normal range”46) on body mass index or weight (Table 5). Of the five trials reporting body mass index, differences in means between treatment and placebo groups ranged from -1 to 1 kg/m^2^. Of the two trials reporting weight, one found a difference in means of -1 kg,48 and one found a 0.1 difference in the percentage of lean body weight.42 None of the trials found a significant difference between treatment and control groups in body mass index or weight. Of the good-quality trials, one (N=40) reported a difference in mean body mass index of -0.3 kg/m^2^ (p=NS) and a difference in mean percentage of lean body weight of 0.1 after 6 months (p=NS);42 the other (N=100) reported a difference in mean weight of -1 kg after 12 weeks.48

#### Subclinical Hyperthyroidism

We identified two small poor-quality trials (N=14 and 20) on effects of treatment of subclinical hyperthyroidism on blood pressure, body mass index, and bone mineral density (Table 6; Appendixes B1 and B2).52,53 In both studies, treatment was compared with no treatment, and subjects were not blinded to treatment status. One trial included adults (mean age, 57 to 59 years) with mean TSH levels of 0.06 mIU/L who took 10 to 15 mg of methimazole for 12 months.52 The other trial included younger adults (mean age, 34 to 39 years) with mean TSH levels of 0.21 to 0.23 mIU/L who took 150 mg of propylthiouracil or radioactive iodine (one patient) for 6 months.53

Blood pressure. Two small poor-quality trials (N=14 and 20) reported no differences between treatment of subclinical hyperthyroidism and no treatment on either systolic or diastolic blood pressure after 6^53^ and 12^52^ months of followup. Across both trials, differences in means between treatment and placebo groups ranged from -2 to 10 mm Hg for systolic blood pressure and from -3 to 0 mm Hg for diastolic blood pressure (Table 6).

Body mass index. One small poor-quality trial (N=14) found no difference in body mass index between treatment of subclinical hyperthyroidism and no treatment after 12 months.52 The difference in means between treatment and placebo groups in body mass index was 0 kg/m^2^ (Table 6).

Bone mineral density. One small poor-quality trial (N=20) found no difference in femur neck or lumbar vertebral bone mineral density between treatment of subclinical hyperthyroidism and no treatment after 6 months.53 The difference in means between treatment and placebo groups was -0.042 g/cm^2^ for femur neck bone mineral density and 0.03 g/cm^2^ for lumbar vertebra bone mineral density (Table 6).

Lipids. One small poor-quality trial (n=20) found no differences between treatment of subclinical hyperthyroidism and no treatment groups in total, LDL, or HDL cholesterol or triglycerides after 6 months.53 The difference in means between treatment and placebo groups was 26 mg/dL for total cholesterol, 15 mg/dL for LDL cholesterol, 0 mg/dL for HDL cholesterol, and -36 mg/dL for triglycerides (Table 6).

#### Overt Thyroid Disease

No studies examined the effect of treatment of overt thyroid disease on intermediate outcomes. One nonrandomized study (N=67) evaluated effects of treatment of hyperthyroidism on bone mineral density but was excluded because it was published in French.60

## Key Question 4 What Are the Harms of Treatment of Screen-Detected Thyroid Dysfunction?

### Summary

Studies of treatment of subclinical thyroid dysfunction assessed and reported harms poorly, precluding reliable conclusions. In addition, the studies were not designed or powered to assess long-term harms or harms associated with thyroid hormone overreplacement. No studies reported harms of treatment of overt thyroid disease.

### Evidence

#### Subclinical Hypothyroidism

The previous USPSTF report found very limited evidence on harms related to treatment of subclinical hypothyroidism. One good-quality trial of patients who developed subclinical hypothyroidism after treatment of Graves' disease found that four of 17 persons randomized to thyroxine felt worse compared with six of 15 who were given placebo (p=0.33).54 Other studies reported one case of angina,55 one case of atrial fibrillation,55 worsened anxiety scores,42 worsened SF-36 vitality scores,57 and two withdrawals due to adverse events.59

Five trials (in six publications) published since the prior USPSTF review reported harms, but harms were assessed and reported poorly, precluding reliable conclusions (Table 7).37,46-48,50,51 In addition, the studies were not designed or powered to assess long-term or serious harms, or harms related to overtreatment. One study reported “no indication of harms,”37 and another study stated that none of the patients reported side effects that required withdrawal or dose reduction.46 One study reported no difference between treatment and placebo groups in risk for withdrawal due to side effects after 12 months (9.6% vs. 14.3%; p=0.49).47 Two other trials (N=100 and 60) reported none48 or two cases50,51 of withdrawals due to adverse events in patients treated for subclinical hypothyroidism.

#### Subclinical Hyperthyroidism

One study (N=14) of patients with subclinical hyperthyroidism reported no harms with methimazole treatment.52

#### Overt Thyroid Disease

No studies reported harms of treatment of overt thyroid disease.

## Contextual Question 1 Currently, Are Persons With Mild TSH Elevation Being Treated?

One cross-sectional study of 500 patients in Rochester, MN, conducted from 1995 to 1996 found that about 39 percent of patients with a TSH level between 5.1 and 10 mIU/L were treated.61 More recent data indicate that the number of thyroid hormone prescriptions have increased substantially in the United States, from 49.8 million in 2006 to 70.5 million in 2010, although the proportion of patients with mild TSH elevation was not reported.16 Similarly, a recent prospective study of community-dwelling adults older than age 65 years in Toronto, Canada found that the proportion taking thyroid hormone increased from 8.9 to 20 percent from 1989 to 2005.^17^ However, some data suggests that increases in prescribing may be related in part to a lower threshold for treatment over time. One study analyzing TSH levels in the U.K. Clinical Practice Research Database from 2001 and 2009 found that the median TSH level decreased from 8.7 to 7.9 mIU/L, and the adjusted odds for prescribing levothyroxine at TSH levels of less than 10.0 mIU/L was 1.30 (95% CI, 1.19 to 1.42; p<0.001).62

## Contextual Question 2 What Are the Cardiovascular Consequences of Untreated Subclinical Thyroid Dysfunction?

### Subclinical Hypothyroidism

A recent meta-analysis of 11 prospective cohorts (n=55,287) found some evidence of an association between severity of hypothyroidism and risk for cardiovascular events.4 Among patients with TSH values of 4.5 to 6.9, 7.0 to 9.9, and 10 to 19.9 mIU/L, respectively, the HR for a cardiac event was 1.00 (95% CI, 0.86 to 1.18), 1.17 (95% CI, 0.96 to 1.43), and 1.89 (95% CI, 1.28 to 2.80) (p<0.001 for trend). The HR for cardiac mortality was 1.09 (95% CI, 0.91 to 1.30), 1.43 (95% CI, 1.03 to 1.95), and 1.58 (95% CI, 1.10 to 2.27) (p=0.005 for trend). One challenge in interpreting these findings is that the cohort studies included some persons with a prior history of heart disease and may have been subject to residual confounding, despite attempts to control for cardiovascular risk factors. Other systematic reviews were somewhat inconsistent in finding an association between presence of subclinical hypothyroidism and cardiovascular risk, but did not perform analyses stratified by TSH level.28,63 One meta-analysis reported an association between presence of subclinical hypothyroidism and risk for cardiovascular events in younger (age <65 years) adults (relative risk [RR], 1.7 [95% CI, 1.3 to 2.2]) but not in older adults (RR, 1.0 [95% CI, 0.90 to 1.2]).5

Four meta-analyses found no clear association between presence of subclinical hypothyroidism and risk for all-cause mortality.4,5,28,29,63 One other meta-analysis found no association between subclinical hypothyroidism and mortality in community cohorts (HR, 1.03 [95% CI, 0.78 to 1.35]), but increased risk in patients with comorbid conditions (HR, 1.76 [95% CI, 1.36 to 2.30]).29

One meta-analysis of six prospective cohorts in the United States and Europe (n=25,390) found no association between the presence of subclinical hypothyroidism and congestive heart failure after adjustment for age and sex, although heterogeneity was present (HR, 1.26 [95% CI, 0.91 to 1.74]; I^2^=77%).6

### Subclinical Hyperthyroidism

One meta-analysis of 10 prospective cohort studies (median followup, 8.8 years; N=52,674) found that subclinical hyperthyroidism was associated with increased risk for all-cause mortality (HR, 1.24 [95% CI, 1.06 to 1.46]), coronary heart disease mortality (HR, 1.29 [95% CI, 1.02 to 1.62]) and atrial fibrillation (HR, 1.68; 95% CI, 1.16 to 2.43), but not coronary heart disease events (HR, 1.21 [95% CI, 0.99 to 1.46]).7 Persons with a TSH level of less than 0.10 mIU/L were at highest risk. Another, much smaller (N=290) meta-analysis of seven cohorts also found an association between subclinical hyperthyroidism and increased risk for all-cause mortality (HR, 1.41 [95% CI, 1.12 to 1.79]).29 A meta-analysis of six cohort studies (n=25,390) found no association between presence of subclinical hyperthyroidism and risk for congestive heart failure after adjustment for age and sex (HR, 1.46 [95% CI, 0.94 to 2.27]; I^2^=61%).6

Challenges in interpreting these meta-analyses are the inclusion of studies that enrolled persons with known thyroid dysfunction, ischemic heart disease, or a TSH level within the euthyroid reference range, and the failure of some included studies to adequately control for potential confounders such as lipid levels, blood pressure, and thyroid hormone use during the followup period. In addition, none of the studies evaluated whether treatment improved outcomes.

## Contextual Question 3 What Proportion of Patients Screened for Thyroid Dysfunction Have Overt Thyroid Disease?

While no studies directly answered this question, two large population-based cross-sectional studies reported similar findings regarding the prevalence of unrecognized overt thyroid disease. NHANES III found that about 0.8 percent of persons without a history of thyroid dysfunction or thyroid medication use had overt thyroid disease.2 Because NHANES III did not assess for presence of thyroid symptoms, it is not possible to determine what proportion of persons with overt thyroid disease had clinically apparent disease. A second large population-based survey (N=25,862) based in Colorado found that about 0.5 percent of persons had undiagnosed overt thyroid disease.3 This study included a 14-question survey that assessed if symptoms of hypothyroidism were currently present or had changed in the past year.3 Persons with overt and subclinical hypothyroidism reported a greater number of hypothyroid symptoms than those who were euthyroid, although sensitivities (range, 2.9% to 28%) and positive predictive values (range, 8% to 12%) for presence of symptoms and overt hypothyroidism were low.