# METHODS

## Key Questions and Analytic Framework

The analytic framework shown in the Figure was used to guide the literature review. It shows the populations, interventions, intermediate outcomes, and health outcomes examined in the review. The population of interest was asymptomatic adults or adults with mild, nonspecific symptoms (e.g., mild fatigue). We included patients with subclinical thyroid dysfunction as well as patients with overt thyroid disease but without clinically obvious symptoms. Key Questions 1 and 2 address direct evidence on the benefits and harms of screening for hypothyroidism and hyperthyroidism on clinical outcomes. Key Questions 3 and 4 address evidence on the benefits and harms of treating thyroid dysfunction.

Figure Analytic Framework

* Includes cardiovascular disease, coronary artery disease/congestive heart failure, and atrial fibrillation.

Abbreviations: KQ=key question; T3=triiodothyronine; T4=thyroxine; TSH=thyroid-stimulating hormone.

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the populations, subtypes of thyroidism, interventions and related harms, and outcomes. The population includes asymptomatic nonpregnant adults without known thyroid disease. Screening may detect one of the four subtypes of thyroidism: overt hyperthyroidism (low TSH and elevated T4 or T3), overt hypothyroidism (high TSH and low T4), subclinical hyperthyroidism (low TSH and normal T4 and T3), and subclinical hypothyroidism (high TSH and normal T4). Intermediate outcomes after treatment include cholesterol and lipid levels, blood pressure, body mass index and weight change, and bone density. The clinical outcomes include cardiovascular outcomes (that is, cardiovascular disease, coronary artery disease/congestive heart failure, and atrial fibrillation), fractures, and quality of life or cognitive function. Screening and treatment may have resulting harms.

The Key Questions are as follows:

1 Does screening for thyroid dysfunction reduce morbidity or mortality?
2 What are the harms of screening for thyroid dysfunction?
3a Does treatment of screen-detected overt or subclinical thyroid dysfunction improve morbidity or mortality?
3b Does treatment of screen-detected overt or subclinical thyroid dysfunction improve intermediate outcomes?
4 What are the harms of treatment of screen-detected thyroid dysfunction?

In addition, we addressed the following Contextual Questions:

1. Currently, are persons with mild TSH elevation being treated?
2. What are the cardiovascular consequences of untreated subclinical thyroid dysfunction?
3. What proportion of patients screened for thyroid dysfunction have overt thyroid disease?

Contextual Questions address background areas that the USPSTF deemed important for informing its recommendations. Contextual Questions are not reviewed using systematic review methodology, but rather summarize the evidence from key informative studies.

## Search Strategies

A research librarian searched MEDLINE, the Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews from 2002 to mid-July 2014 for subclinical hypothyroidism and subclinical hyperthyroidism and without a prior date limitation for overt thyroid disease, since it was not included in the prior review (Appendix A1). Additional studies were identified from review of reference lists of relevant articles and peer review suggestions.

## Study Selection

Two investigators independently evaluated each study at the title/abstract and full-text article stages to determine eligibility for inclusion (Appendix A2). Following the protocol, we included randomized trials and observational studies of thyroid screening versus no screening in adults (excluding pregnant women) without a history of thyroid dysfunction or obvious goiter, nodules, or symptoms, or treatment versus no treatment in adults with subclinical or overt thyroid dysfunction. Screening was based on TSH testing, with followup testing of thyroid hormone levels (free T4, with or without T3). Studies of patients with subclinical hypothyroidism due to Hashimoto's thyroiditis based on antibody testing were included if they did not describe enrollment of symptomatic patients. Clinical outcomes were cardiovascular end-points (cardiovascular disease, coronary artery disease/congestive heart failure, and atrial fibrillation), fractures, measures of quality of life or cognitive function, and harms, including harms related to overreplacement (such as negative effects on bone mineral density or atrial fibrillation). Intermediate outcomes were effects on lipid levels, blood pressure, weight change, and bone mineral density. We restricted inclusion to English-language articles and excluded studies published only as abstracts. The flow of studies from initial identification of titles and abstracts to final inclusion or exclusion using prespecified criteria is shown in Appendix A3. Excluded studies are listed in Appendix A4.

## Data Abstraction and Quality Rating

One investigator abstracted details about the study design, patient population, setting, screening method, interventions, data analysis, and results, and another investigator verified data abstraction for accuracy. Two investigators independently applied criteria developed by the USPSTF to rate the quality of each study as good, fair, or poor (Appendix A5).35,36 Discrepancies in quality ratings were resolved by discussion and consensus. For all studies, we evaluated applicability to populations likely to be encountered in primary care screening settings.

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question qualitatively as “good,” “fair,” or “poor” using methods developed by the USPSTF, based on aggregate study quality, precision of estimates, consistency of results between studies, and directness of evidence.35,36 Meta-analysis was not performed because of the methodological and clinical diversity among the included studies.

## External Review

An earlier draft of this report was reviewed by external experts not affiliated with the USPSTF (Appendix A6) and revised based on their comments.