# Evidence and Quality Tables

Appendix B1 Evidence Table of Studies of Subclinical Hypothyroidism and Hyperthyroidism

Appendix B2 Quality Assessment of Trials

Appendix B3 Quality Assessment of Cohort Study