# Methods

## Appendix A1 Search Strategies

### Screening

Database: Ovid MEDLINE® and Ovid OLDMEDLINE®

Search Strategy:

1. thyroid diseases/ or hyperthyroidism/ or hypothyroidism/
2. (thyroid and disease$).mp.
3. (hypothyroid$ or hyperthyroid$).mp.
4. or/1-3
5. Mass Screening/
6. 4 and 5
7. Pregnancy/
8. (pediatric$ or newborn or neonat$ or child$ or infan$).mp.
9. 6 not (7 or 8)
10. limit 9 to english language
11. limit 9 to abstracts
12. 10 or 11
13. limit 12 to humans

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. thyroid diseases/ or hyperthyroidism/ or hypothyroidism/
2. (thyroid and disease$).mp.
3. (hypothyroid$ or hyperthyroid$).mp.
4. or/1-3
5. Mass Screening/
6. screen$.mp.
7. 5 or 6
8. 4 and 7

### Treatment

Database: Ovid MEDLINE® and Ovid OLDMEDLINE®

1. Thyroid Diseases/
2. Hyperthyroidism/
3. Hypothyroidism/
4. (hyperthyroid$ or hypothyroid$).ti.
5. (“thyroid deficien*” or “thyroid insufficien*” or “thyroid failure”).mp.
6. or/1-5
7. exp Antithyroid Agents/
8. (anti-thyroid or methimazole or propylthiouracil or radioiodine or “radioactive iodine”).ti,ab.
9. exp Thyronines/
10. exp Thyroxine/
11. (t3 or t4 or thyroxine or levothyroxine or triiodothyronine or liothyronine or thyrolar or liotrix).ti,ab.
12. or/7-11
13. 6 and 12
14. 6 and pc.fs.
15. 6 and dt.fs.
16. 6 and th.fs.
17. or/14-16
18. 13 or 17
19. Pregnancy/
20. (child$ or pediatric$ or infan$ or newborn or neonat$ or toddler).mp.
21. grave's.ti.
22. 18 not (19 or 20 or 21)
23. limit 22 to humans
24. limit 23 to english language
25. limit 23 to abstracts
26. 24 or 25
27. limit 26 to (clinical trial, all or comparative study or controlled clinical trial or meta analysis or randomized controlled trial or systematic reviews)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Thyroid Diseases/
2. Hyperthyroidism/
3. Hypothyroidism/
4. (hyperthyroid$ or hypothyroid$).ti. (413)
5. (“thyroid deficien*” or “thyroid insufficien*” or “thyroid failure”).mp.
6. or/1-5
7. exp Antithyroid Agents/
8. (anti-thyroid or methimazole or propylthiouracil or radioiodine or “radioactive iodine”).ti,ab.
9. exp Thyronines/
10. exp Thyroxine/
11. (t3 or t4 or thyroxine or levothyroxine or triiodothyronine or liothyronine or thyrolar or liotrix).ti,ab.
12. or/7-11
13. 6 and 12
14. 6 and pc.fs.
15. 6 and dt.fs.
16. 6 and th.fs.
17. or/14-16
18. 13 or 17
19. Pregnancy/
20. (child$ or pediatric$ or infan$ or newborn or neonat$ or toddler).mp.
21. grave's.ti.
22. 18 not (19 or 20 or 21)

### All Key Questions

Database: Ovid MEDLINE® Without Revisions

1. Thyroid Diseases/
2. Hyperthyroidism/
3. Hypothyroidism/
4. (hyperthyroid$ or hypothyroid$).ti.
5. (“thyroid deficien*” or “thyroid insufficien*” or “thyroid failure”).mp.
6. or/1-5
7. exp Antithyroid Agents/
8. (anti-thyroid or methimazole or propylthiouracil or radioiodine or “radioactive iodine”).ti,ab.
9. exp Thyronines/
10. exp Thyroxine/
11. (t3 or t4 or thyroxine or levothyroxine or triiodothyronine or liothyronine or thyrolar or liotrix).ti,ab.
12. or/7-11
13. 6 and 12
14. 13 not (pregnan$ or pediatric$ or newborn or neonat$ or child$ or infan$).ti.
15. limit 14 to evidence based medicine reviews

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (thyroid or hypothyroid$ or hyperthyroid$).ti.
2. pregnan$.ti.
3. 1 not 2
4. limit 3 to full systematic reviews

## Appendix A2 Inclusion Criteria

PICOS | Include | Exclude
Populations | - Community-living, nonpregnant adults without a history of thyroid disease or clear symptoms of overt hypothyroidism or hyperthyroidism who were screened or treated for thyroid disease; - Patients with subclinical hypothyroidism in studies that do not clearly describe enrollment of symptomatic patients | - Patients with clinically obvious hypothyroidism or hyperthyroidism (e.g., Graves' disease); - Hospitalized or recently hospitalized participants, as they may have elevated TSH levels
Interventions | KQs 1, 2: Screening KQs 3a, 3b, 4: Treatment of overt thyroid disease, subclinical hypothyroidism, and subclinical hyperthyroidism, including hormone replacement therapy, antithyroid medications (i.e., methimazole), and ablation therapy (i.e., radioactive iodine, surgery)
Comparators | KQ 1: No screening KQs 3a, 3b: No treatment or observation
Outcomes | KQs 1, 3a: Clinical outcomes, including cardiovascular outcomes (cardiovascular disease, coronary artery disease/congestive heart failure, atrial fibrillation), fractures, and measures of quality of life or cognitive function KQ 2: Psychological effects, harms of workup KQ 3b: Intermediate outcomes, including cholesterol/lipid levels, blood pressure, weight change, and bone density KQ 4: Harms of treatment
Settings | Representative of primary care
Study designs | Randomized, controlled trials or controlled observational studies

Abbreviations: KQ=key question; PICOS=Populations, Interventions, Comparators, Outcomes, Settings; TSH=thyroid-stimulating hormone.

## Appendix A3 Literature Flow Diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^b^ Other sources include prior reports, reference lists of relevant articles, and systematic reviews.

^c^ Some studies are included for more than one key question.

This figure is a literature flow diagram depicting the search and selection of studies for the present review. The diagram shows that 2,192 abstracts of potentially relevant articles were identified through MEDLINE and Cochrane databases; 2,049 articles and background papers were excluded; 143 articles were reviewed at the full-text level; and 126 articles were excluded for the following reasons: 22 for wrong population, 3 for wrong intervention, 9 for wrong outcome, 83 for wrong study design for the Key Question, 2 for non-English language, and 7 were systematic reviews that were not directly used. Fourteen unique studies (in 17 publications) were ultimately included in the review. No studies were included for Key Questions 1 or 2. For Key Question 3a, 6 studies on subclinical hypothyroidism were included and no studies on subclinical hyperthyroidism or overt thyroid disease were included. For Key Question 3b, 9 studies (in 11 publications) were included on subclinical hypothyroidism, 2 studies on subclinical hyperthyroidism, and no studies on overt thyroid disease. For Key Question 4, 5 studies were included on subclinical hypothyroidism (in 6 publications), 1 study on subclinical hyperthyroidism, and no studies on overt thyroid disease.

## Appendix A4 Excluded Studies

### Wrong Population

Abraham P, Avenell A, McGeoch SC, et al. Antithyroid drug regimen for treating Graves' hyperthyroidism. Cochrane Database Syst Rev. 2010;(1).
Abraham P, Avenell A, Park CM, et al. A systematic review of drug therapy for Graves' hyperthyroidism. Eur J Endocrinol. 2005;153(4):489-98. [pmid: 16189168].
Adrees M, Gibney J, El-Saeity N, et al. Effects of 18 months of L-T4 replacement in women with subclinical hypothyroidism. Clin Endocrinol. 2009;71(2):298-303.
Benker G, Reinwein D, Kahaly G, et al. Is there a methimazole dose effect on remission rate in Graves' disease? Results from a long-term prospective study. The European Multicentre Trial Group of the Treatment of Hyperthyroidism with Antithyroid Drugs. Clin Endocrinol. 1998;49(4):451-7.
Berg G, Michanek A, Holmberg E, et al. Clinical outcome of radioiodine treatment of hyperthyroidism: a follow-up study. J of Intern Med. 1996;239(2):165-71. [pmid: 8568485].
Bunevicius R, Prange AJ. Selective hormone replacement in hypothyroidism: Maintenance mood. Biol Psychiatry. 1997;42(1):156S.
Bunevicius R, Prange AJ Jr. Mental improvement after replacement therapy with thyroxine plus triiodothyronine: Relationship to cause of hypothyroidism. Int J Neuropsychopharmacol. 2000;3(2):167-74. [pmid: 11343593].
Dullaart RP, van Doormaal JJ, Hoogenberg K, et al. Triiodothyronine rapidly lowers plasma lipoprotein (a) in hypothyroid subjects. Neth J Med. 1995;46(4):179-84. [pmid: 7760967].
Faber J, Jensen IW, Petersen L, et al. Normalization of serum thyrotrophin by means of radioiodine treatment in subclinical hyperthyroidism: effect on bone loss in postmenopausal women. Clin Endocrinol. 1998;48(3):285-90.
Franklyn JA, Daykin J, Betteridge J, et al. Thyroxine replacement therapy and circulating lipid concentrations. Clin Endocrinol. 1993;38(5):453-9.
Girard A, Hugues FC, Le Jeunne C, et al. Short-term variability of blood pressure and heart rate in hyperthyroidism. Clin Auton Res. 1998;8(3):181-6. [pmid: 9651668].
Heemstra KA, Smit JW, Eustatia-Rutten CF, et al. Glucose tolerance and lipid profile in longterm exogenous subclinical hyperthyroidism and the effects of restoration of euthyroidism, a randomised controlled trial. Clin Endocrinol. 2006;65(6):737-44.
Ito M, Takamatsu J, Sasaki I, et al. Disturbed metabolism of remnant lipoproteins in patients with subclinical hypothyroidism. Am J Med. 2004;117(9):696-9. [pmid: 15501208].
Meier C, Beat M, Guglielmetti M, et al. Restoration of euthyroidism accelerates bone turnover in patients with subclinical hypothyroidism: a randomized controlled trial. Osteoporos Int. 2004;15(3):209-16. [pmid: 14727010].
Miura S, Iitaka M, Yoshimura H, et al. Disturbed lipid metabolism in patients with subclinical hypothyroidism: effect of L-thyroxine therapy. Intern Med. 1994;33(7):413-7. [pmid: 7949641].
Petersen K, Bengtsson C, Lapidus L, et al. Morbidity, mortality, and quality of life for patients treated with levothyroxine. Arch Intern Med. 1990;150(10):2077-81. [pmid: 2222093].
Prasch F, Wogritsch S, Hurtl I, et al. Severe short-term hypothyroidism is not associated with an increased incidence of myocardial ischemia as assessed by thallium-201 stress/rest myocardial scintigraphy. Thyroid. 1999;9(2):155-8. [pmid: 10090315].
Ravanbod M, Asadipooya K, Kalantarhormozi M, et al. Treatment of iron-deficiency anemia in patients with subclinical hypothyroidism. Am J Med. 2013;126(5):420-4. [pmid: 23582934].
Reuters VS, Almeida CdP, Teixeira PdFdS, et al. Effects of subclinical hypothyroidism treatment on psychiatric symptoms, muscular complaints, and quality of life. Arq Bras Endocrinol Metabol. 2012;56(2):128-36. [pmid: 22584566].
Ross DS, Neer RM, Ridgway EC, et al. Subclinical hyperthyroidism and reduced bone density as a possible result of prolonged suppression of the pituitary-thyroid axis with L-thyroxine. Am J Med. 1987;82(6):1167-70. [pmid: 3605133].
Toh SH, Brown PH. Bone mineral content in hypothyroid male patients with hormone replacement: a 3-year study. J Bone Miner Res. 1990;5(5):463-7. [pmid: 2195844].

### Wrong Intervention

Boekholdt SM, Titan SM, Wiersinga WM, et al. Initial thyroid status and cardiovascular risk factors: the EPIC-Norfolk prospective population study. Clin Endocrinol. 2010;72(3):404-10.
Grozinsky-Glasberg S, Fraser A, Nahshoni E, et al. Thyroxine-triiodothyronine combination therapy versus thyroxine monotherapy for clinical hypothyroidism: meta-analysis of randomized controlled trials. J Clin Endocrinol Metab. 2006;91(7):2592-9. [pmid: 16670166].
Littley MD, Kingswood JC, John R, et al. Effect of nadolol on plasma lipids in hyperthyroidism. Horm Metab Res. 1989;21(6):331-3. [pmid: 2777191].

### Wrong Outcome

Biondi B, Fazio S, Palmieri EA, et al. Left ventricular diastolic dysfunction in patients with subclinical hypothyroidism. J Clin Endocrinol Metab. 1999;84(6):2064-7. [pmid: 10372711].
Biondi B, Fazio S, Palmieri EA, et al. Effects of chronic subclinical hyperthyroidism from levothyroxine on cardiac morphology and function. Cardiologia. 1999;44(5):443-9. [pmid: 10389349].
Dagre AG, Lekakis JP, Papaioannou TG, et al. Arterial stiffness is increased in subjects with hypothyroidism. Int J Cardiol. 2005;103(1):1-6. [pmid: 16061115].
Gam AN, Jensen GF, Hasselstrom K, et al. Effect of thyroxine therapy on bone metabolism in substituted hypothyroid patients with normal or suppressed levels of TSH. J Endocrinol Invest. 1991;14(6):451-5. [pmid: 1774441].
Guang-da X, Hong-yan C, Xian-mei Z. Changes in endothelium-dependent arterial dilation before and after subtotal thyroidectomy in subjects with hyperthyroidism. Clin Endocrinol. 2004;61(3):400-4.
Jensovsky J, Ruzicka E, Spackova N, et al. Changes of event related potential and cognitive processes in patients with subclinical hypothyroidism after thyroxine treatment. Endocr Reg. 2002;36(3):115-22.
Monzani F, Di Bello V, Caraccio N, et al. Effect of levothyroxine on cardiac function and structure in subclinical hypothyroidism: a double blind, placebo-controlled study. J Clin Endocrinol Metab. 2001;86(3):1110-1115. [pmid: 11238494].
Runeberg L, Kreus KE. Effect of lb 46, a new beta-adrenergic antagonist, in hyperthyroidism. Heart rate and blood pressure at rest and during exercise. Acta Med Scand. 1971;189(5):423-6. [pmid: 4397076].
Sisson JC, Schipper MJ, Nelson CC, et al. Radioiodine therapy and Graves' ophthalmopathy. J Nucl Med. 2008;49(6):923-30. [pmid: 18483104].
Yazici M, Gorgulu S, Sertbas Y, et al. Effects of thyroxin therapy on cardiac function in patients with subclinical hypothyroidism: index of myocardial performance in the evaluation of left ventricular function. Int J Cardiol. 2004;95(2-3):135-43. [pmid: 15193811].

### Wrong Study Design for Key Question

Azizi F, Ataie L, Hedayati M, et al. Effect of long-term continuous methimazole treatment of hyperthyroidism: comparison with radioiodine. Eur J Endocrinol. 2005;152(5):695-701. [pmid: 15879354].
Azizi F, Yousefi V, Bahrainian A, et al. Long-term continuous methimazole or radioiodine treatment for hyperthyroidism. Archof Iran Med. 2012;15(8):477-84.
Bahemuka M, Hodkinson HM. Screening for hypothyroidism in elderly inpatients. Br Med J. 1975;2(5971):601-3. [pmid: 1131632].
Bal CS, Kumar A, Chandra P. Effect of iopanoic acid on radioiodine therapy of hyperthyroidism: long-term outcome of a randomized controlled trial. J Clin Endocrinol Metab. 2005;90(12):6536-40. [pmid: 16189259].
Baldini M, Colasanti A, Orsatti A, et al. Neuropsychological functions and metabolic aspects in subclinical hypothyroidism: the effects of L-thyroxine. Prog Neuropsychopharmacol Biol Psychiatry. 2009;33(5):854-9. [pmid: 19389454].
Baqi L, Payer J, Killinger Z, et al. Thyrotropin versus thyroid hormone in regulating bone density and turnover in premenopausal women. Endocr Reg. 2010;44(2):57-63.
Blair ALT, Lowe DC, Hadden DR, et al. Long term follow up of patients treated for hyperthyroidism with low dose radioactive iodine. Ulster Med J. 1980;49(1):71-8. [pmid: 7394928].
Boelaert K, Syed AA, Manji N, et al. Prediction of cure and risk of hypothyroidism in patients receiving 131I for hyperthyroidism. Clin Endocrinol. 2009;70(1):129-38.
Boeving A, Paz-Filho G, Radominski RB, et al. Low-normal or high-normal thyrotropin target levelsduring treatment of hypothyroidism: a prospective, comparative study. Thyroid. 2011;21(4):355-60. [pmid: 21323599].
Brenta G, Mutti LA, Schnitman M, et al. Assessment of left ventricular diastolic function by radionuclide ventriculography at rest and exercise in subclinical hypothyroidism, and its response to L-thyroxine therapy. Am J Cardiol. 2003;91(11):1327-30. [pmid: 12767425].
Bunevicius R, Kazanavicius G, Zalinkevicius R, et al. Effects of thyroxine as compared with thyroxine plus triiodothyronine in patients with hypothyroidism. N Engl J Med. 1999;340(6):424-9. [pmid: 9971866].
Cakal E, Turgut AT, Demirbas B, et al. Effects of L-thyroxine replacement therapy on carotid intima-media thickness in patients with primary hypothyroidism. Exp Clin Endocrinol Diabetes. 2009;117(6):294-300. [pmid: 19085705].
Canaris GJ, Tape TG, Wigton RS. Thyroid disease awareness is associated with high rates of identifying subjects with previously undiagnosed thyroid dysfunction. BMC Public Health. 2013;13:351-7. [pmid: 23590562].
Caraccio N, Natali A, Sironi A, et al. Muscle metabolism and exercise tolerance in subclinical hypothyroidism: a controlled trial of levothyroxine. J Clin Endocrinol Metab. Jul. 2005;90(7):4057-62. [pmid: 15855263].
Celi FS, Zemskova M, Linderman JD, et al. Metabolic effects of liothyronine therapy in hypothyroidism: a randomized, double-blind, crossover trial of liothyronine versus levothyroxine. J Clin Endocrinol Metab. 2011;96(11):3466-74. [pmid: 21865366].
Chadarevian R, Jublanc C, Bruckert E, et al. Effect of levothyroxine replacement therapy on coagulation and fibrinolysis in severe hypothyroidism. J Endocrinol Invest. 2005;28(5):398-404. [pmid: 16075920].
Clyde PW, Harari AE, Getka EJ, et al. Combined levothyroxine plus liothyronine compared with levothyroxine alone in primary hypothyroidism: a randomized controlled trial. JAMA. 2003;290(22):2952-8. [pmid: 14665656].
Collet TH, Gussekloo J, Bauer DC, et al. Subclinical hyperthyroidism and the risk of coronary heart disease and mortality. Arch Intern Med. 2012;172(10):799-809. [pmid: 22529182].
Cornelli U, Belcaro G, Ledda A, et al. Oxidative stress following administration of levothyroxine in subjects suffering from primary hypothyroidism. Panminerva Medica. 2011;53(3 Suppl 1):95-8. [pmid: 22108484].
Correia N, Mullally S, Cooke G, et al. Evidence for a specific defect in hippocampal memory in overt and subclinical hypothyroidism. J Clin Endocrinol Metab. 2009;94(10):3789-97. [pmid: 19584178].
Danese MD, Powe NR, Sawin CT, et al. Screening for mild thyroid failure at the periodic health examination: a decision and cost-effectiveness analysis. JAMA. 1996;276(4):285-92. [pmid: 8656540].
D'Angelo R, Fogato E, Balzaretti M, et al. Screening for hypothyroidism in institutionalized elderly people with cognitive and functional impairment. J Endocrinol Invest. 1999;22(10 Suppl):42. [pmid: 10727037].
den Elzen WPJ, Smit JWA, Mooijaart SP, et al. Should subclinical hypothyroidism in older persons be treated?. Ned Tijdschr Geneeskd. 2012;156(49):A5094. [pmid: 23218030].
Donangelo I, Braunstein GD. Update on subclinical hyperthyroidism. Am Fam Physician. 2011;83(8):933-8. [pmid: 21524033].
Duman D, Demirtunc R, Sahin S, et al. The effects of simvastatin and levothyroxine on intima-media thickness of the carotid artery in female normolipemic patients with subclinical hypothyroidism: a prospective, randomized-controlled study. J Cardiovasc Med. 2007;8(12):1007-11.
Eden S, Sundbeck G, Lindstedt G, et al. Screening for thyroid disease in the elderly. Serum concentrations of thyrotropin and 3,5,3′-triiodothyronine in a representative population of 79-year-old women and men. Compr Gerontol A. 1988;2(1):40-5. [pmid: 3197053].
Escobar-Morreale HF, Botella-Carretero JI, Escobar del Rey F, et al. REVIEW: Treatment of hypothyroidism with combinations of levothyroxine plus liothyronine. J Clin Endocrinol Metab. 2005;90(8):4946-54. [pmid: 15928247].
Escobar-Morreale HF, Botella-Carretero JI, Gomez-Bueno M, et al. Thyroid hormone replacement therapy in primary hypothyroidism: a randomized trial comparing L-thyroxine plus liothyronine with L-thyroxine alone. Ann Intern Med. 2005;142(6):412-24. [pmid: 15767619].
Fadeyev VV, Morgunova TB, Melnichenko GA, et al. Combined therapy with L-thyroxine and L-triiodothyronine compared to L-thyroxine alone in the treatment of primary hypothyroidism. Hormones. 2010;9(3):245-52. [pmid: 20688622].
Flynn RW, Bonellie SR, Jung RT, et al. Serum thyroid-stimulating hormone concentration and morbidity from cardiovascular disease and fractures in patients on long-term thyroxine therapy. J Clin Endocrinol Metab. 2010;95(1):186-93. [pmid: 19906785].
Fowler PB, McIvor J, Sykes L, et al. The effect of long-term thyroxine on bone mineral density and serum cholesterol. J R Coll Physicians Lond. 1996;30(6):527-32. [pmid: 8961207].
Franklyn JA, Maisonneuve P, Sheppard MC, et al. Mortality after the treatment of hyperthyroidism with radioactive iodine. N Eng J Med. 1998;338(11):712-8.
Fraser S, Smith DA, Anderson JB, et al. Osteoporosis and fractures following thyrotoxicosis. Lancet. 1971;297(7707):981-3. [pmid: 4102450].
Gencer B, Collet TH, Virgini V, et al. Subclinical thyroid dysfunction and the risk of heart failure events: an individual participant data analysis from 6 prospective cohorts. Circulation. 2012;126(9):1040-9. [pmid: 22821943].
Gorman CA, Jiang NS, Ellefson RD, et al. Comparative effectiveness of dextrothyroxine and levothyroxine in correcting hypothyroidism and lowering blood lipid levels in hypothyroid patients. J Clin Endocrinol Metab. 1979;49(1):1-7. [pmid: 447807].
Grant DJ, McMurdo ME, Mole PA, et al. Suppressed TSH levels secondary to thyroxine replacement therapy are not associated with osteoporosis. Clin Endocrinol. 1993;39(5):529-33.
Gurlek A, Gedik O. Effect of endogenous subclinical hyperthyroidism on bone metabolism and bone mineral density in premenopausal women. Thyroid. 1999;9(6):539-43. [pmid: 10411115].
Hall P, Lundell G, Holm LE. Mortality in patients treated for hyperthyroidism with iodine-131. Acta Endocrinol. 1993;128(3):230-4. [pmid: 8480472].
Hamano K, Inoue M. Increased risk for atherosclerosis estimated by pulse wave velocity in hypothyroidism and its reversal with appropriate thyroxine treatment. Endocr J. 2005;52(1):95-101. [pmid: 15758564].
Hanna FW, Pettit RJ, Ammari F, et al. Effect of replacement doses of thyroxine on bone mineral density. Clin Endocrinol. 1998;48(2):229-34.
Hershman JM, Givens JR, Cassidy CE, et al. Long-term outcome of hyperthyroidism treated with antithyroid drugs. J Clin Endocrinol Metab. 1966;26(8):803-7. [pmid: 4162249].
Hoang TD, Olsen CH, Mai VQ, et al. Desiccated thyroid extract compared with levothyroxine in the treatment of hypothyroidism: A randomized, double-blind, crossover study. J Clin Endocrinol Metab. 2013;98(5):1982-90. [pmid: 23539727].
Hoppichler F, Sandholzer C, Moncayo R, et al. Thyroid hormone (fT4) reduces lipoprotein(a) plasma levels. Atherosclerosis. 1995;115(1):65-71. [pmid: 7669088].
Ito K, Nishikawa Y, Harada T, et al. A comparative evaluation of the treatment of hyperthyroidism. Endocrinol Jpn. 1974;21(2):131-9. [pmid: 4136484].
Jancar J. Thyroxine, osteoporosis and fractures in the mentally handicapped. West Engl Med J. 1990;105(1):25. [pmid: 2364023].
Jansson S, Berg G, Lindstedt G, et al. Overweight--a common problem among women treated for hyperthyroidism. Postgrad Med J. 1993;69(808):107-11. [pmid: 8506188].
Jodar E, Munoz-Torres M, Escobar-Jimenez F, et al. Bone loss in hyperthyroid patients and in former hyperthyroid patients controlled on medical therapy: influence of aetiology and menopause. Clin Endocrinol. 1997;47(3):279-85.
Joffe RT, Brimacombe M, Levitt AJ, et al. Treatment of clinical hypothyroidism with thyroxine and triiodothyronine: a literature review and metaanalysis. Psychosomatics. 2007;48(5):379-84. [pmid: 17878495].
Joffe RT, Sawka AM, Marriott MJ, et al. Does substitution of T4 with T3 plus T4 for T4 replacement improve depressive symptoms in patients with hypothyroidism?. Ann N Y Acad Sci. 2004;1032:287-8. [pmid: 15677430].
Kuusi T, Taskinen MR, Nikkila EA. Lipoproteins, lipolytic enzymes, and hormonal status in hypothyroid women at different levels of substitution. J Clin Endocrinol Metab. 1988;66(1):51-6. [pmid: 3335609].
Leese GP, Jung RT, Guthrie C, et al. Morbidity in patients on L-thyroxine: a comparison of those with a normal TSH to those with a suppressed TSH. Clin Endocrinol. 1992;37(6):500-3.
Loor M, Giet D. Subclinical primary hypothyroidism in family practice. Rev Med Liege. 2008;63(10):600-8. [pmid: 19009968].
Lupoli G, Nuzzo V, Di Carlo C, et al. Effects of alendronate on bone loss in pre- and postmenopausal hyperthyroid women treated with methimazole. Gynecol Endocrinol. 1996;10(5):343-8. [pmid: 8915664].
Miller KJ, Parsons TD, Whybrow PC, et al. Memory improvement with treatment of hypothyroidism. Int J Neurosci. 2006;116(8):895-906. [pmid: 16861154].
Mitchell WD. A comparison of the effect of clofibrate and thyroxine on serum lipids in three hypothyroid subjects. Clin Chim Acta. 1971;35(2):429-32. [pmid: 4108162].
Muls E, Blaton V, Rosseneu M, et al. Serum lipids and apolipoproteins A-I, A-II, and B in hyperthyroidism before and after treatment. J Clin Endocrinol Metab. 1982;55(3):459-64. [pmid: 6808006].
Nagasaki T, Inaba M, Kumeda Y, et al. Decrease of arterial stiffness at common carotid artery in hypothyroid patients by normalization of thyroid function. Biomed Parmacother. 2005;59(1-2):8-14.
Nygaard B, Jensen EW, Kvetny J, et al. Effect of combination therapy with thyroxine (T4) and 3,5,3′-triiodothyronine versus T4 monotherapy in patients with hypothyroidism, a double-blind, randomised cross-over study. Eur J Endocrinol. 2009;161(6):895-902. [pmid: 19666698].
Oge A, Sozmen E, Karaoglu AO. Effect of thyroid function on LDL oxidation in hypothyroidism and hyperthyroidism. Endocr Res. 2004;30(3):481-9. [pmid: 15554363].
Oikawa M, Kushida K, Takahashi M, et al. Bone turnover and cortical bone mineral density in the distal radius in patients with hyperthyroidism being treated with antithyroid drugs for various periods of time. Clin Endocrinol. 1999;50(2):171-6.
Osman F, Franklyn JA, Holder RL, et al. Cardiovascular manifestations of hyperthyroidism before and after antithyroid therapy: a matched case-control study. J Am Coll Cardiol. 2007;49(1):71-81. [pmid: 17207725].
Panicker V, Evans J, Bjoro T, et al. A paradoxical difference in relationship between anxiety, depression and thyroid function in subjects on and not on T4: findings from the HUNT study. Clin Endocrinol. 2009;71(4):574-80.
Paoli M, Bellabarba G, Velazquez E, et al. Sex steroids, lipids, and lipoprotein cholesterols in women with subclinical and overt hypothyroidism before and after L-thyroxine therapy. Clin Chim Acta. 1998;275(1):81-91. [pmid: 9706846].
Perk M, O'Neill BJ. The effect of thyroid hormone therapy on angiographic coronary artery disease progression. Can J Cardiol. 1997;13(3):273-6. [pmid: 9117915].
Pimstone B, Joffe B, Pimstone N, et al. Clinical response to long-term propranolol therapy in hyperthyroidism. S Afr Med J. 1969;43(39):1203-5. [pmid: 4901143].
Rodondi N, Aujesky D, Vittinghoff E, et al. Subclinical hypothyroidism and the risk of coronary heart disease: a meta-analysis. Am J Med. 2006;119(7):541-51. [pmid: 16828622].
Rodondi N, den Elzen WPJ, Bauer DC, et al. Subclinical hypothyroidism and the risk of coronary heart disease and mortality. JAMA. 2010;304(12):1365-74. [pmid: 20858880].
Rodondi N, Newman AB, Vittinghoff E, et al. Subclinical hypothyroidism and the risk of heart failure, other cardiovascular events, and death. Arch Intern Med. 2005;165(21):2460-6. [pmid: 16314541].
Safi S, Hassikou H, Hadri L, et al. Evaluation of bone mineral density in hyperthyroid patients before and after medical therapy. Ann Endocrinol. 2006;67(1):27-31.
Saravanan P, Simmons DJ, Greenwood R, et al. Partial substitution of thyroxine (T4) with tri-iodothyronine in patients on T4 replacement therapy: results of a large community-based randomized controlled trial. J Clin Endocrinol Metab. 2005;90(2):805-12. [pmid: 15585551].
Saravanan P, Visser TJ, Dayan CM. Psychological well-being correlates with free thyroxine but not free 3,5,3′-triiodothyronine levels in patients on thyroid hormone replacement. J Clin Endocrinol Metab. 2006;91(9):3389-93. [pmid: 16804044].
Sawka AM, Gerstein HC, Marriott MJ, et al. Does a combination regimen of thyroxine (T4) and 3,5,3′-triiodothyronine improve depressive symptoms better than T4 alone in patients with hypothyroidism? Results of a double-blind, randomized, controlled trial. J Clin Endocrinol Metab. 2003;88(10):4551-5. [pmid: 14557420].
Serter R, Demirbas B, Korukluoglu B, et al. The effect of L-thyroxine replacement therapy on lipid based cardiovascular risk in subclinical hypothyroidism. J Endocrinol Invest. 2004;27(10):897-903. [pmid: 15762035].
Slawik M, Klawitter B, Meiser E, et al. Thyroid hormone replacement for central hypothyroidism: a randomized controlled trial comparing two doses of thyroxine (T4) with a combination of T4 and triiodothyronine. J Clin Endocrinol Metab. 2007;92(11):4115-22. [pmid: 17711927].
Toft AD. Is long-term methimazole therapy as effective as radioiodine for treating hyperthyroidism?. Nat Clin Pract Endocrinol Metab. 2005;1(1):14-5. [pmid: 16929359].
Valizadeh M, Seyyed-Majidi MR, Hajibeigloo H, et al. Efficacy of combined levothyroxine and liothyronine as compared with levothyroxine monotherapy in primary hypothyroidism: a randomized controlled trial. Endocr Res. 2009;34(3):80-9. [pmid: 19701833].
Vigario PdS, Vaisman F, Coeli CM, et al. Inadequate levothyroxine replacement for primary hypothyroidism is associated with poor health-related quality of life-a Brazilian multicentre study. Endocrine. 2013;44(2):434-40. [pmid: 23371817].
Wakasugi M, Wakao R, Tawata M, et al. Change in bone mineral density in patients with hyperthyroidism after attainment of euthyroidism by dual energy X-ray absorptiometry. Thyroid. 1994;4(2):179-82. [pmid: 7920000].
Wakasugi M, Wakao R, Tawata M, et al. Bone mineral density in patients with hyperthyroidism measured by dual energy X-ray absorptiometry. Clin Endocrinol. 1993;38(3):283-6.
Walsh JP, Bremner AP, Bulsara MK, et al. Subclinical thyroid dysfunction as a risk factor for cardiovascular disease. Arch Intern Med. 2005;165(21):2467-72. [pmid: 16314542].
Walsh JP, Shiels L, Lim EM, et al. Combined thyroxine/liothyronine treatment does not improve well-being, quality of life, or cognitive function compared to thyroxine alone: a randomized controlled trial in patients with primary hypothyroidism. J Clin Endocrinol Metab. 2003;88(10):4543-50. [pmid: 14557419].
Walsh JP, Ward LC, Burke V, et al. Small changes in thyroxine dosage do not produce measurable changes in hypothyroid symptoms, well-being, or quality of life: results of a double-blind, randomized clinical trial. J Clin Endocrinol Metab. 2006;91(7):2624-30. [pmid: 16670161].
Xiang Gd, He YS, Zhao LS, et al. Impairment of endothelium-dependent arterial dilation in Hashimoto's thyroiditis patients with euthyroidism. Clin Endocrinol. 2006;64(6):698-702.

### Non-English Language, Potentially Relevant

Eiling R, Wieland V, Niestroj M. Improvement of symptoms in mild hyperthyroidism with an extract of lycopus europaeus (thyreogutt mono). Wien Med Wochenschr. 2013;163(3-4):95-101. [pmid: 23247973].
Nekrasova TA, Strongin LG, Ledentsova OV. hematological disturbances in subclinical hypothyroidism and their dynamics during substitution therapy. Klinicheskaia meditsina. 2013;91(9):29-33. [pmid: 24437152].

### Systematic Review, Not Directly Used

Danese MD, Ladenson PW, Meinert CL, et al. Clinical review 115: Effect of thyroxine therapy on serum lipoproteins in patients with mild thyroid failure: a quantitative review of the literature. J Clin Endocrinol Metab. 2000;85(9):2993-3001. [pmid: 10999775].
Faber J, Galloe AM. Changes in bone mass during prolonged subclinical hyperthyroidism due to L-thyroxine treatment: a meta-analysis. Eur J Endocrinol. 1994;130(4):350-6. [pmid: 8162163].
Schneider R, Reiners C. The effect of levothyroxine therapy on bone mineral density: a systematic review of the literature. Exp Clin Endocrinol Diabetes. 2003;111(8):455-70. [pmid: 14714266].
Singh S, Duggal J, Molnar J, et al. Impact of subclinical thyroid disorders on coronary heart disease, cardiovascular and all-cause mortality: a meta-analysis. Int J Cardiol. 2008;125(1):41-8. [pmid: 17434631].
Vestergaard P, Mosekilde L. Hyperthyroidism, bone mineral, and fracture risk--a meta-analysis. Thyroid. 2003;13(6):585-93. [pmid: 12930603].
Villar CH, Saconato H, Valente O, et al. Thyroid hormone replacement for subclinical hypothyroidism. Cochrane Database Syst Rev. 2009;(4).
Villar HCCE, Saconato H, Valente O, et al. Thyroid hormone replacement for subclinical hypothyroidism. Cochrane Database Syst Rev. 2007;(3).

## Appendix A5 USPSTF Task Force Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The USPSTF Methods Workgroup developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria, and the associated definitions of quality categories, that relate to internal validity at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a good-quality study is one that meets all criteria well. A fair-quality study is one that does not meet (or it is not clear that it meets) at least one criterion, but has no known “fatal flaw.” Poor-quality studies have at least one fatal flaw.

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

Initial assembly of comparable groups:

- For randomized, controlled trials (RCTs): adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
- For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.

Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination).

Important differential loss to followup or overall high loss to followup.

Measurements are equal, reliable, and valid (includes masking of outcome assessment).

Clear definition of interventions.

All important outcomes considered.

Analysis includes adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and there is appropriate attention to confounders in analysis. In addition, for RCTs, intention-to-treat analysis is used.

Fair: Any or all of the following problems occur, without the fatal flaws noted below: generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is done for RCTs.

Poor: Any of the following fatal flaws exists: groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention-to-treat analysis is lacking.

### Case-Control Studies

#### Criteria

Accurate ascertainment of cases.

Nonbiased selection of cases/controls with exclusion criteria applied equally to both.

Response rate provided.

Diagnostic testing procedures applied equally to each group.

Measurement of exposure accurate and applied equally to each group.

Appropriate attention to potential confounding variables.

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements are accurate and applied equally to cases and controls; and there is appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic workup bias, but response rate is less than 80 percent or there is attention to some but not all important confounding variables.

Poor: Major selection or diagnostic workup biases, response rate less than 50 percent, or inattention to confounding variables.

### Systematic Reviews

#### Criteria

Comprehensiveness of sources considered/search strategy used.

Standard appraisal of included studies.

Validity of conclusions.

Recency and relevance are especially important for systematic reviews.

#### Definition of ratings from above criteria

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

## Appendix A6 Reviewers of the Draft Report

- Douglas Bauer, MD, Professor of Medicine and Epidemiology and Biostatistics, University of California, San Francisco
- Joseph Chin, MD, MSc, Medical Officer, Centers for Medicare & Medicaid Services
- Hossein Gharib, MD, MACP, MACE, Professor of Medicine, Mayo Clinic College of Medicine
- Valerie J. King, MD, MPH, Associate Professor, Oregon Health and Science University
- Linda Kinsinger, MD, MPH, Chief Consultant for Preventive Medicine, Office of Patient Care Services, Veterans Health Administration
- Martin Surks, MD, MACP, Professor of Medicine and Pathology, Montefiore Medical Center and the Albert Einstein College of Medicine