# References

1 Norris SL, Kansagara D, Bougatsos C, et al. Screening for Type 2 Diabetes: Update of 2003 Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 61. AHRQ Publication No. 08-05116-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. June. 2008. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/type2/type2es.pdf. 20 August 2014.
2 Norris SL, Kansagara D, Bougatsos C, et al. Screening adults for type 2 diabetes: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2008;148(11):855-68. [pmid: 18519931].
3 U.S. Preventive Services Task Force. Screening for type 2 diabetes mellitus in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;148(11):846-54. [pmid: 18519930].
4 Diabetes Prevention Program Research Group, Knowler WC, Barrett-Connor E, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527].
5 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67(2):152-62. [pmid: 15649575].
6 Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343-50. [pmid: 11333990].
7 Ramachandran A, Snehalatha C, Mary S, et al. The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006;49(2):289-97. [pmid: 16391903].
8 Watanabe M, Yamaoka K, Yokotsuka M, et al. Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. 2003;26(12):3209-14. [pmid: 14633803].
9 Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24(4):619-24. [pmid: 11315819].
10 Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20(4):537-44. [pmid: 9096977].
11 Dyson PA, Hanmmersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997;46(12 Suppl 1):50-5. [pmid: 9439560].
12 STOP-NIDDM Trial Research Group, Chiasson JL, Josse RG, et al. Acarbose for the prevention of type 2 diabettes mellitus: the STOP-NIDDM randomised trial. Lancet. 2002;359(9323):2072-7. [pmid: 12086760].
13 Diabetes Prevention Program Research Group, Ratner R, Goldberg R, et al. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the Diabetes Prevention Program. Diabetes Care. 2005;28(4):888-94. [pmid: 15793191].
14 DREAM Trial Investigators, Bosch J, Yusuf S, et al. Effect of ramipril on the incidence of diabetes. N Engl J Med. 2006;355(15):1551-62. [pmid: 16980380].
15 DREAM Trial Investigators, Gerstein HC, Yusuf S, et al. Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomised controlled trial. Lancet. 2006;368(9541):1096-105. [pmid: 16997664].
16 American Diabetes Association. Standards of medical care in diabetes - 2015. Diabetes Care. 2014;38(Suppl 1):S1-90.
17 Centers for Disease Control and Prevention. 2014 National Diabetes Statistics Report. 2014. Atlanta, GA. Accessed at http://www.cdc.gov/diabetes/pubs/factsheet11.htm. 20 August 2014.
18 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2012;35:S64-S71. [pmid: 22187472].
19 Centers for Disease Control and Prevention. Diagnosed Diabetes by Race/Ethnicity, Sex, and Age. 2010. Accessed at http://www.cdc.gov/diabetes/statistics/prev/national/menuage.htm. 20 August 2014.
20 Schiller JS, Lucas JW, Ward BW, et al. Summary Health Statistics for U.S. Adults: National Health Interview Survey, 2010. National Center for Health Statistics. Vital Health Stat. 2012;10(252). Accessed at http://www.cdc.gov/nchs/data/series/sr_10/sr10_252.pdf. 30 January 2013.
21 Centers for Disease Control and Prevention. Increasing prevalence of diagnosed diabetes--United States and Puerto Rico, 1995-2010. MMWR Morb Mortal Wkly Rep. 2012;61(45):918-21. [pmid: 23151951].
22 Centers for Disease Control and Prevention. Age-Adjusted Incidence of End-Stage Renal Disease Related to Diabetes Mellitus (ESRD-DM) Per 100,000 Diabetic Population, by Race, Ethnicity, and Sex, United States, 1980-2008. Accessed at http://www.cdc.gov/diabetes/statistics/esrd/fig5.htm. 30 January 2013.
23 Centers for Disease Control and Prevention. Age-Adjusted Hospital Discharge Rates for Nontraumatic Lower Extremity Amputation Per 1,000 Diabetic Population, by Race, United States, 1988-2009. Accessed at http://www.cdc.gov/diabetes/statistics/lea/fig6.htm. 30 January 2013.
24 Centers for Disease Control and Prevention. Age-Adjusted Percentage of People With Diabetes Aged 35 Years or Older Reporting Heart Disease or Stroke, by Race/Ethnicity, United States, 1997-2011. Accessed at http://www.cdc.gov/diabetes/statistics/cvd/fig6.htm. 30 January 2013.
25 Kochanek KD, Xu J, Murphy SL, et al. Deaths: final data for 2009. Natl Vital Stat Rep. 2011;60(3).
26 Harris MI, Eastman RC. Early detection of undiagnosed diabetes mellitus: a US perspective. Diabetes Metab Res Rev. 2000;16(4):230-6. [pmid: 10934451].
27 Harris MI, Klein R, Welborn TA, et al. Onset of NIDDM occurs at least 4-7 yr before clinical diagnosis. Diabetes Care. 1992;15(7):815-9. [pmid: 1516497].
28 Crawford AG, Cote C, Couto J, et al. Prevalence of obesity, type II diabetes mellitus, hyperlipidemia and hypertension in the United States: findings from the GE Centricity Electronic Medical Record Database. Popul Health Manag. 2010;13(3):151-61. [pmid: 20521902].
29 Whincup PH, Kaye SJ, Owen CG, et al. Birth weight and risk of type 2 diabetes: a systematic review. JAMA. 2008;300(24):2886-97. [pmid: 19109117].
30 Harder T, Rodekamp E, Schellong K, et al. Birth weight and subsequent risk of type 2 diabetes: a meta-analysis. Am J Epidemiol. 2007;165(8):849-57. [pmid: 17215379].
31 Cowie CC, Rust KF, Ford ES, et al. Full accounting of diabetes and pre-diabetes in the U.S. population in 1988-1994 and 2005-2006. Diabetes Care. 2009;32(2):287-94. [pmid: 19017771].
32 Willi C, Bodenmann P, Ghali WA, et al. Active smoking and the risk of type 2 diabetes: a systematic review and meta-analysis. JAMA. 2007;298(22):2654-64. [pmid: 18073361].
33 Parillo M, Riccardi G. Diet composition and the risk of type 2 diabetes: epidemiological and clinical evidence. Br J Nutr. 2004;92(1):7-19. [pmid: 15230984].
34 American Diabetes Association. Standards of Medical Care in Diabetes: Position Statement. Diabetes Care. 2013;36(Suppl 1):S11-66. [pmid: 23264422].
35 World Health Organization. Use of Glycated Haemoglobin (HbA1c) in the Diagnosis of Diabetes Mellitus. Accessed at http://www.who.int/diabetes/publications/report-hba1c_2011.pdf. 24 January 2014.
36 Adamska E, Waszczeniuk M, Goscik J, et al. The usefulness of glycated hemoglobin A1c (HbA1c) for identifying dysglycemic states in individuals without previously diagnosed diabetes. Adv Med Sci. 2012;57(2):296-301. [pmid: 22968341].
37 Soulimane S, Simon D, Shaw J, et al. HbA1c, fasting plasma glucose and the prediction of diabetes: Inter99, AusDiab and D.E.S.I.R. Diabetes Res Clin Pract. 2012;96(3):392-9. [pmid: 21741107].
38 Tankova T, Chakarova N, Dakovska L, et al. Assessment of HbA1c as a diagnostic tool in diabetes and prediabetes. Acta Diabetol. 2012;49(5):371-8. [pmid: 21964885].
39 Handelsman Y, Mechanick JI, Blonde L, et al. American Association of Clinical Endocrinologists Medical Guidelines for Clinical Practice for developing a diabetes mellitus comprehensive care plan. Endocr Pract. 2011;17(Suppl 2):1-53. [pmid: 21474420].
40 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. 2012. Accessed at http://www.aafp.org/online. 30 November 2012.
41 Colagiuri S, Davies D, Girgis S, et al. National Evidence Based Guideline for Case Detection and Diagnosis of Type 2 Diabetes. National Health and Medical Research Council. Australia. Accessed at http://www.nhmrc.gov.au/. 30 November 2012.
42 Diabetes UK. Early Identification of People With and at High Risk of Type 2 Diabetes and Interventions for Those at High Risk. Accessed at http://www.diabetes.org.uk/Documents/. 30 November 2012.
43 Canadian Task Force on Preventive Health Care. Recommendations on screening for type 2 diabetes in adults. CMAJ. 2012;184(15):1687-96. [pmid: 23073674].
44 World Health Organization. Screening for Type 2 Diabetes. Report of a World Health Organization and International Diabetes Federation Meeting. Accessed at http://www.who.int/diabetes/publications/en/. 30 November 2012.
45 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. July. 2008. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 30 January 2013.
46 Cornell JE, Mulrow CD, Localio R, et al. Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014;160(4):267-70. [pmid: 24727843].
47 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. Br Med J. 2003;327(7414):557-60. [pmid: 12958120].
48 Lindeman RD, Yau CL, Baumgartner RN, et al. Longitudinal study of fasting serum glucose concentrations in healthy elderly. The New Mexico Aging Process Study. J Nutr Health Aging. 2003;7(3):172-7. [pmid: 12766795].
49 Simmons RK, Rahman M, Jakes RW, et al. Effect of population screening for type 2 diabetes on mortality: long-term follow-up of the Ely cohort. Diabetologia. 2011;54(2):312-9. [pmid: 20978739].
50 Takahashi O, Farmer AJ, Shimbo T, et al. A1C to detect diabetes in healthy adults: when should we recheck?. Diabetes Care. 2010;33(9):2016-7. [pmid: 20566678].
51 Ogden CL, Fryar CD, Carroll MD, et al. Mean body weight, height and body mass index, United States 1960-2002. Advance Data From Vital and Health Statistics No. 347. Hyattsville, MD. National Center for Health Statistics. 2004. Accessed at http://www.cdc.gov/nchs/data/ad/ad347.pdf.
52 Kahn R, Alperin P, Eddy D, et al. Age at initiation and frequency of screening to detect type 2 diabetes: a cost-effectiveness analysis. [Erratum appears in Lancet. 2010 Apr 17;375(9723):1346]. Lancet. 2010;375(9723):1365-74. [pmid: 20356621].
53 Noble D, Mathur R, Dent T, et al. Risk models and scores for type 2 diabetes: systematic review. BMJ. 2011;343:d7163. [pmid: 22123912].
54 Buijsse B, Simmons RK, Griffin SJ, et al. Risk assessment tools for identifying individuals at risk of developing type 2 diabetes. Epidemiol Rev. 2011;33(1):46-62. [pmid: 21622851].
55 Mann DM, Bertoni AG, Shimbo D, et al. Comparative validity of 3 diabetes mellitus risk prediction scoring models in a multiethnic US cohort: the Multi-Ethnic Study of Atherosclerosis. Am J Epidemiol. 2010;171(9):980-8. [pmid: 20375194].
56 Abbasi A, Peelen LM, Corpeleijn E, et al. Prediction models for risk of developing type 2 diabetes: systematic literature search and independent external validation study. BMJ. 2012;345:e5900. [pmid: 22990994].
57 Waugh N, Scotland G, McNamee P, et al. Screening for type 2 diabetes: literature review and economic modelling. Health Technol Assess. 2007;11(17):iii-iv. ix. xi. 1. 125.
58 CDC Diabetes Cost-Effectiveness Study Group. The cost-effectiveness of screening for type 2 diabetes. JAMA. 1998;280:1757-63. [pmid: 9842951].
59 Goyder EC, Irwig LM. Screening for type 2 diabetes mellitus: a decision analytic approach. Diabetic Med. 2000;17:469-77. [pmid: 10975217].
60 Hofer TP, Vijan S, Hayward RA. Estimating the microvascular benefits of screening for type 2 diabetes mellitus. Int J Technol Assess Health Care. 2000;16(3):822-33. [pmid: 11028137].
61 Chen TH, Yen MF, Tung TH. A computer simulation model for cost-effectiveness analysis of mass screening for type 2 diabetes mellitus. Diabetes Res Clin Pract. 2001;54:S37-42. [pmid: 11580967].
62 Hoerger TJ, Harris R, Hicks KA, et al. Screening for type 2 diabetes mellitus: a cost-effectiveness analysis. Ann Intern Med. 2004;140:689-99. [pmid: 15126252].
63 Glumer C, Yuyun M, Griffin S, et al. What determines the cost-effectiveness of diabetes screening?. Diabetologia. 2006;49(7):1536-44. [pmid: 16752172].
64 Gillies CL, Lambert PC, Abrams KR, et al. Different strategies for screening and prevention of type 2 diabetes in adults: cost effectiveness analysis. BMJ. 2008;336(7654):1180-5. [pmid: 18426840].
65 Hoerger TJ, Hicks KA, Sorensen SW, et al. Cost-effectiveness of screening for pre-diabetes among overweight and obese U.S. adults. Diabetes Care. 2007;30(11):2874-9. [pmid: 17698614].
66 Mortaz S, Wessman C, Duncan R, et al. Impact of screening and early detection of impaired fasting glucose tolerance and type 2 diabetes in Canada; a Markov model simulation. Clinicoecon Outcomes Res. 2012;4:91-7. [pmid: 22553425].
67 Simmons RK, Echouffo-Tcheugui JB, Sharp SJ, et al. Screening for type 2 diabetes and population mortality over 10 years (ADDITION-Cambridge): a cluster-randomised controlled trial. Lancet. 2012;380(9855):1741-8. [pmid: 23040422].
68 Griffin SJ, Borch-Johnsen K, Davies MJ, et al. Effect of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with type 2 diabetes detected by screening (ADDITION-Europe): a cluster-randomised trial. [Erratum appears in Lancet. 2012 Mar 3;379(9818):804]. Lancet. 2011;378(9786):156-67. [pmid: 21705063].
69 Simmons RK, Sharp SJ, Sandbaek A, et al. Does early intensive multifactorial treatment reduce total cardiovascular burden in individuals with screen-detected diabetes? Findings from the ADDITION-Europe cluster-randomized trial. Diabet Med. 2012;29(11):e409-16. [pmid: 22823477].
70 Stern M, Williams K, Eddy D, et al. Validation of prediction of diabetes by the Archimedes model and comparison with other predicting models. Diabetes Care. 2008;31(8):1670-1. [pmid: 18509203].
71 Turnbull F, Neal B, Algert C, et al. Effects of different blood pressure-lowering regimens on major cardiovascular events in individuals with and without diabetes mellitus: results of prospectively designed overviews of randomized trials. Arch Intern Med. 2005;165(12):1410-9. [pmid: 15983291].
72 UK Prospective Diabetes Study (UKPDS) Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. UK Prospective Diabetes Study Group. [Erratum appears in BMJ. 1999 Jan 2;318(7175):29]. BMJ. 1998;317(7160):703-13. [pmid: 9732337].
73 Hansson L, Zanchetti A, Carruthers SG, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998;351(9118):1755-62. [pmid: 9635947].
74 Estacio RO, Jeffers BW, Hiatt WR, et al. The effect of nisoldipine as compared with enalapril on cardiovascular outcomes in patients with non-insulin-dependent diabetes and hypertension. N Engl J Med. 1998;338(10):645-52. [pmid: 9486993].
75 Schrier RW, Estacio RO, Esler A, et al. Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney Int. 2002;61(3):1086-97. [pmid: 11849464].
76 Schrier RW, Estacio RO, Mehler PS, et al. Appropriate blood pressure control in hypertensive and normotensive type 2 diabetes mellitus: a summary of the ABCD trial. Nat Clin Pract Nephrol. 2007;3(8):428-38. [pmid: 17653121].
77 Harris R, Donahue K, Rathore SS, et al. Screening Adults for Type 2 Diabetes: A Review of the Evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138(3):215-29. [pmid: 12558362].
78 Wright JT Jr, Bakris G, Greene T, et al. Effect of blood pressure lowering and antihypertensive drug class on progression of hypertensive kidney disease: results from the AASK trial. [Erratum appears in JAMA. 2006 Jun 21;295(23):2726]. JAMA. 2002;288(19):2421-31. [pmid: 12435255].
79 ACCORD Study Group, Cushman WC, Evans GW, et al. Effects of intensive blood-pressure control in type 2 diabetes mellitus. N Engl J Med. 2010;362(17):1575-85. [pmid: 20228401].
80 Patel A, Group AC, MacMahon S, et al. Effects of a fixed combination of perindopril and indapamide on macrovascular and microvascular outcomes in patients with type 2 diabetes mellitus (the ADVANCE trial): a randomised controlled trial. Lancet. 2007;370(9590):829-40. [pmid: 17765963].
81 Zhang Y, Zhang X, Liu L, et al. Is a systolic blood pressure target <140 mmHg indicated in all hypertensives? Subgroup analyses of findings from the randomized FEVER trial. Eur Heart J. 2011;32(12):1500-8. [pmid: 21345850].
82 Costa J, Borges M, David C, et al. Efficacy of liipid lowering drug treatment for diabetic and non-diabetic patients: meta-analysis of randomized controlled trials. BMJ. 2006;332(7550).
83 Cholesterol Treatment Trialists Collaborators, Kearney PM, Blackwell L, et al. Efficacy of cholesterol-lowering therapy in 18,686 people with diabetes in 14 randomised trials of statins: a meta-analysis. Lancet. 2008;371(9607):117-25. [pmid: 18191683].
84 Tajima N, Kurata H, Nakaya N, et al. Pravastatin reduces the risk for cardiovascular disease in Japanese hypercholesterolemic patients with impaired fasting glucose or diabetes: diabetes subanalysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study. Atherosclerosis. 2008;199(2):455-62. [pmid: 18635188].
85 Antithrombotic Trialists Collaboration. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. [Erratum appears in BMJ. 2002 Jan 19;324(7330):141]. BMJ. 2002;324(7329):71-86. [pmid: 11786451].
86 Sacco M, Pellegrini F, Roncaglioni MC, et al. Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes Care. 2003;26(12):3264-72. [pmid: 14633812].
87 Ridker PM, Cook NR, Lee IM, et al. A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005;352(13):1293-304. [pmid: 15753114].
88 U.S. Preventive Services Task Force. Aspirin for the Primary Prevention of Cardiovascular Events: Final Research Plan. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf/. 4 January 2014.
89 Rahman M, Simmons RK, Hennings SH, et al. How much does screening bring forward the diagnosis of type 2 diabetes and reduce complications? Twelve year follow-up of the Ely cohort. Diabetologia. 2012;55(6):1651-9. [pmid: 22237689].
90 Lauritzen T, Borch-Johnsen K, Griffin S, et al. The ADDITION study: proposed trial of the cost-effectiveness of an intensive multifactorial intervention on morbidity and mortality among people with Type 2 diabetes detected by screening. Int J Obes. 2000;24:S6-S11.
91 Park P, Simmons RK, Prevost AT, et al. Screening for type 2 diabetes is feasible, acceptable, but associated with increased short-term anxiety: a randomised controlled trial in British general practice. BMC Public Health. 2008;8:350. [pmid: 18840266].
92 Rahman M, Simmons RK, Hennings SH, et al. Effect of screening for Type 2 diabetes on population-level self-rated health outcomes and measures of cardiovascular risk: 13-year follow-up of the Ely cohort. Diabet Med. 2012;29(7):886-92. [pmid: 22283392].
93 Paddison CAM, Eborall HC, French DP, et al. Predictors of anxiety and depression among people attending diabetes screening: a prospective cohort study embedded in the ADDITION (Cambridge) randomized control trial. Br J Health Psychol. 2011;16(Pt 1):213-26. [pmid: 21226792].
94 Eborall HC, Griffin SJ, Prevost AT, et al. Psychological impact of screening for type 2 diabetes: controlled trial and comparative study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2007;335(7618):486. [pmid: 17761995].
95 Andrews RC, Cooper AR, Montgomery AA, et al. Diet or diet plus physical activity versus usual care in patients with newly diagnosed type 2 diabetes: the Early ACTID randomised controlled trial. Lancet. 2011;378(9786):129-39. [pmid: 21705068].
96 Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the Diabetes Education and Self Management for Ongoing and Newly Diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. [Erratum appears in BMJ. 2008 Apr 19;336(7649)]. BMJ. 2008;336(7642):491-5. [pmid: 18276664].
97 Khunti K, Gray LJ, Skinner T, et al. Effectiveness of a diabetes education and self management programme (DESMOND) for people with newly diagnosed type 2 diabetes mellitus: three year follow-up of a cluster randomised controlled trial in primary care. BMJ. 2012;344:e2333. [pmid: 22539172].
98 DeFronzo RA, Tripathy D, Schwenke DC, et al. Pioglitazone for diabetes prevention in impaired glucose tolerance. [Erratum appears in N Engl J Med. 2011 Jul 14;365(2):189]. [Erratum appears in N Engl J Med. 2011 Sep 1;365(9):869]. N Engl J Med. 2011;364(12):1104-15. [pmid: 21428766].
99 DREAM Trial Investigators, Dagenais GR, Gerstein HC, et al. Effects of ramipril and rosiglitazone on cardiovascular and renal outcomes in people with impaired glucose tolerance or impaired fasting glucose: results of the Diabetes REduction Assessment with ramipril and rosiglitazone Medication (DREAM) trial. Diabetes Care. 2008;31(5):1007-14. [pmid: 18268075].
100 Florez H, Pan Q, Ackermann RT, et al. Impact of lifestyle intervention and metformin on health-related quality of life: the Diabetes Prevention Program randomized trial. J Gen Intern Med. 2012;27(12):1594-601. [pmid: 22692637].
101 Kawamori R, Tajima N, Iwamoto Y, et al. Voglibose for prevention of type 2 diabetes mellitus: a randomised, double-blind trial in Japanese individuals with impaired glucose tolerance. Lancet. 2009;373(9675):1607-14. [pmid: 19395079].
102 Li G, Zhang P, Wang J, et al. The long-term effect of lifestyle interventions to prevent diabetes in the China Da Qing Diabetes Prevention Study: a 20-year follow-up study. Lancet. 2008;371(9626):1783-9. [pmid: 18502303].
103 NAVIGATOR Study Group, Holman RR, Haffner SM, et al. Effect of nateglinide on the incidence of diabetes and cardiovascular events. [Erratum appears in N Engl J Med. 2010 May 6;362(18):1748]. N Engl J Med. 2010;362(16):1463-76. [pmid: 20228402].
104 NAVIGATOR Study Group, McMurray JJ, Holman RR, et al. Effect of valsartan on the incidence of diabetes and cardiovascular events. [Erratum appears in N Engl J Med. 2010 May 6;362(18):1748]. N Engl J Med. 2010;362(16):1477-90. [pmid: 20228403].
105 Nijpels G, Boorsma W, Dekker JM, et al. A study of the effects of acarbose on glucose metabolism in patients predisposed to developing diabetes: the Dutch acarbose intervention study in persons with impaired glucose tolerance (DAISI). Diabetes Metab Res Rev. 2008;24(8):611-6. [pmid: 18756586].
106 Ramachandran A, Snehalatha C, Mary S, et al. Pioglitazone does not enhance the effectiveness of lifestyle modification in preventing conversion of impaired glucose tolerance to diabetes in Asian Indians: results of the Indian Diabetes Prevention Programme-2 (IDPP-2). Diabetologia. 2009;52(6):1019-26. [pmid: 19277602].
107 Saito T, Watanabe M, Nishida J, et al. Lifestyle modification and prevention of type 2 diabetes in overweight Japanese with impaired fasting glucose levels: a randomized controlled trial. Arch Intern Med. 2011;171(15):1352-60. [pmid: 21824948].
108 Uusitupa M, Peltonen M, Lindström J, et al. Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study—secondary analysis of the randomized trial. PLoS ONE. 2009;4(5):e5656. [pmid: 19479072].
109 Zinman B, Harris SB, Neuman J, et al. Low-dose combination therapy with rosiglitazone and metformin to prevent type 2 diabetes mellitus (CANOE trial): a double-blind randomised controlled study. Lancet. 2010;376(9735):103-11. [pmid: 20605202].
110 Li G, Zhang P, Wang J, et al. Cardiovascular mortality, all-cause mortality, and diabetes incidence after lifestyle intervention for people with impaired glucose tolerance in the Da Qing Diabetes Prevention Study: a 23-year follow-up study. Lancet Diabetes Endocrinol. 2014;2(6):474-80. [pmid: 24731674].
111 Chiasson J-L, Josse RG, Gomis R, et al. Acarbose for prevention of type 2 diabetes mellitus: the STOP-NIDDM randomised trial. Lancet. 2002;359(9323):2072-7. [pmid: 12086760].
112 Chiasson J, Josse RG, Gomis R, et al. Acarbose treatment and the risk of cardiovascular disease and hypertension in patients with impaired glucose tolerance: the STOP-NIDDM trial. JAMA. 2003;290(4):486-94. [pmid: 12876091].
113 Heymsfield SB, Segal KR, Hauptman J, et al. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160(9):1321. [pmid: 10809036].
114 Buehler AM, Cavalcanti AB, Berwanger O, et al. Effect of tight blood glucose control versus conventional control in patients with type 2 diabetes mellitus: a systematic review with meta-analysis of randomized controlled trials. Cardiovasc Ther. 2013;31(3):147-60. [pmid: 22212499].
115 Hemmingsen B, Lund SS, Gluud C, et al. Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev. Nov. 11. 2013;11. CD008143.
116 Coca SG, Ismail-Beigi F, Haq N, et al. Role of intensive glucose control in development of renal end points in type 2 diabetes mellitus: systematic review and meta-analysis intensive glucose control in type 2 diabetes. Arch Intern Med. 2012;172(10):761-9. [pmid: 22636820].
117 Hemmingsen B, Lund SS, Gluud C, et al. Intensive glycaemic control for patients with type 2 diabetes: systematic review with meta-analysis and trial sequential analysis of randomised clinical trials. BMJ. 2011;343:d6898. [pmid: 22115901].
118 Boussageon R, Bejan-Angoulvant T, Saadatian-Elahi M, et al. Effect of intensive glucose lowering treatment on all cause mortality, cardiovascular death, and microvascular events in type 2 diabetes: meta-analysis of randomised controlled trials. BMJ. 2011;343:d4169. [pmid: 21791495].
119 Castagno D, Baird-Gunning J, Jhund PS, et al. Intensive glycemic control has no impact on the risk of heart failure in type 2 diabetic patients: evidence from a 37,229 patient meta-analysis. Am Heart J. 2011;162(5):938-48.e2. [pmid: 22093212].
120 Wu H, Xu M-J, Zou D-J, et al. Intensive glycemic control and macrovascular events in type 2 diabetes mellitus: a meta-analysis of randomized controlled trials. Chin Med J (Engl). 2010;123(20):2908-13. [pmid: 21034605].
121 Kelly TN, Bazzano LA, Fonseca VA, et al. Systematic review: glucose control and cardiovascular disease in type 2 diabetes. Ann Intern Med. 2009;151(6):394-403. [pmid: 19620144].
122 Ray KK, Seshasai SRK, Wijesuriya S, et al. Effect of intensive control of glucose on cardiovascular outcomes and death in patients with diabetes mellitus: a meta-analysis of randomised controlled trials. Lancet. 2009;373(9677):1765-72. [pmid: 19465231].
123 Ma J, Yang W, Fang N, et al. The association between intensive glycemic control and vascular complications in type 2 diabetes mellitus: a meta-analysis. Nutr Metab Cardiovasc Dis. 2009;19(9):596-603. [pmid: 19819121].
124 Mannucci E, Monami M, Lamanna C, et al. Prevention of cardiovascular disease through glycemic control in type 2 diabetes: a meta-analysis of randomized clinical trials. Nutr Metab Cardiovasc Dis. 2009;19(9):604-12. [pmid: 19427768].
125 Bangalore S, Kumar S, Lobach I, et al. Blood pressure targets in subjects with type 2 diabetes mellitus/impaired fasting glucose: observations from traditional and bayesian random-effects meta-analyses of randomized trials. Circulation. 2011;123(24):2799-810. 9 p following 810. [pmid: 21632497].
126 Poulter NR. Blood pressure and glucose control in subjects with diabetes: new analyses from ADVANCE. J Hypertens. 2009;27(1 Suppl):S3-8.
127 ACCORD Study Group, Gerstein HC, Miller ME, et al. Effects of intensive glucose lowering in type 2 diabetes. N Engl J Med. 2008;358(24):2545-59. [pmid: 18539917].
128 ACCORD Study Group, Gerstein HC, Miller ME, et al. Long-term effects of intensive glucose lowering on cardiovascular outcomes. N Engl J Med. 2011;364(9):818-28. [pmid: 21366473].
129 ACCORD Study Group, Ginsberg HN, Elam MB, et al. Effects of combination lipid therapy in type 2 diabetes mellitus. [Erratum appears in N Engl J Med. 2010 May 6;362(18):1748]. N Engl J Med. 2010;362(17):1563-74. [pmid: 20228404].
130 Zoungas S, de Galan BE, Ninomiya T, et al. Combined effects of routine blood pressure lowering and intensive glucose control on macrovascular and microvascular outcomes in patients with type 2 diabetes: new results from the ADVANCE trial. Diabetes Care. 2009;32(11):2068-74. [pmid: 19651921].
131 Gaede P, Lund-Andersen H, Parving H-H, et al. Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. 2008;358(6):580-91. [pmid: 18256393].
132 De Berardis G, Sacco M, Strippoli GFM, et al. Aspirin for primary prevention of cardiovascular events in people with diabetes: meta-analysis of randomised controlled trials. BMJ. 2009;339:b4531. [pmid: 19897665].
133 Stavrakis S, Stoner JA, Azar M, et al. Low-dose aspirin for primary prevention of cardiovascular events in patients with diabetes: a meta-analysis. Am J Med Sci. 2011;341(1):1-9. [pmid: 21191260].
134 Reboldi G, Gentile G, Angeli F, et al. Effects of intensive blood pressure reduction on myocardial infarction and stroke in diabetes: a meta-analysis in 73,913 patients. J Hypertens. 2011;29(7):1253-69. [pmid: 21505352].
135 Charles M, Ejskjaer N, Witte DR, et al. Prevalence of neuropathy and peripheral arterial disease and the impact of treatment in people with screen-detected type 2 diabetes: the ADDITION-Denmark study. Diabetes Care. 2011;34(10):2244-9. [pmid: 21816977].
136 Van den Donk M, Gorter KJ, Rutten GE. No negative effects of a multi-factorial, intensified treatment on self-reported health status, treatment satisfaction, and diabetes-related distress in screen-detected type 2 diabetes patients. The ADDITION-Netherlands study. Qual Life Res. 2010;19(4):509-13. [pmid: 20155327].
137 Janssen PG, Gorter KJ, Stolk RP, et al. Randomised controlled trial of intensive multifactorial treatment for cardiovascular risk in patients with screen-detected type 2 diabetes: 1-year data from the ADDITION Netherlands study. Br J Gen Pract. 2009;59(558):43-8. [pmid: 19105915].
138 Van den Donk M, Griffin SJ, Stellato RK, et al. Effect of early intensive multifactorial therapy compared with routine care on self-reported health status, general well-being, diabetes-specific quality of life and treatment satisfaction in screen-detected type 2 diabetes mellitus patients (ADDITION-Europe): a cluster-randomised trial. Diabetologia. 2013;56:2367-77.
139 Schwartz AV, Margolis KL, Sellmeyer DE, et al. Intensive glycemic control is not associated with fractures or falls in the ACCORD randomized trial. Diabetes Care. 2012;35(7):1525-31. [pmid: 22723583].
140 Ismail-Beigi F, Craven TE, O'Connor PJ, et al. Combined intensive blood pressure and glycemic control does not produce an additive benefit on microvascular outcomes in type 2 diabetic patients. Kidney Int. 2012;81(6):586-94. [pmid: 22166848].
141 O'Connor PJ, Narayan KMV, Anderson R, et al. Effect of intensive versus standard blood pressure control on depression and health-related quality of life in type 2 diabetes: the ACCORD trial. Diabetes Care. 2012;35(7):1479-81. [pmid: 22584134].
142 Sullivan MD, Anderson RT, Aron D, et al. Health-related quality of life and cost-effectiveness components of the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial: rationale and design. Am J Cardiol. 2007;99(12A):90i-102i.
143 ACCORD Study Group, ACCORD Eye Group, Chew EY, et al. Effects of medical therapies on retinopathy progression in type 2 diabetes. [Erratum appears in N Engl J Med. 2011 Jan 13;364(2):190]. N Engl J Med. 2010;363(3):233-44. [pmid: 20587587].
144 Anderson RT, Narayan KMV, Feeney P, et al. Effect of intensive glycemic lowering on health-related quality of life in type 2 diabetes: ACCORD trial. Diabetes Care. 2011;34(4):807-12. [pmid: 21346183].
145 De Galan BE, Perkovic V, Ninomiya T, et al. Lowering blood pressure reduces renal events in type 2 diabetes. J Am Soc Nephrol. 2009;20(4):883-92. [pmid: 19225038].
146 Stefansdottir G, Zoungas S, Chalmers J, et al. Intensive glucose control and risk of cancer in patients with type 2 diabetes. Diabetologia. 2011;54(7):1608-14. [pmid: 21509444].
147 Beulens JW, Patel A, Vingerling JR, et al. Effects of blood pressure lowering and intensive glucose control on the incidence and progression of retinopathy in patients with type 2 diabetes mellitus: a randomised controlled trial. Diabetologia. 2009;52(10):2027-36. [pmid: 19633827].
148 Araki A, Iimuro S, Sakurai T, et al. Long-term multiple risk factor interventions in Japanese elderly diabetic patients: the Japanese Elderly Diabetes Intervention Trial--study design, baseline characteristics and effects of intervention. Geriatr Gerontol Int. 2012;12(Suppl 1):7-17. [pmid: 22435936].
149 Ogawa H, Nakayama M, Morimoto T, et al. Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. [Erratum appears in JAMA. 2009 May 13;301(18):1882]. JAMA. 2008;300(18):2134-41. [pmid: 18997198].
150 Okada S, Morimoto T, Ogawa H, et al. Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes Care. 2011;34(6):1277-83. 1. [pmid: 21515838].
151 Nakamura H, Arakawa K, Itakura H, et al. Primary prevention of cardiovascular disease with pravastatin in Japan (MEGA Study): a prospective randomised controlled trial. Lancet. 2006;368(9542):1155-63. [pmid: 17011942].
152 Howard BV, Roman MJ, Devereux RB, et al. Effect of lower targets for blood pressure and LDL cholesterol on atherosclerosis in diabetes: the SANDS randomized trial. JAMA. 2008;299(14):1678-89. [pmid: 18398080].
153 Gaede P, Vedel P, Larsen N, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003;348(5):383-93. [pmid: 12556541].
154 Holman RR, Paul SK, Bethel MA, et al. 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. 2008;359(15):1577-89. [pmid: 18784090].
155 Holman RR, Paul SK, Bethel MA, et al. Long-term follow-up after tight control of blood pressure in type 2 diabetes. N Engl J Med. 2008;359(15):1565-76. [pmid: 18784091].
156 Duckworth W, Abraira C, Moritz T, et al. Glucose control and vascular complications in veterans with type 2 diabetes. [Erratum appears in N Engl J Med. 2009 Sep 3;361(10):1028]. [Erratum appears in N Engl J Med. 2009 Sep 3;361(10):1024-5. PMID: 19726779]. N Engl J Med. 2009;360(2):129-39. [pmid: 19092145].
157 Stettler C, Allemann S, Juni P, et al. Glycemic control and macrovascular disease in types 1 and 2 diabetes mellitus: meta-analysis of randomized trials. Am Heart J. 2006;152(1):27-38. [pmid: 16824829].
158 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. [Erratum appears in Lancet. 1999 Aug 14;354(9178):602]. Lancet. 1998;352(9131):837-53. [pmid: 9742976].
159 Service FJ, Daube JR, O'Brien PC, et al. Effect of blood glucose control on peripheral nerve function in diabetic patients. Mayo Clin Proc. 1983;58(5):283-9. [pmid: 6341720].
160 Meinert CL, Knatterud GL, Prout TE, et al. A study of the effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. II. Mortality results. Diabetes. 1970;19(Suppl):789-830. [pmid: 4926376].
161 Johnson JA, Bowker SL. Intensive glycaemic control and cancer risk in type 2 diabetes: a meta-analysis of major trials. Diabetologia. 2011;54(1):25-31. [pmid: 20959956].
162 Reboldi G, Gentile G, Manfreda VM, et al. Tight blood pressure control in diabetes: evidence-based review of treatment targets in patients with diabetes. Curr Cardiol Rep. 2012;14(1):89-96. [pmid: 22139528].
163 Lv J, Perkovic V. Blood pressure management in diabetes: a path forward?. J Hypertens. 2011;29(7):1283-4. [pmid: 21659818].
164 Belch J, MacCuish A, Campbell I, et al. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
165 Armato J, DeFronzo RA, Abdul-Ghani M, et al. Successful treatment of prediabetes in clinical practice: targeting insulin resistance and β-cell dysfunction. Endocr Pract. 2012;18(3):342-50. [pmid: 22068250].
166 Lu Y-H, Lu J-M, Wang S-Y, et al. Outcome of intensive integrated intervention in participants with impaired glucose regulation in China. Adv Ther. 2011;28(6):511-9. [pmid: 21533568].
167 Rasmussen SS, Glumer C, Sandbaek A, et al. General effect on high-risk persons when general practitioners are trained in intensive treatment of type 2 diabetes. Scand J Prim Health Care. 2008;26(3):166-73. [pmid: 18677673].
168 Lindblad U, Lindberg G, Mansson NO, et al. Can sulphonylurea addition to lifestyle changes help to delay diabetes development in subjects with impaired fasting glucose? The Nepi ANtidiabetes StudY (NANSY). Diabetes Obes Metab. 2011;13(2):185-8. [pmid: 21199271].
169 Penn L, White M, Oldroyd J, et al. Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009;9:342. [pmid: 19758428].
170 Sakane N, Sato J, Tsushita K, et al. Prevention of type 2 diabetes in a primary healthcare setting: three-year results of lifestyle intervention in Japanese subjects with impaired glucose tolerance. BMC Public Health. 2011;11(1):40. [pmid: 21235825].
171 Lindahl B, Nilsson TK, Borch-Johnsen K, et al. A randomized lifestyle intervention with 5-year follow-up in subjects with impaired glucose tolerance: pronounced short-term impact but long-term adherence problems. Scand J Public Health. 2009;37(4):434-42. [pmid: 19181821].
172 Katula JA, Vitolins MZ, Morgan TM, et al. The Healthy Living Partnerships to Prevent Diabetes study: 2-year outcomes of a randomized controlled trial. Am J Prev Med. 2013;44(4 Suppl 4):S324-32. [pmid: 23498294].
173 Pan C-Y, Gao Y, Chen J-W, et al. Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003;61(3):183-90. [pmid: 12965108].
174 Calles-Escandon J, Lovato LC, Simons-Morton DG, et al. Effect of intensive compared with standard glycemia treatment strategies on mortality by baseline subgroup characteristics: the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. Diabetes Care. 2010;33(4):721-7. [pmid: 20103550].
175 Salpeter SR, Greyber E, Pasternak GA, et al. Risk of fatal and nonfatal lactic acidosis with metformin use in type 2 diabetes mellitus. Cochrane Database Syst Rev. Apr. 14. 2010;(4). CD002967.
176 Morrison A, Polisena J, Husereau D, et al. The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(2):138-44. [pmid: 22559755].
177 Grarup N, Rose CS, Andersson EA, et al. Studies of association of variants near the HHEX, CDKN2A/B, and IGF2BP2 genes with type 2 diabetes and impaired insulin release in 10,705 Danish subjects: validation and extension of genome-wide association studies. Diabetes. 2007;56(12):3105-11. [pmid: 17827400].
178 Sparso T, Andersen G, Nielsen T, et al. The GCKR rs780094 polymorphism is associated with elevated fasting serum triacylglycerol, reduced fasting and OGTT-related insulinaemia, and reduced risk of type 2 diabetes. [Erratum appears in Diabetologia. 2008 Feb;51(2):383]. Diabetologia. 2008;51(1):70-5. [pmid: 18008060].
179 Diabetes Prevention Program Research Group. Long-term safety, tolerability, and weight loss associated with metformin in the Diabetes Prevention Program Outcomes Study. Diabetes Care. 2012;35(4):731-7. [pmid: 22442396].