# Discussion

## Summary of Review Findings

Table 13 summarizes the evidence reviewed for this update. In two trials, one of which focused on persons at higher risk for DM, screening was associated with no effect on mortality versus no screening after 10 years of followup.49,67 Possible explanations for the lack of effect of screening on mortality include limited screening uptake, increased opportunities for DM screening across groups (both studies were conducted in the United Kingdom), improved management of CV disease risk factors contributing to decreased mortality, or inadequate length of followup for mortality outcomes. All of these factors could have attenuated any potential benefits of screening. In addition, the trials did not evaluate nonmortality clinical outcomes, which might require less lengthy followup to detect effects (e.g., microvascular outcomes). Although attending screening was associated with reduced mortality and failure to attend screening with increased mortality, such effects may be confounded by other factors associated with likelihood to attend recommended clinical services.

Table 13 Summary of Evidence

Main Findings from Previous USPSTF Report | Number and Type of Studies Identified for Update | Limitations | Consistency | Applicability | Summary of Findings | Overall Quality^a^
Key Question 1. Is there direct evidence that screening for type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance among asymptomatic, nonpregnant adults improves health outcomes?
No RCTs on the effects of screening for DM on clinical outcomes. One case-control study found no association between screening and improvement in microvascular outcomes | 2 RCTs | Mortality outcomes limited to 10 years | Consistent | Both trials in UK; ADDITION in high risk population; Ely trial in average risk population | Two RCTs found no effect on all-cause or cardiovascular mortality with screening versus no screening after 10 years. | Fair
Key Question 2. What are the harms of screening nonpregnant adults for type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance?
No evidence on serious psychological or other adverse effects associated with a new diagnosis of DM | 3 RCTs | Small sample size in study demonstrating short-term anxiety associated with invitation to screening | Consistent | All trials in UK; 2 studies in high risk population; 1 in average risk population | In the short-term (6-14 weeks), being invited to screening increased anxiety versus not being invited; at 13 years no difference in anxiety or depression between those screening negative for diabetes and those unscreened; at 12 months there was no difference in anxiety or depression in those screened positive for diabetes versus those who screened negative | Fair
Key Question 3. Do interventions for screen-detected or mild type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance provide an incremental benefit in health outcomes compared with no interventions or initiating interventions after clinical diagnosis?
No clear evidence on benefit of treatment in screen-detected DM population or comparing treatment effects in people with screen- and clinically-detected DM although one trial found acarbose associated with reduced risk of MI | 13 RCTs (16 publications) | Some studies underpowered to evaluate mortality and other CV outcomes; most studies limited to three year followup; evidence often limited to a single study per drug | Consistent | Few studies in a non-white population Some studies required patients to have CV disease or risk factor for DM or CV disease; other studies excluded patients with CV disease | Most studies found no benefit on all-cause or cardiovascular mortality with glucose-lowering or antihypertensive medications or with lifestyle modification, though one study of lifestyle modification found reduced risk of all-cause and cardiovascular mortality after 23 years followup. Lifestyle modification improved general health scores | Fair
Key Question 4. What are the harms of interventions for screen-detected or mild type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance?
No studies reported serious harms No studies conducted in people with screen-detected DM reporting harms. Studies conducted in people with IFG or IGT included in the prior report found no differences in withdrawal rates between lifestyle or pharmacologic interventions and control. | 9 RCTs (11 publications) | Few studies in screened-detected or early DM, IFG or IGT populations | Consistent | Few studies in a non-white population Some studies required patients to have CV disease or risk factor for DM or CV disease; other studies excluded patients with CV disease | Little difference between active medication or lifestyle modification versus placebo or usual care in risk of harms. Acarbose was associated with greater withdrawal rates; Single study evidence for: increased risk of any adverse event with pioglitazone and voglibose, increased hypoglycemia with nateglidine and increased hypotension with valsartan; No trial of metformin reported risk of lactic acidosis | Fair
Key Question 5. Is there evidence that more intensive glucose, blood pressure or lipid control interventions improve health outcomes in nonpregnant adults with type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance compared to traditional control? Is there evidence that aspirin use improves health outcomes in these populations compared to nonuse?
No evidence in a screen-detected DM population. Studies that enrolled people with established DM found no clear evidence of a differential effect on individual health outcomes with intensive blood pressure or lipid lowering, or with aspirin for primary prevention of CVD. | [underlined: People with screen-detected DM] 3 RCTs (4 publications) [underlined: People with DM not specifically screen-detected] 13 systematic reviews 10 RCTs (33 publications) | Some studies were underpowered as event rates were lower than anticipated Limited evidence in people with IFG, IGT and screen-detected DM | [underlined: People with screen-detected DM] Consistent [underlined: People with DM not specifically screen-detected] Glucose control: consistent Blood pressure control: inconsistent Lipid lowering: N/A Multifactorial intervention: inconsistent Aspirin: consistent | Only 1 fair-quality trial enrolled people with screen-detected diabetes; other studies enrolled people with established DM | [underlined: People with screen-detected DM] Use of an intensive multifactorial glucose, blood pressure and lipid lowering intervention did not significantly reduce risk of all-cause or CV mortality, MI, stroke or revascularization after 5 years followup. [underlined: People with DM not specifically screen-detected] Intensive glucose-lowering did not significantly decrease risk of all-cause or CV mortality, but was associated with a significant reduction in risk of nonfatal MI in systematic reviews. Intensive BP lowering reduced risk of all-cause mortality and stoke in a good-quality systematic review, but results from recently published trials were mixed on the effect on health outcomes, though different interventions and blood pressure targets were used in these studies. Intensive lipid lowering did not significantly reduce risk of most health outcomes though evidence was very limited. Evidence for use of an intensive multifactorial intervention was mixed; 2 trials found a significant benefit on health outcomes while 2 others did not. Aspirin did not reduce incidence of health outcomes based on 2 good-quality systematic reviews. | Good
Key Question 6. What are the harms of more intensive interventions compared to traditional control in people with screen-detected or early type 2 diabetes, impaired fasting glucose or impaired glucose tolerance?
Not assessed | 5 systematic reviews 6 RCTs | Trials generally not designed to assess harms; interventions and targets varied | Consistent for effects of glucose-lowering therapy; inconsistent for blood pressure lowering therapy | Unclear; no evidence in screen-detected population | Intensive glucose lowering was consistently associated with increased risk of severe hypoglycemia. Evidence on harms of intensive blood pressure lowering was mixed. Aspirin use increased risk of bleeding in a systematic review of 6 trials. | Fair
Key Question 7. Do interventions for impaired fasting glucose or impaired glucose tolerance delay or prevent the progression to type 2 diabetes?
6 studies of lifestyle interventions and 8 studies of pharmacologic interventions found some evidence that intervention delays or prevents progression | Multifactorial interventions: 2 RCTs Lifestyle interventions: 6 RCTs (in 7 publications) Pharmacologic interventions: 8 RCTs (in 9 publications) | Some studies underpowered, lack of blinding in many studies, content of interventions varied widely | Multifactorial interventions: Consistent Lifestyle interventions: Consistent Pharmacologic interventions: Consistent | Few studies reported race/ethnicity, but effects were largely consistent among studies in various countries | Two studies of multifactorial interventions found no effect on risk of progression to diabetes, though the estimate of one study was imprecise Three of six studies of lifestyle interventions found reduced risks of progression to diabetes among intervention participants, and three other studies had point estimates in favor of the interventions that failed to reach significance Four studies of pharmacologic interventions found reduced risk of progression to diabetes among intervention groups receiving thiazolinediones, alpha-glucosidase inhibitors, metformin, and valsartan. Nateglinide was evaluated in one study that reported no effect, glimepiride was not found to be effective at delaying progression, and exenatide was reported in one small study with imprecise estimates. | Good
Key Question 8. Do the effects of screening or interventions for screen-detected or mild type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance vary by subgroups, such as age, sex, or race/ethnicity?
No evidence on how the effects of screening or treatment of screen-detected DM, IFG or IGT varies according to subgroup | 1 systematic review, 4 RCTs | No study designed to assess subgroup differences. Available evidence too limited to draw conclusions | | No evidence in screen-detected population | No direct evidence on the effect of screening in subgroups though men (but not women) who underwent screening and died during followup had significantly longer life compared to those who were not screened. Based on 1 study, intensive glucose lowering increased risk of mortality in people <age 65 years (but not in older people) and in Blacks (but not Whites, Hispanics or Asians). Intensive lipid lowering reduced risk of CV events in men but not women, and aspirin use reduced risk of MI in men. | Poor

a “Overall quality” is based on new evidence identified for this update plus previously reviewed evidence.

Abbreviations: ADDITION = Anglo-Dutch-Danish Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care; BP = blood pressure; CV = cardiovascular; CVD = cardiovascular disease; DM = diabetes mellitus; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; MI = myocardial infarction; RCT = randomized, controlled trial; UK = United Kingdom.

Evidence on harms associated with screening is limited. In one study, patients randomized to screening had greater short-term self-reported anxiety versus those randomized to no screening,91 but there were no negative effects on psychological measures in studies with longer followup.92,93

Lifestyle interventions and pharmacological interventions both appear to be effective at delaying or preventing progression to DM in persons with IFG or IGT.4-7,15,98,101,102,105,107,110,111,168-170,172,173

The long-term benefits of early intervention on clinical outcomes are less clear. The Da Qing study, which included 23 years followup, found that lifestyle modification in persons with IGT significantly reduced risk of all-cause and CV mortality.110 The results of this study are interesting, in that results from 20 years followup showed no significant benefit on these outcomes. Although the study had some limitations, including potentially limited applicability to a U.S.-relevant population, the findings suggest that the positive effects of early intervention may not be observed until more than 20 years following treatment. In other studies of lifestyle modification or pharmacologic treatment for screen-detected or early DM, IFG, or IGT, we found no beneficial effect of any treatment on all-cause mortality, CV mortality, or stroke. This lack of benefit in health outcomes may result from inadequate length of followup in these studies or the fact that most pharmacologic studies included a concomitant lifestyle modification component across treatment arms that could have attenuated any potential effects of drug therapy. There was limited evidence for improvement in other health outcomes (such as nonfatal MI or CV events, renal disease, or quality of life) associated with use of certain glucose-lowering agents, antihypertensive medication, or lifestyle modification in studies with shorter followup (≤5 years),112 and while rosiglitazone was associated with decreased renal disease, it was also associated with increased heart failure versus placebo.99 Intensive lifestyle modification, but not metformin, led to improved quality of life scores versus placebo after 3 years.100

Based on data from RCTs, pharmacologic treatment of screen-detected or early DM, IFG, or IGT was associated with increased risk of withdrawal due to adverse events versus placebo,105,111 with no clear increase in risk of serious adverse events. Many adverse events associated with pharmacologic therapy are bothersome but self-limited with discontinuation of therapy. In general, trials were not designed or powered to specifically assess the risk of serious but uncommon or rare adverse events, although evidence from studies not restricted to persons with screen-detected or early DM did not show a clear increase in risk of serious adverse events, such as lactic acidosis with metformin.175 Specific pharmacotherapy may also be associated with an increase in specific adverse events, such as hypoglycemia with sulfonylureas or edema or congestive heart failure with TZDs.

Since the previous USPSTF report, there is now evidence from a large good-quality trial that intensive multifactorial control aimed at lowering glucose, blood pressure, and lipids appears to offer no benefit in all-cause or CV mortality or morbidity over standard control in persons with screen-detected DM after 5 years.69 In persons with DM not specifically identified by screening, many good-quality systematic reviews found intensive glucose lowering to be consistently associated with no reduction in all-cause or CV mortality versus less intensive glucose therapy.114-124 Intensive glucose-lowering therapy was also associated with reduced risk of nonfatal MI but increased risk of severe hypoglycemia.

The 2008 USPSTF review found that effects of intensive blood pressure control were greater in persons with DM versus those without DM, based on subgroup analyses from trials that were generally less successful at achieving lower blood pressures. Since the 2008 USPSTF review, there is more evidence on the effects of more effective, intensive blood pressure control versus standard therapy, specifically in persons with diabetes. Although good-quality systematic reviews found intensive blood pressure control in persons with DM to be associated with reduced risk of all-cause mortality and stroke versus less intensive blood pressure control,125,134 results from the large recently published ADVANCE80 and ACCORD79 trials are more inconsistent. The ADVANCE trial found that the addition of an ACE inhibitor plus diuretic was associated with decreased risk of all-cause and CV mortality, and the ACCORD study found no difference between an SBP target of 140 versus 120 mm Hg in risk of all-cause or CV mortality. There is no clear evidence on the effect of more versus less intensive lipid lowering interventions and incidence of all-cause or CV mortality. Use of intensive multifactorial interventions was associated with reduced risk of all-cause and CV mortality in two trials.130,131 Aspirin use (vs. nonuse) had no effect on all-cause mortality, CV mortality, MI, or stroke in persons with DM.132

## Limitations

We did not include non–English language articles; a recent review found that limiting to English-language studies did not introduce bias into systematic review findings.176 We identified few screening studies and only one treatment study conducted in a screen-detected population, and evidence in all demographic subgroups is extremely limited.

Interventions included in the review for those with early or screen-detected DM and IFG or IGT were limited to glycemic control, although the effect of blood pressure and lipid control in persons with DM is discussed in Contextual Question 4 and Key Question 5. Studies in screen-detected populations on the effect of intensive glucose, blood pressure, and lipid lowering were limited; thus, evidence from studies in persons with DM was also included and discussed separately.

## Emerging Issues and Next Steps

The ADDITION study is an ongoing study being conducted in the United Kingdom, Denmark, and the Netherlands of persons at high risk for DM. Mortality data from ADDITION-Cambridge on the effect of screening after 10 years were recently published and showed no benefit.67 However, modeling studies that calculate a benefit to screening project patient followup for 30 or more years. Therefore, as time progresses, longer-term followup of the ADDITION study would be informative for understanding benefits and harms of screening.

## Relevance for Priority Populations

The ADDITION trial was conducted in a population at high risk for DM, but there is little clear evidence on how screening for DM, IFG, or IGT differs according to age, sex, or race/ethnicity. The only early intervention study to find an effect on mortality was the Da Qing study conducted in persons with IGT, which found in a subgroup analysis that women, but not men, in a lifestyle-modification group had a significantly lower risk of all-cause or CV mortality after 23 years followup compared with usual care.110 In a subgroup analysis from the ACCORD study of intensive glucose lowering for DM not specifically screen detected, there was no overall effect of age or race, but all-cause mortality risk was highest in persons younger than age 65 years and in black adults,172 while use of intensive lipid lowering significantly reduced risk of CV events in men but not women.126 The ADVANCE trial of intensive blood pressure lowering found no differential effect on vascular outcomes when results were stratified by age or sex.79,80,129,174 Aspirin use in persons with DM was associated with reduced risk of MI in men and associated with a nonstatistically significant reduction in risk of stroke in women based on a systematic review of three studies.132

## Future Research

We identified a number of important research gaps. Screening studies in U.S. populations, in which the prevalence of undiagnosed DM (and IFG and IGT) is likely to be higher than the 3 percent identified in the ADDITION-Cambridge and Ely studies, would be more applicable for informing screening decisions in the United States. There is also little evidence on the effect of screening on ethnic and racial minorities whose prevalence of DM is higher than in those of white European ancestry. More research is also needed to identify optimal treatment strategies for screen-detected DM, given the findings of the treatment phase of the ADDITION trial.69

Recently published studies using data from participants in ADDITION-Denmark validate the existence of DM susceptibility allele variants, suggesting a role for the pathogenesis of pancreatic B-cell dysfunction.177 This and other ongoing genomic research178 related to glucose dysregulation may play a role in the future selection of DM treatments and treatment targets.

Long-term followup of studies of early lifestyle interventions in persons with screen-detected DM, IFG, or IGT is needed to confirm the findings of the Da Qing study.

## Conclusions

Screening for DM did not improve mortality after 10 years followup in two trials,49,67 and more evidence is needed to determine effective treatments for screen-detected DM. However, treatment for IFG and IGT was associated with delayed progression to DM.