# Results

## Contextual Question 1 What Is the Yield (Incidence) of Starting Screening at Different Ages or Rescreening at Different Intervals in Adults With an Initial Normal Fasting Blood Glucose, HbA1c, or Glucose Tolerance Test?

The ADA recommends screening for DM in persons without known risk factors for DM starting at age 45 years.16 This recommendation is based on the increased prevalence of DM after age 44 years (Table 2).17 Based on National Health and Nutrition Examination Survey data from 2005 to 2008, about 4 percent of the U.S. population ages 20 to 44 years had diagnosed or undiagnosed DM. Corresponding proportions in persons ages 45 to 64 years and age 65 years and older were 14 and 27 percent, respectively.17 After age 44 years, men generally have slightly higher prevalence than women; blacks have higher prevalence than whites (Table 2).

Evidence on the yield of rescreening remains limited. The prior USPSTF report1 found one study on rescreening older adults with initially normal glucose levels.48 It screened community-based healthy volunteers older than age 65 years (mean baseline age, 72 years) with an initial fasting serum glucose less than 126 mg/dL annually. The study population was 97 percent white and described as “upper middle class.” Ninety-six percent of study participants had at least six annual screens over a mean 12 years followup, over which time fasting serum glucose declined for most participants. Four participants, none of whom were older than age 75 years at baseline, developed DM during followup.

Results from the Ely cohort,49 a single-center RCT of screening conducted in the United Kingdom, published since the prior USPSTF report, provide some evidence on the yield of rescreening. In this study, mean age was 50 years, about half of study participants were women, and risk factors were not assessed prior to screening. Participants (n=1,106) who had initial negative screening results were rescreened 5 and 10 years later; the corresponding yield of screening was 2 and 3 percent for DM.

A large (n=16,313) retrospective cohort study of middle-aged (median age, 50 years) Japanese men and women reported the yield of annual screening for 3 consecutive years in patients without DM at baseline.50 In 14,800 participants, the overall yield of rescreening for DM with HbA1c was 3.2 percent. Incidence was highest in those with baseline HbA1c levels ranging from 6.0 to 6.4 percent (20% [95% CI, 18% to 23%]). Fewer participants with slightly lower HbA1c at baseline progressed to DM (baseline, 5.5% to 5.9%; cumulative incidence, 1.2% [95% CI, 0.9% to 1.6%]), and nearly all of those with HbA1c less than 5.5 percent at baseline did not develop DM (cumulative incidence, 0.5% [95% CI, 0.001% to 0.3%]). This study may have limited applicability to U.S. settings because of differences related to the Japanese setting and population. For example, mean BMI at baseline was 22.5 kg/m^2^, much lower than the U.S. average of 28 to 29 kg/m^2^ in a similarly aged population.51

A 2010 modeling study of DM screening strategies found that beginning screening at age 30 years with rescreening every 3 years or beginning screening at age 45 years with annual rescreening would result in a similar DM diagnosis lead-time of about 6 years.52 (See Contextual Question 3 for more detailed discussion of modeling studies.)

## Contextual Question 2 What Is the Utility of Using Formal Risk Calculators Versus Risk Factor Assessment (e.g., Family History, Body Mass Index) in Determining a Person's Risk for Developing Diabetes?

Several risk models or scores have been developed to assist clinical decisionmaking concerning screening for DM.53 “Basic” risk models use information from patient history or medical records, including variables such as age, race, and family history, without requiring laboratory testing. “Extended” risk models also include results of blood tests (e.g., lipid profile, fasting glucose).

A systematic review of 94 risk models in populations not preselected on the basis of known risk factors for DM (n=399 to 2.54 million), reported area under the receiver operating characteristic (AUROC) curves of 0.60 to 0.91 for incident DM during 3 to 28 years of followup (DM incidence ranged from 1% to 21% in the studies).53 The systematic review identified seven risk-prediction tools with potential for use in routine clinical practice with AUROCs that ranged from 0.72 to 0.85 (Table 3).53 These tools utilized similar components, most commonly age, BMI/obesity, blood pressure or use of antihypertensive medications, and family history of DM. Four (Ausdrisk, FINDRISC, QDScore, and the Cambridge Risk Score) did not measure fasting glucose as a risk factor in their scoring and are more applicable for guiding initial screening decisions than tools that already include glucose measures. The discriminatory performance of individual risk factors was not assessed.

Table 3 Characteristics of Seven Risk Models or Scores With Potential for Use in Clinical Practice

Score/Model | Risk Factors | Development | | External Validation
| | Country | AUROC | Country | AUROC
ARIC | Age, ethnicity, waist circumference, height, systolic BP, family history of diabetes, FG, TG, HDL-c. | Germany | 0.80 | USA | 0.84
Ausdrisk | Age, sex, ethnicity, parental history of diabetes, history of high blood glucose, use of BP medication, smoking, physical inactivity, waist circumference. | Australia | 0.78 | NA | NA
Cambridge Risk Score | Age, sex, use of steroids, use of BP medication, family history of diabetes, BMI, smoking. | UK | 0.74^a^ | UK | 0.72
FINDRISC | Age, BMI, waist circumference, use of BP medication, history of high blood glucose, physical inactivity, daily consumption of vegetables, fruits, and berries. | Finland | 0.85 | Holland, Denmark, Sweden, UK, Australia^b^ | 0.76
Framingham Offspring | FG, BMI, HDL-c, parental history of diabetes, TG, BP | USA | 0.85 | USA | 0.78
San Antonio | Age, sex, ethnicity, FG, systolic BP, HDL-c, BMI, family history of diabetes in first degree relative. | USA | 0.84 | USA^c^ | 0.83
QDScore | Age, sex, ethnicity, BMI, smoking, family history of diabetes, Townsend deprivation score, CVD, use of steroids. | UK | 0.83 men, 0.85 women | UK | 0.80 men, 0.81 women

a Threshold = 0.38.

b Validation used modification of risk factors from original score or didn't state exact factors used.

c Also validated in Iran and UK.

Abbreviations: ARIC = Atherosclerosis Risk in Communities; AUROC = area under the receiver operating curve; BMI = body mass index: BP = blood pressure; CVD = cardiovascular disease; FG = fasting plasma glucose; FINDRISC = Finnish Diabetes Risk Score; NA = not available; HDL-c = high density lipoprotein cholesterol; TG = triglycerides; UK = United Kingdom; USA = United States of America.

Source: Adapted from Noble 2011.^53^

Another systematic review, which included 46 prospective cohort studies of risk-prediction models, reported AUROCs for prediction of incident DM that ranged from 0.7 to 0.8 for basic models and from 0.68 to 0.85 for extended models.54 Both reviews found that models that incorporated novel biomarkers, such as genetic information, did not demonstrate improved discriminatory performance compared with those without such information.53,54

Evidence on the comparative performance of different risk models in a specific population is limited. A study that compared three DM risk-prediction scoring models in a multiethnic U.S. cohort (n=5,329) reported the discriminative value of risk models derived from the Framingham Offspring, Atherosclerosis Risk in Communities (ARIC), and San Antonio Heart Studies, as well as the discriminatory value of individual risk factors.55 All models included fasting glucose—limiting their utility to guide initial screening—as well as high-density lipoprotein, blood pressure, and family history. In this study, diagnosis of incident DM was based on the first followup visit during which a participant self-reported use of oral hypoglycemic drugs or insulin, or had a fasting serum glucose greater than or equal to 126 mg/dL. At baseline, mean age was 62 years, 47 percent were male, and 43 percent were white. During a median of 5 years of followup, 446 incident cases of DM were diagnosed (9% of the population). All models were associated with similar discrimination (c-statistic ranged from 0.78 to 0.84). The Framingham and ARIC models demonstrated similar discrimination for all racial groups, but the San Antonio model performed more poorly for black than white participants (p<0.05). Individual risk factors performed more poorly than the prediction models (c-statistics ranging from 0.59 to 0.74; p<0.01 vs. models). In terms of calibration, the Framingham risk model underestimated risk of DM, the San Antonio model overestimated risk, and the ARIC model was accurate in all except the highest risk quintile. When models were recalibrated using mean DM incidence rates and risk estimates from the current study's cohort, all the prediction models showed good calibration (Hosmer–Lemeshow goodness-of-fit test; p>0.10).55

A study that evaluated the performance of 25 prediction models (12 basic and 13 extended) in a large (n=38,379) Dutch cohort reported an AUROC ranging from 0.74 to 0.84 for basic models and from 0.81 to 0.93 for extended models for risk of DM at 7.5 years (2.2 incident cases of DM per 1,000 person-years).56 Most models overestimated the risk of DM. Recalibration based on the incidence of DM in the studied cohort improved model performance.

## Contextual Question 3 What Is the Utility of Existing Modeling Studies of Type 2 Diabetes Screening Versus No Screening in Examining Important Health Outcomes?

The prior USPSTF report1 included seven modeling studies on screening.57-63 This included two high-quality studies that found targeted screening for DM in persons with hypertension to be relatively cost-effective when macrovascular benefits of optimal blood pressure control were considered.57,62 These models also found that older persons benefited more from screening than younger persons.57,62 For example, population-based screening with HbA1c, assuming 50-percent uptake of screening and lifetime followup, was estimated to have an incremental cost-effectiveness ratio (ICER) of £2,266/quality-adjusted life-year (QALY) in persons ages 40 to 70 years versus no screening. When stratified by age, the ICER was much higher in the youngest group (ages 40 to 49 years: £10,216/QALY) than in the oldest group (ages 60 to 69 years: £1,152/QALY). The same study estimated ICERs of £1,505/QALY in persons with hypertension and £1,046/QALY in obese persons.57 These findings were sensitive to assumptions regarding the degree of blood glucose control, future treatment protocols, and cost of statins.

We identified four modeling studies published since the prior USPSTF report on the cost-effectiveness of various screening strategies for DM, IFG, or IGT versus no screening in the United States, United Kingdom, or Canada (Table 4).52,64-66 All were performed prior to the publication of the large ADDITION (Danish-Dutch Study of Intensive Treatment in People with Screen-Detected Diabetes in Primary Care) trial on DM screening in a higher risk population, which found no differences after 10 years between persons who were screened or not screened in risk of all-cause, CV, or DM-related mortality (see Key Question 1)67 or between intensive versus less intensive treatment in screen-detected persons with DM after 5 years of followup (see Key Question 5).68,69 The modeling studies all included assumptions regarding benefits from subsequent treatments and reduced progression of disease in patients with screen-detected DM. These assumptions were primarily based on results of the Diabetes Prevention Program (DPP), which evaluated effects of pharmacological and lifestyle interventions on DM progression, in conjunction with the modeled natural history of DM and associated clinical outcomes. All of the studies found screening versus no screening to be associated with ICERs of less than $15,000/QALY, well under traditional thresholds for cost-effectiveness, in scenarios in which screening began at age 40 or 45 years. Screening tests, when described, were based on capillary blood glucose, fasting plasma glucose, and OGTT, with no study evaluating HbA1c as the screening strategy. However, conclusions were generally insensitive to costs and other assumptions related to the screening test used. Three of the studies evaluated screening strategies that included treatment of DM, IFG, or IGT, and the fourth52 included only screening and treatment of DM. In the ADDITION trial, screening focused on identification of DM, but clinicians were informed of screening results, specific therapies were not dictated, and the proportion of patients who were diagnosed with or received treatment for IFG or IGT was not reported.

Table 4 Studies Modeling Screening for DM Published Since the Previous USPSTF Report

Author, Year Country | Screening Details | Type of Model | Assumptions Regarding Treatment Benefits | Cost Effectiveness Outcomes | Length of Followup | Calibrated? | Comments
Gillies, 2008^64^ UK | 1. Screening for diabetes; 2. Screening for IGT or diabetes, followed by lifestyle intervention; 3. Screening for IGT or diabetes, followed by pharmacological interventions; 4. No screening; Start screening at age 45 | Hybrid: decision tree + Markov model | Intervention effects on risk of developing diabetes for: Lifestyle vs standard treatment: HR -0.65 Drugs vs placebo: HR −0.43 Mortality rates: 0.32 to 15.68 (increases with age) per 100 person years Increased risk of death with diabetes: HR 0.76 Increased risk of death for 1% increase in HbA1c: HR 0.104 | ICER compared with no screening: Screening for diabetes (no intervention for patients with IGT): £14,150 ($27,860)/QALY Screening for diabetes and IGT followed by lifestyle interventions: £6,242 ($12,290)/QALY Screening for diabetes and IGT followed by pharmacological interventions: £7,023 ($13,828)/QALY | 50 years | No | Needed to run model for at least 30 years for cost effectiveness
Hoerger, 2007^65^ US | 1. Screening overweight and obese subjects (BMI ≥25) followed by DPP lifestyle intervention for those with both IGT and IFG; 2. Same as A except for those with either IGT or IFG or both; 3. No screening and no treatment; Population 45 to 74 years of age at screening | Markov model | DPP lifestyle intervention reduction in risk for onset of diabetes 55.3% Effect of diabetes on clinical outcomes NR | ICER compared with no screening: Strategy 1: $8,181 per QALY Strategy 2: $9,511 per QALY | Lifetime | No | DPP = lifestyle modification program with goals of 7% weight loss and 150 minutes of weekly physical activity
Kahn, 2010^52^ US | 1. Start screening at age 30 years and repeat every 3 years; 2. Start screening at age 45 years and repeat every year; 3. Start screening at age 45 years and repeat every 3 years; 4. Start screening at age 45 years and repeat every 5 years; 5. Start screening at age 60 years and repeat every 3 years; 6. Start screening when BP >140/90 mmHg and repeat every year; 7. Start screening when BP >135/80 mmHg and repeat every 5 years; 8. Start screening at age 30 years and repeat every 6 months (max screening); 9. No screening | Archimedes | Model calibrated with effects of metformin and lifestyle modification in the DPP study and effects of atorvastatin on cardiovascular risk in the CARDS trial (underestimated effect of atorvastatin on stroke, but modified to account for these effects) | ICER compared with no screening: Age 30 years, every 3 years: $10,512/QALY Age 45 years, every year: $15,509/QALY Age 45 years, every 3 years: $9,731/QALY Age 45 years, every 5 years: $9,786/QALY Age 60 years, every 3 years: $25,738/QALY Hypertension diagnosis, every year: $6,287/QALY Hypertension diagnosis, every 5 years: $6,490/QALY Age 30 years, every 6 months (max): $40,778/QALY | 50 years | Model validated for incidence of type 2 diabetes melitus and rate of hyperglycemia progression | Time and biological variables are continuous and the interaction of variables preserved with the Archimedes model compared to the Markov model
Mortaz, 2012^66^ Canada | 1. Screening for prediabetes and diabetes every 3 years; 2. Screening for prediabetes and diabetes every 5 years; 3. If patient has prediabetes, then annual screening; 4. No screening; Start screening at age 40 | Markov model | DPP lifestyle intervention reduction in incidence of diabetes by 58% Effect of diabetes on clinical outcomes NR | Costs/QALY with screening: Once every 3 years: $2,281 Once every 5 years: $2,116 Annually: $2,367 Costs for each QALY with no screening: $2,890 | 10 years | No | DPP = lifestyle modification program with goals of 7% weight loss and 150 minutes of weekly physical activity

Abbreviations: BMI = body mass index; BP = blood pressure; CARDS = Collaborative Atorvastatin Diabetes Study; DPP = Diabetes Prevention Program; HR = hazard ratio; ICER = incremental cost-effectiveness ratios; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; NR = not reported; QALY = quality adjusted life year.

No study reported the timeframe over which incremental benefits were observed with regard to time since screening. One study that included screening and management of IFG or IGT found screening to be cost-effective when modeled to a horizon of 10 years.66 Another study found that cost-effectiveness was not observed for at least 30 years after screening.64 Information about the timing of accrued benefits would be helpful for evaluating the consistency of model results with findings from the ADDITION trial, in which no benefits were observed within 10 years of screening.

Similar to the ADDITION trial, one of the modeling studies evaluated one-time screening.64 The other studies evaluated strategies that included rescreening. All of the models appeared to assume complete attendance at screening. In the ADDITION trial, 78 percent of those invited to screening participated, and primary analyses were based on invitation to screen.

One of the U.S. studies was based on the Archimedes model, focused on screening and treatment for DM, and used a 50-year time horizon.52 A strength of the Archimedes model is that assumptions regarding rates of DM progression and associated outcomes have been well validated against epidemiological and clinical studies, showing good calibration.70 In this study, beginning screening with fasting plasma glucose at age 45 years followed by rescreening every 3 years was associated with an ICER of $9,731/QALY versus no screening; beginning at age 30 years and rescreening every 3 years, with $10,512/QALY; and annual screening beginning at age 45 years, with $15,509/QALY.52 Less cost-effective strategies were waiting to start screening until age 60 ($25,738/QALY) or beginning at age 30 years and screening every 6 months ($40,778/QALY). Screening persons with hypertension was the most cost-effective strategy ($6,287/QALY to $6,490/QALY). Results were sensitive to the disutility assigned to the state of having DM diagnosed with or without symptoms. The expected number of events prevented by each screening strategy compared with no screening after 50 years of followup per 1,000 persons screened was 2 to 5 events for death, 3 to 9 events for MI, 3 to 9 events for microvascular complications, and 0 events to 1 event for stroke.52 The strategies that involved screening persons with hypertension resulted in the highest estimates of number of events prevented for each outcome.

Other modeling studies evaluated strategies that included screening and subsequent treatments for IFG or IGT. Details regarding calibration of these models against epidemiological and clinical studies were limited. A U.S. study based on a Markov model found screening for IFG or IGT (random capillary blood glucose followed by fasting plasma glucose or OGTT) followed by lifestyle interventions to be associated with ICERs of $8,181/QALY to $9,511/QALY versus no screening over a lifetime horizon.65 Findings were sensitive to assumptions regarding the effectiveness and costs of the lifestyle intervention, which were based on the DPP study. Modeling studies from the United Kingdom and Canada were generally consistent with the U.S. studies. A 2008 U.K. modeling study of screening for DM (without treatment for patients with IGT), screening for DM or IGT followed by lifestyle interventions, and screening for DM or IGT followed by pharmacological interventions in a population at above average risk reported ICERs of $27,860, $12,290, or $13,828, respectively, versus no screening based on a 50-year time horizon.64 A 2012 Canadian modeling study found that screening for DM, IFG, or IGT every 1, 3, or 5 years starting at age 40 (with annual screening in persons with IFG or IGT) dominated the nonscreening strategy (lower costs and more QALYs) over a 10-year horizon. For the three strategies, the cost/QALYs were $2,367, $2,281, and $2,116 versus $2,890 with the nonscreening strategy.66

## Contextual Question 4 Is There Evidence That Intensive Blood Pressure or Lipid Lowering or Use of Aspirin Is More Effective in Persons With Diabetes Compared With Persons Without Diabetes?

Effects of more intensive blood pressure therapy, lipid-lowering therapy, and use of aspirin in persons with DM is addressed in Key Question 5. Contextual Question 4 focuses on differences in the effectiveness of these interventions in persons with versus without DM.

The 2008 USPSTF report1 included evidence on the effect of more versus less intensive blood pressure lowering in persons with and without DM from a meta-analysis of five trials:71 four trials72-76 were older studies included in the 2003 USPSTF diabetes report,77 and the remaining study78 enrolled only persons with kidney disease and without DM, and therefore was not included in older (pre-2008) USPSTF reports. Only the Hypertension Optimal Treatment (HOT) study73 enrolled both persons with and without DM and stratified results according to DM status; the other studies enrolled patients with DM (with or without hypertension).72,74-76 Target diastolic blood pressure (DBP) in the studies ranged from either less than or equal to 75 to 85 mm Hg, or 10 mm Hg lower than DBP at baseline in the intensive groups, and less than or equal to 80 to 105 mm Hg in the standard treatment groups;72-75 one study used mean arterial pressure targets of 92 mm Hg in the intensive group and 102 to 107 mm Hg in the standard group.78 Treatment regimens varied. In the intensive groups, angiotensin-converting enzyme (ACE) inhibitors, calcium channel blockers, and/or beta blockers were used in all of the studies. The standard treatment groups received placebo or no intervention in two studies,73,78 and use of an ACE inhibitor, beta blocker, or calcium channel blocker was prohibited in the three other studies.72,74, 75 In the five studies that contributed data to the meta-analysis, mean achieved blood pressures were 139/81 mm Hg in the intensive groups and 143/84 mm Hg in the standard treatment groups, or higher than in the more recent Action to Control Cardiovascular Risk in Diabetes (ACCORD)79 and Action in Diabetes and Vascular Disease: Preterax and Diamicron Modified Release Controlled Evaluation (ADVANCE)80 trials of intensive antihypertensive therapy in persons with diabetes, in which mean achieved blood pressures were 119/64 and 136/73 mm Hg with intensive therapy, and 134/71 and 140/73 mm Hg with standard therapy, respectively (see Key Question 5).

The largest study included in the meta-analysis was the HOT trial, which enrolled 1,501 persons with DM and 17,289 persons without DM.73 Study participants had a mean baseline blood pressure of 170/105 mm Hg. All were treated with felodipine with the addition of the dose-titrated ACE inhibitors, beta blockers, and/or diuretics necessary to achieve blood pressure targets. Patients were randomized to treatment goals of DBP less than or equal to 80 mm Hg (intensive lowering) versus less than or equal to 85 or 90 mm Hg (combined as standard lowering because outcomes were very similar). Mean achieved blood pressure was 140/81 mm Hg in the intensive group and 143/84 mm Hg in the standard group. Results from the HOT trial and the overall results of the 2005 meta-analysis included in the prior USPSTF report are shown in Table 5. In HOT, intensive blood pressure lowering in patients with DM was associated with decreased risk of all-cause mortality (RR, 0.58 [95% CI, 0.34 to 0.98]) and CV mortality (RR, 0.33 [95% CI, 0.15 to 0.74]), but it was not associated with decreased risk in patients without DM (RR, 1.18 [95% CI, 0.99 to 1.40] and RR, 1.32 [95% CI, 1.01 to 1.72], respectively). Effects on CV events in persons with DM were of borderline statistical significance (RR, 0.67 [95% CI, 0.45 to 1.00]), with no effect in those without DM (RR, 1.01 [95% CI, 0.87 to 1.18]). Intensive blood pressure lowering was not associated with decreased risk of stroke in persons either with or without DM. In the meta-analysis (including HOT), intensive blood pressure lowering in persons with DM was associated with decreased risk of all-cause mortality (RR, 0.73 [95% CI, 0.56 to 0.95]), CV mortality (RR, 0.67 [95% CI, 0.40 to 1.12]), stroke (RR, 0.64 [95% CI, 0.46 to 0.89]), and CV events (RR, 0.75 [95% CI, 0.61 to 0.94]). For those without DM, intensive blood pressure lowering was associated with increased risk of CV mortality (RR, 1.30 [95% CI, 1.01 to 1.66]) and had no effect on other outcomes.

Table 5 More Versus Less Intensive Blood Pressure Control in Persons With and Without DM

2005 Meta-Analysis of Five Trials

| Intensive vs. Standard Blood Pressure Lowering (Mean Achieved BP 139/81 vs. 143/84 mm Hg) Relative Risk; 95% CI
| All-Cause Mortality | Cardiovascular Mortality | Stroke | Cardiovascular Events^a^
DM | 10% (179/1731) vs 10% (184/1868); 0.73; 0.56 to 0.95 | 6% (106/1731) vs 6% (120/1868); 0.67; 0.40 to 1.12 | 4% (63/1731) vs 5% (86/1868); 0.64; 0.46 to 0.89 | 14% (236/1731) vs 14% (262/1868); 0.75; 0.61 to 0.94
No DM | 4% (225/6303) vs 3% (365/12080); 1.07; 0.80 to 1.42 | 2% (105/6303) vs 1% (149/12080); 1.30; 1.01 to 1.66 | 2% (103/6303) vs 2% (204/12080); 0.89; 0.70 to 1.13 | 4% (266/6303) vs 4% (460/12080); 1.01; 0.87 to 1.17

a Cardiovascular events = CV mortality, stroke, CHD events, and heart failure.

b Intensive = DBP <80 mm HG; Standard = DBP ≤85 or 90 mm Hg.

c Cardiovascular events = CV mortality, nonfatal MI, nonfatal stroke.

d n/N not reported.

e Cardiovascular events = CV mortality, non-fatal stroke, non-fatal MI, aortic aneurysm, heart failure, coronary angioplasty or CABG, peripheral vascular disease requiring surgery.

Hypertension Optimal Treatment (HOT) Trial73

| Intensive vs. Standard Blood Pressure Lowering^b^ (Mean Achieved BP 140/81 vs. 143/84 mm Hg) Relative Risk; 95% CI
| All-Cause Mortality | Cardiovascular Mortality | Stroke | Cardiovascular Events^c^
DM | 3% (17/499) vs 6% (59/1002); 0.58; 0.34 to 0.98 | 1% (7/499) vs 4% (42/1002); 0.33; 0.15 to 0.74 | 3% (12/499) vs 3% (30/1002); 0.80; 0.41 to 1.56 | 6% (30/499) vs 9% (90/1002); 0.67; 0.45 to 1.00
No DM | 3% (190/5763) vs 3% (323/11526); 1.18; 0.99 to 1.40 | 2% (89/5763) vs 1% (135/11526); 1.32; 1.01 to 1.72 | 1% (77/5763) vs 2% (175/11526); 0.88; 0.67 to 1.15 | 4% (233/5763) vs 4% (460/11526); 1.01; 0.87 to 1.18

a Cardiovascular events = CV mortality, stroke, CHD events, and heart failure.

b Intensive = DBP <80 mm HG; Standard = DBP ≤85 or 90 mm Hg.

c Cardiovascular events = CV mortality, nonfatal MI, nonfatal stroke.

d n/N not reported.

e Cardiovascular events = CV mortality, non-fatal stroke, non-fatal MI, aortic aneurysm, heart failure, coronary angioplasty or CABG, peripheral vascular disease requiring surgery.

Felodipine Event Reduction (FEVER) Trial81

| Intensive vs. Standard Blood Pressure Lowering (Mean Achieved BP 138/82 vs. 142/84 mm Hg) Hazard Ratio; 95% CI^d^
| All-Cause Mortality | Cardiovascular Mortality | Stroke | Cardiovascular Events^c^
DM | 1.00; 0.56 to 1.77 | 1.01; 0.5 to 1.99 | 0.56; 0.34 to 0.92 | 0.80; 0.54 to 1.17
No DM | 0.64; 0.48 to 0.84 | 0.64; 0.45 to 0.92 | 0.77; 0.62 to 0.96 | 0.71; 0.59 to 0.86

a Cardiovascular events = CV mortality, stroke, CHD events, and heart failure.

b Intensive = DBP <80 mm HG; Standard = DBP ≤85 or 90 mm Hg.

c Cardiovascular events = CV mortality, nonfatal MI, nonfatal stroke.

d n/N not reported.

e Cardiovascular events = CV mortality, non-fatal stroke, non-fatal MI, aortic aneurysm, heart failure, coronary angioplasty or CABG, peripheral vascular disease requiring surgery.

The Felodipine Event Reduction (FEVER)81 trial on effects of more intensive blood pressure lowering,81 published since the prior USPSTF review, reported results stratified by DM status. This RCT, conducted in China, enrolled 9,711 patients with hypertension, including 1,241 persons with DM, to more intensive treatment with a calcium channel blocker and diuretic (felodipine plus hydrochlorothiazide) or standard treatment with a diuretic (hydrochlorothiazide) and placebo.81 In the FEVER trial, achieved systolic blood pressure (SBP) was similar to that in the studies described above, with little separation between groups (138 mm Hg with combination therapy vs. 142 mm Hg with diuretic monotherapy). Intensive blood pressure–lowering treatment was associated with no reduction in risk of all-cause mortality (RR, 1.00 [95% CI, 0.56 to 1.77]) or CV mortality (RR, 1.01 [95% CI, 0.51 to 1.99]) in persons with DM but was associated with decreased risk in persons with no DM (RR, 0.64 [95% CI, 0.48 to 0.84] and RR, 0.64 [95% CI, 0.45 to 0.92], respectively).81 More intensive blood pressure therapy was associated with reduced risk of stroke in both persons with diabetes (RR, 0.56 [95% CI, 0.34 to 0.92]) and without diabetes (RR, 0.77 [95% CI, 0.62 to 0.96]). Possible explanations for the conflicting findings between this study and those in the earlier meta-analysis include the shorter duration of followup (mean, 3 vs. 4 to 8 years), lower achieved blood pressures, failure to achieve separation in blood pressure rates between more intensive and standard treatments, the specific antihypertensive therapies evaluated, or differences over time in the management of patients with DM.

The prior USPSTF report did not evaluate effects of more versus less intensive lipid-lowering therapy in persons with DM versus without DM, although it determined that lipid-lowering therapy in general appeared to be similarly effective regardless of DM status.1 This conclusion was primarily based on a meta-analysis that included six studies that found lipid-lowering therapy to be associated with similarly reduced risk of CV events in persons with DM (RR, 0.79 [95% CI, 0.70 to 0.89]) and without DM (RR, 0.77 [95% CI, 0.67 to 0.88]) relative to placebo.82 These results were consistent with a more recent meta-analysis of 14 trials of statins, published since the prior USPSTF report, which found no difference in risk of vascular events in persons with DM (RR, 0.79 [95% CI, 0.72 to 0.87]) or without DM (RR, 0.79 [95% CI, 0.76 to 0.82]).83 In the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study, also published since the prior USPSTF report, persons with dyslipidemia were randomized to diet plus pravastatin or diet plus placebo.84 The study enrolled 7,892 Japanese with DM (n=1,746), IFG (n=464), or normal glucose levels (n=5,622). Estimates for risk of all-cause mortality, stroke, coronary heart disease, and CV disease were very similar for the DM, IFG, and normal glucose groups (Appendix B10).

Prior USPSTF reports1,77 included an older meta-analysis that found aspirin associated with no clear effect on risk of CV events in persons with DM (RR, 0.93 [95% CI, 0.83 to 1.07]; see Key Question 5).85 Using data from this meta-analysis, we calculated a pooled RR of 0.81 (95% CI, 0.78 to 0.83) in persons without DM. Results from two other studies included in the prior report,1 the Primary Prevention Study86 and the Women's Health Study,87 also found no benefit with aspirin use in persons with DM compared with those without DM for vascular events86 and stroke.87 We did not identify any new studies on differential effects of aspirin use versus nonuse in persons with and without DM. The USPSTF is currently in the process of updating its recommendation on aspirin for primary prevention of CV events;88 persons with DM are included as a subgroup in that review.

## Key Question 1 Is There Direct Evidence That Screening (Either Targeted or Universal) for Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance in Asymptomatic Adults Improves Health Outcomes?

### Summary

The previous USPSTF report found no RCTs on the effects of screening for DM on clinical outcomes.1 One case-control study (303 cases) found no association between screening and improvement in microvascular complications. We identified two RCTs on screening for DM versus no screening published since the prior report: the ADDITION-Cambridge trial (n=19,226)67 and a study conducted in Ely, United Kingdom (n=4,936).49,89 Both trials found no difference between invitation to screening and no invitation to screening in risk of all-cause mortality after approximately 10 years (hazard ratio [HR], 1.06 [95% CI, 0.90 to 1.25] and HR, 0.79 [95% CI, 0.63 to 1.00], respectively).

### Evidence

The good-quality ADDITION-Cambridge trial (n=19,226)67 and the fair-quality Ely trial (n=4,936)49,89 reported the effects of screening for DM on health outcomes (Appendixes B1 and B2; Table 6). The ADDITION-Cambridge trial is part of the larger ADDITION-Europe trial, an ongoing trial on effects of screening for DM, as well as effects of intensive versus standard treatment for screen-detected DM (see Key Question 5 for effects of treatment).90 Both ADDITION-Cambridge and the Ely study were conducted in the United Kingdom. Mean age of study participants ranged from 51 to 58 years, 36 to 54 percent were women, and followup was 10 years.49,67,89 Methodological shortcomings in the Ely study included inadequate detail regarding methods of randomization, unclear allocation concealment, and baseline differences between groups (Appendix B1).49

Table 6 Effect of Screening for DM on Health Outcomes

Author, Year Study Name Quality | Study Design Setting Country | Interventions | Population | Duration of Followup | Results
Simmons 2012^67^ ADDITION-Cambridge Good | Cluster RCT 33 general practices United Kingdom | A. Invited to stepwise screening of high-risk participants with random capillary blood glucose and HbA1c (n=15,089; 27 sites); A1 Invited to and attended screening (n=11,737/15,089; 78%); A2 Did not attend screening (n=3,352/15,089; 22%); B. No screening (n=4,137; 5 sites) | A vs. B Mean age 58 vs. 58 years 64% vs. 64% male Race not reported Mean BMI 30.6 vs. 30.5 kg/m^2^ Median diabetes risk score 0.34 vs. 0.35^a^ Index of Multiple Deprivation score: 12.9 (SD 7.7) vs. 16.1 (SD 9.0)^b^ | 10 years | A vs. B All-cause mortality: HR 1.06 (95% CI 0.90 to 1.25) Cardiovascular mortality: HR 1.02 (95% CI 0.75 to 1.38) Cancer mortality: HR 1.08 (95% CI 0.90 to 1.30) Diabetes-related mortality: HR 1.26 (95% CI 0.75 to 2.10) Other mortality: HR 1.10 (95% CI 0.87 to 1.39) A1 vs. A2 All-cause mortality: HR 2.01, 95% CI 1.74 to 2.32
Simmons 2011^49^ Ely cohort Fair | RCT 1 general practice United Kingdom | [underlined: Phase 1 (1990-1999)]; A. Invited to screening with OGTT; rescreening at 5 and 10 years (n=1,705); A1 Attended screening (n=1,157/1,705; 68%); A2 Did not attend screening (n=548/1,705; 32%); B. No screening (n=3,231) | [underlined: Phase 1] A vs. B Mean age 53 vs. 51 years 45% vs. 51% male Race not reported Townsend Index of Deprivation Score -1.3 vs. -1.5^c^ | [underlined: Phase 1] 10 years | [underlined: Phase 1] A vs. B All-cause mortality: HR 0.96, 95% CI 0.77 to 1.20; aHR^d^ 0.79 (95% CI 0.63 to 1.00) A1 vs. B All-cause mortality: HR 0.64, 95% CI 0.47 to 0.86; aHR 0.54, 95% CI 0.40 to 0.74) A2 vs. B All-cause mortality: HR 1.68, 95% CI 1.27 to 2.22; aHR 1.36, 95% CI 1.01 to 1.82
| | [underlined: Phase 2 (2000-2008)]^e^; A. Invited to screening; A1 Attended screening (n=714/1,577; 45%); A2 Did not attend screening (n=863/1,577; 55%); B. No screening (n=1,425) | [underlined: Phase 2] Population characteristics not reported; similar proportion of men and women in each group (data not reported) | [underlined: Phase 2] 8 years | [underlined: Phase 2] A vs. B All-cause mortality: HR 1.20, 95% CI 0.95 to 1.51; aHR 1.18, 95% CI 0.93 to 1.51 A1 vs. B All-cause mortality: HR 0.46, 95% CI 0.311 to 0.69; aHR 0.52, 95% CI 0.35 to 0.78 A2 vs. B All-cause mortality: HR 1.85, 95% CI 1.45 to 2.36; aHR 1.73, 95% CI 1.34 to 2.24
Rahman 2012^91^ Ely cohort | RCT 1 general practice United Kingdom | A. Health assessment in people with diabetes previously screened (n=92); B. Health assessment in people with diabetes not previously screened (n=60) | A vs. B Mean age: 68 vs. 66 years 47% vs. 46% female Race not reported Age at time of diabetes diagnosis 64 vs. 64 years Time since diabetes diagnosis 5 vs. 2 years (p=0.006) Proportion with screen-detected diabetes 93% vs. 31% | 12 years | A vs. B Self-reported MI: 7/92 vs. 8/60; RR 0.57, 95% CI 0.22 to 1.49 Self reported stroke: 3/92 vs. 5/60; RR 0.39, 95% CI 0.10 to 1.58 Ischemic heart disease: 30/92 vs. 28/60; RR 0.70, 95% CI 0.47 to 1.04 Nephropathy: 4/92 vs. 1/60; RR 2.61, 95% CI 0.30 to 23) Peripheral neuropathy: 39/92 vs. 32/60; RR 0.79, 95% CI 0.57 to 1.11 Peripheral vascular disease: 5/92 vs. 2/60; RR 1.63, 95% CI 0.33 to 8.13 Mean SF-36^f^ physical function score: 67.2 (SD 29.4) vs. 69.6 (SD 30.7); p=0.64 Mean SF-36 mental health score: 77.8 (SD 16.5) vs. 79.7 (SD 16.1); p=0.47

a Risk score determined using a previously validated model incorporating age, gender, BMI, use of steroids or antihypertensives, family history and smoking history.68 A risk score of 0.35 was estimated to have 41% sensitivity, 86% specificity, 12% positive predictive value, and 96% negative predictive value.

b Higher score = higher level of deprivation.

c Score >0 = greater deprivation that the mean; <0 = less deprivation than the mean.

d Adjusted for age, sex and Index of Deprivation Score.

e Participants in Phase 2 were randomly selected from those not invited to screening in Phase 1.

f Short Form Health Survey, scale 0-100. Higher score = less disability.

Abbreviations: HR = adjusted hazard ratio; BMI = body mass index; CI = confidence interval; HR = hazard ratio; MI = myocardial infarction; OGTT = oral glucose tolerance test; RR = relative risk; SD = standard deviation.

Both studies were conducted in general practices, although they used different methods to identify participants. In ADDITION-Cambridge, persons at high risk for DM (based on known risk factors) were cluster-randomized by general practice site to screening (n=16,047 participants from 27 practice sites; of 16,047 randomized participants, 15,089 [94%] were invited to screening) or no screening (n=4,137 participants from five practice sites).67 The Ely study randomly enrolled participants to screening (n=1,705) or no screening (n=3,231) from a single practice site without consideration of baseline risk of DM (study phase 1).49 Screening for DM was performed with initial random capillary blood glucose and HbA1c followed by confirmatory OGTT in the ADDITION-Cambridge study, while the Ely study used OGTT for initial screening. ADDITION participants underwent one-time screening, while Ely participants in the screening groups were invited back for subsequent screenings after 5 and 10 years. Seventy-eight percent (11,737/15,089) of those invited to screening underwent screening in the ADDITION trial,67 while participation in the Ely study was slightly lower (1,157/1,705 [68%]).49 Factors associated with attendance at screening were older age and prescription of antihypertensive medication, female sex, and lower BMI in the ADDITION study,67 and those attending screening in the Ely study were less socioeconomically disadvantaged, with younger persons and women more likely to attend in some screening cycles.49 To obtain a sufficient number of persons with screen-detected DM, 22 additional screening sites were added in the ADDITION study, with no additional nonscreening sites.67 Prevalence of DM at the time of initial screening was 3 percent in both the ADDITION-Cambridge and the Ely study.

There was no significant difference between screening and no screening in risk of all-cause mortality in either the ADDITION (HR, 1.06 [95% CI, 0.90 to 1.25])67 or Ely (unadjusted HR, 0.96 [95% CI, 0.77 to 1.20]; adjusted HR, 0.79 [95% CI, 0.63 to 1.00])67 study (Table 6). In ADDITION-Cambridge, those who were invited to screening but did not attend had a higher risk of all-cause mortality than those who were invited and attended screening (HR, 2.01 [95% CI, 1.74 to 2.32]). In the Ely study, those who were invited but did not attend screening had increased risk of mortality versus those who were not invited to screening (unadjusted HR, 1.68 [95% CI, 1.27 to 2.22]; adjusted HR, 1.36 [95% CI, 1.01 to 1.82]; Table 6).

Ten years after study initiation, in study phase 2, a subset of never-screened Ely participants were randomized to invitation to screening (n=1,577) or no screening (n=1,425). After 8 years followup, there was no difference in all-cause mortality between invitation to screening and no screening (unadjusted HR, 1.20 [95% CI, 0.95 to 1.51]; adjusted HR, 1.18 [95% CI, 0.93 to 1.51]; Table 6).49 As with the results from phase 1 of the Ely study, those who were invited but did not attend screening had increased risk of mortality versus the nonscreening group (unadjusted HR, 1.85 [95% CI, 1.45 to 2.36]; adjusted HR, 1.73 [95% CI, 1.34 to 2.24]).

There was also no difference in the ADDITION trial between screening and no screening in risk of CV mortality (HR, 1.02 [95% CI, 0.75 to 1.38]), cancer-related mortality (HR, 1.08 [95% CI, 0.90 to 1.30]), DM-related mortality (HR, 1.26 [95% CI, 0.75 to 2.10]), or death due to other causes (HR, 1.10 [95% CI, 0.87 to 1.39]; Table 6).67 Nonmortality health outcomes were not reported in either study.

Of the original 4,936 patients enrolled in phase 1 of the Ely study, 152 persons with DM (92 from the screening group; 60 from the nonscreening group) underwent additional assessment after 12 years followup.89 Diagnosis of DM occurred 3.3 years earlier in the screening group than the nonscreening group (diagnosis 5.0 vs. 1.7 years prior, p=0.006). Despite the observed lead time with screening, there was no difference in health outcomes between screening and no screening (Table 6).

## Key Question 2 What Are the Harms of Screening Adults for Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance?

### Summary

The previous USPSTF report found limited evidence on the harms of screening for DM, IFG, or IGT, and no studies reported serious psychological or other adverse effects associated with a new diagnosis of DM.1 We identified three studies on psychological effects associated with screening or a new diagnosis of DM published since the prior report. Although one study found invitation to screening for DM and a new diagnosis of DM to be associated with short-term anxiety,91 two longer term studies found no negative psychological effects associated with invitation to screening or notification of positive DM status.92,93

### Evidence

The previous USPSTF report found limited evidence on the harms of screening for DM, IFG, or IGT.1 No study reported serious psychological or other adverse effects associated with a new diagnosis of DM. The ADDITION-Cambridge study94 found that subjects who screened positive for DM reported poorer health, higher anxiety, more depression, and more DM-specific worry than those with a negative screening test at the time of screening.

We identified three studies on psychological effects of screening or a new diagnosis of DM published since the prior USPSTF report (Appendixes B1 and B2). A fair-quality pilot study for the ADDITION trial randomized 355 patients at high risk for DM.91 Participants who were invited to and attended screening and who had completed a self-rated psychological assessment (n=77/116 [66%]) reported higher scores for anxiety based on the short-form Spielberger State Anxiety Inventory (scale, 20 to 80; higher score indicates greater anx0iety; mean score, 37.6) compared with those not invited to screening (mean score, 34.1; p=0.015), measured 6 to 14 weeks after last contact with study personnel. In those screened, the six participants who were diagnosed with DM reported higher mean anxiety scores than those screened and found to not have DM (46.7 vs. 37.0; p=0.031). There was no difference between the invited and not invited groups on a single-item 5-point Likert scale on self-perceived health (invited score, 2.97 vs. not invited score, 2.95; p=0.82) and on illness representation subscales.91

A followup study of the Ely cohort found no differences after 13 years between persons initially screened and found to be without DM (n=731) versus those unscreened (n=1,694) in self-reported use of antidepressant or anxiolytic medications (p=0.4 and 0.8, respectively) or on physical and mental health summary scores on the SF-36 or the EuroQol-5D.92 Similarly, a subgroup analysis of screened ADDITION-Cambridge participants (n=3,240) found no differences between those informed that they did or did not have DM in measures of anxiety or depression (as measured by the Hospital Anxiety and Depression Scale) at 12 months followup (p-values not reported).93

We identified no studies on psychological effects associated with a diagnosis of IFG or IGT. We also identified no studies on harms associated with false-positive tests for DM, IFG, or IGT.

## Key Question 3 Do Interventions for Screen-Detected or Early Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance Provide an Incremental Benefit in Health Outcomes Compared With No Interventions or Initiating Interventions After Clinical Diagnosis?

### Summary

The prior USPSTF report identified no trials on the effects of interventions for screen-detected DM on health outcomes, and limited evidence from five trials of persons with IFG or IGT showed no clear effect on all-cause or CV mortality or other health outcomes.1 New evidence from 12 trials (in 14 publications) indicates that lifestyle modification or early use of pharmacologic interventions for glycemic control or blood pressure therapy did not reduce risk of all-cause mortality, CV mortality, or stroke, but most trials were underpowered to evaluate these outcomes.95-109 One study of lifestyle modification found a reduction in all-cause and CV mortality after 23 years followup.110 Lifestyle modification, but not metformin, was associated with better quality of life based on physical health scores in a fair-quality trial (n=3,234).100

### Evidence

The prior USPSTF report included one good-quality trial and four fair-quality trials that found no clear evidence that interventions improve health outcomes in persons with screen-detected or early DM, IFG, or IGT. We identified 13 studies (in 16 publications) published since the prior report on effects of interventions on health outcomes in these populations (Appendix B3),95-110 including longer followup or new analyses from three studies included in the prior report.99,100,108 Studies evaluated the effect of glucose-lowering agents (six studies),98,101,103,105,106,109 antihypertensive agents (two studies),99,104 and lifestyle modification (five studies in seven publications)95-97,100,102,108,110 compared with placebo or usual care. No study enrolled a screen-detected DM population. Two studies95-97 enrolled persons with early DM, and the remainder enrolled those with IFG or IGT. Mean age ranged from 45 to 64 years, and 13 to 69 percent of the population in these studies were women. Duration of followup ranged from 1 year to 23 years (median, 3 years). Six studies were rated good quality and five were rated fair quality; no studies were poor quality (Appendix B4). Limitations of the fair-quality studies were unclear methods of randomization and allocation concealment, and lack of details regarding blinding.

The effect of interventions on progression to DM in patients with IFG or IGT is discussed in Key Question 6.

#### All-Cause and Cardiovascular Mortality

Studies of glucose-lowering interventions included in the previous USPSTF report found no difference in risk of all-cause or CV mortality with rosiglitazone,15 metformin,7,13 or acarbose111 versus placebo in persons with IFG or IGT, although event rates were very low (≤1%) in all groups.

Five studies published since the prior USPSTF report evaluated risk of all-cause mortality with acarbose,105 voglibose,101 pioglitazone,98,106 or nateglinide103 versus placebo for IFG or IGT (Table 7; Appendix B3). No individual trial reported a beneficial effect on mortality. A pooled analysis of these five trials plus the three trials included in the prior USPSTF report also found no reduction in all-cause mortality after 3 to 5 years followup (RR, 1.00 [95% CI, 0.87 to 1.16]; I^2^=0%; Figure 2).7,98,99,101,103,105,106,111 Stratified analyses based on drug class did not affect the findings. Pharmacological therapies for IFG or IGT also were associated with no reduction in CV mortality (RR, 1.07 [95% CI, 0.84 to 1.35]; I^2^=0%; Figure 3), based on pooled results from three trials included in the previous report (one each of acarbose,112 metformin,13 and rosiglitazone15) plus two trials published since the prior report (one each of pioglitazone106 and nateglinide103). The pooled estimates for all-cause and CV mortality were both dominated by the large, multicountry (n=9,306) NAVIGATOR study, which compared nateglinide versus placebo and valsartan versus placebo in a 2×2 design.103

Table 7 Health Outcomes in Studies of Interventions for Screen-Detected and Early Type 2 DM, IFG, or IGT

Author, Year Country Study Design Study Name Treatment Duration Followup | Intervention and Comparison | Population | Health Outcomes | Quality
Lifestyle interventions
Andrews, 2011^95^ 217 sites + community recruitment in the United Kingdom RCT Early ACTID Treatment duration and followup: 1 year | A. Intensive dietary advice and exercise (n=246); B. Intensive dietary advice (n=248); C. Usual care (n=99) | Patients with newly diagnosed DM A vs. B vs. C Mean age: 60 vs. 60 vs. 60 years Female sex: 36% vs. 34% vs. 37% Race: 94% vs. 96% vs. 97% White; other races not reported HbA1c: 6.7 vs. 6.6 vs. 6.7% | A vs. B vs. C All-cause mortality: 0% (0/246) vs. 0% (0/248) vs. 1%(1/99); A vs. C: RR 0.14 (95% CI 0.01 to 3.31); B vs. C: RR 0.14 (95% CI 0.01 to 3.29) | Good
Davies, 2008^96^ and Khunti 2012^97^ 13 sites in the United Kingdom Cluster RCT DESMOND Treatment duration: one 6-hour education session Followup: 3 years | A. Single, 6-hour group education session focusing on lifestyle, food, physical activity and cardiovascular risk factors + standard clinical management (n=437); B. Usual care (n=387) | Patients with newly diagnosed DM A vs. B Mean age: 60 vs. 60 years Female sex: 47% vs. 43% (p<0.05) Race: 94% vs. 94% White; other races not reported HbA1c: 8.3% vs. 7.9% (p<0.05) | A vs. B Quality of life, WHOQOL-BREF – Overall satisfaction with quality of life: 4.0 vs. 4.0; p=0.48 Overall satisfaction with health: 4.0 vs. 4.0; p=0.94 | Fair
Li, 2008^102^ and Li 2014^110^ 33 centers, China Cluster RCT Da Qing DPS Treatment duration: 6 years Followup: 23 years | A. Interventions - combined lifestyle, diet, or lifestyle + diet diet intervention: increase vegetable intake and lose weight by decreasing calories from sugar and alcohol; increase leisure time physical activity (n=438); B. Control (n=138) | Patients with IGT A vs. B Mean age: 45 vs. 47 years Female sex: 47% vs. 43% Race: NR Mean BMI: 25.7 vs. 26.2 | A vs. B: 20-year results All-cause mortality: 25% vs. 29%; HR 0.96 (95% CI 0.65 to 1.41) Cardiovascular mortality: 12% vs 17%; HR 0.83 (95% CI 0.48 to 1.40) Cardiovascular events: 41% vs 44%; HR 0.98 (95% CI 0.71 to 1.37) A vs. B: 23-year results All-cause mortality: 28% (121/430) vs. 38% (53/138); HR 0.71 (95% CI 0.51 to 0.99) Cardiovascular mortality: 12% (51/430) vs. 20% (27/138); HR 0.59 (95% CI 0.36 to 0.96) | Fair
Saito, 2011^107^ 38 centers in Japan RCT Treament duration: 3 years Followup: 3 years | A. Individual lifestyle counseling session aimed at decreasing body weight and increasing physical activity with follow up at 1, 3, 6, 12, 18, 24, 30, and 36 months (n=330); B. Usual care (n=311) | Patients with IFG A vs. B Mean age: 50 vs. 48 years Female sex: 28% vs. 29% Race not reported Mean BMI 26.9 vs. 27.1 kg/m2 Mean HbA1c 5.4% vs. 5.4% | A vs. B All-cause mortality: 0.3% (1/311) vs. 0% (0/330); RR 3.18 (95% CI 0.13 to 78) | Fair
Uusitupa, 2009^107^ Finnish DPS 5 centers in Finland RCT Followup: 11-14 years (varied by intervention group) | A. Intensive diet and counseling group (n=257); B. Control group (n=248) | Patients with IGT and BMI >25 kg/m^2^ A vs. B Mean age: 55 vs. 55 Female sex: 66% vs. 68% Race not reported BMI: 31.4 vs. 31.2 kg/m^2^ | A vs. B All-cause mortality: 2.2 vs. 3.8 events/1,000 person years; HR 0.57; 95% CI 0.21 to 1.58 Cardiovascular events: 22.9 vs. 22.0 events/1,000 person-years; HR 1.04; 95% CI 0.72 to 1.51 | Fair
Pharmacologic interventions
DeFronzo, 2011^98^ 8 centers in United States RCT Followup: 2.4 years | A. Pioglitazone 30 mg/day for one month, increased to 45 mg/day (n=303); B. Placebo (n=299) | Patients with IGT, BMI > 25, and ≥1 other RF diabetes A vs. B Mean age: 53 vs. 52 years Female sex: 58% vs. 58% Race: 51% vs. 57% White; 26 vs. 25% Hispanic; 19% vs. 15% Black; 3% vs. 3% other Mean BMI: 33.0 vs. 34.5 kg/m^2^ Mean HbA1c: 5.5% vs. 5.5% | A vs. B All-cause mortality: 1% (3/303) vs. 0.3% (1/299); RR 2.96; 95% CI 0.31 to 28 Cardiovascular events: 9% (26/303) vs. 8% (23/299); RR 1.11; 95% CI 0.65 to 1.91 | Fair
DREAM Trial Investigators, 2008^98^ 191 centers in 21 countries RCT Followup: 3 years | A. Ramapril 15 mg/day (n=2623); B. Placebo (n=2646); C. Rosiglitazone 0.8mg/day (n=2635); D. Placebo (n=2634); Patients randomized twice, to ramapril or placebo and rosiglitazone or placebo | Patients with IFG or IGT A vs. B & C vs. D Mean age: 55 vs. 55 years & 55 vs. 55 years Female sex: 60% vs. 59% & 58% vs. 60% Race not reported | A vs. B Total mortality: 1 % (31/2623) vs. 1% (32/2646); HR 0.98, 95% CI 0.60 to 1.61 Cardiovascular mortality: 0.5% (12/2623) vs. 0.4% (10/2646); HR 1.21, 95% CI 0.52 to 2.80 Cardiovascular events: 3% (69/2623) vs. 2% (64/2646); HR 1.09, 95% CI 0.78 to 1.53 MI: 0.5% (14/2623) vs. 0.4% (11/2646); HR 1.29, 95% CI 0.59 to 2.84 Stroke: 0.2% (4/2623) vs. 0.3% (8/2646); HR 0.50, 95% CI 0.15 to 1.66 Renal events: 14% (353/2623) vs. 14% (365/2646); HR 0.97; 95% CI 0.83 to 1.14 C vs. D Total mortality: 1% (30/2635) vs. 1% (33/2634); RR 0.91, 95% CI 0.56 to 1.49 Cardiovascular mortality: 0.5% (12/2635) vs. 0.4% (10/2634); HR 1.20, 95% CI 0.52 to 2.77 Cardiovascular events: 3% (77/2635) vs. 2% (56/2634); HR 1.38, 95% CI 0.98 to 1.95 MI: 0.6% (16/2635) vs. 0.3% (9/2634); HR 1.78, 95% CI 0.79 to 4.03 Stroke: 0.3% (7/2635) vs. 0.2% (5/2634); HR 1.40, 95% CI 0.44 to 4.40 Renal events: 7% (193/2635) vs. 7% (185/2634); HR 1.18; 95% CI 0.88 to 1.57 | Good
Kawamori, 2009^100^ 103 centers in Japan RCT Treatment duration: 5 years Followup: 3 years | A. Voglibose 0.2 mg/day (n=897); B. Placebo (n=881) | Patients with IFG A vs. B Mean age 56 vs. 56 years Female sex: 40% vs. 40% Race not reported | A vs. B All-cause mortality: 0.7% (6/897) vs. 0% (0/881); RR 13; 95% CI 0.72 to 226 | Good
NAVIGATOR, 2010^102^ (Nateglinide results) 806 centers in 40 countries RCT Followup: 5 years | A. Nateglinide 60 mg/3 times daily (n=4645); B. Placebo (n=4661); Patients also randomized in 2×2 factorial design to receive valsartan or placebo | Patients with IGT and at least one CV risk factor or known CVD A vs. B Mean age: 64 vs. 64 years Female sex: 51% vs. 50% Race: 83% vs. 83% White; 3% vs. 3% Black; 7% vs. 8% Asian; 8% vs. 8% other Mean BMI: 30.5 vs. 30.5 kg/m^2^ HbA1c: 5.8% vs. 5.8% | A vs. B All-cause mortality: 7% (310/4645) vs. 7% (312/4661); RR 1.00; 95% CI 0.86 to 1.16; HR 1.00; 95% CI 0.85 to 1.17 Cardiovascular mortality: 3% (126/4645) vs. 4% (118/4661); RR 1.07; 95% CI 0.84 to 1.37; HR 1.07; 95% CI 0.83 to 1.38 Stroke: 4% (111/4645) vs. 3% (126/4661); HR 0.89; 95% CI 0.69 to 1.15 | Good
NAVIGATOR, 2010^103^ (Valsartan results) 806 centers in 40 countries RCT Followup: 5 years | A. Valsartan 160 mg/once daily (n=4631); B. Placebo (n=4675); Patients also randomized in 2×2 factorial design to receive nateglinide or placebo | Patients with IGT and at least one CV risk factor or known CVD A vs. B Mean age: 64 vs. 64 years Female sex: 50% vs. 51% Race: 83% vs. 83% White; 2% vs. 3% Black, 6% vs. 7% Asian, 8% vs. 8% other Mean BMI: 30.4 vs. 30.6 kg/m^2^ HbA1c: 5.8% vs. 5.8% | A vs. B All-cause mortality: 6% (295/4631) vs. 12% (327/4675); HR 0.90; 95% CI 0.77 to 1.05 Cardiovascular mortality: 3% (128/4631) vs. 3% (116/4675); HR 1.09; 95% CI 0.85 to 1.40 MI: 3% (138/4631) vs. 3% (140/4675); HR 0.97; 95% CI 0.77 to 1.23 Heart failure requiring hospitalization: 2% (91/4631) vs. 2% (94/4675); HR 0.97; 95% CI 0.72 to 1.29 Stroke: 2% (105/4631) vs. 3% (132/4675); HR 0.79; 95% CI 0.61 to 1.02 | Good
Nijpels, 2008^104^ 1 center in The Netherlands RCT DAISI Treatment duration: 3 years | A. Acarbose 50 mg/3 times daily (n=60); B. Placebo (n=58) | Patients with IGT A vs. B Mean age: 59 vs. 57 years Female sex: 49% vs. 50% Race not reported Mean BMI: 28.4 vs. 29.5 kg.m^2^ HbA1c: 5.9% vs. 5.6% | A vs. B All-cause mortality: 2% (1/60) vs. 5 % (3/58); RR 0.32; 95% CI 0.03 to 3.01 | Fair
Ramachandran, 2009^105^ India RCT IDPP-2 Followup: 3 years | A. Pioglitazone (n=181); B. Placebo (n=186) | Patients with IGT A vs. B Mean age 45.1 vs. 45.5 Female sex: 13% vs. 14% Race not reported | A vs. B All-cause mortality: 1% (2/203) vs. 0.5% (1/203); RR 2.00; 95% CI 0.18 to 22 Cardiovascular mortality: 0.9% (2/204) vs. 0% (0/203); RR 4.98; 95% CI 0.24 to 103 | Fair
Zinman, 2010^108^ 2 centers in Canada RCT CANOE Treatment duration: NR Followup: 4 years | A. Metformin 500 mg plus rosiglitazone 2 mg/twice daily as a fixed dose combination (n=103); B. Placebo (n=104) | Patients with IGT and ≥one risk factor for DM A vs. B Mean age: 50 vs. 55 years Female sex: 65% vs. 68% Race: 75% vs. 74% White; 8% vs. 7% South Asian; 7% vs. 7% Latino, 11% vs. 13% other | A vs. B Myocardial infarction: 0% (0/103) vs. 1% (1/104), RR 0.34, 95% CI 0.01 to 8.17 Congestive heart failure: 0% (0/103) vs. 1% (1/104), RR 0.34, 95% CI 0.01 to 8.17 | Good
Lifestyle and pharmacologic interventions
Florez 2012^100^ 27 centers in the U.S. RCT Diabetes Prevention Program Treatment duration: 3 years Followup: 5 years | A. Intensive lifestyle intervention, including diet and exercise to achieve modest weight reduction (n=1048); B. Metformin 850 mg/twice daily (n=1043); C. Placebo (n=1041) | Patients with IGT and BMI ≥24 kg/m^2^ (≥22 kg/m^2^ in Asian Americans) A vs. B vs. C Mean age: 51 vs. 51 vs. 50 years Female sex: 68% vs. 66% vs. 69% Race: 54% vs. 56% vs. 54% White; 19% vs. 21% vs. 20% Black; 17% vs. 15% vs. 16% Hispanic; 9% vs. 8% vs. 10% Other | A vs. C Quality of life, SF-36 score changes from baseline, mean between-group difference:; - SF-6D: 0.0084 (SD 0.0041; p<0.05); - PCS: 1.57 (SD 0.30; p<0.01); - MCS: -0.29 (SD 0.32; p=NS); - Physical function: 3.58 (SD 0.66; p<0.01); - Body pain: 1.93 (SD 0.78; p<0.01); - General health: 3.23 (SD 0.66; p<0.01); - Vitality: 2.05 (SD 0.77; p<0.01); B vs. C Quality of life, SF-36 score changes from baseline, mean between-group difference:; - SF-6D: 0.0019 (SD 0.0041; p=NS); - PCS: 0.15 (SD 0.30; p=NS); - MCS: 0.22 (SD 0.32; p=NS); - Physical function: 0.13 (SD 0.71; p=NS); - Body pain: 0.50 (SD 0.78; p=NS); - General health: 0.06 (SD 0.66; p=NS); - Vitality: 0.09 (SD 0.76; p=NS) | Good

Abbreviations: WHOQOL-BREF = World Health Organization Quality of Life Assessment, short version. Scale 1-5 for each domain; higher score = higher quality of life.

Figure 2 Meta-Analysis of the Effect of Glucose-Lowering Drugs on All-Cause Mortality in Persons With Screen-Detected and Early DM, IFG, or IGT

* From prior report

This figure is a meta-analysis forest plot. Risk ratios of the effect of glucose-lowering interventions for screen-detected or early type 2 diabetes mellitus, impaired fasting glucose, or impaired glucose tolerance were calculated for 8 studies, with a pooled risk ratio of 1.00, 95% CI of 0.87 to 1.16, and an I-squared value of 0%.

Figure 3 Meta-Analysis of the Effect of Glucose-Lowering Drugs on Cardiovascular Mortality in Persons With Screen-Detected and Early DM, IFG, or IGT

* From prior report

This figure is a meta-analysis forest plot. Risk ratios of the effect of glucose-lowering drugs on cardiovascular mortality in persons with screen-detected or early type 2 diabetes mellitus, impaired fasting glucose, or impaired glucose tolerance were calculated for 5 studies, with a pooled risk ratio of 1.07, 95% CI of 0.84 to 1.35, and an I-squared value of 0%.

Trials of antihypertensive medication for IFG or IGT also found no reduction in all-cause or CV mortality with ramipril (HR, 0.98 [95% CI, 0.60 to 1.61] and HR, 1.21 [95% CI, 0.52 to 2.80])14,99 or valsartan (HR, 0.90 [95% CI, 0.77 to 1.05] and HR, 1.09 [95% CI, 0.85 to 1.40])104 versus placebo after 3 and 7 years, respectively, in persons with IFG or IGT (Table 7; Appendix B3).

Three studies of lifestyle modification interventions versus usual care included in the prior report and one study published since the prior report found no difference in all-cause mortality between groups after 1 to 3 years followup in persons with early DM, IFG, or IGT, although they were underpowered to evaluate this outcome.6,7,13,95 There remained no difference in all-cause mortality after 10 years followup in the Finnish Diabetes Prevention Study (DPS) in persons receiving intensive diet and exercise counseling versus a control group given general health behavior information (HR, 0.57 [95% CI, 0.21 to 1.58]; Appendix B3).108

Results were similar in another study of lifestyle modification (either diet or exercise alone, or diet plus exercise) versus general DM or IGT health information in risk of all-cause and CV mortality after 20 years followup (HR, 0.96 [95% CI, 0.65 to 1.41] and HR, 0.83 [95% CI, 0.48 to 1.40], respectively).102 However, after 23 years followup, both all-cause mortality (HR, 0.71 [95% CI, 0.51 to 0.99]) and CV mortality (HR, 0.59 [95% CI, 0.36 to 0.96]) were significantly reduced in the lifestyle-modification group (Table 7).110 Limitations of the study include a relatively small sample size (n=577; 439 in the intervention group and 138 in the control group). Also, mortality was not a prespecified outcome and study participants were not regularly monitored beyond the 6-year intervention; deaths were ascertained using hospital records and physician interviews. Additionally, the study was conducted in China, which may limit applicability to a U.S. population.

#### Cardiovascular Events

One fair-quality trial included in the prior report found that acarbose for IGT was associated with reduced risk of acute MI (HR, 0.09 [95% CI, 0.01 to 0.72]) and total CV events, including MI, new angina, revascularization, CV death, congestive heart failure, cerebrovascular events, and peripheral vascular disease (HR, 0.51 [95% CI, 0.28 to 0.95]) versus placebo.112 However, three additional good-quality trials of nateglinide103 and rosiglitazone with109 or without99 metformin and one fair-quality trial of pioglitazone98 published since the prior USPSTF report found no beneficial effect on risk of MI versus placebo when patients were followed for 2 to 5 years (Table 7; Appendix B3).

Two studies of antihypertensive medications in patients with IFG or IGT found no reduction in risk of MI with ramipril (HR, 1.29 [95% CI, 0.59 to 2.84])99 or valsartan (HR, 0.97 [95% CI, 0.77 to 1.23])104 versus placebo after 3 and 5 years followup, respectively. Risk estimates for heart failure were imprecise or showed no effect (HR, 3.06 [95% CI, 0.99 to 9.48] for ramipril; HR, 0.97 [95% CI, 0.72 to 1.29] for valsartan; Table 7; Appendix B3).

Two trials7,13 included in the prior USPSTF report found no difference in CV events or CV morbidity with lifestyle modification versus usual care in patients with IGT or IFG.1 These results were consistent with 10 and 20 years followup in the Finnish DPS108 and the Da Qing102 studies, respectively (two fair-quality studies of diet, exercise, or diet plus exercise and physical activity, weight reduction, and dietary counseling, respectively, published since the prior report), although event rates were low in both studies (Table 7; Appendix B3).

#### Stroke

A fair-quality study included in the prior USPSTF report found no difference in risk of stroke with acarbose versus placebo (HR, 0.56 [95% CI, 0.10 to 18.30]),112 and two studies published since the prior USPSTF report found no association between rosiglitazone (HR, 1.40 [95% CI, 0.44 to 4.40]99) or nateglinide (HR, 0.89 [95% CI, 0.69 to 1.15])103 versus placebo in risk of stroke after 3 years and 5 years, respectively. Trials of the antihypertensive medications ramipril (HR, 0.50 [95% CI, 0.15 to 1.66])99 and valsartan (HR, 0.79 [95% CI, 0.61 to 1.02])104 also showed no effects on risk of stroke versus placebo in persons with IFG or IGT after 5 years (Table 7; Appendix B3).

#### Renal Disease

No studies reported incidence of serious renal disease as an individual outcome. The large (n=5,269) multicountry 2×2 factorial design DREAM trial, which compared ramapril versus placebo and rosiglitazone versus placebo, reported a composite renal outcome that included intermediate (e.g., progression from normal albuminuria to microalbuminuria) and clinical (renal insufficiency requiring dialysis or transplantation) outcomes. It found rosiglitazone (HR, 0.80 [95% CI, 0.68 to 0.93]) but not ramipril (HR, 0.97 [95% CI, 0.83 to 1.14]) to be associated with reduced risk versus placebo after 3 years (Table 7; Appendix B3).99

#### Quality of Life

Two studies reported quality of life measures. Followup from the Diabetes Prevention Program study (n=3,234)100 found an intensive lifestyle intervention to be associated with better SF-36 scores for general health (+3.2; p<0.01), physical function (+3.6; p<0.01), bodily pain (+1.9; p<0.01), and vitality (+2.1; p<0.01) versus placebo (Appendix B3). In the same study, there was no difference between metformin and placebo on quality of life measures. A second study that compared usual care plus a single education session with usual care and no education component in persons with newly diagnosed diabetes found no difference in quality of life measures at 1 year96 and 3 years followup.97

## Key Question 4 What Are the Harms of Interventions for Screen-Detected or Early Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance?

### Summary

The previous USPSTF report1 found no studies that reported serious harms and no studies of harms associated with interventions in persons with screen-detected DM. Most studies conducted in persons with IFG or IGT included in the 2008 USPSTF report found no differences in withdrawal rates between lifestyle or pharmacologic interventions and placebo or usual care.

Studies of interventions for screen-detected or early DM, IFG, or IGT published since the 2008 USPSTF report found few differences between lifestyle or pharmacologic interventions versus usual care or placebo in risk of harms, although evidence was limited. One trial found that acarbose was associated with higher risk of withdrawal due to adverse events versus placebo.105 Rosiglitazone was associated with increased congestive heart failure in one trial, although the estimate was imprecise (HR, 7.04 [95% CI, 1.60 to 31]).99 There was also no difference in risk of serious adverse events between interventions and placebo or usual care in three other studies,101, 106,107 but few events were reported. A large good-quality study found nateglinide to be associated with increased risk of hypoglycemia versus placebo (20% vs. 11%; RR, 1.73 [95% CI, 1.57 to 1.92]) and valsartan to be associated with increased risk of hypotension-related adverse events (42% vs. 36%; RR, 1.16 [95% CI, 1.11 to 1.23]).103,104

### Evidence

The previous USPSTF report1 found no studies of harms associated with interventions for screen-detected DM. Most studies conducted in persons with IFG or IGT included in the 2008 USPSTF report found no differences in withdrawal rates between lifestyle or pharmacologic interventions versus control placebo or usual care,4,6,113 although one study reported a higher risk of withdrawal with acarbose versus placebo (RR, 1.63 [95% CI, 1.34 to 1.97]).111 For treatment of DM in general (not restricted to screen-detected cases), systematic reviews included in the 2008 USPSTF report found hypoglycemia to be more common with sulfonylureas versus other glucose-lowering drugs (e.g., metformin, TZDs) and with glyburide versus other secretagogues (RR, 1.83 [95% CI, 1.21 to 1.92]) and other sulfonylureas (RR, 1.83 [95% CI, 1.35 to 2.49]).1

We identified four good- and five fair-quality trials published since the 2008 USPSTF report that reported harms associated with interventions for screen-detected or early DM, IFG, or IGT (Appendix B5).96-98,101,103-107,109 The fair-quality studies had unclear methods of randomization, allocation concealment, and/or blinding (Appendix B4). One study was conducted in persons with screen-detected or early DM, and the other seven enrolled persons with IFG or IGT. Two studies evaluated the effects of lifestyle interventions96,97,107 and seven evaluated pharmacologic interventions, including TZDs (three studies),98,106 alpha-glucosidase inhibitors (two studies),101, 105 nateglinide and valsartan (one study),103,104 metformin (one study),179 and combination therapy (one study).109 Sample sizes ranged from 118 to more than 9,000 participants, and duration of followup was from 1 to 5 years. No study was specifically designed to assess harms.

Withdrawals due to adverse events were reported in three studies of pharmacologic interventions published since the 2008 USPSTF report. Two of these studies reported no difference in risk of withdrawals between active intervention and placebo (Appendix B5).101,103,104 In the other study, acarbose was associated with higher risk of withdrawal due to adverse events than placebo (37% vs. 14%; RR, 2.66 [95% CI, 1.29 to 5.48]).105 This finding was consistent with a study of acarbose versus placebo included in the prior USPSTF report (29% vs. 18%; RR, 1.63 [95% CI, 1.34 to 1.97]).111

Two trials found that pioglitazone (50% vs. 42%; RR, 1.23 [95% CI, 1.03 to 1.47])98 and voglibose (90% vs. 85%; RR, 1.06 [95% CI, 1.02 to 1.10])101 were associated with increased risk of any adverse event versus placebo. In these trials, serious adverse events were rare, with no difference between voglibose (0.6% vs. 0.2%; RR, 2.46 [95% CI, 0.48 to 13])101 or pioglitazone (2% vs. 5%; RR, 0.41 [95% CI, 0.13 to 1.29])106 versus placebo. Rosiglitazone was associated with increased congestive heart failure (HR, 7.04 [95% CI, 1.60 to 31]) in the DREAM trial, although this estimate was imprecise.99 A placebo-controlled trial of acarbose included in the prior report112 and three trials of pioglitazone,98 nateglinide,103 or metformin plus rosiglitazone109 published since the prior report found no new or worsening heart failure events, although few events were reported in three of these trials (Appendix B3).98,109,112 One trial found nateglinide to be associated with increased risk of hypoglycemia versus placebo (20% vs. 11%; RR, 1.73 [95% CI, 1.57 to 1.92]) and valsartan to be associated with increased risk of hypotension-related adverse events (42% vs. 36%; RR, 1.16 [95% CI, 1.11 to 1.23]).103,104 Two trials found no difference between pioglitazone98 or metformin plus rosiglitazone109 versus placebo in risk of cancer, although the trials were not designed to evaluate this outcome and were underpowered (Appendix B5). No trial of metformin reported risk of lactic acidosis, while one trial reported no differences in serious or not serious hypoglycemia or serious anemia.179

Two studies on educational lifestyle interventions versus usual care published since the prior review reported few adverse events, with no difference in risk of all-cause withdrawal rates in one study (5% vs. 6%; RR, 0.81 [95% CI, 0.45 to 1.44)96 and no serious adverse events in the other study (Appendix B5).107

No observational study of harms associated with pharmacological interventions focused on populations with screen-detected or early DM.

## Key Question 5 Is There Evidence That More Intensive Glucose, Blood Pressure, or Lipid Control Interventions Improve Health Outcomes in Adults With Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance Compared With Traditional Control? Is There Evidence That Aspirin Use Improves Health Outcomes in These Populations Compared With Nonuse?

### Summary

The previous USPSTF report included no studies of more versus less intensive glucose, blood pressure, or lipid control for screen-detected DM.1 For DM not specifically screen detected, the prior report found intensive glycemic control to be associated with reduced risk of various composite vascular events and intensive blood pressure control to be associated with reduced CV morbidity, and no evidence on the effect of intensive lipid control on health outcomes versus standard therapy.1 The prior USPSTF report also included a systematic review that found aspirin use in persons with DM to be associated with a small, non–statistically significant benefit in reducing risk of CV events (RR, 0.93 [95% CI, 0.83 to 1.07]).85

The ADDITION-Europe study of persons with newly screen-detected DM (baseline HbA1c, 6.5%), published since the prior report, found no difference between treatment with an intensive multifactorial intervention aimed at glucose, blood pressure, and lipid-lowering and standard treatment in risk of all-cause mortality (HR, 0.91 [95% CI, 0.69 to 1.21]), CV mortality (HR, 0.83 [95% CI, 0.65 to 1.05]), MI (HR, 0.70 [95% CI, 0.41 to 1.21]), stroke (HR, 0.98 [95% CI, 0.57 to 1.71]), or revascularization (HR, 0.79 [95% CI, 0.53 to 1.18]) after 5 years.68,69

For DM not specifically identified by screening, many good-quality systematic reviews found fair- to good-quality consistent evidence that intensive glucose lowering to a target HbA1c of from less than 6 to 7.5 percent was associated with no reduction in all-cause or CV mortality compared with less intensive therapy.114-124 Intensive glucose-lowering therapy was associated with reduced risk of nonfatal MI in six reviews (pooled RR range, 0.83 to 0.87) and retinopathy in three reviews (pooled RR, 0.75 to 0.80).114,117,118,121,122,124

Intensive blood pressure lowering reduced risk of all-cause mortality and stroke in a good-quality systematic review,125 but large, recently published trials are inconsistent with respect to the effects of more versus less intensive blood pressure therapy in patients with DM. The ADVANCE trial80,126 found the addition of an ACE inhibitor plus diuretic to be associated with decreased risk of all-cause and CV mortality, and the ACCORD study127,128 found no difference between an SBP target of 140 versus 120 mm Hg in risk of all-cause or CV mortality. Limited evidence from two trials of persons with DM found no benefit from the addition of a fibrate to statin monotherapy or the addition of statin to lifestyle interventions in risk of all-cause or CV mortality.84,129 Two trials found that use of multifactorial interventions in persons with DM aimed at more intensive glucose, blood pressure, and/or lipid lowering was associated with reduced risk of all-cause and CV mortality.130,131 Two good-quality systematic reviews found fair-quality evidence of no effect of aspirin use versus nonuse on health outcomes in persons with DM, including all-cause mortality, CV mortality, MI, and stroke.132,133

### Evidence

We identified 13 good-quality systematic reviews (Appendixes B6, B7, and B8)114-125,134 and 10 trials in 33 publications (Appendixes B9, B10, and B11)68,69,79,80,84,126-131,135-156 published since the prior USPSTF report on the effects of more intensive glucose, blood pressure, or lipid control or the use of aspirin on health outcomes. They include the primary publications of the treatment phase of the ADDITION trial (conducted in persons with screen-detected DM),68,69 the large ACCORD127,128 and ADVANCE trials,80,126,145 and their many substudies. Four of the trials were rated fair quality68,69,84,148-151 and the remainder were rated good quality. Common limitations of the fair-quality trials were unclear methods of randomization and treatment allocation (Appendix B11). Studies ranged in size from 160 to more than10,000 participants, with followup from 3 to 13 years; mean age was 53 to 72 years. Only the ADDITION trial enrolled a screen-detected DM population;68,69,135-137 all other trials enrolled persons with DM not specifically screen detected.

#### Screen-Detected Diabetes

The prior USPSTF report included no studies of more versus less intensive glucose, blood pressure, or lipid control for screen-detected DM.1 The recently published findings from the fair-quality treatment phase of the ADDITION-Europe trial evaluated effects of more intensive treatment for screen-detected DM (Appendix B9).68,69,138 Patients, but not caregivers, were blinded to treatment allocation. Study participants were residents of Denmark (n=1,533), the United Kingdom, (n=1,026), or the Netherlands (n=498) and newly diagnosed with DM through screening. Mean HbA1c was 6.5 percent, about one fourth of participants were smokers, mean BMI was 31.5 kg/m^2^ (meeting criteria for obesity), and 6 to 7 percent had a history of MI at the time of enrollment. The study used a cluster-randomized design in which care centers were randomized to a multifactorial intervention that included use of intensive glucose, blood pressure, and lipid-lowering targets (HbA1c <7.0%, blood pressure <135/85 mm Hg, and total cholesterol ≤4.5 to 5.0 mmol/L, respectively) plus a lifestyle education component (n=1,678) or standard targets according to local guidelines (n=1,379). In the intensive treatment group, selection of glucose, blood pressure, or lipid-lowering therapy was determined using a prespecified treatment algorithm, and aspirin could be added if deemed necessary by caregivers. Participants were followed for 5 years or until the first CV event (the primary outcome), which included CV mortality, nonfatal MI or stroke, revascularization, or nontraumatic amputation (Appendix B9).68

There was no difference between groups in incidence of first CV event after adjustment for country (HR, 0.83 [95% CI, 0.65 to 1.05]).68 Intensive treatment was also associated with no reduction in risk of all-cause mortality (HR, 0.83 [95% CI, 0.65 to 1.05]) or CV mortality (HR, 0.88 [95% CI, 0.51 to 1.51]), stroke (HR, 0.98 [95% CI, 0.57 to 1.71]), MI (HR, 0.70 [95% CI, 0.41 to 1.21]), or revascularization (HR, 0.79 [95% CI, 0.52 to 1.18]; Appendix B9). Results for all-cause mortality varied by study country (I^2^=55%): intensive treatment was associated with lower risk in the United Kingdom (HR, 0.59 [95% CI, 0.35 to 0.98]), but not the Netherlands (HR, 0.91 [95% CI, 0.69 to 1.21]) or Denmark (HR, 1.15 [95% CI, 0.80 to 1.66]). Results for CV mortality showed a similar pattern when stratified by country, but none of the estimates were statistically significant. Both mortality and CV event rates were lower than anticipated, and there was little difference between groups in final HbA1c, blood pressure, and total cholesterol values (Appendix B9).68 There was no difference in self-reported measures of general and DM-specific quality of life in ADDITION-Europe participants after 5 years followup (Appendix B9).138

Analyses of 1,161 ADDITION-Denmark participants found no difference between intensive and standard treatment in measures of neuropathy after 6 years (Appendix B9).135 In the ADDITION-Netherlands trial (n=498), there was no difference between intensive and standard treatment in most measures of quality of life, based on the SF-36 and DM-specific scales. However, intensive treatment was associated with slightly worse (lower) SF-36 mental health component scores after 3 years of followup (76 vs. 80; p=0.04).136,137

#### Diabetes Not Specifically Screen Detected

Glucose control. The prior USPSTF report found that intensive glycemic control in persons with DM was associated with reduced risk of various vascular events.1 This was largely based on a meta-analysis of six trials that found reduced risk of macrovascular events (RR, 0.81 [95% CI, 0.73 to 0.91]; I^2^=53%), peripheral vascular events (RR, 0.58 [95% CI, 0.38 to 0.89]; I^2^=0%), and cerebrovascular events (RR, 0.58 [95% CI, 0.46 to 0.74]; I^2^=53%) but no reduction in cardiac events (RR, 0.91 [95% CI, 0.80 to 1.03]; I^2^=2%).157

We identified 11 good-quality systematic reviews on the effect of intensive glucose control on vascular outcomes published since the prior report (Appendixes B6 and B7).114-124 The reviews had substantial overlap in included studies, although a few were more comprehensive (Appendix B12).115,117,118 One of the largest and most recent reviews117 analyzed evidence from 14 trials (n=28,614), including the good-quality ACCORD trial,127ADVANCE80 trial, and the Veterans Affairs Diabetes Trial (VADT),156 all published since the prior USPSTF report. Eleven of the studies included in this review were conducted in patients with established DM (duration, 3 to 12 years), although three older studies in the review enrolled persons with newly or recently diagnosed DM.158-160 Six of the included studies were judged to have low risk of bias based on assessment of allocation methods, blinding, outcome reporting, and potential for other sources of bias. The studies did not report the proportion of patients diagnosed by screening or through other methods. In four studies the glucose control target was HbA1c less than or equal to 6.5 percent; in four studies, HbA1c less than 7 to 7.5 percent; and in the remaining five studies, fasting blood glucose less than 6.6 to 6.1 mmol/L or normalization of fasting blood glucose.

The review found no difference between intensive versus standard glucose control and risk of all-cause mortality (12 studies; RR, 1.02 [95% CI, 0.91 to 1.12]; I^2^=30%) or CV mortality (12 studies; RR, 1.11 [95% CI, 0.92 to 1.35]; I^2^=46%; Table 8).117 These results are consistent with findings reported in the other systematic reviews (Appendix B7). Intensive glucose control was associated with lower risk of nonfatal MI versus standard control (eight studies; 4% vs. 5%; RR, 0.85 [95% CI, 0.76 to 0.95]; I^2^=0%). Risk of retinopathy was also reduced with intensive glucose control (seven studies; 12% vs. 14%; RR, 0.80 [95% CI, 0.67 to 0.94]; I^2^=59%), although heterogeneity was high and estimates were not consistently significant in the four other reviews114,115,118,123 that assessed risk of retinopathy (Appendix B7). Across the 11 systematic reviews, there was no difference between intensive and standard glucose control for most other outcomes, including stroke and renal disease.

Table 8 Intensive Glucose Control and Health Outcomes in a Systematic Review of 14 Trials

Outcome | Number of Studies | Number of Patients | | Relative Risk; 95% CI
Outcome | Number of Studies | Intensive Control | Conventional Control | Relative Risk; 95% CI
All-cause mortality | 12 | 1460/15142 | 1111/13217 | 1.02, 0.91 to 1.13; I^2^=30%
Cardiovascular mortality | 12 | 765/15142 | 545/13217 | 1.11, 0.92 to 1.35; I^2^=46%
Non-fatal MI | 8 | 644/15017 | 593/13094 | 0.85, 0.76 to 0.95; I^2^=0%
Microvascular outcomes^a^ | 3 | 1331/13770 | 1312/11830 | 0.88, 0.79 to 0.97; I^2^=45%
Retinopathy | 7 | 740/6175 | 660/4618 | 0.80, 0.67 to 0.94; I^2^=59%
Nephropathy | 8 | 3402/14675 | 3497/13094 | 0.83, 0.64 to 1.06; I^2^=75%
Severe hypoglycemia | 9 | 1094/14887 | 380/12957 | 2.39, 1.71 to 3.34; I^2^=73%

a Microvascular outcomes = presence or progression of nephropathy or retinopathy, end-stage renal disease, and retinal photocoagulation.

Abbreviations: CI = confidence interval; MI = myocardial infarction

Three major trials published since the prior report each found no benefit of intensive versus standard glucose control on clinical outcomes.126-128,156 Target HbA1c was from less than 6.0 percent to less than or equal to 6.5 percent in the intensive glucose control groups in all three studies. In the ACCORD study (n=10,251), intensive treatment was associated with significantly increased risk of all-cause mortality (HR, 1.21 [95% CI, 1.02 to 1.44]) and a nonsignificant increase in risk of CV mortality (HR, 1.27 [95% CI, 0.99 to 1.63]; Appendix B10).127,128 As a result, study participants receiving intensive glucose control were transitioned to standard control after about 4 years of followup. One year after the transition to standard treatment, the risk estimates were similar to earlier findings (all-cause mortality: HR, 1.19 [95% CI, 1.03 to 1.38]; CV mortality: HR, 1.29 [95% CI, 1.04 to 1.60]). The VADT study of 1,791 primarily male U.S. veterans found no difference between intensive and standard glucose control and all-cause mortality (HR, 1.07 [95% CI, 0.81 to 1.42]) or CV mortality (HR, 1.32 [95% CI, 0.81 to 2.14]), although estimates were in the same direction as ACCORD.156 Participants in the VADT trial had somewhat higher baseline HbA1c levels than those in ACCORD (9.4% vs. 8.3%), longer duration of DM (12 vs. 10 years), and similar rates of previous CV events (40% vs. 35%). The ADVANCE trial, which enrolled 11,140 participants with less severe DM (mean HbA1c, 7.5%) and of shorter duration (mean, 8 years), also found no difference between intensive and standard treatment in all-cause mortality (RR, 0.93 [95% CI, 0.83 to 1.05]) or CV mortality (RR, 0.88 [95% CI, 0.74 to 1.03]) (Appendix B10).126

The ACCORD-Eye study found a significant reduction in progression of retinopathy with intensive glucose control (RR, 0.70 [95% CI, 0.55 to 0.89]) compared with standard control in a subgroup of ACCORD participants (n=2,856),143 although there was no difference between groups for this outcome in the VADT study (RR, 0.86 [95% CI, 0.66 to 1.13]).156 There were no differences in either the ACCORD and VADT studies between intensive and standard glucose control in risk of other vascular outcomes, such as stroke, congestive heart failure, or sudden death (Appendix B10).127,128,156

Long-term post-trial monitoring data from the good-quality U.K. Prospective Diabetes Study (UKPDS) has also been published since the prior USPSTF report.154 Although the UKPDS concluded in 1997, continued followup of participants has been performed to determine the long-term effects of intensive glucose (target, <6.0 mmol/L) and blood pressure lowering (target, <150/85 mm Hg, discussed in the following section). Based on earlier UKPDS results, the 2003 USPSTF report noted a nonsignificant reduction in risk of MI with intensive glucose control (RR, 0.84 [95% CI, 0.71 to 1.0]), with no difference between intensive and standard groups for other CV outcomes.77 With additional followup (mean, 10 years) intensive treatment was associated with reduced risk of all-cause and DM-related mortality (RR, 0.88 [95% CI, 0.82 to 0.94] and RR, 0.85 [95% CI, 0.76 to 0.94]), and risk of MI remained reduced (RR, 0.86 [95% CI, 0.78 to 0.95]; Appendix B10).154

A separate analysis of data from the ADVANCE trial found no difference between intensive and standard glucose control and risk of various cancers or cancer mortality (Appendix B10).146 These results were consistent with those reported in a meta-analysis of the ACCORD, UKPDS, and VADT studies (RR, 1.03 [95% CI, 0.83 to 1.29]).161 An analysis of a random subset of ACCORD participants found no clinically meaningful difference in quality of life between intensive and standard treatment in SF-36 and DM-specific quality of life measures,144 and the ACCORD-Bone substudy found no difference in risk of fractures or falls139 (Appendix B10).

Blood pressure control. The 2008 USPSTF report found that more intensive blood pressure control was associated with reduced CV morbidity compared with standard treatment.1 This conclusion was based on four studies72-76 included in the 2003 USPSTF report,77 as well as a subsequent meta-analysis of comparative effects of antihypertensive treatments on mortality and CV events in persons with and without DM (described in Contextual Question 4).71 We identified two additional good-quality systematic reviews published since the 2008 report (Appendixes B6 and B7).125,134 These two reviews included five trials (n=8,332) and 13 trials (n=37,736) of more versus less intensive blood pressure lowering, respectively, and both included data from the blood pressure–lowering arms of ADVANCE and ACCORD (discussed below). The larger review excluded studies with an achieved SBP of greater than 140 mm Hg in the standard treatment group, studies that reported less than 3 mm Hg difference between intensive and standard treatment groups, and studies of patients with type 1 diabetes.125 The review also included two studies of persons with IFG; one was included in the previous USPSTF report14 and the other,104 published since the prior report, is included in Key Question 6. Ten of the studies were assessed as having a low risk of bias, using quality assessment based on method of treatment allocation and blinding. Baseline HbA1c in participants in the included studies ranged from 6 to 11.5 percent in 10 studies reporting HbA1c levels, and duration of followup ranged from 2 to 7 years.

Results of the two meta-analyses are summarized in Table 9. The number of studies pooled for specific outcomes varied slightly between the reviews, but risk estimates were generally consistent. Intensive blood pressure control (achieved SBP ≤135 mm Hg) was associated with reduced risk of all-cause mortality (RR, 0.90 [95% CI, 0.82 to 0.98]; I^2^=0%) compared with standard control (achieved BP ≤140 mm Hg).125 Intensive blood pressure treatment was also associated with reduced risk of stroke (RR, 0.83 [95% CI, 0.73 to 0.95]; I^2^=27%^125^ and RR, 0.61 [95% CI, 0.48 to 0.79]; I^2^=0%^134^), although the effect was most pronounced when lower blood pressure targets were achieved (SBP ≤130 mm Hg; RR, 0.53 [95% CI, 0.38 to 0.75]; I^2^=0%).125 There was no difference between intensive and standard blood pressure control in risk of CV mortality, MI, or heart failure.125,134

Table 9 Summary of Meta-Analyses of Intensive Versus Standard Blood Pressure Control in Persons With DM

| Number of Studies; Intensive vs. Standard Blood Pressure Control RR, 95% CI; I^2^ (if reported)
Study | All-Cause Mortality | CV Mortality | Stroke | Myocardial Infarction | Heart Failure | Other Outcomes
Bangalore, 2011^125^ | 12 studies; 0.90, 0.82 to 0.98; I^2^=0% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 6 studies; 0.87, 0.79 to 0.95; I^2^=0% SBP ≤130 mm Hg, 6 studies; 1.04, 0.86 to 1.25; I^2^=0% | 7 studies; 0.93, 0.82 to 1.06; I^2^=7% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 4 studies; 0.90, 0.78 to 1.03; I^2^=29% SBP ≤130 mm Hg, 3 studies; 1.11, 0.82 to 1.52; I^2^=0% | 9 studies; 0.83, 0.73 to 0.95; I^2^=27% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 5 studies; 0.90, 0.78 to 1.03; I^2^=0% SBP ≤130 mm Hg, 4 studies; 0.53, 0.38 to 0.75; I^2^=0% | 8 studies; 0.92, 0.80 to 1.06; I^2^=0% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 4 studies; 0.92, 0.76 to 1.11; I^2^=13% SBP ≤130 mm Hg, 4 studies; 0.92, 0.80 to 1.06; I^2^=0% | 6 studies; 0.90, 0.75 to 1.06; I^2^=48% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 3 studies; 0.82, 0.66 to 1.02; I^2^=45% SBP ≤130 mm Hg, 3 studies; 1.03, 0.78 to 1.35; I^2^=54% | Nephropathy: 5 studies; 0.73, 0.64 to 0.84; I^2^=61% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 3 studies; 0.83, 0.68 to 1.00; I^2^=0% SBP ≤130 mm Hg, 2 studies; 0.64, 0.53 to 0.78; I^2^=83%
Reboldi, 2011^134^ | 12 studies; 0.90, 0.82 to 0.98; I^2^=0% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 6 studies; 0.87, 0.79 to 0.95; I^2^=0% SBP ≤130 mm Hg, 6 studies; 1.04, 0.86 to 1.25; I^2^=0% | 7 studies; 0.93, 0.82 to 1.06; I^2^=7% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 4 studies; 0.90, 0.78 to 1.03; I^2^=29% SBP ≤130 mm Hg, 3 studies; 1.11, 0.82 to 1.52; I^2^=0% | 5 studies; 0.61, 0.48 to 0.79; I^2^=0% | 5 studies; 0.87, 0.74 to 1.02; I^2^=0% | 6 studies; 0.90, 0.75 to 1.06; I^2^=48% Results stratified according to achieved SBP: SBP ≤135 mm Hg, 3 studies; 0.82, 0.66 to 1.02; I^2^=45% SBP ≤130 mm Hg, 3 studies; 1.03, 0.78 to 1.35; I^2^=54%

Abbreviations: CI = confidence interval; CV = cardiovascular; RR = relative risk; SBP = systolic blood pressure.

The two major new trials on effects of more versus less intense blood pressure control on clinical outcomes in persons with DM are the good-quality ACCORD-BP79 and ADVANCE80 trials (Appendix B10). Long-term post-treatment followup of the UKPDS has also become available.155 The studies had important differences in design and patient demographics. The ACCORD-BP trial included 4,733 participants randomized to intensive (target SBP <120 mm Hg) or standard (target SBP <140 mm Hg) blood pressure control. Mean blood pressure at baseline was 139/76 mm Hg. After 1 year of treatment, participants in the intensive arm were taking an average of three blood pressure medications, compared with two blood pressure medications in the standard group; the proportion of patients taking an ACE inhibitor (60% vs. 52%), angiotensin II receptor blocker (ARB) (41% vs. 30%), or either (90% vs. 80%) was slightly higher in the intensive therapy group than the standard therapy group. Mean blood pressures were 119/64 versus 134/71 mm Hg, respectively, at 1 year, and blood pressure control remained stable through 5 years of followup.79 The ADVANCE trial (n=11,140) did not utilize a specific blood pressure target. Rather, participants were randomized to a fixed-dose ACE inhibitor–diuretic combination (perindopril plus indapamide) or placebo added onto their existing therapy. Mean baseline blood pressures were 145/81 mm Hg in both groups. At 5 years followup, mean blood pressure was 136/73 mm Hg in the perindopril/indapamide group and 140/73 mm Hg in the placebo group. Thus, the “intensive” group in ADVANCE achieved marginally higher SBP and DBP readings than the “standard” ACCORD group. In the UKPDS cohort, differences in blood pressures between the intensive and standard blood pressure control groups at the beginning of the post-trial monitoring period (143/79 vs. 152/82 mm Hg; p<0.001) did not persist with longer followup, and no attempt was made to maintain treatments.155 All three studies used different composite outcomes as the primary outcome but also reported results for individual outcomes (Appendix B10).

Results from the four studies included in the prior reports and the ACCORD and ADVANCE trials are summarized in Table 10. There are some inconsistencies between the ACCORD and ADVANCE trials. The ADVANCE trial found that intensive blood pressure control was associated with decreased risk of all-cause (RR, 0.87 [95% CI, 0.76 to 0.98]) and CV mortality (RR, 0.82 [95% CI, 0.69 to 0.98]).80 The ACCORD trial found no differences between intensive versus standard treatment in risk of all-cause mortality (RR, 1.11 [95% CI, 0.89 to 1.38]) or CV mortality (RR, 1.04 [95% CI, 0.73 to 1.48]), but decreased risk of fatal and nonfatal stroke (RR, 0.58 [95% CI, 0.39 to 0.88]).79 Long-term post-trial followup of UKPDS participants found no difference between intensive versus standard therapy in risk of all-cause mortality (RR, 0.89 [95% CI, 0.75 to 1.06]) or stroke (RR, 0.77 [95% CI, 0.55 to 1.07]).155 None of the studies reported differences between intensive and standard blood pressure control in other outcomes, including MI, heart failure, renal failure, retinopathy, neuropathy, and quality of life (Table 10; Appendix B10).

Table 10 Trials of Variably Defined Intensive Versus Standard Blood Pressure Control in Persons With DM

| | | Intensive vs. Standard BP Lowering, RR (95% CI)
Study n Duration of Followup | Interventions | BP: Baseline; Target; Achieved (mm Hg) | All-Cause Mortality | CV Mortality | Stroke | Myocardial Infarction | Other Outcomes
ABCD (H)74,* n=470 5 years | Intensive: nisoldipine or enalapril, plus open label antihypertensives to achieve target DBP Standard: nisoldipine or enalapril | [underlined: Baseline] Intensive: 156/98 Standard: 154/98 [underlined: Target] Intensive: DBP ≤75 Standard: DBP 80-89 [underlined: Achieved] Intensive: 132/78 Standard: 138/86 | 6% (13/237) vs. 10% (25/233); 0.51 (0.27 to 0.97) | | | 7% (16/237) vs. 6% (14/233); 1.12 (0.56 to 2.25) | Nephropathy: 7% (16/237) vs. 10% (23/233); 0.68 (0.37 to 1.26)
ABCD (N)75,* n=480 5 years | Intensive: nisoldipine 10-60mg/day or enalapril 5-40 mg/day Standard: placebo | [underlined: Baseline] Intensive: 136/84 Standard: 137/84 [underlined: Target] Intensive: DBP decrease of ≥10 Standard: no DBP decrease (DBP 80-89) [underlined: Achieved] Intensive: 128/75 Standard: 137/81 | 8% (18/237) vs. 8% (20/243); 0.92 (0.50 to 1.70) | 5% (13/237) vs. 4% (9/243); 1.48 (0.65 to 3.40) | 2% (4/237) vs. 5% (13/243); 0.32 (0.10 to 0.95) | 8% (19/237) vs. 6% (15/243); 1.30 (0.68 to 2.50) | Congestive heart failure: 5% (12/237) vs. 5% (11/243); 1.12 (0.50 to 2.49)
ACCORD79 n=4732 5 years | Intensive: use of antihypertensives necessary to reach target according to a prespecified treatment algorithm Standard: usual care | [underlined: Baseline] Intensive:139/76 Standard: 139/76 [underlined: Target] Intensive: SBP <120 Standard: SBP <140 [underlined: Achieved] Intensive: 119/64 Standard: 134/71 | 6% (150/2363) vs. 6% (144/2371); 1.11 (0.89 to 1.38) | 3% (60/2363) vs. 2% (58/2372); 1.04 (0.73 to 1.48) | 2% (36/2363) vs. 3% (62/2371); 0.58 (0.39 to 0.88) | 5% (126/2362) vs. 6% (146/2371); 0.87 (0.69 to 1.09) | Fatal or nonfatal heart failure: 4% (83/2363) vs. 4% (90/2371); 0.93 (0.69 to 1.24) Loss of visual acuity: 35% (819/2339) vs. 36% (849/2352); 0.97 (0.90 to 1.05) Score >2 on Michigan Neuropathy Screening Instrument: 53% (722/1353) vs. 56% (781/1388); 0.95 (0.89 to 1.02)
ADVANCE80 n=11140 4 years | Intensive: addition to existing BP regimen of fixed-dose combination of perindoprilindapamide; no target set Standard: existing BP regimen with addition of placebo | [underlined: Baseline] Intensive: 145/81 Standard: 145/81 [underlined: Target] Intensive: No target Standard: No target [underlined: Achieved] Intensive: 136/73 Standard: 140/73 | 7% (408/5569) vs. 9% (471/5571); 0.87 (0.76 to 0.98) | 4% (211/5569) vs. 5% (257/5571); 0.82 (0.69 to 0.98) | | | Renal events: 22% (1243/5569) vs. 27% (1500/5571); 0.83 (0.78 to 0.89) New or worsening retinopathy: 5% (289/5569) vs. 5% (286/5571); 1.01 (0.86 to 1.19) New or worsening nephropathy: 3% (181/5569) vs. 4% (216/5571); 0.84 (0.69 to 1.02)
HOT73,* n=1501 with DM 4 years | Intensive: felodipine + others added incrementally if needed to reach target Standard: felodipine | [underlined: Baseline] Intensive: 170/105 Standard: 170/105 [underlined: Target] Intensive: DBP ≤80 Standard: DBP ≤85 or 90 [underlined: Achieved] Intensive: 140/81 Standard: 143/84 | 3% (17/499) vs. 6% (59/1002); 0.58 (0.34 to 0.94) | 1% (7/499) vs. 4% (42/1002); 0.33 (0.15 to 0.74) | 2% (12/499) vs. 3% (30/1002); 0.80 (0.41 to 1.56) | 3% (15/499) vs. 3% (34/1002); 0.89 (0.49 to 1.61)
UKPDS72,* n=1148 8 years | Intensive: captopril or atenolol + others added incrementally if needed to reach target Standard: no use of ACE inhibitors or beta blockers | [underlined: Baseline] Intensive: 160/93 Standard: 160/93 [underlined: Target] Intensive: <150/85 Standard: <180/105 [underlined: Achieved] Intensive: 143/79 Standard: 152/22 | 18% (134/758) vs. 21% (83/390); 0.83 (0.65 to 1.06) | 1% (7/499) vs. 4% (42/1002); 0.33 (0.15 to 0.74) | 5 %(38/758) vs. 9% (34/390); 0.58 (0.37 to 0.90) | 14% (107/758) vs. 18% (69/390); 0.80 (0.60 to 1.05) | Diabetes-related death: 11% (82/758) vs. 16% (62/390); 0.68 (0.50 to 0.92)
UKPDS n=1148 16 years (8 years on trial + 8 years post-trial monitoring) | Intensive: captopril or atenolol + others added incrementally if needed to reach target Standard: no use of ACE inhibitors or beta blockers | [underlined: Baseline] Intensive: 160/93 Standard: 160/93 [underlined: Target] Intensive: <150/85 Standard: <180/105 [underlined: Achieved] Intensive: 143/79 Standard: 152/22 | 49% (373/758) vs. 54% (211/390); 0.89 (0.75 to 1.06) | | 12% (90/758) vs. 15% (58/390); 0.77 (0.55 to 1.07) | 27% (205/758) vs. 29% (115/390); 0.90 (0.71 to 1.13) | Diabetes-related death: 27% (203/758) vs. 31% (122/390); 0.84 (0.67 to 1.05)

* Included in previous USPSTF reviews.

Abbreviations: BP = blood pressure; CI = confidence interval; CV = cardiovascular; RR = relative risk; SBP = systolic blood pressure.

Some potential reasons for the differences between the results of the ACCORD and ADVANCE trials include the use of different types of interventions (blood pressure treated to target vs. the addition of a specific medication combination), differences in the blood pressures achieved with the intervention, and others (e.g., differences in populations).162,163 In addition, the annual rate for the primary outcome (CV mortality, nonfatal MI, and nonfatal stroke) in the standard treatment group of the ACCORD study was only about half the anticipated rate (actual rate of 2% per year vs. anticipated rate of 4% per year), potentially reducing statistical power.79

Lipid control. The previous USPSTF report1 did not include any studies of intensive versus standard lipid control in persons with DM, although it did include studies comparing the differential effects of lipid-lowering therapy in persons with and without DM (see Contextual Question 4). We identified two trials published since the prior USPSTF report on effects of additional lipid-lowering therapies in persons with DM (Appendix B10). The ACCORD-Lipid substudy analyzed 5,518 participants randomized to simvastatin plus fenofibrate versus simvastatin plus placebo; it did not utilize specific lipid targets.129 HbA1c was 8.3 percent in both groups at baseline and lipid levels were similar (total cholesterol, approximately 175 mg/dL and low-density lipoprotein, approximately 100 mg/dL). There was no significant difference in all-cause (RR, 0.91, [95% CI, 0.76 to 1.10]) or CV mortality (RR, 0.86 [95% CI, 0.66 to 1.13]), or in most individual (e.g., stroke, MI, heart failure) or composite outcomes. However, lipid lowering was associated with a reduction in progression of retinopathy in a subgroup of 2,856 ACCORD participants (RR, 0.63 [95% CI, 0.45 to 0.89]; Appendix B10).143 The second study (MEGA) enrolled persons with and without DM (see Contextual Question 4).84 Study participants with DM (n=1,746; mean HbA1c, 6.9%) were randomized to pravastatin plus diet or diet alone. There was no difference between groups in risk of all-cause or CV mortality, stroke, cerebral infarction, or composite vascular outcomes (Appendix B10).

Multifactorial interventions. The 2008 USPSTF evidence report did not include studies of more versus less intensive multifactorial interventions for glucose, blood pressure, or lipid lowering in persons with DM.1 We identified three good-quality studies130,131,152,153 and one fair-quality study148 (reported in five publications) on the effects of combined glucose, blood pressure, and lipid lowering on health outcomes (Table 11; Appendix B10). Duration of followup ranged from 3 to 15 years (median, 6 years). The multifactorial interventions varied in studies and were based on treatment algorithms148,152,153 or recommended protocols.130 For example, the ADVANCE trial added perindopril plus indapamide for blood pressure lowering and gliclazide modified release for glucose control in the intensive group, compared with placebo and physician-determined glucose-lowering regimens in the standard group.130 In the Steno-2 trial, a single-center trial in Denmark, participants in the intensive control group received an ACE inhibitor (or an ARB if an ACE inhibitor was contraindicated), aspirin, a multivitamin supplement, diet and exercise recommendations, and if HbA1c levels were not adequately controlled with diet and exercise alone, an oral hypoglycemic. In the trials, adjustments to blood pressure– and glucose-lowering agents could be made based on the treatment algorithms. The trials also varied in their use of targets. For example, the ADVANCE trial evaluated the addition of an ACE inhibitor–diuretic drug combination without a blood pressure target.130 In the three studies that utilized blood pressure targets, the Stop Atherosclerosis in Native Diabetics Study (SANDS) used a lower SBP target (<115 mm Hg) than the other two studies (<130 mm Hg).131,148,152,153 Although glucose, blood pressure, and lipid levels were reduced with intensive treatment in all of the studies, targets were generally not met in any study (Table 11).

Table 11 Effects of Multifactorial Interventions on Health Outcomes in Persons with DM Not Specifically Screen-Detected

Study Followup n | Target Values | | Baseline Values | | Values at End of Followup | | Outcomes Intensive vs. Standard Control^a^
Study Followup n | Intensive Group | Standard Group | Intensive Group | Standard Group | Intensive Group | Standard Group | Outcomes Intensive vs. Standard Control^a^
ADVANCE130 4 years n=5566 | HbA1c: ≤6.5% BP: no target | Usual care targets | HbA1c: 7.5% BP: 145/81 mm Hg | HbA1c: 7.5% BP: 145/81 mm Hg | HbA1c: 6.9% BP: 138/78 mm Hg | HbA1c: 7.5% BP: 145/81 mm Hg | All-cause mortality: 7% (198/2783) vs 9% (240/2783); RR 0.83 (95% CI 0.70 to 0.99) CV mortality: 4% (104/2783) vs 5% (136/2783); RR 0.76 (95% CI 0.60 to 0.98)
JEDIT148 6 years n=1173 | HbA1c: <6.9% BP: <130/85 mm Hg TC: <180 mg/dL | Usual care targets | HbA1c: 8.4% BP: 138/74 TC: 202 mg/dL | HbA1c: 8.5% BP: 137/75 mm Hg TC: 202 mg/dL | HbA1c: 7.7% BP: 134/71^b^ mm Hg TC: 188 mg/dL | HbA1c: 7.8% BP: 134/71 mm Hg TC: 190 mg/dL | Events and p-values of between-group comparisons (numbers for groups NR) Death due to diabetes: 35 events (p=0.85) Death not related to diabetes: 59 events (p=0.30) Fatal MI: 12 events (p=0.08) Sudden death: 13 events (p=0.99) Fatal stroke: 6 events (p=0.66) Death due to renal failure: 3 events (p=0.08) Death due to hyper/hypoglycemia: 1 event (p=0.32) Nonfatal MI: 17 events (p=1.0) Any stroke: 67 events (p=0.29)
SANDS152,153 3 years n=499 | BP: ≤115/75 mm Hg LDL-C: <70 mg/dL Non-HDL-C: <100 mg/dL | BP: <130/85 mm Hg LDL-C: <100 mg/dL Non-HDL-C: <130 mg/dL | BP: 128/74 mm Hg LDL-C: 104 mg/dL Non-HDL-C: 138 mg/dL | BP: 133/76 mm Hg LDL-C: 104 mg/dL Non-HDL-C: 140mg/dL | BP: 117/67^b^ mm Hg LDL-C: 72 mg/dL Non-HDL-C: 102 mg/dL | BP: 129/73^b^ mm Hg LDL-C: 104 mg/dL Non-HDL-C: 138 mg/dL | Non-CV death: 0.8% (2/252) vs. 2% (4/247); RR 0.49 (95% CI 0.09 to 2.65)
Steno-2^131^ 13 years n=160 | HbA1c: <6.5% BP: <130/80 mm Hg TC: <150 mg/dL | Usual care targets | HbA1c: 8.4% BP: 146/85 mm Hg TC: 210 mg/dL | HbA1c: 8.8% BP: 149/86 mm Hg TC: 233 mg/dL | HbA1c: 7.7% BP: 140/74^b^ mm Hg TC: 147^b^ mg/dL | HbA1c: 8.0% BP: 146/73^b^ mm Hg TC: 155 mg/dL | All-cause mortality: 30% (24/80) vs. 50% (40/80); RR 0.60 (95% CI 0.40 to 0.90) CV mortality: 11% (9/80) vs. 24% (19/80); RR 0.47 (95% CI 0.23 to 0.98) MI: 10% (8/80) vs. 26% (21/80); RR 0.38 (95% CI 0.18 to 0.81) Stroke: 8% (6/80) vs. 23% (18/80); RR 0.33 (95% CI 0.14 to 0.80) Nephropathy: 25% (20/80) vs. 46% (37/80); RR 0.44 (95% CI 0.25 to 0.77) Retinopathy: 51% (41/80) vs. 68% (54/80); RR 0.57 (95% CI 0.37 to 0.88)

a Additional outcomes reported in Appendix B10.

b Target achieved; in some cases values were lower than target levels at baseline.

Abbreviations: BP = blood pressure; CI = confidence interval; CV = cardiovascular; HDL-C = high-density lipoprotein-cholesterol; LDL-C = low-density lipoprotein-cholesterol; MI = myocardial infarction NR = not reported; RR = relative risk; TC = total cholesterol

The intensive multifactorial intervention was associated with reduced risk of all-cause mortality in the ADVANCE (RR, 0.83 [95% CI, 0.70 to 0.99])130 and Steno-2 trials (RR, 0.60 [95% CI, 0.40 to 0.90]).131 The multifactorial intervention was also associated with lower risk of CV mortality in these trials (RR, 0.76 [95% CI, 0.60 to 0.98] and RR, 0.47 [95% CI, 0.23 to 0.98], respectively). However, results from the fair-quality Japanese Elderly Diabetes Intervention Trial (JEDIT) (n=1,173), which enrolled an older population than the other studies (mean age, 72 vs. 55 to 66 years) with a longer duration of DM at baseline (approximately 17 vs. 8 years in the ADVANCE trial), found no difference between intensive and standard groups for any outcome after 6 years.148 Absolute event rates were lower in this study than in the ADVANCE and Steno-2 trials. There was an 8-percent incidence of all-cause mortality in JEDIT, compared with 15 and 40 percent in the ADVANCE and Steno-2 trials after 5 and 13 years, respectively. Risk estimates could not be calculated for this study, making comparisons with the other trials difficult. Both the ADVANCE and Steno-2 trials found the multifactorial intervention to be associated with reduced risk of nephropathy (RR, 0.68 [95% CI, 0.51 to 0.89] and RR, 0.44 [95% CI, 0.24 to 0.77]).130,131 The good-quality SANDS found no difference between intensive and standard groups in incidence of CV events, a composite outcome that included fatal coronary heart disease, fatal and nonfatal MI and stroke, and need for revascularization procedures (RR, 1.35 [95% CI, 0.55 to 3.29]).152 Results for other outcomes were inconsistent between trials and are reported in Appendix B10.

Aspirin. The previous USPSTF report found that aspirin use in persons with DM was associated with relatively small benefit in reducing the risk of CV events.1 This conclusion was based on data from DM subgroups in a meta-analysis of nine studies (n=5,000 patients approximately) that found aspirin use to be associated with a slightly reduced risk of vascular events (including CV events and stroke).85 Based on the data provided in the meta-analysis, we calculated a pooled RR of 0.93 (95% CI, 0.83 to 1.07). The prior report also included two studies published subsequent to the meta-analysis that reported DM subgroup data. These studies found no effect of aspirin use versus nonuse on risk of CV events,86,87 although there was a significant reduction in risk of stroke in women taking aspirin in one study (RR, 0.83 [95% CI, 0.69 to 0.99]).87

We identified one fair-quality trial (in two publications149,150) and two good-quality systematic reviews132,133 published since the previous USPSTF report on the association between aspirin use and health outcomes in persons with DM. One other study of aspirin use versus nonuse was excluded because it included persons with type 1 diabetes and did not stratify results according to population.164

The Japanese Primary Prevention of Atherosclerosis with Aspirin for Diabetes (JPAD) trial randomized 2,539 persons with diabetes to daily aspirin use or nonuse (Appendix B10).149,150 After 4 years, there was no difference in risk of atherosclerotic events, a composite outcome (e.g., coronary heart disease, MI, and stroke) (68/1,262 [5%] vs. 86/1,277 [7%]; HR, 0.80 [95% CI, 0.58 to 1.10]). There was also no significant difference in risk of individual outcomes between groups, with the exception of coronary and cerebrovascular mortality (1/1,262 [0.08%] vs. 10/1,277 [0.8%]; HR, 0.10 [95% CI, 0.01 to 0.79]), although the absolute incidence for all outcomes was low.

Consistent with the meta-analysis included in the prior USPSTF report, a more recent good-quality systematic review132 of six studies (n >10,000 persons with DM), including the JPAD trial, found no difference between aspirin use and nonuse and risk of all-cause mortality (four studies; RR, 0.93 [95% CI, 0.82 to 1.05]; I^2^=0%), CV mortality (four studies; RR, 0.94 [95% CI, 0.72 to 1.23]; I^2^=57%), major CV events (five studies; RR, 0.90 [95% CI, 0.81 to 1.0]; I^2^=0%), MI (six studies; RR, 0.86 [95% CI, 0.61 to 1.21]; I^2^=62%), and stroke (five studies; RR, 0.83 [95% CI, 0.60 to 1.14]; I^2^=53%), although some heterogeneity was present in most analyses (Appendix B7). Sensitivity analyses found no effect based on aspirin dose or treatment duration for most outcomes. However, risk of stroke was significantly reduced when analyses were restricted to aspirin dose <100 mg/day (p=0.02), to studies of greater than 5 years duration (p=0.01), and to patients who adhered to aspirin therapy (p=0.02). A second good-quality systematic review that included most of the same trials reported very similar risk estimates and found no significant difference between aspirin use and nonuse for any outcome (Appendix B7).133

#### Persons With IFG or IGT

We identified one study of intensive versus standard lipid therapy in persons with IFG.84 It was a subgroup analysis from the large Japanese MEGA trial151 of persons with hypercholesterolemia (mean total cholesterol of 243 mg/L and low-density lipoprotein cholesterol of 156 mg/L). It found no differences between diet plus pravastatin versus diet alone on risk of health outcomes, including all-cause mortality, stroke, and coronary heart disease, after 5 years followup (Appendix B10). We identified no study on effects of intensive glucose or blood pressure control versus standard control in persons with IFG or IGT.

## Key Question 6 What Are the Harms of More Intensive Interventions Compared With Traditional Control in Adults With Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance?

### Summary

The prior USPSTF report did not include evidence on harms associated with more versus less intensive glucose, blood pressure, or lipid control or with aspirin use versus nonuse.1 Four good-quality systematic reviews found that intensive glucose control was associated with increased risk of severe hypoglycemia.115,117,121,123 More intensive blood pressure–lowering therapy was associated with increased risk of serious adverse events in the ACCORD study (RR, 2.58 [95% CI, 1.70 to 3.91])79 but not the ADVANCE study (RR, 1.02 [95% CI, 0.72 to 1.42]).80 Results for other outcomes were inconsistent between trials and are reported in Appendix B10. Aspirin was associated with an increased risk of major and gastrointestinal bleeding in a good-quality systematic review, although heterogeneity was high (I^2^=66% and 72%) for both estimates (RR, 3.02 [95% CI, 0.48 to 19] and RR, 2.12 [95% CI, 0.63 to 7.08], respectively).133

### Evidence

The previous USPSTF report did not include evidence on harms associated with more versus less intensive glucose, blood pressure, or lipid control or with aspirin use versus nonuse,1 and harms were not reported in most trials published since the prior report (Appendix B10).

Glucose-lowering therapy was associated with increased risk of severe hypoglycemia (four systematic reviews; pooled RR range, 1.76 to 2.39; Appendix B7).115,117,121,123 Definitions for severe hypoglycemia varied across studies, and included documentation of glucose <50 mg/dL and events requiring medical assistance (ranging in severity from cognitive impairment to coma or seizure). The ACCORD and VADT studies both also found intensive therapy to be associated with increased risk of serious nonhypoglycemia adverse events requiring medical intervention (2.4% vs. 1.6%; RR, 1.44 [95% CI, 1.09 to 1.90] and 24% vs. 18%; RR, 1.37 [95% CI, 1.14 to 1.65]).128,156 Serious adverse events were also more likely in the intensive blood pressure–lowering group of the ACCORD-BP trial (3% vs. 1%; RR, 2.58 [95% CI, 1.70 to 3.91])128 but not in the ADVANCE blood pressure–lowering trial (RR, 1.02 [95% CI, 0.72 to 1.42]).80 The ACCORD-Lipid substudy found no significant difference between intensive lipid lowering and standard treatment in rates of serious adverse events (RR, 1.29 [95% CI, 0.96 to 1.74]).129 The use of an intensive multifactorial intervention resulted in higher rates of serious adverse events in SANDS (27% vs. 15%; RR, 1.72 [95% CI, 1.21 to 2.47])152 but not in incidence of severe hypoglycemia in the Steno-2 trial (RR, 0.71 [95% CI, 0.34 to 1.51]).131

In the JPAD trial of aspirin use versus nonuse, serious adverse events were rare, with no difference in incidence between aspirin use and nonuse groups.149,150 A good-quality systematic review of six studies of aspirin use versus nonuse found that aspirin increased risk of major bleeding (two studies; RR, 3.02 [95% CI, 0.48 to 19]; I^2^=66%) and gastrointestinal bleeding (three studies; RR, 2.12 [95% CI, 0.63 to 7.08]; I^2^=72%) events in persons with DM, although risk estimates were not statistically significant and heterogeneity was high.133

## Key Question 7 Do Interventions for Impaired Fasting Glucose or Impaired Glucose Tolerance Delay or Prevent Progression to Type 2 Diabetes?

### Summary

The previous USPSTF report1 found that lifestyle and pharmacologic interventions were associated with decreased risk of progression to DM in patients with IFG or IGT.1 Sixteen studies (in 18 publications) published since the prior report evaluated the effects of multifactorial, lifestyle, and pharmacologic interventions on risk of subsequent DM in patients with IFG or IGT at baseline.98,101-104,110,165 Two studies of multifactorial interventions found no effect on risk of progression to DM, although the estimate was imprecise in one study (RR, 0.89 [95% CI, 0.78 to 1.02] and RR, 0.08 [95% CI, 0.00 to 1.42]).166,167 Six studies assessed lifestyle interventions, with three of the studies reporting reduced risk of progression to DM (RRs ranged from 0.26 to 0.55) and the other three studies reporting a non–statistically significant effect (RR, 0.45 [95% CI, 0.17 to 1.21]; RR, 0.51 [95% CI, 0.24 to 1.11]; and RR, 0.36 [95% CI, 0.12 to 1.11]).102,107,110,169-172 The pooled risk estimate for progression to DM with lifestyle interventions, including four studies from the prior USPSTF report, was 0.53 (95% CI, 0.39 to 0.72; I^2^=88%).

Eight studies published since the prior USPSTF report evaluated effects of various pharmacologic interventions on progression to DM in patients with IFG or IGT.98,101,103,105,106,109, 165,168 TZDs (three trials; RR, 0.50 [95% CI, 0.27 to 0.92]; I^2^=92%) and alpha-glucosidase inhibitors (four trials; RR, 0.64 [95% CI, 0.45 to 0.90]; I^2^=66%) were more effective than placebo at reducing risk of progression to DM. One trial found valsartan (RR, 0.90 [95% CI, 0.85 to 0.95]) but not nateglinide (RR, 1.05 [95% CI, 0.99 to 1.11]) to be associated with decreased risk of progression to DM.103,104 Finally, one study reported that low-dose sulphonylurea added to lifestyle counseling was not effective in delaying progression to diabetes.168

### Evidence

The previous USPSTF report1 included a meta-analysis that found lifestyle interventions (five studies; n=3,490; duration of followup, 3 to 6 years) or pharmacological interventions (seven studies; n=12,519; duration of followup, 2 to 4 years) to be associated with decreased risk of progression to DM in patients with IFG or IGT (pooled RRs, 0.48 [95% CI, 0.40 to 0.58]; I^2^=34% and 0.65 [95% CI, 0.51 to 0.83]; I^2^=74%).

We identified 16 studies (in 18 publications) published since the prior report on the effect of interventions on progression to DM in patients with IFG or IGT (Table 12; Appendixes B13, B14, and B15).98,101-107,109,110,165-172 In these studies, progression to diabetes was generally assessed by means of fasting plasma glucose, 2-hour plasma glucose, or OGTT using WHO criteria (FPG >7.0 mmol/L [126 mg/dL] or 2-hour plasma glucose or OGTT >11.0 mmol/L [200 mg/dL]). Interventions included intensive multifactorial interventions (two studies),166,167 lifestyle interventions (six studies),102,107,110,169-172 and pharmacologic interventions (eight studies).98,101,103-106,109,165,168 Studies were conducted in the United States,98,165,172 Canada,109 Europe,105,167-169,171 and Asia,101,102,107,110,170 and one multicenter study was conducted in 40 countries.103,104 Treatment duration ranged from 6 months to 6 years, with followup extending up to 23 years (median or mean followup ranged from 6 months to 9 years). All studies enrolled patients with IFG or IGT at baseline, with several studies also requiring the presence of one or more other risk factors for DM,98,103,104,109,167,172 such as baseline BMI above a specific threshold.98,107,166,169,171,172 Mean ages of participants ranged from 45 to 65 years, and mean BMI ranged from 25.7 to 34.5 kg/m^2^. In studies reporting race/ethnicity, enrollees were primarily white,103,104,109,165,172 although one study98 enrolled 49 percent nonwhite participants. Three trials were rated good quality;101,103, 104,109 the other 13 trials and the cohort study were rated fair quality. Methodological shortcomings of the fair trials included unclear methods of randomization and allocation concealment,98,102,110 baseline differences between groups,105 unclear blinding or failure to blind,98,102,110 and lack of intention-to-treat analysis.106,166,167,170,171

Table 12 Studies of Interventions to Prevent or Delay Progression to DM

Author, Year Country Study Design Study Name Treatment Duration Followup | Intervention and Comparison | Population | Progression to Diabetes | Quality
Lifestyle interventions
Katula, 2013^172^ Community setting, United States RCT Treatment duration: 2 years | A. Intensive lifestyle intervention (n=151); B. Usual care (n=150) | Overweight or obese patients with IFG A vs. B Mean age: 57.3 vs. 58.5 years Female sex: 58% vs. 57% Race: 73.5% White, 25.8% Black, 0.7% other vs. 74% White, 23.3% Black, 2.7% other Mean BMI: 32.8 vs. 32.6 | A vs. B Incidence: 2.6% (4/151) vs. 7.3% (11/150); RR 0.36, 95% CI 0.12 to 1.11 | Fair
Li, 2008^102^ and Li 2014^110^ 33 centers, China Cluster RCT Da Qing DPS Treatment duration: 6 years Followup: 20 years (mean 9.4 years) | A. Interventions - combined lifestyle, diet, or lifestyle + diet; diet intervention: increase vegetable intake and lose weight by decreasing calories from sugar and alcohol; increase leisure time physical activity (n=438); B. Control (n=138) | Patients with IGT A vs. B Mean age: 45 vs. 47 years Female sex: 47% vs. 43% Race: NR Mean BMI: 25.7 vs. 26.2 | A vs. B: 20-year results Incidence: 6.9 vs. 11.3 cases/100 person-years per year Cumulative incidence: 79.7% vs. 92.8%; RR 0.86, 95% CI 0.80 to 0.92 Adjusted hazard rate ratio: 0.57, 95% CI 0.41 to 0.81 NNT: 6 A vs. B: 23-year results Incidence: 7.3 vs. 12.3 cases/100 person-years per year Cumulative incidence: 73% (312/430) vs. 90% (124/138); RR 0.86, 95% CI 0.80 to 0.92 Adjusted hazard rate ratio: 0.55, 95% CI 0.40 to 0.76 | Fair
Lindahl, 2009^171^ Single center, Sweden Vasterbotten Intervention Programme Treatment duration: 1 year Followup: 5 years | A. Intensive lifestyle intervention, including a month-long stay in a wellness center and four-day followup one year later (n=83); B. Usual care (n=85) | Patients with IGT and BMI >27 A vs. B Mean age: 52 vs. 54 years Female sex: 70% vs. 61% Race: NR Mean BMI: 31.2 vs. 30.2 | A vs. B Incidence at one year (end of intervention): 6% (5/83) vs. 23.5% (20/85); RR 0.26, 95% CI 0.10 to 0.65 Incidence at three years: 14.5% (12/83) vs. 23.5% (20/85); RR 0.61, 95% CI 0.32 to 1.18 Incidence at five years: 20% (17/83) vs. 27% (23/85); RR 0.75, 95% CI 0.44 to 1.31 | Fair
Penn, 2009^169^ United Kingdom RCT EDIPS Treatment duration: Up to 5 years Median followup: 3.1 years | A. Biweekly sessions for 1 month and monthly for 3 months, and every 3m for up to 5 years; Motivational interview from dietician and physiotherapist with quarterly newsletter and advice to target >50% energy from carbohydrates (n=51); B. One session of health promotion advice (n=51) | Patients with IGT and BMI>25 A vs. B Mean age: 56.8 vs. 57.4 years Female sex: 59% vs. 61% Race: NR | A vs. B Incidence: 9.8% (5/51) vs. 21.6% (11/51); RR 0.45, 95% CI 0.17 to 1.21 Incidence rate per 1,000 persons: 32.7 vs. 67.1 | Fair
Saito, 2011^107^ 38 centers in Japan RCT Zensharen Study for Prevention of Lifestyle Diseases Treatment duration: 5 years and 3 months Mean followup: 2.7 years | A. Individual session and goal to decrease weight by 5% with follow up at 1, 3, 6, 12, 18, 24, 30, and 36 months (n=330); B. One session advise to reduce weight by 5% (n=311) | Patients with IGT and BMI > 24 A vs. B Mean age: 50 vs. 48 Female sex: 28% vs. 29% Race: NR | A vs. B Cumulative incidence: 10.6% (35/330) vs. 16.4% (51/311); RR 0.65, 95% CI 0.43 to 0.97 | Fair
Sakane, 2011^170^ 32 community clinics in Japan RCT JDPP Treatment duration: 6 years Followup: 3 years | A. Individual and group sessions (4 group session lasting 2-3 hrs, biannual individual session lasting 20-40 min) (n=146); B. One group session (n=150) | Patients with IGT A vs. B Mean age: 51 years Female sex: 50% vs. 49% Race: NR | A vs. B Incidence: 6.1% (9/146) vs. 12% (18/150); RR 0.51, 95% CI 0.24 to 1.11 | Fair
Pharmacologic interventions
Armato, 2012^165^ United States Prospective Cohort Mean followup: 6.9 vs. 5.5 vs. 8.9 months | A. Pioglitazone 15 mg/day and metformin 850 mg/day (n=40); B. Pioglitazone 15 mg/day, metformin 850 mg/day, and exenatide 10 mcg/twice daily (n=47); C. Lifestyle counseling, including weight loss 7% over 3 months, diet information, walking 30 minutes per day 7 days per week (n=18) | Patients with IFG or IGT A vs. B Mean age: 62 vs. 56 vs. 61 years; p=0.03 Female sex: 28% vs. 43% vs. 39% Race: 82.5% White, 2.5% Black, 15% other vs. 83% White, 2.1% Black, 14.9% other vs. 100% White Mean BMI: 27.0 vs. 29.7 vs. 27.5 HbA1c: 5.8 vs. 5.7 vs. 5.6 | A vs. B vs. C Incidence: 0 vs. 0 vs. 5.6% (1/18); A vs. C, RR 0.15, 95% CI 0.01 to 3.62; B vs. C, RR 0.13, 95% CI 0.01 to 3.10 | Fair
DeFronzo, 2011^98^ 8 centers in United States RCT Median followup: 2.4 years | A. Pioglitazone 30 mg/day for one month, increased to 45 mg/day (n=303); B. Placebo (n=299) | Patients with IGT, BMI > 25, and ≥1 other RF diabetes A vs. B Mean age: 53 vs. 52 years Female sex: 58% vs. 58% Race: 51% White, 26% Hispanic, 19% Black, 3% other vs. 57% White, 25% Hispanic, 15% Black, 3% other Mean BMI: 33.0 vs. 34.5 Mean HbA1c: 5.5 vs. 5.5 | A vs. B Incidence: 5.0% (15/303) vs. 16.7% (50/299); RR 0.30, 95% CI 0.17 to 0.52 Annual average incidence: 2.1% vs. 7.6%; p<0.001 HR: 0.28 (95% CI 0.16 to 0.49) NNT for duration of trial (2.2 years): 8 NNT for one year: 18 | Fair
Kawamori, 2009^101^ 103 centers in Japan RCT Treatment duration: 5 years Mean followup: 3 years | A. Voglibose 0.2 mg/day (n=897); B. Placebo (n=881) | Patients with IFG A vs. B Mean age 55.7 vs. 55.7 years Female sex: 40% vs. 40% Race: NR | A vs. B Incidence 5.5% (50/897) vs. 12% (106/881); RR 0.46, 95% CI 0.34 to 0.64 HR: 0.595 | Good
Lindblad, 2011^168^ 23 centers in Sweden RCT Median followup: 3.7 years | A. Glimepiride 1 mg/day (n=136); B. Placebo (n=138) | Patients with IFG A vs. B Mean age: 60.4 vs. 59.6 years Female sex: 35.3% vs. 45.7% Race: NR Mean BMI: 29.9 vs. 29.6 Mean HbA1c: 4.9 vs. 4.9 | A vs. B Incidence: 30.1% (41/136) vs. 39.9% (55/138); RR 0.76, 95% CI 0.55 to 1.05 Incidence, adjusted for baseline HbA1c, proinsulin, and CRP: OR 0.62 (p=0.028) | Fair
NAVIGATOR, 2010^103^ (Nateglinide results) 806 centers in 40 countries RCT Median followup: 5 years | A. Nateglinide 60 mg/3 times daily (n=4645); B. Placebo (n=4661); *Patients also randomized in 2×2 factorial design to receive valsartan or placebo | Patients with IGT and at least one CV risk factor or known CVD A vs. B Mean age: 64 vs. 64 years Female sex: 51% vs. 50% Race: 83% White, 2.6% Black, 6.7% Asian, 7.8% other vs. 83.2% White, 2.5% Black, 6.5% Asian, 7.8% other Mean BMI: 30.5 vs. 30.5 | A vs. B Incidence: 36.0% (1647/4645) vs. 33.9% (1580/4661); RR 1.05, 95% CI 0.99 to 1.11 Absolute hazard difference: 6.18 (95% CI 0.47 to 11.90) HR: 1.07 (95% CI 1.00 to 1.15) | Good
NAVIGATOR, 2010^104^ (Valsartan results) 806 centers in 40 countries RCT Median followup: 5 years | A. Valsartan 160 mg/once daily (n=4631); B. Placebo (n=4675); *Patients also randomized in 2×2 factorial design to receive nateglinide or placebo | Patients with IGT and at least one CV risk factor or known CVD A vs. B Mean age: 64 vs. 64 years Female sex: 50% vs. 51% Race: 83.1% White, 2.4% Black, 6.4% Asian, 8.0% other vs. 83.1% White, 2.6% Black, 6.7% Asian, 7.5% other Mean BMI: 30.4 vs. 30.6 HbA1c: 5.8 vs. 5.8 | A vs. B Incidence: 33.1% (1532/4631) vs. 36.8% (1722/4675); RR 0.90, 95% CI 0.85 to 0.95 Absolute hazard difference: -12.6 (95% CI -18.4 to -6.9) HR: 0.86 (95% CI 0.80 to 0.92) | Good
Nijpels, 2008^105^ 1 center in The Netherlands RCT DAISI Treatment duration: 3 years | A. Acarbose 50 mg/3 times daily (n=60); B. Placebo (n=58) | Patients with IGT A vs. B Mean age: 59 vs. 57 years Female sex: 49% vs. 50% Race: NR Mean BMI: 28.4 vs. 29.5 HbA1c: 5.9 vs. 5.6 | A vs. B Incidence: 18.3% (11/60) vs. 24.1% (14/58); RR 0.76, 95% CI 0.38 to 1.53 Attributable risk: -0.14 (95% CI -0.46 to 0.21) Absolute risk reduction: 6% (95% CI -9% to 21%) | Fair
Ramachandran, 2009^106^ India RCT IDPP-2 Mean followup: 3 years | A. Pioglitazone (n=181); B. Placebo (n=186) | Patients with IGT A vs. B Mean age 45.1 vs. 45.5 Female sex: 13% vs. 14% Race: NR | A vs. B Cumulative incidence: 29.8% (54/181) vs. 31.6% (59/186); RR 0.94, 95% CI 0.69 to 1.28 | Fair
Zinman, 2010^109^ 2 centers in Canada RCT CANOE Treatment duration: NR Median followup: 3.9 years | A. Metformin 500 mg plus rosiglitazone 2 mg/twice daily as a fixed dose combination (n=103); B. Placebo (n=104) | Patients with IGT and ≥one risk factor for DM A vs. B Mean age: 50 vs. 55 years Female sex: 65% vs. 68% Race: 74.8% White, 7.8% South Asian, 6.8% Latino, 10.7% other vs. 74% White, 6.8% South Asian, 6.7% Latino, 12.5% other | A vs. B Incidence: 13.6% (14/103) vs. 39.4% (41/104); RR 0.34, 95% CI 0.20 to 0.59 RR reduction: 66% (95% CI 41-80%) Absolute risk reduction: 26% (95% CI 14-37%) NNT over 3.9 years: 4 (95% CI 2.7-7.1) Hazard ratio: 0.31 (95% CI 0.17 to 0.58) | Good
Multifactorial interventions
Lu, 2011^166^ 4 communities in China RCT Treatment duration: 2 years | A. IGT - acarbose 50 mg/3 times daily; IFG or IGT/IFG - metformin 250 mg/3 times daily; antihypertensives, antidyslipidemia agents, and aspirin (n=95); B. Control – health/diabetic education once a month (n=86) | Patients with IGT and BMI>19 A vs. B Mean age: 62 vs. 65 years Female sex: 47% vs. 48% Race: NR Mean BMI: 27.1 vs. 26.9 HbA1c: 5.9 vs. 6.0 | A vs. B Incidence: 0% vs. 5.8% (5/86); RR 0.08, 95% CI 0.00 to 1.42 | Fair
Rasmussen, 2008^167^ Multicenter, Denmark Cluster RCT ADDITION | A. Intensive management, including lifestyle advice, aspirin, drug treatment of blood glucose, blood pressure, and lipids according to strict targets (n=865) Subgroup got motivational interviewing training; B. Standard care (n=645) | Patients with IGT or IFG, high risk based on a self-administered questionnaire A vs. B [underlined: IFG] Mean age: 60 vs. 60 years Female sex: 43% vs. 43% Race: NR Mean BMI: 29.1 vs. 29.1 [underlined: IGT] Mean age: 61 vs. 61 years Female sex: 53% vs. 60% Race: NR Mean BMI: 29.5 vs. 29.8 | A vs. B Incidence: 14.1 vs. 15.8 cases/100 person-years; RR 0.89, 95% CI 0.78 to 1.02 [underlined: Sub-analyses] Motivational interviewing + intensive intervention: RR 0.83, 95% CI 0.68-1.00 Intensive treatment alone: RR 0.95, 95% CI 0.80 to 1.14 IFG: RR 0.90, 95% CI 0.73 to 1.12 IGT: RR 0.90, 95% CI 0.77 to 1.07 | Fair

Abbreviations: ADDITION = Anglo-Dutch-Danish Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care; BMI = body mass index; CANOE = Canadian Normoglycemia Outcomes Evaluation; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DAISI = Dutch Acarbose Intervention Study in Persons With Impaired Glucose Tolerance; DM = diabetes mellitus; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; HR = hazard ratio; IDPP-2 = Indian Diabetes Prevention Program-2; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; JDPP = Japanese Diabetes Prevention Program; NNT = number needed to treat; RCT = randomized, controlled trial; RR = relative risk.

#### Lifestyle Interventions

The previous USPSTF report included four studies of lifestyle interventions providing new evidence, all of which found that lifestyle interventions were associated with decreased risk of progression to DM versus usual care over followup periods ranging from 3 to 6 years.2 RRs ranged from 0.32 (95% CI, 0.11 to 0.96) to 0.62 (95% CI, 0.42 to 0.92), with a pooled risk estimate of 0.48 (95% CI, 0.40 to 0.58).

Six fair-quality studies (in seven publications) published since the previous USPSTF report assessed the effect of lifestyle interventions on risk of progression to DM (Table 12; Appendix B13).102,107,110,169-172 Studies were conducted in patients with IGT in Japan, China, and Europe. Interventions varied across studies and involved combinations of individual and group diet and exercise counseling sessions. The duration of interventions also varied substantially, from a 1-month intervention based in a wellness center with a 4-day followup intervention 1 year later to a 6-year intervention. Duration of followup ranged from 3 to 23 years. The Da Qing trial, conducted in China, reported a higher rate of progression to DM (73% in the intervention group and 90% in the comparison group) than the other studies (6% to 11% in the intervention groups and 12% to 24% in the comparison groups), consistent with its longer duration of followup and selection of patients with mean BMI greater than 25 kg/m^2^.102,110

Three of the studies, including the Da Qing trial, found that lifestyle intervention was associated with decreased risk of progression to DM (adjusted HR 0.57 [95% CI, 0.41 to 0.81] at 20 years;102 adjusted HR, 0.55 [95% CI, 0.40 to 0.76] at 23 years;110 RR, 0.65 [95% CI, 0.43 to 0.97] at 2.7 years;107 and RR, 0.26 [95% CI, 0.10 to 0.65] at 5 years171), while the other three studies favored the lifestyle intervention but failed to reach statistical significance (RR, 0.45 [95% CI, 0.17 to 1.21];169 RR, 0.51 [95% CI, 0.24 to 1.11];170 and RR, 0.36 [95% CI, 0.12 to 1.11]172). The pooled RR, including six new studies and four studies included in the prior report, was 0.53 (95% CI, 0.39 to 0.72; I^2^=88%; Figure 4).102,110,169 Sensitivity analysis excluding the study with the longest followup (23 years; the Da Qing trial) showed similar results (pooled RR, 0.53 [95% CI, 0.44 to 0.63]; I^2^=25%), as did analysis using the profile likelihood estimate (RR, 0.57 [95% CI, 0.43 to 0.70], I^2^=67%).

Figure 4 Meta-Analysis of the Effect of Lifestyle Interventions on Incidence of Progression to DM

* From prior report

This figure is a meta-analysis forest plot. Risk ratios of the effect of lifestyle interventions on the incidence of progression to diabetes from impaired fasting glucose or impaired glucose tolerance were calculated for 10 studies, with a pooled risk ratio of 0.53, 95% CI of 0.39 to 0.72, and an I-squared value of 88%.

#### Pharmacologic Interventions

Eight studies (three of good quality and five of fair quality) published since the previous USPSTF report assessed the effect of pharmacologic interventions on risk of progression to DM in patients with IFG or IGT (Table 12; Appendix B13).98,101,103,105,106,109,165,168 Interventions included several classes of medications for glycemic control (eight trials), as well as the antihypertensive medication valsartan (one trial), an ARB. Diabetic medication classes included biguanides, TZDs (three trials), alpha-glucosidase inhibitors (three trials), meglitinides, sulphonylureas, and glucagon-like peptide-1 agonists, or combinations of these medications. One study used a prospective cohort design165 and the rest were RCTs. Followup ranged from 6 months to 5 years.

Metformin. The previous USPSTF report1 included the good-quality DPP study and fair-quality Indian Diabetes Prevention Program (IDPP) study; both reported the effect of metformin on progression to DM.4,7 The DPP study (n=3,234; 49% were ages 45 to 59 years; 32% male) randomized patients to lifestyle modification, metformin, or placebo and followed patients for 3 years. The IDPP study (n=531; mean age, 46 years; 79% male) also randomized patients to lifestyle modification, metformin, or no intervention.7 The overall incidence of progression to DM was 8 cases per 100 person-years in the metformin group and 11 cases per 100 person-years in the placebo group (risk reduction, 31% [95% CI, 24% to 51%]) in the DPP study.4 In the IDPP, incidence of DM was 41 percent in the metformin group and 55 percent in the nonintervention group after 3 years of followup (risk reduction, 26% [95% CI, 19.1% to 35.1%]). Lifestyle modification resulted in greater effects than metformin relative to placebo or no intervention in both studies (risk reduction, 58% [95% CI, 48% to 66%]4 and 29% [95% CI, 21% to 37%]7).

We identified one new study of metformin reporting progression to DM.166 A small (n=181) Chinese study employed a staged intensive intervention in which participants with isolated IFG or combined IFG and IGT received metformin 250 mg three times per day and participants with isolated IGT received acarbose 50 mg three times per day, with all participants also receiving aspirin and pharmacologic treatment for hypertension and dyslipidemia. In the group receiving metformin, no intervention participant progressed to DM versus five control participants (0% vs. 12.2%; RR, 0.08 [95% CI, 0.00 to 1.42]).

TZDs. The previous USPSTF report included one study on the effect of TZDs on progression to DM. The large (n=5,269) good-quality DREAM trial used a 2×2 factorial design to randomize patients to rosiglitazone (a TZD) or placebo and ramipril (an ACE inhibitor) or placebo, with followup for 3 years. It found no effect of ramipril on risk of progression to DM (17% vs. 19%; RR, 0.91 [95% CI, 0.77 to 1.08]); rosiglitazone was associated with decreased risk (11% vs. 25%; RR, 0.38 [95% CI, 0.31 to 0.47]).

Two fair-quality studies (n=887) published since the previous USPSTF report assessed the effect of TZDs on risk of progression to DM in patients with IGT (Table 12; Appendix B13).98,106 One study required patients to have at least one other risk factor (e.g., BMI >25 kg/m^2^, family history, gestational diabetes, polycystic ovarian syndrome, or African American ethnicity) for DM.98 The studies were conducted in India106 and the United States.98 The IDPP-2^106^ (n=367) and a study by Defronzo and colleagues98 (n=602) compared pioglitazone versus placebo for a median of 3 and 2 years, respectively. The dosing of medications ranged from 15 to 45 mg for pioglitazone. One trial found that TZDs were associated with decreased risk of progression to DM versus placebo (5.0% vs. 16.7%; RR, 0.30 [95% CI, 0.17 to 0.52]),98 while the other trial found no effect (29.8% vs. 31.6%; RR, 0.94 [95% CI, 0.69 to 1.28]).106 The number needed to treat to prevent one patient from developing DM was 8 over 2 years in the study by Defronzo and colleagues98 and 52 over 3 years in the IDPP-2 trial.106 The pooled estimate for the effect of TZDs on progression to DM, including the two new trials and the earlier DREAM trial,15 was 0.50 (95% CI, 0.27 to 0.92), but statistical heterogeneity was substantial (I^2^=92%; Figure 5).15,98,106,107 Analysis using the profile likelihood method slightly reduced heterogeneity (RR, 0.51 [95% CI, 0.23 to 1.06]; I^2^=89%), although this result was no longer statistically significant. Removing results of the IDPP-2 trial,106 which was conducted in India in mostly male participants, eliminated much of the heterogeneity (I^2^=36%), with an RR of 0.42 (95% CI, 0.37 to 0.47).15,98 Stratified analyses showed that rosiglitazone and pioglitazone were similar in their effects.

Figure 5 Meta-Analysis of the Effect of Thiazolidinediones on Incidence of Progression to DM

* From prior report

This figure is a meta-analysis forest plot. Risk ratios of the effect of thiazolidinediones on the incidence of progression to diabetes from impaired fasting glucose or impaired glucose tolerance were calculated for 3 studies, with a pooled risk ratio of 0.50, 95% CI of 0.27 to 0.92, and an I-squared value of 92%.

Alpha-glucosidase inhibitors. The previous USPSTF report included two studies on the effects of alpha-glucosidase inhibitors on risk of progression to DM in patients with IFG or IGT.111,173 Both studies assessed acarbose versus placebo, with followup durations of 16 weeks173 and 3.3 years.111 The longer study, by Chiasson and colleagues, found acarbose to be associated with reduced risk of progression to DM (32% vs. 42%; RR, 0.78 [95% CI, 0.68 to 0.90]), while the shorter duration trial reported a point estimate in favor of acarbose that failed to reach statistical significance (5.6% vs. 9.5%; RR, 0.59 [95% CI, 0.24 to 1.46]).

Two new studies (one good and one fair quality) assessed the effect of alpha-glucosidase inhibitors on incidence of DM in persons with IFG/IGT (Table 12; Appendix B13).101,105 The good-quality trial (n=1,778) found that voglibose 0.2 mg/day was associated with decreased risk of progression to DM versus placebo after a mean of 3 years (5.5% vs. 12%; RR, 0.46 [95% CI, 0.34 to 0.64]).101 The fair-quality study (n=118) found no statistically significant difference between acarbose 150 mg/day versus placebo in risk of progression to DM after 3 years (18% vs. 24%; RR, 0.76 [95% CI, 0.38 to 1.53])105 but was underpowered because of difficulties in recruitment and had high rates of dropout because of medication side effects. The pooled estimate for the effect of alpha-glucosidases, including these two trials as well as two studies from the prior report, was 0.64 (95% CI, 0.45 to 0.90).101,105,111,173 Although statistical heterogeneity was present (I^2^=66%; Figure 6), estimates favored the alpha-glucosidase in each trial. Pooling the three trials of acarbose105,111,173 eliminated the heterogeneity (pooled RR, 0.77 [95% CI, 0.68 to 0.89]; I^2^=0%).

Figure 6 Meta-Analysis of the Effect of Alpha-Glucosidase Inhibitors on Incidence of Progression to DM

* From prior report

This figure is a meta-analysis forest plot. Risk ratios of the effect of alpha-glucosidase inhibitors on the incidence of progression to diabetes from impaired fasting glucose or impaired glucose tolerance were calculated for 4 studies, with a pooled risk ratio of 0.64, 95% CI of 0.45 to 0.90, and an I-squared value of 66%.

Nateglinide and valsartan. The large (n=9,306) good-quality NAVIGATOR trial was a multicenter study in 40 countries with median followup of 5 years that used a 2×2 factorial design to randomize patients with IGT and at least one other risk factor for CV disease to nateglinide (a newer insulin secretagogue) versus placebo and valsartan versus placebo.103,104 Nateglinide was not associated with decreased risk of DM over 5 years (RR, 1.05 [95% CI, 0.99 to 1.11]), but valsartan was associated with decreased risk (33% vs. 37%; RR, 0.90 [95% CI, 0.85 to 0.95]; Table 12; Appendix B13).

Sulphonylureas. One fair-quality multicenter trial conducted in Sweden assessed the effect of 1 mg/day glimepiride on progression to diabetes compared with placebo.168 The Nepi Antidiabetes Study (n=274) enrolled patients ages 40 to 70 years with IFG and reported incidences of progression to diabetes of 30.1 percent in the intervention group and 39.9 percent in the placebo group over a mean followup of 3.7 years (RR, 0.76 [95% CI, 0.55 to 1.05]).

Combination pharmacologic therapies. One good-quality RCT and one fair-quality cohort study assessed the effect of combination pharmacologic therapy on prevention of DM in patients with IFG or IGT.109,165 The CANOE trial109 (n=207) compared low-dose metformin plus rosiglitazone versus placebo and followed patients for a median of 4 years. The incidence of DM in the combination drug therapy group was 14 percent, compared with 39 percent in the placebo group (RR, 0.34 [95% CI, 0.20 to 0.59]). The cohort study (n=105)165 compared pioglitazone plus metformin (with and without exenatide) with a lifestyle intervention and reported no cases of progression to DM in patients who used TZDs versus 6 percent in the lifestyle group after 6 to 9 months.165 Estimates were imprecise for pioglitazone plus metformin with exenatide (RR, 0.13 [95% CI, 0.01 to 3.10]) and without exenatide (RR, 0.15 [95% CI, 0.01 to 3.62]) versus the lifestyle intervention.165

#### Multifactorial Interventions

No trial included in the previous USPSTF report evaluated effects of multifactorial interventions versus placebo or usual care on risk of progression to DM. Two fair-quality trials published since the previous report examined the effect of multifactorial interventions consisting of intensive glucose, blood pressure, and lipid control in addition to lifestyle counseling and aspirin (Table 12; Appendix B13).166,167 The large (n=1,510) ADDITION-Denmark trial reported a nonstatistically significant difference in risk of progression to DM (14.1 cases per 100 person-years in the intervention group vs. 15.8 cases/100 person-years in the usual-care group; RR, 0.89 [95% CI, 0.78 to 1.02]).167 A subgroup analysis found a stronger effect in a subgroup of patients randomized to the multifactorial intervention that also received motivational interviewing (RR, 0.83 [95% CI, 0.68 to 1.00]) than in the subgroup that did not receive motivational interviewing (RR, 0.95 [95% CI, 0.80 to 1.14]). A smaller (n=181) Chinese study reported a lower incidence of progression to DM in the intervention compared with the control group, although the difference was not statistically significant and the estimate was imprecise because of the small number of events (0% vs. 5.8%; RR, 0.08 [95% CI, 0.00 to 1.42]).166

## Key Question 8 Do the Effects of Screening or Interventions for Screen-Detected or Early Type 2 Diabetes, Impaired Fasting Glucose, or Impaired Glucose Tolerance Vary by Subgroups, Such as Age, Sex, or Race/Ethnicity?

### Summary

The prior report did not include evidence on the effect of screening or interventions in screen-detected or early DM, IFG, or IGT in subgroups.1 No study directly evaluated whether benefits or harms of screening for DM, IFG, or IGT or subsequent interventions vary according to subgroups defined by age, sex, or race/ethnicity. Men, but not women, who underwent screening and died during followup had significantly longer life compared with those who were not screened.49 One study comparing lifestyle modification with usual care in persons with IGT found a reduction in all-cause and CV mortality in women, but not men, after 23 years followup.110 A subgroup analysis from one study of more versus less intensive treatment in persons with DM not specifically screen detected found no overall effect of age or race, although the highest mortality risk was in persons younger than age 65 years and in blacks.174 Intensive lipid lowering reduced risk of a composite outcome that included CV mortality, nonfatal MI, and nonfatal stroke in men (RR, 0.84 [95% CI, 0.71 to 0.997]) but not in women (RR, 1.36 [95% CI, 0.98 to 1.9]) compared with standard lipid control in one study.129 Aspirin use versus nonuse was associated with a significant reduction in risk of MI in men (RR, 0.57 [95% CI, 0.34 to 0.94]) but not in women (RR, 1.08 [95% CI, 0.71 to 1.65]), with no difference between the two for other CV outcomes in a good-quality systematic review.132 We found no evidence that effectiveness of interventions to prevent progression to DM in persons with IFG and IGT varies in subgroups.

### Evidence

#### Screening

We did not identify any evidence from the ADDITION trial on the differential effect of screening in subgroups defined by age, sex, or race/ethnicity. The ADDITION trial focused on screening persons at higher risk for DM. The Ely study reported that, of study participants who died, men who were invited to screening were significantly older than men not invited to screening at time of death (64 vs. 61 years; p=0.01). There was no significant age difference between screened and not-screened women in age at time of death (64 vs. 62 years; p=0.17).49

#### Treatment

Persons with screen-detected DM. We identified no subgroup analyses from the ADDITION study on the effect of intensive versus standard multifactorial interventions in subgroups of persons with DM. More than 95 percent of persons enrolled in the ADDITION study were white Europeans and about 40 percent were women; mean age was 60 years.68,69

Persons with IFG or IGT. The long-term Da Qing study, which randomized persons with IFG to lifestyle modification or usual care, found that incidence of all-cause and CV mortality was significantly reduced in the lifestyle group after 23 years of treatment (see Key Question 3.)110 When these results were stratified according to sex, women had a significantly lower risk of all-cause (HR, 0.46 [95% CI, 0.24 to 0.87]) or CV mortality (HR, 0.28 [95% CI, 0.11 to 0.71]). The effect in men was not significant for either outcome (HR, 0.97 [95% CI, 0.65 to 1.46] and HR, 0.91 [95% CI, 0.50 to 1.65]; Appendix B3). Despite adjusting for baseline differences such as smoking status (a higher proportion of men than women were smokers), study authors were unable to explain the disparity, although they hypothesized that poor compliance to lifestyle modification by men may have contributed to the long-term lack of effect.

Persons with DM not specifically screen detected. The ACCORD study of more versus less intensive glucose lowering found intensive glucose lowering to be associated with increased risk of all-cause mortality versus standard glucose lowering (HR, 1.22 [95% CI, 1.02 to 1.44). In analyses stratified by age, intensive glucose-lowering therapy was associated with significantly increased risk of all-cause mortality in persons younger than age 65 years (HR, 1.39 [95% CI, 1.05 to 1.82]) but not in persons ages 65 to 69 years (HR, 1.23 [95% CI, 0.84 to 1.82]), 70 to 74 years (HR, 1.01 [95% CI, 0.65 to 1.59]), or older than age 75 years (HR, 0.90 [95% CI, 0.55 to 1.47]; Appendix B10).174 Risk of all-cause mortality was similar in men (HR, 1.21 [95% CI, 0.98 to 1.52]) and women (HR, 1.23 [95% CI, 0.87 to 1.74]). Compared with standard glucose control, blacks in the intensive glucose-lowering group had a higher risk of all-cause mortality (HR, 1.60 [95% CI, 1.01 to 2.52]) than whites (HR, 1.21 [95% CI, 0.98 to 1.52]), Hispanics (HR, 0.60 [95% CI, 0.27 to 1.33]), and Asians or other races and ethnicities (HR, 1.06 [95% CI, 0.54 to 2.07]). In the ACCORD-Lipid substudy, men in the intensive lipid-lowering group had a significantly lower risk of experiencing a CV event, a composite outcome that included CV mortality, nonfatal MI, and nonfatal stroke (RR, 0.84 [95% CI, 0.71 to 0.997]) than women (RR, 1.36 [95% CI, 0.98 to 1.9]; p for interaction=0.01).129 There was no difference in effects of intensive versus standard lipid lowering when results were stratified according to age or race (Appendix B11).129 In the ADVANCE trial, no difference in composite vascular outcomes (CV mortality, nonfatal MI, nonfatal stroke, new or worsening nephropathy, or retinopathy) was found when analyses were restricted to persons younger than age 65 years or when stratified by sex (Appendix B10).80

In a good-quality systematic review of aspirin use versus nonuse for primary prevention of CV events in persons with DM, subgroup analyses found a significant reduction in risk of MI in men (three studies; RR, 0.57 [95% CI, 0.34 to 0.94]) but not in women (three studies; RR, 1.08 [95% CI, 0.71 to 1.65]), with no difference between the two for other CV outcomes.132 The review also found a decreased risk of stroke in women taking aspirin (three studies; RR, 0.75 [95% CI,0.37 to 1.53]) and an increased risk in men (two studies; RR, 1.11 [95% CI, 0.75 to 1.64]), although neither risk estimate was statistically significant. Analyses of heterogeneity were not reported for these subgroups.

#### Progression to DM

One study included in the prior report found that progression to DM was significantly reduced with acarbose use versus placebo; this result was consistent when stratified by age (≤55 vs. >55 years) or sex.111

The ADDITION study reported rates of progression to DM stratified by IFG or IGT status, but the study did not report other subgroup differences. Comparing the intervention (lifestyle modification) and usual-care groups, progression rates were higher in participants with IGT (16% vs. 18% per person-year) than those with IFG (11% vs. 13% per person-year); the effect of lifestyle modification was similar in both groups.167 The multicenter study in Zensharen, Japan also reported the intervention (lifestyle modification) to be effective compared with usual care in patients with combined IFG and IGT (6.8 vs. 12.6 cases per 100 person-years; adjusted HR, 0.41 [95% CI, 0.24 to 0.69]) but not in patients with isolated IFG (2.4 vs. 1.8 cases per 100-person years; adjusted HR, 1.17 [95% CI, 0.50 to 2.74]).107