# Methods

## Key Questions and Analytic Framework

Using established methods,45 the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and Key Questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1).

Figure 1 Analytic Framework

This figure depicts the analytic framework, which outlines the evidence areas covered in the review, including the population, intervention and related harms, and outcomes. The population includes asymptomatic, nonpregnant adults. Screening of these individuals separates the population into high and average risk, and harms of screening are assessed. Diagnosis of either diabetes or impaired fasting glucose/impaired glucose tolerance follows. Arrows from these boxes represent drug and/or lifestyle interventions on the following health outcomes: mortality, cardiovascular morbidity (including myocardial infarction, stroke, and congestive heart failure), quality of life, and other outcomes. The incidence of diabetes is also examined as an outcome for those with impaired fasting glucose/impaired glucose tolerance. Subsequent arrows from the interventions examine any harms of interventions. In addition, an overarching arrow from screening to the health outcomes represents the direct effect of screening on these health outcomes.

### Key Questions

1. Is there direct evidence that screening for type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance in asymptomatic adults improves health outcomes?
2. What are the harms of screening adults for type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance?
3. Do interventions for screen-detected or early type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance provide an incremental benefit in health outcomes compared with no interventions or initiating interventions after clinical diagnosis?
4. What are the harms of interventions for screen-detected or early type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance?
5. Is there evidence that more intensive glucose, blood pressure, or lipid control interventions improve health outcomes in adults with type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance compared with traditional control? Is there evidence that aspirin use improves health outcomes in these populations compared with nonuse?
6. What are the harms of more intensive interventions compared with traditional control in adults with type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance?
7. Do interventions for impaired fasting glucose or impaired glucose tolerance delay or prevent progression to type 2 diabetes?
8. Do the effects of screening or interventions for screen-detected or early type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance vary by subgroups, such as age, sex, or race/ethnicity?

Four Contextual Questions were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.45 Rather, the approach to Contextual Questions is to focus on evidence from key high-quality studies.

### Contextual Questions

1. What is the yield (incidence) of starting screening at different ages or rescreening at different intervals in adults with an initial normal fasting blood glucose, HbA1c, or glucose tolerance test?
2. What is the utility of using formal risk calculators versus less formal risk factor assessment (e.g., family history, body mass index) in determining a person's risk for developing diabetes?
3. What is the utility of existing modeling studies of type 2 diabetes screening versus no screening in examining important health outcomes?
4. Is there evidence that intensive blood pressure or lipid lowering or use of aspirin is more effective in persons with diabetes compared with persons without diabetes?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews (through March 2014), and Ovid MEDLINE^®^ (2007 through March 2014) for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each Key Question (Appendix A2). For Key Questions related to screening, we selected studies of asymptomatic adults without known DM, IFG, or IGT who underwent testing with HbA1c, OGTT, random plasma glucose, or fasting plasma glucose. For Key Questions related to treatment, we selected studies of adults with screen-detected DM, IFG, or IGT that compared pharmacological interventions for glycemic control or lifestyle interventions versus placebo, no intervention, or usual care. Because few studies specifically enrolled patients with screen-detected DM, we also included studies of patients with early DM (defined as pharmacologically untreated HbA1C less than 8.5% or diagnosis of DM within the last year), who are likely to be more similar to persons identified by screening than those with more advanced or longstanding DM. We excluded studies conducted in pregnant women and children. We included studies on whether more intensive glucose, blood pressure, or lipid control interventions (compared with traditional control) or aspirin use (compared with nonuse) improve health outcomes in adults with DM, IFG, or IGT. For these interventions, we included studies of patients with screen-detected or established DM without an HbA1c or duration restriction, as few trials examined the effects of more versus less intensive therapies for early DM as defined above. Outcomes included all-cause and CV mortality, CV morbidity (including myocardial infarction [MI], stroke, congestive heart failure), chronic kidney disease, amputations, skin ulcers, visual impairment (including blindness), periodontitis (including tooth loss), neuropathy, quality of life, and progression from IFG or IGT to DM. Harms included potential harms of screening such as labeling, anxiety, and false-positive results,34 as well as harms of treatment. We included RCTs, cohort studies, and case-control studies for all Key Questions, and relevant systematic reviews that were of good quality and current enough to include critical recent studies. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, screening method, interventions, analysis, followup, and results; when appropriate, we contacted study authors for missing data. Two investigators independently applied criteria developed by the USPSTF45 to rate the quality of each study as good, fair, or poor (Appendix A5). Discrepancies were resolved through a consensus process. When otherwise not reported and where possible, we calculated relative risks (RRs) and 95-percent confidence intervals (CIs).

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, and poor) using methods developed by the USPSTF, based on the number, quality, and size of studies; precision of estimates; consistency of results between studies; and directness of evidence.45

We conducted meta-analyses to calculate risk ratios for progression from IFG or IGT to DM and for effects of interventions using the DerSimonian–Laird random effects model with RevMan software (Review Manager Version 5.2, Copenhagen: The Nordic Cochrane Centre, The Cochrane Collaboration, 2012). When statistical heterogeneity was present, we performed sensitivity analysis using the profile likelihood method using Stata (Stata 10.1), as the DerSimonian–Laird model results in overly narrow CIs in this situation.46 We stratified results by drug class or lifestyle intervention where appropriate. Statistical heterogeneity was assessed using the I^2^ statistic.47 We performed additional sensitivity analyses based on study quality and presence of outlier trials.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and Federal and non-Federal collaborative partners.

## Response to Public Comment

The draft evidence review was posted for public comment on the USPSTF Web site from October 6 to November 5, 2014. In response to one reviewer's comment, we edited Table 1 (on test values for normal and impaired fasting glucose, impaired glucose tolerance, and type 2 diabetes definitions) by deleting the test values for random plasma glucose and noting that all tests should be repeated. No other comments were made that required edits to the report.