# Introduction

## Purpose

This report updates a 2008 systematic review on screening for type 2 diabetes mellitus (DM) in adults.1,2 It will be used by the U.S. Preventive Services Task Force (USPSTF) to update their recommendations on screening for DM.3 This update focuses on benefits and harms of screening for DM, impaired fasting glucose (IFG), or impaired glucose tolerance (IGT) in adults, and benefits and harms of subsequent treatments for IFG, IGT, or DM. Prenatal screening and screening of children are not addressed in this review.

## Previous USPSTF Recommendation

In 2008, the USPSTF recommended screening for DM in asymptomatic adults with sustained blood pressure (either treated or untreated) greater than 135/80 mm Hg (B recommendation). Although direct evidence on benefits and harms of screening was not available, the USPSTF recommendation was based on the ability of screening to identify persons with DM and evidence that, in patients with diabetes and hypertension, more intensive blood pressure treatment was associated with reduced risk of cardiovascular (CV) events, including CV mortality.

The USPSTF found insufficient evidence to assess the balance of benefits and harms of screening in adults without blood pressure greater than 135/80 mm Hg (I statement). The USPSTF found that lifestyle and/or drug interventions in patients with IFG or IGT were associated with reduced risk of progression to DM after up to 7 years followup,4-11 but three trials on the effects of drug and lifestyle interventions in persons with IFG or IGT reported inconsistent effects on CV outcomes and had some methodological shortcomings.12-15 The USPSTF also identified a number of evidence gaps:

- No randomized, controlled trials (RCTs) directly addressed the health benefits of either targeted or mass screening for DM, IFG, or IGT.
- Harms of screening were sparsely reported.
- No study directly compared effectiveness of treatments in persons with screen-detected versus clinically detected DM, and no study evaluated treatment effects in an exclusively screen-detected or recently diagnosed DM cohort.
- Evidence on harms of treating DM early as a result of screening were not available. However, many systematic reviews examined adverse effects of commonly used DM medications.
- Evidence on screening frequency was limited to modeling studies.

## Condition Definition

DM is a metabolic disorder characterized by hyperglycemia. There are two types of DM: type 1, often diagnosed in childhood and characterized by autoimmune destruction of pancreatic islet cells that produce insulin, and type 2 (the focus of this report), characterized by insulin resistance and relative insulin deficiency. Diagnosis of DM, IFG, and IGT is based on measures of glycated hemoglobin (HbA1c), random and fasting blood sugar, or oral glucose tolerance test (OGTT) values, as shown in Table 1.^16^ DM is defined as HbA1c of 6.5 percent or higher, fasting plasma glucose of 126 mg/dL or higher, or OGTT values after 2 hours of 200 mg/dL or higher; parameters for IFG and IGT are HbA1c less than 6.5 percent with fasting plasma glucose levels of 100 to 125 mg/dL and OGTT values of 140 to 199 mg/dL, respectively.16

Table 1 Test Values for Normal, IFG, or IGT and Type 2 Diabetes Definitions

Test | Normal | IFG or IGT | Type 2 Diabetes
Hemoglobin a1c | <5.7% | 5.7 to 6.4% | ≥6.5%
Fasting plasma glucose | <100 mg/dL | 100 to 125 mg/dL | ≥126 mg/dL
OGTT after 2 hours | <140 mg/dL | 140 to 199 mg/dL | ≥200 mg/dL

Abbreviations: IFG = impaired fasting glucose; IGT = impaired glucose tolerance; OGTT = oral glucose tolerance test.

Note: All positive tests should be confirmed on repeat testing.

Source: American Diabetes Association. Standards of medical care in diabetes – 2015. Diabetes Care. 2015;38(Suppl 1):S1-90. [pmid: 25537700].

## Prevalence and Burden of Disease

In the United States, about 19 million persons were diagnosed with diabetes in 2010, with an estimated 7 million persons undiagnosed; about 90 to 95 percent of those have type 2 DM.17,18 Prevalence of DM increases with age and varies according to sex and race/ethnicity (Table 2).19-21 From 2005 to 2008, the proportion of persons with diagnosed or undiagnosed DM was 4 percent in persons ages 20 to 44 years, 14 percent in persons ages 45 to 64 years, and 27 percent in persons age 65 years and older. In 2010, about 1 million adults with newly diagnosed DM were ages 45 to 64 years, with 465,000 new cases in younger adults and 390,000 new cases in older adults.17 In persons younger than age 44 years, similar proportions of men and women are diagnosed with DM; however, prevalence is slightly higher in men in older age groups (Table 2). Prevalence varies substantially according to age, ranging from 1 to 2 percent in women younger than age 44 years to 22 to 41 percent in men older than age 75 years (Table 2).17,19,20 Racial and ethnic groups with the highest risk of diagnosed DM include blacks (rates are 77% higher than whites), Hispanics (rates are 66% higher than whites), and Asians (rates are 18% higher than whites).17

Table 2 Prevalence of Diagnosed Diabetes in the United States

Race/Ethnicity | Sex | Ages 0–44 | Ages 45–64 | Ages 65–74 | Ages 75+ | Age-Adjusted
White | Males | 1.5% | 12.4% | 22.8% | 21.7% | 6.8%
White | Females | 1.5% | 10.0% | 18.4% | 16.6% | 5.4%
Black | Males | 2.5% | 17.6% | 30.7% | 38.1% | 9.9%
Black | Females | 2.4% | 17.1% | 31.2% | 25.9% | 9.0%
Asian | Males | 1.4% | 12.7% | 34.4% | 30.4% | 7.8%
Asian | Females | 1.0% | 11.3% | 18.3% | 18.7% | 5.5%
Hispanic | Males | 1.8% | 16.7% | 29.1% | 41.1% | 9.3%
Hispanic | Females | 1.6% | 19.0% | 31.6% | 31.4% | 9.3%
Native Pacific Islanders | - | | | | | 23.7%^*^
American Indians/Alaska Natives | - | | | | | 16.3%

* Standard error >30% and ≤50%; estimate should be interpreted with caution as it does not meet standards of reliability or precision.

Diabetes is the leading cause of kidney failure, nontraumatic lower-limb amputations, and new cases of blindness in the United States. Diabetes is also a major cause of heart disease and stroke, and the seventh leading cause of death in adults.17 Prevalence of DM in adults in the United States has steadily increased over the past 15 years, rising from about 5 percent in 1995 to 8 percent in 2010.^21^ Some racial and ethnic groups are disproportionately affected by complications of diabetes. For example, blacks and Hispanics are more likely than whites to experience end-stage renal disease,22 and blacks are almost twice as likely to have amputations of lower extremities.23 Whites and blacks are more likely to experience diabetes-related heart disease or stroke compared with Hispanics,24 and blacks, American Indians/Alaska Natives, and Hispanics are more likely to die from DM than whites (age-adjusted death rates, 39.5, 34.0, and 25.6 vs. 19.1 per 100,000, respectively).25

## Etiology and Natural History

DM is caused by insulin resistance, relative insulin deficiency, and inability to maintain normal blood glucose levels. DM typically develops slowly, and progression from normal glycemia to asymptomatic subclinical disease, and finally to frank DM may take 10 years or longer.26,27 However, during the subclinical phase, vascular damage can occur and microvascular disease (e.g., retinopathy and neuropathy) may already be present at the time of DM diagnosis.16,26

## Risk Factors

Many risk factors are associated with development of DM in adults. Nonmodifiable risk factors include a first-degree relative with DM, a genetic predisposition to insulin resistance, race/ethnicity, and, in women, history of polycystic ovarian syndrome, gestational diabetes, or giving birth to a baby weighing more than 9 lb.16,17,19,20,28-30 The risk of developing DM also increases with advancing age (see above).16,31 Modifiable risk factors for DM include obesity or a high percentage of visceral (abdominal) fat, physical inactivity, smoking, and consumption of a diet high in saturated fat. DM is also frequently associated with other health conditions, such as hyperlipidemia, hypertension, and metabolic syndrome.16,17,28,32,33

## Rationale for Screening and Screening Strategies

Screening asymptomatic adults for DM may lead to earlier identification and therefore earlier or more intensive treatments to prevent the negative health outcomes associated with DM.18 Strategies for screening include routine screening, targeted screening based on presence of risk factors, and using risk-assessment instruments.

## Interventions and Treatment

Lifestyle interventions for glycemic control are considered first-line therapies in most patients and include diet and physical activity or exercise. Numerous drugs from a variety of classes are used to treat DM. These include the biguanide metformin, which lowers glucose production in the liver and is considered a first-line pharmacological treatment for newly diagnosed DM;34 sulfonylureas (glipizide, glyburide, gliclazide, glimepiride) and meglitinides (repaglinide, nateglinide), which stimulate the pancreas to produce and release more insulin; thiazolidinediones (TZDs; pioglitazone, rosiglitazone), which make tissues more sensitive to insulin; dipeptidyl peptidase IV inhibitors (sitagliptin, saxagliptin, linagliptin), which increase insulin secretion and reduce sugar production; and alpha-glucosidase inhibitors (acarbose, voglibose, miglitol), which block enzymes that help digest starches, slowing the postprandial rise in blood sugar; and insulin.

Patients with high body mass index (BMI) (>35 kg/m^2^), persons younger than age 60 years, and women with a history of gestational diabetes may be initially treated with metformin in addition to lifestyle interventions.16 In addition to treatment of DM, screening for and treatment of other modifiable diseases that often accompany DM, including dyslipidemia and hypertension, may be initiated. Other interventions to reduce risk of CV disease and microvascular complications include blood pressure and lipid-lowering therapy; aspirin; and monitoring and treatments for retinopathy, nephropathy, or neuropathy.16

## Current Clinical Practice

Screening for DM can be performed by testing fasting plasma glucose (FPG), 2-hour plasma glucose following an OGTT, or HbA1c.16 Screening with HbA1c is generally more convenient than FPG or OGTT, as pretest fasting is not required, and HbA1c is now considered a diagnostic test for DM by the American Diabetes Association (ADA) and the World Health Organization (WHO),16,35 although there is some evidence suggesting that HbA1c may be less sensitive than FPG or OGTT when using the currently recommended diagnostic cutpoint of greater than or equal to 6.5 percent.36-38 The ADA recommends confirmatory retesting when feasible or in the absence of unequivocal hyperglycemia following initial testing.16 Following diagnosis of DM, lifestyle and other interventions are initiated to lower glucose levels and reduce risk of vascular complications (see above). Recent guidelines from the ADA recommend target HbA1c levels of 6.5 to 8 percent, depending on the individual patient.16

## Recommendations of Other Groups

### Initial Screening

The ADA16 recommends screening for DM in persons age 45 years and older and screening those with risk factors regardless of age. Most other groups, including the American Association of Clinical Endocrinologists,39 the American Academy of Family Physicians,40 the Australian National Evidence-based Guidelines group,41 Diabetes UK,42 and the Canadian Task Force on Preventive Health Care,43 recommend screening persons with risk factors. Identifying at-risk persons who may warrant screening can be based on the presence of known risk factors or by using DM risk calculators (see Contextual Question 2). In 2002, the WHO concluded there was no direct evidence that individuals benefit from early detection of DM through screening, but stated that health authorities and professional organizations should develop their own screening policies based on individual benefits and costs.44

### Screening Intervals

For persons with normal initial screening tests, the ADA16 and Australian National Guidelines41 recommend rescreening every 3 years. The American Association of Clinical Endocrinologists,39 ADA,16 and Australian National Guidelines41 recommend annual testing of persons initially identified as having IFG or IGT. The Canadian Task Force recommends rescreening either annually or every 3 to 5 years, depending on risk level.43