# Evidence and Quality Tables

## Appendix B1 Studies of Screening for DM

## Appendix B2 Quality Assessment of Studies on Screening for DM

## Appendix B3 Studies of the Effect of Interventions for Screen-Detected and Early DM, IFG, or IGT on Health Outcomes

## Appendix B4 Quality Assessment of Studies of Interventions for Screen-Detected and Early DM, IFG, or IGT

## Appendix B5 Harms of Interventions for Screen-Detected and Early DM, IFG, or IGT

## Appendix B6 Study Characteristics of Systematic Reviews of Intensive Glucose, Blood Pressure Control, or Aspirin Use

## Appendix B7 Results of Systematic Reviews of Intensive Glucose, Blood Pressure Control, or Aspirin Use

## Appendix B8 Quality Assessment of Systematic Reviews of More Versus Less Intensive Treatment

## Appendix B9 Trials of More Versus Less Intensive Glucose, Blood Pressure, Lipid Control, or Aspirin Use in Screen-Detected DM

## Appendix B10 Trials of More Versus Less Intensive Glucose, Blood Pressure, Lipid Control, or Aspirin Use in Persons With DM Not Specifically Screen-Detected

## Appendix B11 Quality Assessment of Trials of More Versus Less Intensive Glucose, Blood Pressure, Lipid Control, or Aspirin Use

## Appendix B12 Summary of Trials of Intensive Glucose Control Included in Systematic Reviews

## Appendix B13 Studies of Interventions to Prevent or Delay Progression to DM

## Appendix B14 Quality Assessment of Trials of Interventions to Prevent or Delay Progression to DM

## Appendix B15 Quality Assessment of Cohort Studies of Interventions to Prevent or Delay Progression to DM