# Detailed Methods

## Appendix A1 Search Strategies

### KQ 1-2

Ovid MEDLINE(R) without Revisions 1996 to January Week 1 2013

1. exp Diabetes Mellitus, Type 2/
2. Prediabetic State/
3. Glucose Intolerance/
4. (“impaired fasting glucose” or “ifg”).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
5. (“impaired glucose tolerance” or “itg”).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
6. prediabet$.mp.
7. or/1-6
8. Mass Screening/
9. screen$.ti.
10. 8 or 9
11. 7 and 10
12. Pregnancy/
13. 11 not 12
14. limit 13 to yr=“2007 - 2013”
15. limit 14 to “all adult (19 plus years)”
16. limit 15 to english language
17. limit 15 to abstracts
18. 16 or 17

Cochrane Central Register of Controlled Trials January 2013

1. exp Diabetes Mellitus, Type 2/
2. Prediabetic State/
3. Glucose Intolerance/
4. (“impaired fasting glucose” or “ifg”).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
5. (“impaired glucose tolerance” or “itg”).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
6. prediabet$.mp.
7. or/1-6
8. Mass Screening/
9. screen$.ti.
10. 8 or 9
11. 7 and 10
12. Pregnancy/
13. 11 not 12
14. limit 13 to yr=“2007 – 2013

### KQ 3-6

Ovid MEDLINE(R) without Revisions 1996 to January Week 1 2013

1. exp Diabetes Mellitus, Type 2/
2. Prediabetic State/
3. Glucose Intolerance/
4. (“impaired fasting glucose” or “ifg”).mp.
5. (“impaired glucose tolerance” or “itg”).mp.
6. prediabet$.mp.
7. or/1-6
8. (de or dt or th).fs.
9. 7 and 8
10. exp Hypoglycemic Agents/tu [Therapeutic Use]
11. 7 and 10
12. 9 or 11
13. (200708$ or 200709$ or 20071$ or 2008$ or 2009$ or 2010$ or 2011$ or 2012$ or 2013$).ed.
14. 12 and 13
15. limit 14 to “all adult (19 plus years)”
16. limit 15 to (english language and humans)
17. 16 not (case series or case reports or letter or editorial or comment).pt.

Cochrane Central Register of Controlled Trials January 2013

1. exp Diabetes Mellitus, Type 2/
2. Prediabetic State/
3. Glucose Intolerance/
4. (“impaired fasting glucose” or “ifg”).mp.
5. (“impaired glucose tolerance” or “itg”).mp.
6. prediabet$.mp.
7. or/1-6
8. (de or dt or th).fs.
9. 7 and 8
10. exp Hypoglycemic Agents/tu [Therapeutic Use]
11. 7 and 10
12. 9 or 11
13. Pregnancy/
14. 12 not 13
15. limit 14 to yr=“2007 -Current”
16. limit 15 to medline records
17. 15 not 16

### All KQs

Cochrane Database of Systematic Reviews 2005 to January 2013

1. diabetes mellitus.ti.
2. type 2 diabetes.ti.
3. (child$ or pediatri$ or adolescen$ or pregnan$).ti.
4. (1 or 2) not 3
5. (“impaired fasting glucose” or “impaired glucose tolerance” or “ifg” or “itg” or “prediabete$”).ti.
6. 4 or 5
7. limit 6 to protocols
8. 6 not 7

## Appendix A2 Inclusion and Exclusion Criteria per Key Question

| Include | Exclude
Populations | KQs 1, 2: Asymptomatic, nonpregnant adults KQs 3, 4: Asymptomatic, nonpregnant adults with screen-detected or early type 2 diabetes (based on untreated A1c levels), impaired fasting glucose, or impaired glucose tolerance KQs 5, 6: Asymptomatic, nonpregnant adults with screen-detected or early type 2 diabetes (based on untreated A1c levels), impaired fasting glucose, or impaired glucose tolerance, and also abnormal blood pressure and/or lipid levels KQ 7: Asymptomatic, nonpregnant adults with impaired fasting glucose or impaired glucose tolerance KQ 8: All of the above | KQs 1–8: Children, adolescents, pregnant women; individuals with symptomatic type 2 diabetes, impaired fasting glucose, or impaired glucose tolerance
Interventions | KQs 1, 2: Screening (targeted or universal) for impaired fasting glucose, impaired glucose tolerance, or diabetes KQs 3, 4, 7: Any intervention for glycemic control; lifestyle modification KQs 5, 6: Any intervention for more stringent blood pressure or lipid control or aspirin; more intensive lifestyle modification KQ 8: All of the above
Comparison | KQs 1, 2: No screening or alternative screening strategies KQs 3, 4: No intervention/usual care or interventions in individuals with advanced diabetes KQs 5, 6: Conventional intervention KQ 7: No intervention or usual care KQ 8: All of the above
Outcomes | KQs 1, 3, 5: Mortality, cardiovascular morbidity (including myocardial infarction, stroke, congestive heart failure), chronic kidney disease, amputations, skin ulcers, visual impairment including blindness, periodontitis including tooth loss, moderate-severe neuropathy, quality of life KQ 2: Labeling, anxiety, false-positive results KQs 4, 6: Serious side effects from treatments, including death, heart attack, stroke, cancer, and hypoglycemic event requiring medical attention KQ 7: Development of type 2 diabetes KQ 8: All of the above
Settings | KQs 1–8: Applicable to primary care
Study Designs | KQs 1, 3, 5, 6, 7: Randomized, controlled trials and controlled observational studies, systematic reviews KQs 2: Any KQ 4: Randomized, controlled trials and controlled observational studies, systematic reviews, and large longitudinal studies. KQ 8: All of the above

Abbreviation: KQ = key question.

## Appendix A3 Literature Flow Diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^b^ Other sources include prior reports, reference lists of relevant articles, systematic reviews, etc.

^c^ Some studies have multiple publications and some are included for more than one Key Question.

This figure is a literature flow diagram depicting the search and selection of articles for the review. The figure shows that 7,746 abstracts of potentially relevant articles were identified through MEDLINE, Cochrane, and other sources. After excluding 7,175 non-relevant abstracts and background articles, 571 articles were reviewed at the full-text level. Of these, 485 articles were excluded for the following reasons: wrong population (34), wrong intervention (15), wrong outcomes (129), wrong study design (70), wrong publication type (39), wrong population due to diabetic status (113), systematic review not directly used (33), wrong comparison (32), duplicate data (8), or review used as a source document only (12). 86 publications were included in the review, as follows: 2 studies (in 3 publications) for Key Question 1; 3 studies for Key Question 2; 13 studies (in 16 publications) for Key Question 3; 9 studies (in 11 publications) for Key Question 4; 10 studies (in 33 publications) and 13 systematic reviews for Key Question 5; 6 studies (in 8 publications) and 5 systematic reviews for Key Question 6; 16 studies (in 18 publications) for Key Question 7; and 4 studies and 1 systematic review for Key Question 8. A footnote indicates that some studies are included for more than one Key Question.

## Appendix A4 Excluded Studies

### Wrong population

Aas AM, Ohrvik J, Malmberg K, Ryden L, Birkeland KI, Investigators D. Insulin-induced weight gain and cardiovascular events in patients with type 2 diabetes. A report from the DIGAMI 2 study. Diabetes Obes Metab. 2009;11(4):323-9. [pmid: 19267710].
Ali M, White J, Lee C-H, Palmer JL, Smith-Palmer J, Fakhoury W, et al. Therapy conversion to biphasic insulin aspart 30 improves long-term outcomes and reduces the costs of type 2 diabetes in Saudi Arabia. J Med Econ. 2008;11(4):651-70. [pmid: 19450074].
Athyros VG, Ganotakis E, Kolovou GD, Nicolaou V, Achimastos A, Bilianou E, et al. Assessing the treatment effect in metabolic syndrome without perceptible diabetes (ATTEMPT): a prospective-randomized study in middle aged men and women. Curr Vasc Pharmacol. 2011;9(6):647-57. [pmid: 21476961].
Bayraktar S, Hernadez-Aya LF, Lei X, Meric-Bernstam F, Litton JK, Hsu L, et al. Effect of metformin on survival outcomes in diabetic patients with triple receptor-negative breast cancer. Cancer. 2012;118(5):1202-11. [pmid: 21800293].
Belch J, MacCuish A, Campbell I, Cobbe S, Taylor R, Prescott R, et al. The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. [pmid: 18927173].
Bhatt DL, Chew DP, Grines C, Mukherjee D, Leesar M, Gilchrist IC, et al. Peroxisome proliferator–activated receptor γ agonists for the Prevention of Adverse events following percutaneous coronary Revascularization—results of the PPAR Study. Am Heart J. 2007;154(1):137-43. [pmid: 17584566].
Bilous R, Chaturvedi N, Sjolie AK, Fuller J, Klein R, Orchard T, et al. Effect of candesartan on microalbuminuria and albumin excretion rate in diabetes: three randomized trials. Ann Intern Med. 2009;151(1):11-20. W3. 4. [pmid: 19451554].
Bo S, Ciccone G, Baldi C, Benini L, Dusio F, Forastiere G, et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22(12):1695-703. [pmid: 17922167].
Burgess DC, Hunt D, Li L, Zannino D, Williamson E, Davis TM, et al. Incidence and predictors of silent myocardial infarction in type 2 diabetes and the effect of fenofibrate: an analysis from the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Eur Heart J. 2010;31(1):92-9. [pmid: 19797259].
Carter AA, Gomes T, Camacho X, Juurlink DN, Shah BR, Mamdani MM. Risk of incident diabetes among patients treated with statins: population based study. [Erratum appears in BMJ. 2013;347:f4356]. BMJ. 2013;346:f2610. [pmid: 23704171].
Cholesterol Treatment Trialists C, Kearney PM, Blackwell L, Collins R, Keech A, Simes J, et al. Efficacy of cholesterol-lowering therapy in 18,686 people with diabetes in 14 randomised trials of statins: a meta-analysis. Lancet. 2008;371(9607):117-25. [pmid: 18191683].
Davidson MB, Raskin P, Tanenberg RJ, Vlajnic A, Hollander P. A stepwise approach to insulin therapy in patients with type 2 diabetes mellitus and basal insulin treatment failure. Endocr Pract. 2011;17(3):395-403. [pmid: 21324825].
Du X, Ninomiya T, de Galan B, Abadir E, Chalmers J, Pillai A, et al. Risks of cardiovascular events and effects of routine blood pressure lowering among patients with type 2 diabetes and atrial fibrillation: results of the ADVANCE study. Eur Heart J. 2009;30(9):1128-35. [pmid: 19282274].
Duckworth WC, Abraira C, Moritz TE, Davis SN, Emanuele N, Goldman S, et al. The duration of diabetes affects the response to intensive glucose control in type 2 subjects: the VA Diabetes Trial. J Diabetes Complications. 2011;25(6):355-61. [pmid: 22055259].
Duran-Perez EG, Almeda-Valdes P, Cuevas-Ramos D, Campos-Barrera E, Munoz-Hernandez L, Gomez-Perez FJ. Treatment of metabolic syndrome slows progression of diabetic nephropathy. Metab Syndr Relat Disord. 2011;9(6):483-9. [pmid: 21875335].
Graffy J, Grant J, Williams K, Cohn S, Macbay S, Griffin S, et al. More than measurement: practice team experiences of screening for type 2 diabetes. Fam Pract. 2010;27(4):386-94. [pmid: 20403926].
Hanefeld M, Karasik A, Koehler C, Westermeier T, Chiasson J-L. Metabolic syndrome and its single traits as risk factors for diabetes in people with impaired glucose tolerance: the STOP-NIDDM trial. Diab Vasc Dis Res. 2009;6(1):32-7. [pmid: 19156626].
Hermanns N, Kulzer B, Maier B, Mahr M, Haak T. The effect of an education programme (MEDIAS 2 ICT) involving intensive insulin treatment for people with type 2 diabetes. Patient Educ Couns. 2012;86(2):226-32. [pmid: 21715124].
James WPT, Caterson ID, Coutinho W, Finer N, Van Gaal LF, Maggioni AP, et al. Effect of sibutramine on cardiovascular outcomes in overweight and obese subjects. N Engl J Med. 2010;363(10):905-17. [pmid: 20818901].
Juul L, Sandbaek A, Foldspang A, Frydenberg M, Borch-Johnsen K, Lauritzen T. Adherence to guidelines in people with screen-detected type 2 diabetes, ADDITION, Denmark. Scand J Prim Health Care. 2009;27(4):223-31. [pmid: 19929182].
Kereiakes DJ, Petersen JL, Batchelor WB, Fitzgerald PJ, Mehran R, Lansky A, et al. Clinical and angiographic outcomes in diabetic patients following single or multivessel stenting in the COSTAR II randomized trial. J Invasive Cardiol. 2008;20(7):335-41. [pmid: 18599890].
Kjeldsen SE, McInnes GT, Mancia G, Hua TA, Julius S, Weber MA, et al. Progressive effects of valsartan compared with amlodipine in prevention of diabetes according to categories of diabetogenic risk in hypertensive patients: the VALUE trial. Blood Press. 2008;17(3):170-7. [pmid: 18608200].
Krane V, Heinrich F, Meesmann M, Olschewski M, Lilienthal J, Angermann C, et al. Electrocardiography and outcome in patients with diabetes mellitus on maintenance hemodialysis. Clin J Am Soc Nephrol. 2009;4(2):394-400. [pmid: 19158371].
Krane V, Winkler K, Drechsler C, Lilienthal J, Marz W, Wanner C, et al. Effect of atorvastatin on inflammation and outcome in patients with type 2 diabetes mellitus on hemodialysis. Kidney Int. 2008;74(11):1461-7. [pmid: 18818679].
Lowe J, Linjawi S, Mensch M, James K, Attia J. Flexible eating and flexible insulin dosing in patients with diabetes: Results of an intensive self-management course. Diabetes Res Clin Pract. 2008;80(3):439-43. [pmid: 18353485].
Martinez-Martin FJ, Rodriguez-Rosas H, Peiro-Martinez I, Soriano-Perera P, Pedrianes-Martin P, Comi-Diaz C. Olmesartan/amlodipine vs olmesartan/hydrochlorothiazide in hypertensive patients with metabolic syndrome: the OLAS study. J Hum Hypertens. 2011;25(6):346-53. [pmid: 21107432].
Nieuwdorp M, Stroes ES, Kastelein JJ, Fenofibrate/Metformin Study G. Normalization of metabolic syndrome using fenofibrate, metformin or their combination. Diabetes Obes Metab. 2007;9(6):869-78. [pmid: 17924869].
Oh EG, Bang SY, Hyun SS, Kim SH, Chu SH, Jeon JY, et al. Effects of a 6-month lifestyle modification intervention on the cardiometabolic risk factors and health-related qualities of life in women with metabolic syndrome. Metabolism. 2010;59(7):1035-43. [pmid: 20045151].
Pignone M, Alberts MJ, Colwell JA, Cushman M, Inzucchi SE, Mukherjee D, et al. Aspirin for primary prevention of cardiovascular events in people with diabetes. J Am Coll Cardiol. 2010;55(25):2878-86. [pmid: 20579547].
Rosenstock J, Klaff LJ, Schwartz S, Northrup J, Holcombe JH, Wilhelm K, et al. Effects of exenatide and lifestyle modification on body weight and glucose tolerance in obese subjects with and without pre-diabetes. Diabetes Care. 2010;33(6):1173-5. [pmid: 20332357].
Sargeant LA, Simmons RK, Barling RS, Butler R, Williams KM, Prevost AT, et al. Who attends a UK diabetes screening programme? Findings from the ADDITION-Cambridge study. Diabet Med. 2010;27(9):995-1003. [pmid: 20722672].
Scott R, O'Brien R, Fulcher G, Pardy C, D'Emden M, Tse D, et al. Effects of fenofibrate treatment on cardiovascular disease risk in 9,795 individuals with type 2 diabetes and various components of the metabolic syndrome: the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Diabetes Care. 2009;32(3):493-8. [pmid: 18984774].
Singh S, Loke YK, Furberg CD. Long-term use of thiazolidinediones and the associated risk of pneumonia or lower respiratory tract infection: systematic review and meta-analysis. Thorax. 2011;66(5):383-8. [pmid: 21325145].
Ting RD, Keech AC, Drury PL, Donoghoe MW, Hedley J, Jenkins AJ, et al. Benefits and safety of long-term fenofibrate therapy in people with type 2 diabetes and renal impairment: the FIELD Study. Diabetes Care. 2012;35(2):218-25. [pmid: 22210576].

### Wrong intervention

Cleveringa FGW, Welsing PMJ, van den Donk M, Gorter KJ, Niessen LW, Rutten GEHM, et al. Cost-effectiveness of the diabetes care protocol, a multifaceted computerized decision support diabetes management intervention that reduces cardiovascular risk. Diabetes Care. 2010;33(2):258-63. [pmid: 19933991].
Coronel F, Cigarran S, Herrero JA. Early initiation of peritoneal dialysis in diabetic patients. Scand J Urol Nephrol. 2009;43(2):148-53. [pmid: 19085460].
Grant SJ, Bensoussan A, Chang D, Kiat H, Klupp NL, Liu PJ, et al. Chinese herbal medicines for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database Syst Rev. 2009;(4).
Ip MS, Bressler SB, Antoszyk AN, Flaxel CJ, Kim JE, Friedman SM, et al. A randomized trial comparing intravitreal triamcinolone and focal/grid photocoagulation for diabetic macular edema: baseline features. Retina. 2008;28(7):919-30. [pmid: 18698292].
Jones TH, Arver S, Behre HM, Buvat J, Meuleman E, Moncada I, et al. Testosterone replacement in hypogonadal men with type 2 diabetes and/or metabolic syndrome (the TIMES2 study). Diabetes Care. 2011;34(4):828-37. [pmid: 21386088].
Kamoi K, Ito T, Miyakoshi M, Minagawa S. Usefulness of home blood pressure measurement in the morning in patients with type 2 diabetes: long-term results of a prospective longitudinal study. Clin Exp Hypertens. 2010;32(3):184-92. [pmid: 20504126].
Karagiannis T, Paschos P, Paletas K, Matthews DR, Tsapas A. Dipeptidyl peptidase-4 inhibitors for treatment of type 2 diabetes mellitus in the clinical setting: systematic review and meta-analysis. BMJ. 2012;344:e1369. [pmid: 22411919].
Lievre MM, Moulin P, Thivolet C, Rodier M, Rigalleau V, Penfornis A, et al. Detection of silent myocardial ischemia in asymptomatic patients with diabetes: results of a randomized trial and meta-analysis assessing the effectiveness of systematic screening. Trials. 2011;12:23. [pmid: 21269454].
Londahl M, Landin-Olsson M, Katzman P. Hyperbaric oxygen therapy improves health-related quality of life in patients with diabetes and chronic foot ulcer. Diabet Med. 2011;28(2):186-90. [pmid: 21219427].
Nield L, Moore H, Hooper L, Cruickshank K, Vyas A, Whittaker V, et al. Dietary advice for treatment of type 2 diabetes mellitus in adults. Cochrane Database Syst Rev. 2009;(1).
Nield L, Summerbell CD, Hooper L, Whittaker V, Moore H. Dietary advice for the prevention of type 2 diabetes mellitus in adults. Cochrane Database Syst Rev. 2008;(3).
Ose D, Miksch A, Urban E, Natanzon I, Szecsenyi J, Kunz CU, et al. Health related quality of life and comorbidity. A descriptive analysis comparing EQ-5D dimensions of patients in the German disease management program for type 2 diabetes and patients in routine care. BMC Health Serv Res. 2011;11:179. [pmid: 21810241].
Ratner R, Han J, Nicewarner D, Yushmanova I, Hoogwerf BJ, Shen L. Cardiovascular safety of exenatide BID: an integrated analysis from controlled clinical trials in participants with type 2 diabetes. Cardiovasc Diabetol. 2011;10:22. [pmid: 21410975].
Ruggenenti P, Fassi A, Ilieva AP, Iliev IP, Chiurchiu C, Rubis N, et al. Effects of verapamil added-on trandolapril therapy in hypertensive type 2 diabetes patients with microalbuminuria: the BENEDICT-B randomized trial. J Hypertens. 2011;29(2):207-16. [pmid: 21243736].
Wang C-C, Chen W-L, Kao T-W, Chang Y-W, Loh C-H, Chou C-C. Incidence of cardiovascular events in which 2 thiazolidinediones are used as add-on treatments for type 2 diabetes mellitus in a Taiwanese population. [Erratum appears in Clin Ther. 2012 Feb;34(2):508 Note: Chou, Chih-Chieh [corrected to Chou, Chin-Chieh]]. Clin Ther. 2011;33(12):1904-13. [pmid: 22118894].

### Wrong outcomes

Abe H, Minatoguchi S, Ohashi H, Murata I, Minagawa T, Okuma T, et al. Renoprotective effect of the addition of losartan to ongoing treatment with an angiotensin converting enzyme inhibitor in type-2 diabetic patients with nephropathy. Hypertens Res. 2007;30(10):929-35. [pmid: 18049024].
Adachi M, Yamaoka K, Watanabe M, Nishikawa M, Hida E, Kobayashi I, et al. Effects of lifestyle education program for type 2 diabetes patients in clinics: study design of a cluster randomized trial. BMC Public Health. 2010;10:742. [pmid: 21118514].
Adarkwah CC, Gandjour A. Cost-effectiveness of angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers in newly diagnosed type 2 diabetes in Germany. Int J Technol Assess Health Care. 2010;26(1):62-70. [pmid: 20059782].
Afzali HHA, Karnon J, Gray J, Beilby J. A model-based evaluation of collaborative care in management of patients with type 2 diabetes in Australia: an initial report. Aust Health Rev. 2012;36(3):258-63. [pmid: 22935112].
Al Mazroui NR, Kamal MM, Ghabash NM, Yacout TA, Kole PL, McElnay JC. Influence of pharmaceutical care on health outcomes in patients with Type 2 diabetes mellitus. Br J Clin Pharmacol. 2009;67(5):547-57. [pmid: 19552750].
Allen P, Thompson JL, Herman CJ, Whyte AN, Wolfe VK, Qualls C, et al. Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Prev Chronic Dis. 2008;5(3):A76. [pmid: 18558026].
Alvarsson M, Sundkvist G, Lager I, Berntorp K, Fernqvist-Forbes E, Steen L, et al. Effects of insulin vs. glibenclamide in recently diagnosed patients with type 2 diabetes: a 4-year follow-up. Diabetes Obes Metab. 2008;10(5):421-9. [pmid: 17394534].
Alvear-Galindo MG, Laurell AC. Analysis of the diabetes mellitus screening program in the Federal District, Mexico. Cad Saude Publica. 2010;26(2):299-310. [pmid: 20396845].
Andersson U, Berger K, Hogberg A, Landin-Olsson M, Holm C. Effects of rose hip intake on risk markers of type 2 diabetes and cardiovascular disease: a randomized, double-blind, cross-over investigation in obese persons. Eur J Clin Nutr. 2012;66(5):585-90. [pmid: 22166897].
Askew DA, Jackson CL, Ware RS, Russell A. Protocol and baseline data from The Inala Chronic Disease Management Service evaluation study: a health services intervention study for diabetes care. BMC Health Serv Res. 2010;10:134. [pmid: 20492731].
Athyros VG, Elisaf MS, Alexandrides T, Achimastos A, Ganotakis E, Bilianou E, et al. Long-term impact of multifactorial treatment on new-onset diabetes and related cardiovascular events in metabolic syndrome: a post hoc ATTEMPT analysis. Angiology. 2012;63(5):358-66. [pmid: 22007026].
Aujla N, Skinner TC, Khunti K, Davies MJ. The prevalence of depressive symptoms in a white European and South Asian population with impaired glucose regulation and screen-detected Type 2 diabetes mellitus: a comparison of two screening tools. Diabet Med. 2010;27(8):896-905. [pmid: 20653747].
Bakris GL, Toto RD, McCullough PA, Rocha R, Purkayastha D, Davis P, et al. Effects of different ACE inhibitor combinations on albuminuria: results of the GUARD study. Kidney Int. 2008;73(11):1303-9. [pmid: 18354383].
Balkau B, Bouee S, Avignon A, Verges B, Chartier I, Amelineau E, et al. Type 2 diabetes treatment intensification in general practice in France in 2008-2009: the DIAttitude Study. Diabetes Metab. Suppl 3. 2012;38:S29-35. [pmid: 22541600].
Balkrishnan R, Arondekar BV, Camacho FT, Shenolikar RA, Horblyuk R, Anderson RT. Comparisons of rosiglitazone versus pioglitazone monotherapy introduction and associated health care utilization in medicaid-enrolled patients with type 2 diabetes mellitus. Clin Ther. 2007;29. Spec No: 1306-15.
Bayliss EA, Blatchford PJ, Newcomer SR, Steiner JF, Fairclough DL. The effect of incident cancer, depression and pulmonary disease exacerbations on type 2 diabetes control. J Gen Intern Med. 2011;26(6):575-81. [pmid: 21203859].
Bek T, Lund-Andersen H, Hansen AB, Johnsen KB, Sandbaek A, Lauritzen T. The prevalence of diabetic retinopathy in patients with screen-detected type 2 diabetes in Denmark: the ADDITION study. Acta Ophthalmol (Oxf). 2009;87(3):270-4.
Bertram MY, Lim SS, Barendregt JJ, Vos T. Assessing the cost-effectiveness of drug and lifestyle intervention following opportunistic screening for pre-diabetes in primary care. Diabetologia. 2010;53(5):875-81. [pmid: 20135088].
Beyazit E, Mollaoglu M. Investigation of effect on glycosylated hemoglobin, blood pressure, and body mass index of diabetes intensive education program in patients with type 2 diabetes mellitus. Am J Mens Health. 2011;5(4):351-7. [pmid: 21406489].
Black. Change in cardiovascular risk factors following early diagnosis of type 2 diabetes. In press.
Black JA, Sharp SJ, Wareham NJ, Sandbæk A, Rutten GEHM, Lauritzen T, et al. Does early intensive multifactorial therapy reduce modelled cardiovascular risk in individuals with screen-detected diabetes? Results from the ADDITION-Europe cluster randomized trial. Diabet Med. 2014. n/a-n/a.
Bodmer M, Meier C, Krahenbuhl S, Jick SS, Meier CR. Metformin, sulfonylureas, or other antidiabetes drugs and the risk of lactic acidosis or hypoglycemia: a nested case-control analysis. Diabetes Care. 2008;31(11):2086-91. [pmid: 18782901].
Bonds DE, Craven TE, Buse J, Crouse JR, Cuddihy R, Elam M, et al. Fenofibrate-associated changes in renal function and relationship to clinical outcomes among individuals with type 2 diabetes: the Action to Control Cardiovascular Risk in Diabetes (ACCORD) experience. Diabetologia. 2012;55(6):1641-50. [pmid: 22450889].
Bouchard DR, Baillargeon J-P, Gagnon C, Brown C, Langlois M-F. Impact of health professionals' contact frequency on response to a lifestyle intervention with individuals at high risk for diabetes. Diabetes Res Clin Pract. 2012;96(2):129-34. [pmid: 22245692].
Brouwer BG, Visseren FLJ, Algra A, van Bockel JH, Bollen ELEM, Doevendans PA, et al. Effectiveness of a hospital-based vascular screening programme (SMART) for risk factor management in patients with established vascular disease or type 2 diabetes: a parallel-group comparative study. J Intern Med. 2010;268(1):83-93. [pmid: 20337856].
Bulcao C, Ribeiro-Filho FF, Sanudo A, Roberta Ferreira SG. Effects of simvastatin and metformin on inflammation and insulin resistance in individuals with mild metabolic syndrome. Am J Cardiovasc Drugs. 2007;7(3):219-24. [pmid: 17610348].
Chakreeyarat S, Saetung S, Chailurkit L-o, Rattanasiri S, Ditbanjong S, Chitrapazt N, et al. Elevated vitamin D status in postmenopausal women on thiazolidinediones for type 2 diabetes. Endocrine. 2011;39(3):278-82. [pmid: 21069575].
Chalmers J, Hunter JE, Robertson SJ, Baird J, Martin M, Franks CI, et al. Effects of early use of pioglitazone in combination with metformin in patients with newly diagnosed type 2 diabetes. Curr Med Res Opin. 2007;23(8):1775-81. [pmid: 17712875].
Chalmers J, Kengne A-P, Joshi R, Perkovic V, Patel A. New insights from ADVANCE. Journal of Hypertension - Supplement. 2007;25(1):S23-30.
Chamnan P, Simmons RK, Khaw KT, Wareham NJ, Griffin SJ. Estimating the population impact of screening strategies for identifying and treating people at high risk of cardiovascular disease: modelling study. BMJ. 2010;340:c1693. [pmid: 20418545].
Chao T-F, Leu H-B, Huang C-C, Chen J-W, Chan W-L, Lin S-J, et al. Thiazolidinediones can prevent new onset atrial fibrillation in patients with non-insulin dependent diabetes. Int J Cardiol. 2012;156(2):199-202. [pmid: 21930315].
Charbonnel B, DeFronzo R, Davidson J, Schmitz O, Birkeland K, Pirags V, et al. Pioglitazone use in combination with insulin in the prospective pioglitazone clinical trial in macrovascular events study (PROactive19). J Clin Endocrinol Metab. 2010;95(5):2163-71. [pmid: 20237169].
Charles M, Fleischer J, Witte DR, Ejskjaer N, Borch-Johnsen K, Lauritzen T, et al. Impact of early detection and treatment of diabetes on the 6-year prevalence of cardiac autonomic neuropathy in people with screen-detected diabetes: ADDITION-Denmark, a cluster-randomised study. Diabetologia. 2013;56(1):101-8. [pmid: 23064291].
Chatterjee R, Narayan KMV, Lipscomb J, Phillips LS. Screening adults for pre-diabetes and diabetes may be cost-saving. Diabetes Care. 2010;33(7):1484-90. [pmid: 20587721].
Chon S, Oh S, Kim SW, Kim J-W, Kim YS, Woo J-t. The effect of early insulin therapy on pancreatic -cell function and long-term glycemic control in newly diagnosed type 2 diabetic patients. Korean J Intern Med. 2010;25(3):273-81. [pmid: 20830224].
Ciardullo AV, Daghio MM, Bevini M, Feltri G, Novi D, Fattori G, et al. Joint and distinct risk factors associated with micro- and macrovascular complications in a cohort of type 2 diabetic patients cared through disease management. Acta Diabetol. 2010;47(4):301-8. [pmid: 20383650].
Coclami T, Cross M. Psychiatric comorbidity with type 1 and type 2 diabetes mellitus. East Mediterr Health J. 2011;17(10):777-83. [pmid: 22256413].
Colagiuri S, Walker AE. Using an economic model of diabetes to evaluate prevention and care strategies in Australia. Health Aff (Millwood). 2008;27(1):256-68. [pmid: 18180502].
Cooper GJS, Young AA, Gamble GD, Occleshaw CJ, Dissanayake AM, Cowan BR, et al. A copper(II)-selective chelator ameliorates left-ventricular hypertrophy in type 2 diabetic patients: a randomised placebo-controlled study. Diabetologia. 2009;52(4):715-22. [pmid: 19172243].
Cosson E, Nguyen MT, Hamo-Tchatchouang E, Banu I, Chiheb S, Charnaux N, et al. What would be the outcome if the American Diabetes Association recommendations of 2010 had been followed in our practice in 1998-2006?. Diabet Med. 2011;28(5):567-74. [pmid: 21480967].
Covington P, Christopher R, Davenport M, Fleck P, Mekki QA, Wann ER, et al. Pharmacokinetic, pharmacodynamic, and tolerability profiles of the dipeptidyl peptidase-4 inhibitor alogliptin: a randomized, double-blind, placebo-controlled, multiple-dose study in adult patients with type 2 diabetes. Clin Ther. 2008;30(3):499-512. [pmid: 18405788].
Dalsgaard EM, Lauritzen T, Christiansen T, Mai KS, Borch-Johnsen K, Sandbaek A. Socioeconomic factors related to attendance at a Type 2 diabetes screening programme. Diabet Med. 2009;26(5):518-25. [pmid: 19646192].
Dalsgaard E-M, Christensen JO, Skriver MV, Borch-Johnsen K, Lauritzen T, Sandbaek A. Comparison of different stepwise screening strategies for type 2 diabetes: Finding from Danish general practice, Addition-DK. Prim Care Diabetes. 2010;4(4):223-9. [pmid: 20675208].
Davidson JA, Lacaya LB, Jiang H, Heilmann CR, Scism-Bacon JL, Gates JR, et al. Impact of race/ethnicity on the efficacy and safety of commonly used insulin regimens: a post hoc analysis of clinical trials in type 2 diabetes mellitus. Endocr Pract. 2010;16(5):818-28. [pmid: 20439249].
Doucet J, Chacra A, Maheux P, Lu J, Harris S, Rosenstock J. Efficacy and safety of saxagliptin in older patients with type 2 diabetes mellitus. Curr Med Res Opin. 2011;27(4):863-9. [pmid: 21323504].
Dunkley AJ, Davies MJ, Stone MA, Taub NA, Troughton J, Yates T, et al. The Reversal Intervention for Metabolic Syndrome (TRIMS) study: rationale, design, and baseline data. Trials. 2011;12:107. [pmid: 21542913].
Eborall H, Davies R, Kinmonth A-L, Griffin S, Lawton J. Patients' experiences of screening for type 2 diabetes: prospective qualitative study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2007;335(7618):490. [pmid: 17762000].
Fakhoury WKH, Lereun C, Wright D. A meta-analysis of placebo-controlled clinical trials assessing the efficacy and safety of incretin-based medications in patients with type 2 diabetes. Pharmacology. 2010;86(1):44-57. [pmid: 20616619].
Feldman L, Shani M, Efrati S, Beberashvili I, Baevsky T, Weissgarten J, et al. Association between rosiglitazone use and decline in renal function in patients with type 2 diabetes mellitus. J Nephrol. 2010;23(3):350-6. [pmid: 20155725].
Forst T, Uhlig-Laske B, Ring A, Graefe-Mody U, Friedrich C, Herbach K, et al. Linagliptin (BI 1356), a potent and selective DPP-4 inhibitor, is safe and efficacious in combination with metformin in patients with inadequately controlled Type 2 diabetes. Diabet Med. 2010;27(12):1409-19. [pmid: 21059094].
Giorda CB, Avogaro A, Maggini M, Lombardo F, Mannucci E, Turco S, et al. Recurrence of cardiovascular events in patients with type 2 diabetes: epidemiology and risk factors. Diabetes Care. 2008;31(11):2154-9. [pmid: 18782902].
Goldberg RB, Temprosa M, Haffner S, Orchard TJ, Ratner RE, Fowler SE, et al. Effect of progression from impaired glucose tolerance to diabetes on cardiovascular risk factors and its amelioration by lifestyle and metformin intervention: the Diabetes Prevention Program randomized trial by the Diabetes Prevention Program Research Group. Diabetes Care. 2009;32(4):726-32. [pmid: 19171717].
Goyder E, Wild S, Fischbacher C, Carlisle J, Peters J. Evaluating the impact of a national pilot screening programme for type 2 diabetes in deprived areas of England. Fam Pract. 2008;25(5):370-5. [pmid: 18765406].
Hanefeld M, Herman GA, Wu M, Mickel C, Sanchez M, Stein PP, et al. Once-daily sitagliptin, a dipeptidyl peptidase-4 inhibitor, for the treatment of patients with type 2 diabetes. Curr Med Res Opin. 2007;23(6):1329-39. [pmid: 17559733].
Hare JL, Hordern MD, Leano R, Stanton T, Prins JB, Marwick TH. Application of an exercise intervention on the evolution of diastolic dysfunction in patients with diabetes mellitus: efficacy and effectiveness. Circ Heart Fail. 2011;4(4):441-9. [pmid: 21576281].
Hartmann M, Kopf S, Kircher C, Faude-Lang V, Djuric Z, Augstein F, et al. Sustained effects of a mindfulness-based stress-reduction intervention in type 2 diabetic patients: design and first results of a randomized controlled trial (the Heidelberger Diabetes and Stress-study). Diabetes Care. 2012;35(5):945-7. [pmid: 22338101].
Huisman S, de Gucht V, Maes S, Schroevers M, Chatrou M, Haak H. Self-regulation and weight reduction in patients with type 2 diabetes: a pilot intervention study. Patient Educ Couns. 2009;75(1):84-90. [pmid: 19097740].
Ikeda H, Hamamoto Y, Honjo S, Nabe K, Wada Y, Koshiyama H. Olmesartan reduced microalbuminuria in Japanese subjects with type 2 diabetes. Diabetes Res Clin Pract. 2009;83(1):117-8. [pmid: 19062123].
Investigators AES, Group AC. Effects of perindopril-indapamide on left ventricular diastolic function and mass in patients with type 2 diabetes: the ADVANCE Echocardiography Substudy. J Hypertens. 2011;29(7):1439-47. [pmid: 21610514].
Investigators DT. Incidence of diabetes following ramipril or rosiglitazone withdrawal. Diabetes Care. 2011;34(6):1265-9. [pmid: 21515846].
Iwamoto Y, Taniguchi T, Nonaka K, Okamoto T, Okuyama K, Arjona Ferreira JC, et al. Dose-ranging efficacy of sitagliptin, a dipeptidyl peptidase-4 inhibitor, in Japanese patients with type 2 diabetes mellitus. Endocr J. 2010;57(5):383-94. [pmid: 20332588].
Janssen PGH, Gorter KJ, Stolk RP, Akarsubasi M, Rutten GEHM. Three years follow-up of screen-detected diabetic and non-diabetic subjects: who is better off? The ADDITION Netherlands study. BMC Fam Pract. 2008;9:67. [pmid: 19087327].
Janssen PGH, Gorter KJ, Stolk RP, Rutten GEHM. Low yield of population-based screening for Type 2 diabetes in the Netherlands: the ADDITION Netherlands study. Fam Pract. 2007;24(6):555-61. [pmid: 17962235].
Johansen NB, Charles M, Vistisen D, Rasmussen SS, Wiinberg N, Borch-Johnsen K, et al. Effect of intensive multifactorial treatment compared with routine care on aortic stiffness and central blood pressure among individuals with screen-detected type 2 diabetes: the ADDITION-Denmark study. Diabetes Care. 2012;35(11):2207-14. [pmid: 22787176].
Kamber N, Davis WA, Bruce DG, Davis TME. Metformin and lactic acidosis in an Australian community setting: the Fremantle Diabetes Study. Med J Aust. 2008;188(8):446-9. [pmid: 18429709].
Katula JA, Vitolins MZ, Rosenberger EL, Blackwell CS, Morgan TM, Lawlor MS, et al. One-year results of a community-based translation of the Diabetes Prevention Program: Healthy-Living Partnerships to Prevent Diabetes (HELP PD) Project. [Erratum appears in Diabetes Care. 2012 Feb;35(2):455]. Diabetes Care. 2011;34(7):1451-7. [pmid: 21593290].
Kawamori R, Inagaki N, Araki E, Watada H, Hayashi N, Horie Y, et al. Linagliptin monotherapy provides superior glycaemic control versus placebo or voglibose with comparable safety in Japanese patients with type 2 diabetes: a randomized, placebo and active comparator-controlled, double-blind study. Diabetes Obes Metab. 2012;14(4):348-57. [pmid: 22145698].
Ke B, Shi L, Jun-jie Z, Chen D-s, Meng J, Qin J. Protective effects of modified linggui zhugan decoction combined with short-term very low calorie diets on cardiovascular risk factors in obese patients with impaired glucose tolerance. J Tradit Chin Med. 2012;32(2):193-8. [pmid: 22876442].
Kellar I, Mann E, Kinmonth AL, Prevost AT, Sutton S, Marteau TM. Can informed choice invitations lead to inequities in intentions to make lifestyle changes among participants in a primary care diabetes screening programme? Evidence from a randomized trial. Public Health. 2011;125(9):645-52. [pmid: 21764087].
Kelley DS, Adkins Y, Woodhouse LR, Swislocki A, Mackey BE, Siegel D. Docosahexaenoic acid supplementation improved lipocentric but not glucocentric markers of insulin sensitivity in hypertriglyceridemic men. Metab Syndr Relat Disord. 2012;10(1):32-8. [pmid: 21999398].
Kerr JL, Timpe EM, Petkewicz KA. Bromocriptine mesylate for glycemic management in type 2 diabetes mellitus. Ann Pharmacother. 2010;44(11):1777-85. [pmid: 20978217].
Khowaja K, Waheed H. Self-glucose monitoring and glycaemic control at a tertiary care university hospital, Karachi, Pakistan. JPMA - Journal of the Pakistan Medical Association. 2010;60(12):1035-8.
Kikuchi M, Abe N, Kato M, Terao S, Mimori N, Tachibana H. Vildagliptin dose-dependently improves glycemic control in Japanese patients with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2009;83(2):233-40. [pmid: 19118913].
Kim CS, Park SY, Kang JG, Lee SJ, Ihm SH, Choi MG, et al. Insulin dose titration system in diabetes patients using a short messaging service automatically produced by a knowledge matrix. Diabetes Technol Ther. 2010;12(8):663-9. [pmid: 20615108].
Kim HJ, Park KS, Lee SK, Min KW, Han KA, Kim YK, et al. Effects of pinitol on glycemic control, insulin resistance and adipocytokine levels in patients with type 2 diabetes mellitus. Ann Nutr Metab. 2012;60(1):1-5. [pmid: 22179130].
Kim MK, Ko S-H, Baek K-H, Ahn Y-B, Yoon K-H, Kang M-I, et al. Long-term effects of rosiglitazone on the progressive decline in renal function in patients with type 2 diabetes. Korean J Intern Med. 2009;24(3):227-32. [pmid: 19721859].
Kim S-I, Kim H-S. Effectiveness of mobile and internet intervention in patients with obese type 2 diabetes. Int J Med Inf. 2008;77(6):399-404.
King AB, Wolfe GS. Evaluation of a diabetes specialist-guided primary care diabetes treatment program. J Am Acad Nurse Pract. 2009;21(1):24-30. [pmid: 19125892].
Kipnes MS, Hollander P, Fujioka K, Gantz I, Seck T, Erondu N, et al. A one-year study to assess the safety and efficacy of the CB1R inverse agonist taranabant in overweight and obese patients with type 2 diabetes. Diabetes Obes Metab. 2010;12(6):517-31. [pmid: 20518807].
Klein Woolthuis EP, de Grauw WJC, van Gerwen WHEM, van den Hoogen HJM, van de Lisdonk EH, Metsemakers JFM, et al. Yield of opportunistic targeted screening for type 2 diabetes in primary care: the diabscreen study. Ann Fam Med. 2009;7(5):422-30. [pmid: 19752470].
Koekkoek PS, Ruis C, van den Donk M, Biessels GJ, Gorter KJ, Kappelle LJ, et al. Intensive multifactorial treatment and cognitive functioning in screen-detected type 2 diabetes--the ADDITION-Netherlands study: a cluster-randomized trial. J Neurol Sci. 2012;314(1-2):71-7. [pmid: 22093142].
Kosuri M, Sridhar GR. Yoga practice in diabetes improves physical and psychological outcomes. Metab Syndr Relat Disord. 2009;7(6):515-7. [pmid: 19900155].
Lambers S, Van Laethem C, Van Acker K, Calders P. Influence of combined exercise training on indices of obesity, diabetes and cardiovascular risk in type 2 diabetes patients. Clin Rehabil. 2008;22(6):483-92. [pmid: 18511528].
Lazo M, Solga SF, Horska A, Bonekamp S, Diehl AM, Brancati FL, et al. Effect of a 12-month intensive lifestyle intervention on hepatic steatosis in adults with type 2 diabetes. Diabetes Care. 2010;33(10):2156-63. [pmid: 20664019].
Lundby Christensen L, Almdal T, Boesgaard T, Breum L, Dunn E, Gade-Rasmussen B, et al. Study rationale and design of the CIMT trial: the Copenhagen Insulin and Metformin Therapy trial. Diabetes Obes Metab. 2009;11(4):315-22. [pmid: 19267709].
Mai KS, Sandbaek A, Borch-Johnsen K, Lauritzen T. Are lifestyle changes achieved after participation in a screening programme for Type 2 diabetes? The ADDITION Study, Denmark. Diabet Med. 2007;24(10):1121-8. [pmid: 17725631].
Maindal HT, Sandbaek A, Kirkevold M, Lauritzen T. Effect on motivation, perceived competence, and activation after participation in the “Ready to Act” programme for people with screen-detected dysglycaemia: a 1-year randomised controlled trial, Addition-DK. Scand J Public Health. 2011;39(3):262-71. [pmid: 21427147].
Malanda UL, Welschen MCL, Riphagen II, Dekker JM, Nijpels G, Bot DMS. Self-monitoring of blood glucose in patients with type 2 diabetes mellitus who are not using insulin. Cochrane Database Syst Rev. 2012;(5).
Malin SK, Nightingale J, Choi SE, Chipkin SR, Braun B. Metformin modifies the exercise training effects on risk factors for cardiovascular disease in impaired glucose tolerant adults. Obesity (Silver Spring). 2013;21(1):93-100. [pmid: 23505172].
Memişoğullari R, Akçay F, Coşkun A, Korkmaz U. Comparison of Gliclazide Treatment with Diet Therapy on Acute Phase Protein Levels in Patients with Type 2 Diabetes. Turk J Med Sci. 2009;39(1):73-6.
Mychaleckyj JC, Craven T, Nayak U, Buse J, Crouse JR, Elam M, et al. Reversibility of fenofibrate therapy-induced renal function impairment in ACCORD type 2 diabetic participants. Diabetes Care. 2012;35(5):1008-14. [pmid: 22432114].
Norris SL, Zhang X, Avenell A, Gregg E, Brown T, Schmid CH, et al. Long-term non-pharmacological weight loss interventions for adults with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(1).
Norris SL, Zhang X, Avenell A, Gregg E, Schmid CH, Lau J. Long-term non-pharmacological weight loss interventions for adults with prediabetes. Cochrane Database Syst Rev. 2009;(1).
Norris SL, Zhang X, Avenell A, Gregg E, Schmid CH, Lau J. Pharmacotherapy for weight loss in adults with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(3).
Okada S, Hiuge A, Makino H, Nagumo A, Takaki H, Konishi H, et al. Effect of exercise intervention on endothelial function and incidence of cardiovascular disease in patients with type 2 diabetes. J Atheroscler Thromb. 2010;17(8):828-33. [pmid: 20467191].
Perreault L, Kahn SE, Christophi CA, Knowler WC, Hamman RF, Diabetes Prevention Program Research G. Regression from pre-diabetes to normal glucose regulation in the diabetes prevention program. Diabetes Care. 2009;32(9):1583-8. [pmid: 19587364].
Perreault L, Pan Q, Mather KJ, Watson KE, Hamman RF, Kahn SE, et al. Effect of regression from prediabetes to normal glucose regulation on long-term reduction in diabetes risk: results from the Diabetes Prevention Program Outcomes Study. Lancet. 2012;379(9833):2243-51. [pmid: 22683134].
Pop-Busui R, Evans GW, Gerstein HC, Fonseca V, Fleg JL, Hoogwerf BJ, et al. Effects of cardiac autonomic dysfunction on mortality risk in the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. Diabetes Care. 2010;33(7):1578-84. [pmid: 20215456].
Preiss D, Giles TD, Thomas LE, Sun J-L, Haffner SM, Holman RR, et al. Predictors of stroke in patients with impaired glucose tolerance: results from the Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research trial. Stroke. 2013;44(9):2590-3. [pmid: 23899915].
Raisch DW, Feeney P, Goff DC Jr., Narayan KMV, O'Connor PJ, Zhang P, et al. Baseline comparison of three health utility measures and the feeling thermometer among participants in the Action to Control Cardiovascular Risk in Diabetes trial. Cardiovasc Diabetol. 2012;11:35. [pmid: 22515638].
Rasmussen SS, Glumer C, Sandbaek A, Lauritzen T, Borch-Johnsen K. Determinants of progression from impaired fasting glucose and impaired glucose tolerance to diabetes in a high-risk screened population: 3 year follow-up in the ADDITION study, Denmark. Diabetologia. 2008;51(2):249-57. [pmid: 18060659].
Rasmussen SS, Glumer C, Sandbaek A, Lauritzen T, Carstensen B, Borch-Johnsen K. Short-term reproducibility of impaired fasting glycaemia, impaired glucose tolerance and diabetes The ADDITION study, DK. Diabetes Res Clin Pract. 2008;80(1):146-52. [pmid: 18082284].
Redmon JB, Bertoni AG, Connelly S, Feeney PA, Glasser SP, Glick H, et al. Effect of the look AHEAD study intervention on medication use and related cost to treat cardiovascular disease risk factors in individuals with type 2 diabetes. Diabetes Care. 2010;33(6):1153-8. [pmid: 20332353].
Rejeski WJ, Ip EH, Bertoni AG, Bray GA, Evans G, Gregg EW, et al. Lifestyle change and mobility in obese adults with type 2 diabetes. N Engl J Med. 2012;366(13):1209-17. [pmid: 22455415].
Renders MC, Valk GD, Griffin SJ, Wagner E, van Eijk TJ, Assendelft JJW. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database Syst Rev. 2009;(1).
Retnakaran R, Qi Y, Harris SB, Hanley AJ, Zinman B. Changes over time in glycemic control, insulin sensitivity, and beta-cell function in response to low-dose metformin and thiazolidinedione combination therapy in patients with impaired glucose tolerance. Diabetes Care. 2011;34(7):1601-4. [pmid: 21709296].
Richter B, Bandeira-Echtler E, Bergerhoff K, Clar C, Ebrahim SH. Rosiglitazone for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(1).
Richter B, Bandeira-Echtler E, Bergerhoff K, Lerch C. Dipeptidyl peptidase-4 (DPP-4) inhibitors for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(3).
Roman MJ, Howard BV, Howard WJ, Mete M, Fleg JL, Lee ET, et al. Differential impacts of blood pressure and lipid lowering on regression of ventricular and arterial mass: the Stop Atherosclerosis in Native Diabetics Trial. Hypertension. 2011;58(3):367-71. [pmid: 21788602].
Rosenstock J, Fonseca VA, Garvey WT, Goldberg RB, Handelsman Y, Abby SL, et al. Initial combination therapy with metformin and colesevelam for achievement of glycemic and lipid goals in early type 2 diabetes. Endocr Pract. 2010;16(4):629-40. [pmid: 20634175].
Rubak S, Sandbaek A, Lauritzen T, Borch-Johnsen K, Christensen B. Effect of “motivational interviewing” on quality of care measures in screen detected type 2 diabetes patients: a one-year follow-up of an RCT, ADDITION Denmark. Scand J Prim Health Care. 2011;29(2):92-8. [pmid: 21306296].
Rytter E, Vessby B, Asgard R, Ersson C, Moussavian S, Sjodin A, et al. Supplementation with a combination of antioxidants does not affect glycaemic control, oxidative stress or inflammation in type 2 diabetes subjects. Free Radic Res. 2010;44(12):1445-53. [pmid: 20942575].
Sabherwal S, Bravis V, Devendra D. Effect of oral vitamin D and calcium replacement on glycaemic control in South Asian patients with type 2 diabetes. Int J Clin Pract. 2010;64(8):1084-9. [pmid: 20642708].
Sacks FM. After the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study: implications for fenofibrate. Am J Cardiol. 2008;102(12A):34L-40L.
Saenz A, Fernandez-Esteban I, Mataix A, Ausejo Segura M, Roque i Figuls M, Moher D. Metformin monotherapy for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(1).
Safaei H, Janghorbani M, Aminorroaya A, Amini M. Lovastatin effects on bone mineral density in postmenopausal women with type 2 diabetes mellitus. Acta Diabetol. 2007;44(2):76-82. [pmid: 17530471].
Salinero-Fort MA, Carrillo-de Santa Pau E, Arrieta-Blanco FJ, Abanades-Herranz JC, Martin-Madrazo C, Rodes-Soldevila B, et al. Effectiveness of PRECEDE model for health education on changes and level of control of HbA1c, blood pressure, lipids, and body mass index in patients with type 2 diabetes mellitus. BMC Public Health. 2011;11:267. [pmid: 21524316].
Samaropoulos XF, Light L, Ambrosius WT, Marcovina SM, Probstfield J, Jr DCG. The effect of intensive risk factor management in type 2 diabetes on inflammatory biomarkers. Diabetes Res Clin Pract. 2012;95(3):389-98. [pmid: 22019270].
Sandbaek A, Griffin SJ, Rutten G, Davies M, Stolk R, Khunti K, et al. Stepwise screening for diabetes identifies people with high but modifiable coronary heart disease risk. The ADDITION study. Diabetologia. 2008;51(7):1127-34. [pmid: 18443762].
Service FJ, Daube JR, O'Brien PC, Zimmerman BR, Swanson CJ, Brennan MD, et al. Effect of blood glucose control on peripheral nerve function in diabetic patients. Mayo Clin Proc. 1983;58(5):283-9. [pmid: 6341720].
Sridharan K, Mohan R, Ramaratnam S, Panneerselvam D. Ayurvedic treatments for diabetes mellitus. Cochrane Database Syst Rev. 2011;(12). CD008288.
Tang TS, Funnell MM, Brown MB, Kurlander JE. Self-management support in “real-world” settings: an empowerment-based intervention. Patient Educ Couns. 2010;79(2):178-84. [pmid: 19889508].
Thomas D, Elliott EJ, Naughton GA. Exercise for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(1).
Thoolen B, De Ridder D, Bensing J, Maas C, Griffin S, Gorter K, et al. Effectiveness of a self-management intervention in patients with screen-detected type 2 diabetes. Diabetes Care. 2007;30(11):2832-7. [pmid: 17666461].
van den Donk M, Sandbaek A, Borch-Johnsen K, Lauritzen T, Simmons RK, Wareham NJ, et al. Screening for type 2 diabetes. Lessons from the ADDITION-Europe study. Diabet Med. 2011;28(11):1416-24. [pmid: 21679235].
Wang W, Bu R, Su Q, Liu J, Ning G. Randomized study of repaglinide alone and in combination with metformin in Chinese subjects with type 2 diabetes naive to oral antidiabetes therapy. Expert Opin Pharmacother. 2011;12(18):2791-9. [pmid: 21780853].
Webb DR, Khunti K, Gray LJ, Srinivasan BT, Farooqi A, Wareham N, et al. Intensive multifactorial intervention improves modelled coronary heart disease risk in screen-detected Type 2 diabetes mellitus: a cluster randomized controlled trial. Diabet Med. 2012;29(4):531-40. [pmid: 21913966].
Weber MB, Ranjani H, Meyers GC, Mohan V, Narayan KMV. A model of translational research for diabetes prevention in low and middle-income countries: The Diabetes Community Lifestyle Improvement Program (D-CLIP) trial. Prim Care Diabetes. 2012;6(1):3-9. [pmid: 21616737].
Yeung VTF, Lee KF, Chan SH, Ho LF, Leung SK, Wong HY, et al. MicroAlbuminuria Prevalence Study (MAPS) in hypertensive type 2 diabetic patients in Hong Kong. Hong Kong Med J. 2006;12(3):185-90. [pmid: 16760545].

### Wrong study design for Key Question

Anand SS, Dagenais GR, Mohan V, Diaz R, Probstfield J, Freeman R, et al. Glucose levels are associated with cardiovascular disease and death in an international cohort of normal glycaemic and dysglycaemic men and women: the EpiDREAM cohort study. Eur J Prev Cardiolog. 2012;19(4):755-64.
Aujla N, Davies MJ, Skinner TC, Gray LJ, Webb DR, Srinivasan B, et al. The association between anxiety and measures of glycaemia in a population-based diabetes screening programme. Diabet Med. 2011;28(7):785-8. [pmid: 21672003].
Banerjee S, Ghosh US, Dutta S. Clinicopathological profile of hepatic involvement in type-2 diabetes mellitus and its significance. J Assoc Physicians India. 2008;56:593-9. [pmid: 19051703].
Bartram S, Rigby D. Diabetes screening as part of a vascular disease risk management programme. Community Pract. 2012;85(10):24-7. [pmid: 23162979].
Baur DM, Klotsche J, Hamnvik O-PR, Sievers C, Pieper L, Wittchen H-U, et al. Type 2 diabetes mellitus and medications for type 2 diabetes mellitus are associated with risk for and mortality from cancer in a German primary care cohort. Metabolism. 2011;60(10):1363-71. [pmid: 21081242].
Bazelier MT, Vestergaard P, Gallagher AM, van Staa T-P, Cooper C, Leufkens HGM, et al. Risk of fracture with thiazolidinediones: disease or drugs?. Calcif Tissue Int. 2012;90(6):450-7. [pmid: 22488176].
Beever R. The effects of repeated thermal therapy on quality of life in patients with type II diabetes mellitus. J Altern Complement Med. 2010;16(6):677-81. [pmid: 20569036].
Bennett CM, Guo M, Dharmage SC. HbA(1c) as a screening tool for detection of Type 2 diabetes: a systematic review. Diabet Med. 2007;24(4):333-43. [pmid: 17367307].
Bilik D, McEwen LN, Brown MB, Selby JV, Karter AJ, Marrero DG, et al. Thiazolidinediones, cardiovascular disease and cardiovascular mortality: translating research into action for diabetes (TRIAD). Pharmacoepidemiol Drug Saf. 2010;19(7):715-21. [pmid: 20583206].
Brown SH, Abdelhafiz AH. Trials Review. Postgrad Med. 2009;121(5).
Buyken AE, von Eckardstein A, Schulte H, Cullen P, Assmann G. Type 2 diabetes mellitus and risk of coronary heart disease: results of the 10-year follow-up of the PROCAM study. Eur J Cardiovasc Prev Rehabil. 2007;14(2):230-6. [pmid: 17446801].
Carlsson LMS, Peltonen M, Ahlin S, Anveden A, Bouchard C, Carlsson B, et al. Bariatric surgery and prevention of type 2 diabetes in Swedish obese subjects. N Engl J Med. 2012;367(8):695-704. [pmid: 22913680].
Chamnan P, Simmons RK, Khaw KT, Wareham NJ, Griffin SJ. Estimating the potential population impact of stepwise screening strategies for identifying and treating individuals at high risk of Type 2 diabetes: a modelling study. Diabet Med. 2012;29(7):893-904. [pmid: 22340130].
Chamnan P, Simmons RK, Khaw KT, Wareham NJ, Griffin SJ. Change in HbA1c over 3 years does not improve the prediction of cardiovascular disease over and above HbA1c measured at a single time point. Diabetologia. 2013;56(5):1004-11. [pmid: 23404444].
Chan S-P, Ji L-N, Nitiyanant W, Baik SH, Sheu WHH. Hypoglycemic symptoms in patients with type 2 diabetes in Asia-Pacific-Real-life effectiveness and care patterns of diabetes management: the RECAP-DM study. Diabetes Res Clin Pract. 2010;89(2):e30-2. [pmid: 20541826].
Charles M, Simmons RK, Williams KM, Roglic G, Sharp SJ, Kinmonth A-L, et al. Cardiovascular risk reduction following diagnosis of diabetes by screening: 1-year results from the ADDITION-Cambridge trial cohort. Br J Gen Pract. 2012;62(599):e396-402. [pmid: 22687231].
Charlton J, Latinovic R, Gulliford MC. Explaining the decline in early mortality in men and women with type 2 diabetes: a population-based cohort study. Diabetes Care. 2008;31(9):1761-6. [pmid: 18509209].
Choi SH, Kim TH, Lim S, Park KS, Jang HC, Cho NH. Hemoglobin A1c as a diagnostic tool for diabetes screening and new-onset diabetes prediction: a 6-year community-based prospective study. Diabetes Care. 2011;34(4):944-9. [pmid: 21335372].
Chung YW, Han DS, Park KH, Eun CS, Yoo K-S, Park CK. Insulin therapy and colorectal adenoma risk among patients with Type 2 diabetes mellitus: a case-control study in Korea. Dis Colon Rectum. 2008;51(5):593-7. [pmid: 18219529].
Cooper-DeHoff RM, Gong Y, Handberg EM, Bavry AA, Denardo SJ, Bakris GL, et al. Tight blood pressure control and cardiovascular outcomes among hypertensive patients with diabetes and coronary artery disease. JAMA. 2010;304(1):61-8. [pmid: 20606150].
Davila EP, Florez H, Trepka MJ, Fleming LE, Niyonsenga T, Lee DJ, et al. Strict glycemic control and mortality risk among US adults with type 2 diabetes. J Diabetes Complications. 2011;25(5):289-91. [pmid: 21658973].
Drury PL, Ting R, Zannino D, Ehnholm C, Flack J, Whiting M, et al. Estimated glomerular filtration rate and albuminuria are independent predictors of cardiovascular events and death in type 2 diabetes mellitus: the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Diabetologia. 2011;54(1):32-43. [pmid: 20668832].
Echouffo-Tcheugui JB, Sargeant LA, Prevost AT, Williams KM, Barling RS, Butler R, et al. How much might cardiovascular disease risk be reduced by intensive therapy in people with screen-detected diabetes?. Diabet Med. 2008;25(12):1433-9. [pmid: 19046242].
Eeg-Olofsson K, Cederholm J, Nilsson PM, Zethelius B, Nunez L, Gudbjornsdottir S, et al. Risk of cardiovascular disease and mortality in overweight and obese patients with type 2 diabetes: an observational study in 13,087 patients. Diabetologia. 2009;52(1):65-73. [pmid: 18985314].
Florez H, Luo J, Castillo-Florez S, Mitsi G, Hanna J, Tamariz L, et al. Impact of metformin-induced gastrointestinal symptoms on quality of life and adherence in patients with type 2 diabetes. Postgrad Med. 2010;122(2):112-20. [pmid: 20203462].
Frederich R, Alexander JH, Fiedorek FT, Donovan M, Berglind N, Harris S, et al. A systematic assessment of cardiovascular outcomes in the saxagliptin drug development program for type 2 diabetes. Postgrad Med. 2010;122(3):16-27. [pmid: 20463410].
Geiss LS, James C, Gregg EW, Albright A, Williamson DF, Cowie CC. Diabetes Risk Reduction Behaviors Among U.S. Adults with Prediabetes. Am J Prev Med. 2010;38(4):403-9. [pmid: 20307809].
Goz F, Karaoz S, Goz M, Ekiz S, Cetin I. Effects of the diabetic patients' perceived social support on their quality-of-life. J Clin Nurs. 2007;16(7):1353-60. [pmid: 17584354].
Green AJ, Fox KM, Grandy S, Group SS. Self-reported hypoglycemia and impact on quality of life and depression among adults with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2012;96(3):313-8. [pmid: 22296853].
Grimley Evans J, Areosa Sastre A. Effect of the treatment of Type II diabetes mellitus on the development of cognitive impairment and dementia. Cochrane Database Syst Rev. 2009;(1).
Guerrero-Romero F, Rodriguez-Moran M. Validation of an instrument for screening cases of type 2 diabetes and monitoring at-risk individuals in Mexico. Rev Panam Salud Publica. 2010;27(3):181-6. [pmid: 20414507].
Habib ZA, Tzogias L, Havstad SL, Wells K, Divine G, Lanfear DE, et al. Relationship between thiazolidinedione use and cardiovascular outcomes and all-cause mortality among patients with diabetes: a time-updated propensity analysis. Pharmacoepidemio. Drug Saf. 2009;18(6):437-47.
Hu Y, Liu W, Chen Y, Zhang M, Wang L, Zhou H, et al. Combined use of fasting plasma glucose and glycated hemoglobin A1c in the screening of diabetes and impaired glucose tolerance. Acta Diabetol. 2010;47(3):231-6. [pmid: 19760291].
Hung AM, Roumie CL, Greevy RA, Liu X, Grijalva CG, Murff HJ, et al. Comparative effectiveness of incident oral antidiabetic drugs on kidney function. Kidney Int. 2012;81(7):698-706. [pmid: 22258320].
Ilanne-Parikka P, Laaksonen DE, Eriksson JG, Lakka TA, Lindstr J, Peltonen M, et al. Leisure-time physical activity and the metabolic syndrome in the Finnish diabetes prevention study. Diabetes Care. 2010;33(7):1610-7. [pmid: 20413514].
Janka HU, Hessel F, Walzer S, Ma Ller E. Insulin glargine added to therapy with oral antidiabetic agents improves glycemic control and reduces long-term complications in patients with type 2 diabetes - a simulation with the Diabetes Mellitus Model (DMM). Int J Clin Pharmacol Ther. 2007;45(12):623-30. [pmid: 18184530].
Kalesnykiene V, Sorri I, Voutilainen R, Uusitupa M, Niskanen L, Uusitalo H. The effect of glycaemic control on the quantitative characteristics of retinopathy lesions in patients with type 2 diabetes mellitus: 10-year follow-up study. Graefes Arch Clin Exp Ophthalmol. 2009;247(3):335-41. [pmid: 19043734].
Kasai T, Miyauchi K, Kajimoto K, Kubota N, Kurata T, Daida H. Influence of diabetes on >10-year outcomes after percutaneous coronary intervention. Heart Vessels. 2008;23(3):149-54. [pmid: 18484156].
Kawamori R, Fujita T, Matsuoka H, Umemura S, Saito Y. Relation between cardiovascular complications and blood pressure/blood glucose control in diabetic patients with hypertension receiving long-term candesartan cilexetil therapy: Challenge-DM study. Diabetes Res Clin Pract. 2009;83(2):241-8. [pmid: 19097664].
Kengne AP, Patel A, Colagiuri S, Heller S, Hamet P, Marre M, et al. The Framingham and UK Prospective Diabetes Study (UKPDS) risk equations do not reliably estimate the probability of cardiovascular events in a large ethnically diverse sample of patients with diabetes: the Action in Diabetes and Vascular Disease: Preterax and Diamicron-MR Controlled Evaluation (ADVANCE) Study. Diabetologia. 2010;53(5):821-31. [pmid: 20157695].
Kim C, Edelstein SL, Crandall JP, Dabelea D, Kitabchi AE, Hamman RF, et al. Menopause and risk of diabetes in the Diabetes Prevention Program. Menopause. 2011;18(8):857-68. [pmid: 21709591].
Kolb H, Martin S, Lodwig V, Heinemann L, Scherbaum WA, Schneider B. Are type 2 diabetes patients who self-monitor blood glucose special? The role of confounders in the observational ROSSO study. J Diabetes Sci Technol. 2009;3(6):1507-15. [pmid: 20144407].
Koro CE, Lee BH, Bowlin SJ. Antidiabetic medication use and prevalence of chronic kidney disease among patients with type 2 diabetes mellitus in the United States. Clin Ther. 2009;31(11):2608-17. [pmid: 20110005].
Krum H, McMurray JJV, Horton E, Gerlock T, Holzhauer B, Zuurman L, et al. Baseline characteristics of the Nateglinide and Valsartan Impaired Glucose Tolerance Outcomes Research (NAVIGATOR) trial population: comparison with other diabetes prevention trials. Cardiovasc Ther. 2010;28(2):124-32. [pmid: 20184589].
Kunte H, Schmidt S, Eliasziw M, del Zoppo GJ, Simard JM, Masuhr F, et al. Sulfonylureas improve outcome in patients with type 2 diabetes and acute ischemic stroke. Stroke. 2007;38(9):2526-30. [pmid: 17673715].
Lee LJ, Fahrbach JL, Nelson LM, McLeod LD, Martin SA, Sun P, et al. Effects of insulin initiation on patient-reported outcomes in patients with type 2 diabetes: results from the durable trial. Diabetes Res Clin Pract. 2010;89(2):157-66. [pmid: 20537750].
Lee VWY, Ho ICH, Chan WSY, Tam KY, Lee KKC. Statin utilization patterns for the primary prevention of cardiovascular events: a retrospective study in patients with diabetes mellitus in Hong Kong. Am J Cardiovasc Drugs. 2008;8(3):199-205. [pmid: 18533740].
Li D, Yeung S-CJ, Hassan MM, Konopleva M, Abbruzzese JL. Antidiabetic therapies affect risk of pancreatic cancer. Gastroenterology. 2009;137(2):482-8. [pmid: 19375425].
Marrett E, Stargardt T, Mavros P, Alexander CM. Patient-reported outcomes in a survey of patients treated with oral antihyperglycaemic medications: associations with hypoglycaemia and weight gain. Diabetes Obes Metab. 2009;11(12):1138-44. [pmid: 19758360].
Mather KJ, Funahashi T, Matsuzawa Y, Edelstein S, Bray GA, Kahn SE, et al. Adiponectin, change in adiponectin, and progression to diabetes in the Diabetes Prevention Program. Diabetes. 2008;57(4):980-6. [pmid: 18192541].
McAfee AT, Koro C, Landon J, Ziyadeh N, Walker AM. Coronary heart disease outcomes in patients receiving antidiabetic agents. Pharmacoepidemiol Drug Saf. 2007;16(7):711-25. [pmid: 17551989].
McBride PE, Einerson JA, Grant H, Sargent C, Underbakke G, Vitcenda M, et al. Putting the Diabetes Prevention Program into practice: a program for weight loss and cardiovascular risk reduction for patients with metabolic syndrome or type 2 diabetes mellitus. J Nutr Health Aging. 2008;12(10):745S-9S. [pmid: 19043651].
Paddison CAM, Eborall HC, Sutton S, French DP, Vasconcelos J, Prevost AT, et al. Are people with negative diabetes screening tests falsely reassured? Parallel group cohort study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2009;339:b4535. [pmid: 19948642].
Pendergrass M, Fenton C, Haffner SM, Chen W. Exenatide and sitagliptin are not associated with increased risk of acute renal failure: a retrospective claims analysis. Diabetes Obes Metab. 2012;14(7):596-600. [pmid: 22268550].
Quilliam BJ, Simeone JC, Ozbay AB. Risk factors for hypoglycemia-related hospitalization in patients with type 2 diabetes: a nested case-control study. Clin Ther. 2011;33(11):1781-91. [pmid: 22018449].
Ramos-Nino ME, MacLean CD, Littenberg B. Association between cancer prevalence and use of thiazolidinediones: results from the Vermont Diabetes Information System. BMC med. 2007;5:17. [pmid: 17584937].
Rao AD, Kuhadiya N, Reynolds K, Fonseca VA. Is the combination of sulfonylureas and metformin associated with an increased risk of cardiovascular disease or all-cause mortality?: a meta-analysis of observational studies. Diabetes Care. 2008;31(8):1672-8. [pmid: 18458139].
Richter B, Bandeira-Echtler E, Bergerhoff K, Clar C, Ebrahim SH. Pioglitazone for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2009;(1).
Saaristo T, Barengo N, Korpi-Hyovalti E, Oksa H, Puolijoki H, Saltevo J, et al. High prevalence of obesity, central obesity and abnormal glucose tolerance in the middle-aged Finnish population. BMC Public Health. 2008;8(1):423. [pmid: 19113993].
Sadikot SM, Mogensen CE. Risk of coronary artery disease associated with initial sulphonylurea treatment of patients with type 2 diabetes: a matched case-control study. Diabetes Res Clin Pract. 2008;82(3):391-5. [pmid: 18945509].
Schneider B, Martin S, Heinemann L, Lodwig V, Kolb H. Interrelations between diabetes therapy, self-monitoring of blood glucose, blood glucose and non-fatal or fatal endpoints in patients with type 2 diabetes / results of a longitudinal cohort study (ROSSO 5). Arzneimittelforschung. 2007;57(12):762-9. [pmid: 18380408].
Schweizer A, Dejager S, Foley JE, Couturier A, Ligueros-Saylan M, Kothny W. Assessing the cardio-cerebrovascular safety of vildagliptin: meta-analysis of adjudicated events from a large Phase III type 2 diabetes population. [Erratum appears in Diabetes Obes Metab. 2010 Sep;12(9):832]. Diabetes Obes Metab. 2010;12(6):485-94. [pmid: 20518804].
Stevens L. Antihypertensive therapy for preventing cardiovascular complications in people with diabetes mellitus. Cochrane Database Syst Rev. 2005;(3).
Sullivan SD, Garrison LP Jr., Rinde H, Kolberg J, Moler EJ. Cost-effectiveness of risk stratification for preventing type 2 diabetes using a multi-marker diabetes risk score. J Med Econ. 2011;14(5):609-16. [pmid: 21740291].
Turnbull FM, Abraira C, Anderson RJ, Byington RP, Chalmers JP, Duckworth WC, et al. Intensive glucose control and macrovascular outcomes in type 2 diabetes. [Erratum appears in Diabetologia. 2009 Nov;52(1):2470 Note: Control Group [added]]. Diabetologia. 2009;52(11):2288-98. [pmid: 19655124].
Walsh M, Spurling G. Aspirin in type 2 diabetes: is there any evidence base?. BMJ. 2008;337:a1902. [pmid: 18927174].
Wilding JPH, Hardy K. Glucagon-like peptide-1 analogues for type 2 diabetes. BMJ. 2011;342:d410. [pmid: 21325387].
Yeboah J, Bertoni AG, Herrington DM, Post WS, Burke GL. Impaired fasting glucose and the risk of incident diabetes mellitus and cardiovascular events in an adult population: MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol. 2011;58(2):140-6. [pmid: 21718910].
Zhang C-Y, Sun A-J, Zhang S-N, Wu C-n, Fu M-Q, Xia G, et al. Effects of intensive glucose control on incidence of cardiovascular events in patients with type 2 diabetes: a meta-analysis. Ann Med. 2010;42(4):305-15. [pmid: 20429797].
Zhuo X, Zhang P, Gregg EW, Barker L, Hoerger TJ, Pearson-Clarke T, et al. A Nationwide Community-Based Lifestyle Program Could Delay Or Prevent Type 2 Diabetes Cases And Save $5.7 Billion In 25 Years. Health Aff (Millwood). 2012;31(1):50-60. [pmid: 22232094].

### Wrong publication type

Bloomgarden ZT. Glycemic Control in Diabetes: A Tale of Three Studies. Diabetes Care. 2008;31(9):1913-9. [pmid: 18753670].
Boehm CM, Smith S. Altering the course. Screening for prediabetes. Adv Nurse Pract. 2007;15(11):43-6. [pmid: 19998913].
Caballero AE. Long-term benefits of insulin therapy and glycemic control in overweight and obese adults with type 2 diabetes. J Diabetes Complications. 2009;23(2):143-52. [pmid: 18413192].
Dailey G. Overall mortality in diabetes mellitus: where do we stand today?. Diabetes Technol Ther. Suppl 1. 2011;13:S65-74. [pmid: 21668339].
Delahanty LM, Nathan DM. Implications of the diabetes prevention program and Look AHEAD clinical trials for lifestyle interventions. J Am Diet Assoc. 2008;108(4 Suppl 1):S66-72. [pmid: 18358260].
Demssie YN, Soran H, Younis N. Tight glycaemic control and cardiovascular disease in type 2 diabetes. Br J Hosp Med. 2009;70(1):31-2. 4.
Diabetes UK. Early Identification of people with and at high risk of type 2 diabetes and interventions for those at high risk. 2012. [cited 2012 November 30 ]; Available from: http://www.diabetes.org.uk/Documents/Position%20statements/Early%20identification%20of%20Type%202%20diabetes%20Position%20statement.pdf.
Dominguez LJ, Paolisso G, Barbagallo M. Glucose control in the older patient: from intensive, to effective and safe. Aging Clin Exp Res. 2010;22(4):274-80. [pmid: 19934622].
Donnelly R. Effect of pioglitazone on the drivers of cardiovascular risk in type 2 diabetes. Int J Clin Pract. 2007;61(7):1160-9. [pmid: 17511791].
Dunn FL. Management of dyslipidemia in people with type 2 diabetes mellitus. Rev Endocr Metab Disord. 2010;11(1):41-51. [pmid: 20221703].
Edwards SP. Prevention: Nipped in the bud. Nature. 2012;485(7398):S18-9. [pmid: 22616102].
Finucane TE. “Tight control” in geriatrics: the emperor wears a thong. J Am Geriatr Soc. 2012;60(8):1571-5. [pmid: 22881447].
Fradkin JE, Roberts BT, Rodgers GP. What's preventing us from preventing type 2 diabetes?. N Engl J Med. 2012;367(13):1177-9. [pmid: 23013070].
Fravel MA, McDanel DL, Ross MB, Moores KG, Starry MJ. Special considerations for treatment of type 2 diabetes mellitus in the elderly. Am J Health Syst Pharm. 2011;68(6):500-9. [pmid: 21378298].
Gebel E. Stopping diabetes before it starts: diabetes prevention works out at the Y. Diabetes Forecast. 2012;65(2):44-6. [pmid: 22439264].
Ghiadoni L. Management of high blood pressure in type 2 diabetes: perindopril/indapamide fixed-dose combination and the ADVANCE trial [corrected]. [Erratum appears in Expert Opin Pharmacother. 2010 Aug;11(11);1963]. Expert Opin Pharmacother. 2010;11(10):1647-57. [pmid: 20518617].
Goldberg RB, Holman R, Drucker DJ. Clinical decisions. Management of type 2 diabetes. [Erratum appears in N Engl J Med. 2008 May 1;358(18):1977]. N Engl J Med. 2008;358(3):293-7. [pmid: 18199869].
Gomez-Huelgas R, Bernal-Lopez MR, Mancera J, Tinahones FJ. HbA1c for diabetes diagnosis. Are we ready?. Diabet Med. 2010;27(3):367-8. [pmid: 20536505].
Grzywa M, Mazur A, Skrzypiec J. Screening for the detection of impaired fasting glucose, impaired glucose tolerance and type 2 diabetes in welfare homes residents from south-eastern region of Poland. Int J Clin Pract. 2011;65(7):818-9. [pmid: 21676124].
Hawkes N. Screening for type 2 diabetes doesn't affect mortality at 10 years. BMJ. 2012;345:e6687. [pmid: 23034925].
Idris I. Safety of very tight glucose control in type 2 diabetes in question. Diabetes Obes Metab. 2008;10(5):438. [pmid: 18431839].
Kalaitzidis RG, Bakris GL. Pros and cons of aggressive blood pressure lowering in patients with type 2 diabetes. Curr Vasc Pharmacol. 2012;10(2):156-61. [pmid: 22239626].
Kamp SJ. Diabetes in older adults. Consider presentation, functioning and more. Adv Nurse Pract. 2007;15(11):37-8. 40. 2. [pmid: 19998912].
Karthikeyan VJ, Bakris G, MacFadyen RJ. The ADVANCE trial: further PROGRESS with HOPE. J Hum Hypertens. 2007;21(12):911-3. [pmid: 17960167].
Katula JA, Vitolins MZ, Rosenberger EL, Blackwell C, Espeland MA, Lawlor MS, et al. Healthy Living Partnerships to Prevent Diabetes (HELP PD): design and methods. Contemp Clin Trials. 2010;31(1):71-81. [pmid: 19758580].
Khunti K, Davies M. Should we screen for type 2 diabetes: Yes. BMJ. 2012;345:e4514. [pmid: 22777029].
Klein Woolthuis EP, de Grauw WJC, van Weel C. Opportunistic screening for type 2 diabetes in primary care. Lancet. 2010;376(9742):683-4. [pmid: 20801397].
Lindstrom J, Absetz P, Hemio K, Peltomaki P, Peltonen M. Reducing the risk of type 2 diabetes with nutrition and physical activity - efficacy and implementation of lifestyle interventions in Finland. Public Health Nutr. 2010;13(6A):993-9. [pmid: 20513271].
Lloret-Linares C, Greenfield JR, Czernichow S. Effect of weight-reducing agents on glycaemic parameters and progression to Type 2 diabetes: a review. Diabet Med. 2008;25(10):1142-50. [pmid: 19046191].
Ma J, King AC, Wilson SR, Xiao L, Stafford RS. Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Fam Pract. 2009;10:71. [pmid: 19909549].
Meier M, Hummel M. Cardiovascular disease and intensive glucose control in type 2 diabetes mellitus: moving practice toward evidence-based strategies. Vasc Health Risk Manag. 2009;5:859-71. [pmid: 19898642].
Neumiller JJ, Setter SM. Review of linagliptin for the treatment of type 2 diabetes mellitus. Clin Ther. 2012;34(5):993-1005. [pmid: 22440191].
Reboldi G, Gentile G, Angeli F, Verdecchia P. Optimal therapy in hypertensive subjects with diabetes mellitus. Curr Atheroscler Rep. 2011;13(2):176-85. [pmid: 21234720].
Rutten G. Screening for type 2 diabetes--where are we now?. Lancet. 2010;375(9723):1324-6. [pmid: 20356620].
Scott T. Does pioglitazone benefit patients with type 2 diabetes?. Am Fam Physician. 2007;76(7):969-70. [pmid: 17956065].
Seley JJ. Does tight glycemic control increase the risk of death?. Am J Nurs. 2008;108(11):31. [pmid: 18946261].
Skyler JS, Bergenstal R, Bonow RO, Buse J, Deedwania P, Gale EAM, et al. Intensive glycemic control and the prevention of cardiovascular events: implications of the ACCORD, ADVANCE, and VA diabetes trials: a position statement of the American Diabetes Association and a scientific statement of the American College of Cardiology Foundation and the American Heart Association. [Erratum appears in Diabetes Care. 2009 Apr;32(4):754]. Diabetes Care. 2009;32(1):187-92. [pmid: 19092168].
Soejima H, Morimoto T, Saito Y, Ogawa H. Aspirin for the primary prevention of cardiovascular events in patients with peripheral artery disease or diabetes mellitus. Analyses from the JPAD, POPADAD and AAA trials. Thromb Haemost. 2010;104(6):1085-8. [pmid: 20941462].
Younis N, Soran H, Hassanein M. Cardiovascular disease and intensive glucose lowering in type 2 diabetes. QJM. 2009;102(4):293-6. [pmid: 19147659].

### Wrong population due to advanced diabetes (A1c >8) or long duration (>1 year)

Agardh E, Tababat-Khani P. Adopting 3-year screening intervals for sight-threatening retinal vascular lesions in type 2 diabetic subjects without retinopathy. Diabetes Care. 2011;34(6):1318-9. [pmid: 21562322].
Akin I, Bufe A, Eckardt L, Reinecke H, Senges J, Richardt G, et al. Comparison of outcomes in patients with insulin-dependent versus non-insulin dependent diabetes mellitus receiving drug-eluting stents (from the first phase of the prospective multicenter German DES.DE registry). Am J Cardiol. 2010;106(9):1201-7. [pmid: 21029813].
Ali MK, Feeney P, Hire D, Simmons DL, O'Connor PJ, Ganz-Lord F, et al. Glycaemia and correlates of patient-reported outcomes in ACCORD trial participants. Diabet Med. 2012;29(7):e67-74. [pmid: 22141437].
Andersson C, Olesen JB, Hansen PR, Weeke P, Norgaard ML, Jorgensen CH, et al. Metformin treatment is associated with a low risk of mortality in diabetic patients with heart failure: a retrospective nationwide cohort study. Diabetologia. 2010;53(12):2546-53. [pmid: 20838985].
Aschner P, Chan J, Owens DR, Picard S, Wang E, Dain M-P, et al. Insulin glargine versus sitagliptin in insulin-naive patients with type 2 diabetes mellitus uncontrolled on metformin (EASIE): a multicentre, randomised open-label trial. Lancet. 2012;379(9833):2262-9. [pmid: 22683131].
Athyros VG, Hatzitolios A, Karagiannis A, Didangelos TP, Iliadis F, Dolgyras S, et al. Initiative for a new diabetes therapeutic approach in a Mediterranean country: the INDEED study. Curr Med Res Opin. 2009;25(8):1931-40. [pmid: 19558210].
Bailey CJ, Gross JL, Hennicken D, Iqbal N, Mansfield TA, List JF. Dapagliflozin add-on to metformin in type 2 diabetes inadequately controlled with metformin: a randomized, double-blind, placebo-controlled 102-week trial. BMC med. 2013;11(43).
Balducci S, Zanuso S, Massarini M, Corigliano G, Nicolucci A, Missori S, et al. The Italian Diabetes and Exercise Study (IDES): design and methods for a prospective Italian multicentre trial of intensive lifestyle intervention in people with type 2 diabetes and the metabolic syndrome. Nutr Metab Cardiovasc Dis. 2008;18(9):585-95. [pmid: 18061415].
Bebakar WMW, Chow CC, Kadir KA, Suwanwalaikorn S, Vaz JA, Bech OM, et al. Adding biphasic insulin aspart 30 once or twice daily is more efficacious than optimizing oral antidiabetic treatment in patients with type 2 diabetes. Diabetes Obes Metab. 2007;9(5):724-32. [pmid: 17593237].
Bergenstal RM, Li Y, Porter TKB, Weaver C, Han J. Exenatide once weekly improved glycaemic control, cardiometabolic risk factors and a composite index of an HbA1c < 7%, without weight gain or hypoglycaemia, over 52 weeks. Diabetes Obes Metab. 2013;15(3):264-71. [pmid: 23078638].
Best JH, Hoogwerf BJ, Herman WH, Pelletier EM, Smith DB, Wenten M, et al. Risk of cardiovascular disease events in patients with type 2 diabetes prescribed the glucagon-like peptide 1 (GLP-1) receptor agonist exenatide twice daily or other glucose-lowering therapies: a retrospective analysis of the LifeLink database. Diabetes Care. 2011;34(1):90-5. [pmid: 20929995].
Bode B, Stenlof K, Sullivan D, Fung A, Usiskin K. Efficacy and safety of canagliflozin treatment in older subjects with type 2 diabetes mellitus: a randomized trial. Hosp Pract (Minneap). 2013;41(2):72-84.
Bodmer M, Becker C, Meier C, Jick SS, Meier CR. Use of metformin is not associated with a decreased risk of colorectal cancer: a case-control analysis. Cancer Epidemiol Biomarkers Prev. 2012;21(2):280-6. [pmid: 22178569].
Bodmer M, Meier C, Krahenbuhl S, Jick SS, Meier CR. Long-term metformin use is associated with decreased risk of breast cancer. Diabetes Care. 2010;33(6):1304-8. [pmid: 20299480].
Brooks MM, Chaitman BR, Nesto RW, Hardison RM, Feit F, Gersh BJ, et al. Clinical and angiographic risk stratification and differential impact on treatment outcomes in the Bypass Angioplasty Revascularization Investigation 2 Diabetes (BARI 2D) trial. Circulation. 2012;126(17):2115-24. [pmid: 23008442].
Caterson ID, Finer N, Coutinho W, Van Gaal LF, Maggioni AP, Torp-Pedersen C, et al. Maintained intentional weight loss reduces cardiovascular outcomes: results from the Sibutramine Cardiovascular OUTcomes (SCOUT) trial. Diabetes Obes Metab. 2012;14(6):523-30. [pmid: 22192338].
Chalmers J, Joshi R, Kengne AP, MacMahon S. Blood pressure lowering with fixed combination perindopril-indapamide: key findings from ADVANCE. J Hypertens. Supplement : official journal of the International Society of Hypertension. 2008;26(2):S11-5.
Chan JC, So W-Y, Yeung C-Y, Ko GT, Lau I-T, Tsang M-W, et al. Effects of structured versus usual care on renal endpoint in type 2 diabetes: the SURE study: a randomized multicenter translational study. Diabetes Care. 2009;32(6):977-82. [pmid: 19460913].
Chang C-H, Lin J-W, Wu L-C, Lai M-S, Chuang L-M. Oral insulin secretagogues, insulin, and cancer risk in type 2 diabetes mellitus. J Clin Endocrinol Metab. 2012;97(7):E1170-5. [pmid: 22563104].
Cook W, Bryzinski B, Slater J, Frederich R, Allen E. Saxagliptin efficacy and safety in patients with type 2 diabetes mellitus and cardiovascular disease history or cardiovascular risk factors: results of a pooled analysis of phase 3 clinical trials. Postgrad Med. 2013;125(3):145-54. [pmid: 23748515].
Currie CJ, Poole CD, Gale EAM. The influence of glucose-lowering therapies on cancer risk in type 2 diabetes. Diabetologia. 2009;52(9):1766-77. [pmid: 19572116].
Curtis PJ, Sampson M, Potter J, Dhatariya K, Kroon PA, Cassidy A. Chronic ingestion of flavan-3-ols and isoflavones improves insulin sensitivity and lipoprotein status and attenuates estimated 10-year CVD risk in medicated postmenopausal women with type 2 diabetes: a 1-year, double-blind, randomized, controlled trial. Diabetes Care. 2012;35(2):226-32. [pmid: 22250063].
Davidson JA, McMorn SO, Waterhouse BR, Cobitz AR. A 24-week, multicenter, randomized, double-blind, placebo-controlled, parallel-group study of the efficacy and tolerability of combination therapy with rosiglitazone and sulfonylurea in African American and Hispanic American patients with type 2 diabetes inadequately controlled with sulfonylurea monotherapy. Clin Ther. 2007;29(9):1900-14. [pmid: 18035190].
Davies M, Lavalle-Gonzalez F, Storms F, Gomis R, Group ALS. Initiation of insulin glargine therapy in type 2 diabetes subjects suboptimally controlled on oral antidiabetic agents: results from the AT.LANTUS trial. Diabetes Obes Metab. 2008;10(5):387-99. [pmid: 18355327].
Dobs AS, Goldstein BJ, Aschner P, Horton ES, Umpierrez GE, Duran L, et al. Efficacy and safety of sitagliptin added to ongoing metformin and rosiglitazone combination therapy in a randomized placebo-controlled 54-week trial in patients with type 2 diabetes. Journal of diabetes. 2013;5(1):68-79. [pmid: 22742523].
Donadon V, Balbi M, Mas MD, Casarin P, Zanette G. Metformin and reduced risk of hepatocellular carcinoma in diabetic patients with chronic liver disease. Liver Int. 2010;30(5):750-8. [pmid: 20331505].
Donadon V, Balbi M, Valent F, Avogaro A. Glycated hemoglobin and antidiabetic strategies as risk factors for hepatocellular carcinoma. World J Gastroenterol. 2010;16(24):3025-32. [pmid: 20572306].
Dormandy J, Bhattacharya M, van Troostenburg de Bruyn A-R, investigators PR. Safety and tolerability of pioglitazone in high-risk patients with type 2 diabetes: an overview of data from PROactive. Drug Saf. 2009;32(3):187-202. [pmid: 19338377].
Erdmann E, Spanheimer R, Charbonnel B, Investigators PRS. Pioglitazone and the risk of cardiovascular events in patients with Type 2 diabetes receiving concomitant treatment with nitrates, renin-angiotensin system blockers, or insulin: results from the PROactive study (PROactive 20). Journal Of Diabetes. 2010;2(3):212-20. [pmid: 20923486].
Evans JMM, Doney ASF, AlZadjali MA, Ogston SA, Petrie JR, Morris AD, et al. Effect of Metformin on mortality in patients with heart failure and type 2 diabetes mellitus. Am J Cardiol. 2010;106(7):1006-10. [pmid: 20854965].
Fal AM, Jankowska B, Uchmanowicz I, Sen M, Panaszek B, Polanski J. Type 2 diabetes quality of life patients treated with insulin and oral hypoglycemic medication. Acta Diabetol. 2011;48(3):237-42. [pmid: 21191622].
Faludi P, Brodows R, Burger J, Ivanyi T, Braun DK. The effect of exenatide re-exposure on safety and efficacy. Peptides. 2009;30(9):1771-4. [pmid: 19576255].
Farkouh ME, Aneja A, Reeder GS, Smars PA, Lennon RJ, Wiste HJ, et al. Usefulness of diabetes mellitus to predict long-term outcomes in patients with unstable angina pectoris. Am J Cardiol. 2009;104(4):492-7. [pmid: 19660600].
Fegan PG, Davis WA, Kamber N, Sivakumar S, Beilby J, Davis TME. Renin-angiotensin-aldosterone system blockade and urinary albumin excretion in community-based patients with Type 2 diabetes: the Fremantle Diabetes Study. Diabet Med. 2011;28(7):849-55. [pmid: 21231957].
Ferrannini E, Fonseca V, Zinman B, Matthews D, Ahren B, Byiers S, et al. Fifty-two-week efficacy and safety of vildagliptin vs. glimepiride in patients with type 2 diabetes mellitus inadequately controlled on metformin monotherapy. [Erratum appears in Diabetes Obes Metab. 2009 Apr;11(4):405]. Diabetes Obes Metab. 2009;11(2):157-66. [pmid: 19125777].
Filion KB, Joseph L, Boivin J-F, Suissa S, Brophy JM. Thiazolidinediones and the risk of incident congestive heart failure among patients with type 2 diabetes mellitus. Pharmacoepidemiol Drug Saf. 2011;20(8):785-96. [pmid: 21671441].
Fonseca VA, Ferrannini E, Wilding JP, Wilpshaar W, Dhanjal P, Ball G, et al. Active- and placebo-controlled dose-finding study to assess the efficacy, safety, and tolerability of multiple doses of ipragliflozin in patients with type 2 diabetes mellitus. J Diabetes Complications. 2013;27(3):268-73. [pmid: 23276620].
Giles TD, Elkayam U, Bhattacharya M, Perez A, Miller AB. Comparison of pioglitazone vs glyburide in early heart failure: insights from a randomized controlled study of patients with type 2 diabetes and mild cardiac disease. Congest Heart Fail. 2010;16(3):111-7. [pmid: 20557330].
Giles TD, Miller AB, Elkayam U, Bhattacharya M, Perez A. Pioglitazone and heart failure: results from a controlled study in patients with type 2 diabetes mellitus and systolic dysfunction. J Card Fail. 2008;14(6):445-52. [pmid: 18672190].
Goke B, Hershon K, Kerr D, Calle Pascual A, Schweizer A, Foley J, et al. Efficacy and safety of vildagliptin monotherapy during 2-year treatment of drug-naive patients with type 2 diabetes: comparison with metformin. Horm Metab Res. 2008;40(12):892-5. [pmid: 18726829].
Gonzalez-Clemente JM, Pinies JA, Calle-Pascual A, Saavedra A, Sanchez C, Bellido D, et al. Cardiovascular risk factor management is poorer in diabetic patients with undiagnosed peripheral arterial disease than in those with known coronary heart disease or cerebrovascular disease. Results of a nationwide study in tertiary diabetes centres. Diabet Med. 2008;25(4):427-34. [pmid: 18341592].
Habib ZA, Havstad SL, Wells K, Divine G, Pladevall M, Williams LK. Thiazolidinedione use and the longitudinal risk of fractures in patients with type 2 diabetes mellitus. J Clin Endocrinol Metab. 2010;95(2):592-600. [pmid: 20061432].
Haller H, Ito S, Izzo JL Jr., Januszewicz A, Katayama S, Menne J, et al. Olmesartan for the delay or prevention of microalbuminuria in type 2 diabetes. N Engl J Med. 2011;364(10):907-17. [pmid: 21388309].
Home PD, Lagarenne P. Combined randomised controlled trial experience of malignancies in studies using insulin glargine. Diabetologia. 2009;52(12):2499-506. [pmid: 19756478].
Hsu C-C, Wahlqvist ML, Lee M-S, Tsai H-N. Incidence of dementia is increased in type 2 diabetes and reduced by the use of sulfonylureas and metformin. J Alzheimers Dis. 2011;24(3):485-93. [pmid: 21297276].
Jermendy G, Hungarian RG, Erdesz D, Nagy L, Yin D, Phatak H, et al. Outcomes of adding second hypoglycemic drug after metformin monotherapy failure among type 2 diabetes in Hungary. Health Qual Life Outcomes. 2008;6:88. [pmid: 18976457].
Kadoglou NPE, Iliadis F, Liapis CD, Perrea D, Angelopoulou N, Alevizos M. Beneficial effects of combined treatment with rosiglitazone and exercise on cardiovascular risk factors in patients with type 2 diabetes. Diabetes Care. 2007;30(9):2242-4. [pmid: 17586747].
Kaku K, Daida H, Kashiwagi A, Yamashina A, Yamazaki T, Momomura S-i, et al. Long-term effects of pioglitazone in Japanese patients with type 2 diabetes without a recent history of macrovascular morbidity. Curr Med Res Opin. 2009;25(12):2925-32. [pmid: 19835463].
Kapitza C, Heise T, Birman P, Jallet K, Ramis J, Balena R. Pharmacokinetic and pharmacodynamic properties of taspoglutide, a once-weekly, human GLP-1 analogue, after single-dose administration in patients with Type 2 diabetes. Diabet Med. 2009;26(11):1156-64. [pmid: 19929995].
Khanna A, Bush AL, Swint JM, Peskin MF, Street RL Jr., Naik AD. Hemoglobin A1c improvements and better diabetes-specific quality of life among participants completing diabetes self-management programs: a nested cohort study. Health Qual Life Outcomes. 2012;10:48. [pmid: 22583609].
Kikuchi M, Kaku K, Odawara M, Momomura S-i, Ishii R. Efficacy and tolerability of rosiglitazone and pioglitazone in drug-naive Japanese patients with type 2 diabetes mellitus: a double-blind, 28 weeks' treatment, comparative study. Curr Med Res Opin. 2012;28(6):1007-16. [pmid: 22587483].
Kleefstra N, Hortensius J, Logtenberg SJJ, Slingerland RJ, Groenier KH, Houweling ST, et al. Self-monitoring of blood glucose in tablet-treated type 2 diabetic patients (ZODIAC). Neth J Med. 2010;68(1):311-6. [pmid: 20739728].
Kooy A, de Jager J, Lehert P, Bets D, Wulffele MG, Donker AJM, et al. Long-term effects of metformin on metabolism and microvascular and macrovascular disease in patients with type 2 diabetes mellitus. Arch Intern Med. 2009;169(6):616-25. [pmid: 19307526].
Kostev K, Dippel FW, Rockel T, Siegmund T. Risk of diabetic foot ulceration during treatment with insulin glargine and NPH insulin. J Wound Care. 2012;21(10):483-4. 6. 9. [pmid: 23103482].
Kress S, Kostev K, Dippel FW, Giani G, Rathmann W. Micro- and macrovascular outcomes in Type 2 diabetic patients treated with insulin glulisine or human regular insulin: a retrospective database analysis. Int J Clin Pharmacol Ther. 2012;50(11):821-9. [pmid: 22578200].
Lewis JD, Capra AM, Achacoso NS, Ferrara A, Levin TR, Quesenberry CP Jr., et al. Thiazolidinedione therapy is not associated with increased colonic neoplasia risk in patients with diabetes mellitus. Gastroenterology. 2008;135(6):1914-23. 23.e1. [pmid: 18930061].
Li C, Xia J, Zhang G, Wang S, Wang L. Nateglinide versus repaglinide for type 2 diabetes mellitus in China. Acta Diabetol. 2009;46(4):325-33. [pmid: 19183841].
Look ARG, Wing RR, Bolin P, Brancati FL, Bray GA, Clark JM, et al. Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. N Engl J Med. 2013;369(2):145-54. [pmid: 23796131].
Lowe JM, Mensch M, McElduff P, Fitzgerald M, Attia J. Does an advanced insulin education programme improve outcomes and health service use for people with Type 2 diabetes? A 5-year follow-up of the Newcastle Empowerment course. Diabet Med. 2009;26(12):1277-81. [pmid: 20002481].
Luk AO, Yang X, Ma RC, Ng VW, Yu LW, Lau WW, et al. Association of statin use and development of renal dysfunction in type 2 diabetes--the Hong Kong Diabetes Registry. Diabetes Res Clin Pract. 2010;88(3):227-33. [pmid: 20236720].
Lukashevich V, Schweizer A, Shao Q, Groop PH, Kothny W. Safety and efficacy of vildagliptin versus placebo in patients with type 2 diabetes and moderate or severe renal impairment: a prospective 24-week randomized placebo-controlled trial. Diabetes Obes Metab. 2011;13(10):947-54. [pmid: 21733061].
MacDonald MR, Eurich DT, Majumdar SR, Lewsey JD, Bhagra S, Jhund PS, et al. Treatment of type 2 diabetes and outcomes in patients with heart failure: a nested case-control study from the U.K. General Practice Research Database. Diabetes Care. 2010;33(6):1213-8. [pmid: 20299488].
Maddigan SL, Majumdar SR, Toth EL, Feeny DH, Johnson JA, Investigators D. Health-related quality of life deficits associated with varying degrees of disease severity in type 2 diabetes. Health Qual Life Outcomes. 2003;1:78. [pmid: 14675484].
Makino H, Haneda M, Babazono T, Moriya T, Ito S, Iwamoto Y, et al. Microalbuminuria reduction with telmisartan in normotensive and hypertensive Japanese patients with type 2 diabetes: a post-hoc analysis of The Incipient to Overt: Angiotensin II Blocker, Telmisartan, Investigation on Type 2 Diabetic Nephropathy (INNOVATION) study. Hypertens Res. 2008;31(4):657-64. [pmid: 18633177].
Mancini T, Mazziotti G, Doga M, Carpinteri R, Simetovic N, Vescovi PP, et al. Vertebral fractures in males with type 2 diabetes treated with rosiglitazone. Bone. 2009;45(4):784-8. [pmid: 19527806].
Masuda H, Sakamoto M, Irie J, Kitaoka A, Shiono K, Inoue G, et al. Comparison of twice-daily injections of biphasic insulin lispro and basal-bolus therapy: glycaemic control and quality-of-life of insulin-naive type 2 diabetic patients. Diabetes Obes Metab. 2008;10(12):1261-5. [pmid: 18494811].
Meier C, Kraenzlin ME, Bodmer M, Jick SS, Jick H, Meier CR. Use of thiazolidinediones and fracture risk. Arch Intern Med. 2008;168(8):820-5. [pmid: 18443256].
Mellbin LG, Malmberg K, Norhammar A, Wedel H, Ryden L, Investigators D. The impact of glucose lowering treatment on long-term prognosis in patients with type 2 diabetes and myocardial infarction: a report from the DIGAMI 2 trial. Eur Heart J. 2008;29(2):166-76. [pmid: 18156614].
Mellbin LG, Malmberg K, Norhammar A, Wedel H, Ryden L, Investigators D. Prognostic implications of glucose-lowering treatment in patients with acute myocardial infarction and diabetes: experiences from an extended follow-up of the Diabetes Mellitus Insulin-Glucose Infusion in Acute Myocardial Infarction (DIGAMI) 2 Study. Diabetologia. 2011;54(6):1308-17. [pmid: 21359582].
Mellbin LG, Malmberg K, Waldenstrom A, Wedel H, Ryden L, Investigators D. Prognostic implications of hypoglycaemic episodes during hospitalisation for myocardial infarction in patients with type 2 diabetes: a report from the DIGAMI 2 trial. Heart. 2009;95(9):721-7. [pmid: 19029171].
Miao Y, Dobre D, Heerspink HJL, Brenner BM, Cooper ME, Parving HH, et al. Increased serum potassium affects renal outcomes: a post hoc analysis of the Reduction of Endpoints in NIDDM with the Angiotensin II Antagonist Losartan (RENAAL) trial. [Erratum appears in Diabetologia. 2011 Aug;54(8):2209]. Diabetologia. 2011;54(1):44-50. [pmid: 20882268].
Miao Y, Ottenbros SA, Laverman GD, Brenner BM, Cooper ME, Parving H-H, et al. Effect of a reduction in uric acid on renal outcomes during losartan treatment: a post hoc analysis of the reduction of endpoints in non-insulin-dependent diabetes mellitus with the Angiotensin II Antagonist Losartan Trial. Hypertension. 2011;58(1):2-7. [pmid: 21632472].
Miksch A, Laux G, Ose D, Joos S, Campbell S, Riens B, et al. Is there a survival benefit within a German primary care-based disease management program?. Am J Manag Care. 2010;16(1):49-54. [pmid: 20148605].
Milman U, Blum S, Shapira C, Aronson D, Miller-Lotan R, Anbinder Y, et al. Vitamin E supplementation reduces cardiovascular events in a subgroup of middle-aged individuals with both type 2 diabetes mellitus and the haptoglobin 2-2 genotype: a prospective double-blinded clinical trial. Arterioscler Thromb Vasc Biol. 2008;28(2):341-7. [pmid: 18032779].
Mohan V, Yang W, Son H-Y, Xu L, Noble L, Langdon RB, et al. Efficacy and safety of sitagliptin in the treatment of patients with type 2 diabetes in China, India, and Korea. Diabetes Res Clin Pract. 2009;83(1):106-16. [pmid: 19097665].
Mohanram A, Zhang Z, Shahinfar S, Lyle PA, Toto RD. The effect of losartan on hemoglobin concentration and renal outcome in diabetic nephropathy of type 2 diabetes. Kidney Int. 2008;73(5):630-6. [pmid: 18094675].
Monami M, Balzi D, Lamanna C, Barchielli A, Masotti G, Buiatti E, et al. Are sulphonylureas all the same? A cohort study on cardiovascular and cancer-related mortality. Diabetes Metab Res Rev. 2007;23(6):479-84. [pmid: 17385195].
Monami M, Colombi C, Balzi D, Dicembrini I, Giannini S, Melani C, et al. Metformin and cancer occurrence in insulin-treated type 2 diabetic patients. Diabetes Care. 2011;34(1):129-31. [pmid: 20980415].
Monami M, Cresci B, Colombini A, Pala L, Balzi D, Gori F, et al. Bone fractures and hypoglycemic treatment in type 2 diabetic patients: a case-control study. Diabetes Care. 2008;31(2):199-203. [pmid: 18024851].
Monami M, Lamanna C, Balzi D, Marchionni N, Mannucci E. Sulphonylureas and cancer: a case-control study. Acta Diabetol. 2009;46(4):279-84. [pmid: 19082520].
Monami M, Lamanna C, Pala L, Bardini G, Cresci B, Francesconi P, et al. Treatment with insulin secretagogues and cancer-related mortality in type 2 diabetic patients a retrospective cohort study. Exp Clin Endocrinol Diabetes. 2008;116(3):184-9. [pmid: 18273755].
Monami M, Marchionni N, Mannucci E. Winners and losers at the rosiglitazone gamble A meta-analytical approach at the definition of the cardiovascular risk profile of rosiglitazone. Diabetes Res Clin Pract. 2008;82(1):48-57. [pmid: 18775581].
Neumann A, Weill A, Ricordeau P, Fagot JP, Alla F, Allemand H. Pioglitazone and risk of bladder cancer among diabetic patients in France: a population-based cohort study. Diabetologia. 2012;55(7):1953-62. [pmid: 22460763].
Newman CB, Szarek M, Colhoun HM, Betteridge DJ, Durrington PN, Hitman GA, et al. The safety and tolerability of atorvastatin 10 mg in the Collaborative Atorvastatin Diabetes Study (CARDS). Diab Vasc Dis Res. 2008;5(3):177-83. [pmid: 18777490].
Nicolucci A, Balducci S, Cardelli P, Cavallo S, Fallucca S, Bazuro A, et al. Relationship of exercise volume to improvements of quality of life with supervised exercise training in patients with type 2 diabetes in a randomised controlled trial: the Italian Diabetes and Exercise Study (IDES). Diabetologia. 2012;55(3):579-88. [pmid: 22234648].
Ninomiya T, Zoungas S, Neal B, Woodward M, Patel A, Perkovic V, et al. Efficacy and safety of routine blood pressure lowering in older patients with diabetes: results from the ADVANCE trial. J Hypertens. 2010;28(6):1141-9. [pmid: 20486273].
Opsteen C, Qi Y, Zinman B, Retnakaran R. Effect of short-term intensive insulin therapy on quality of life in type 2 diabetes. J Eval Clin Pract. 2012;18(2):256-61. [pmid: 20846320].
Origin Trial Investigators, Gerstein HC, Bosch J, Dagenais GR, Diaz R, Jung H, et al. Basal insulin and cardiovascular and other outcomes in dysglycemia. N Engl J Med. 2012;367(4):319-28. [pmid: 22686416].
Oyer DS, Shepherd MD, Coulter FC, Bhargava A, Brett J, Chu P-L, et al. A(1c) control in a primary care setting: self-titrating an insulin analog pre-mix (INITIATEplus trial). Am J Med. 2009;122(11):1043-9. [pmid: 19854333].
Oyer DS, Shepherd MD, Coulter FC, Bhargava A, Deluzio AJ, Chu P-L, et al. Efficacy and tolerability of self-titrated biphasic insulin aspart 70/30 in patients aged >65 years with type 2 diabetes: an exploratory post hoc subanalysis of the INITIATEplus trial. Clin Ther. 2011;33(7):874-83. [pmid: 21741089].
Paile-Hyvarinen M, Wahlbeck K, Eriksson JG. Quality of life and metabolic status in mildly depressed patients with type 2 diabetes treated with paroxetine: a double-blind randomised placebo controlled 6-month trial. BMC Fam Pract. 2007;8:34. [pmid: 17570858].
Pala L, Monami M, Lamanna C, Cresci B, Colombi C, Bardini G, et al. Failure to metformin and insulin secretagogue monotherapy: an observational cohort study. Acta Diabetol. 2010;47(Suppl 1):7-11. [pmid: 19290462].
Pan CY, Yang W, Tou C, Gause-Nilsson I, Zhao J. Efficacy and safety of saxagliptin in drug-naive Asian patients with type 2 diabetes mellitus: a randomized controlled trial. Diabetes Metab Res Rev. 2012;28(3):268-75. [pmid: 22081481].
Pantalone KM, Kattan MW, Yu C, Wells BJ, Arrigain S, Jain A, et al. The risk of overall mortality in patients with type 2 diabetes receiving glipizide, glyburide, or glimepiride monotherapy: a retrospective analysis. Diabetes Care. 2010;33(6):1224-9. [pmid: 20215447].
Pantalone KM, Kattan MW, Yu C, Wells BJ, Arrigain S, Nutter B, et al. The risk of overall mortality in patients with Type 2 diabetes receiving different combinations of sulfonylureas and metformin: a retrospective analysis. Diabet Med. 2012;29(8):1029-35. [pmid: 22248043].
Parving H-H, Brenner BM, McMurray JJV, de Zeeuw D, Haffner SM, Solomon SD, et al. Aliskiren Trial in Type 2 Diabetes Using Cardio-Renal Endpoints (ALTITUDE): rationale and study design. Nephrol Dial Transplant. 2009;24(5):1663-71. [pmid: 19145003].
Parving H-H, Brenner BM, McMurray JJV, de Zeeuw D, Haffner SM, Solomon SD, et al. Cardiorenal end points in a trial of aliskiren for type 2 diabetes. N Engl J Med. 2012;367(23):2204-13. [pmid: 23121378].
Parving H-H, Persson F, Lewis JB, Lewis EJ, Hollenberg NK, Investigators AS. Aliskiren combined with losartan in type 2 diabetes and nephropathy. [Reprint in Ugeskr Laeger. 2009 Mar 9;171(11):881-4; PMID: 19291865]. N Engl J Med. 2008;358(23):2433-46. [pmid: 18525041].
Pattzi HMR, Pitale S, Alpizar M, Bennett C, O'Farrell AM, Li J, et al. Dutogliptin, a selective DPP4 inhibitor, improves glycaemic control in patients with type 2 diabetes: a 12-week, double-blind, randomized, placebo-controlled, multicentre trial. Diabetes Obes Metab. 2010;12(4):348-55. [pmid: 20380656].
Pfutzner A, Paz-Pacheco E, Allen E, Frederich R, Chen R, Investigators CV. Initial combination therapy with saxagliptin and metformin provides sustained glycaemic control and is well tolerated for up to 76 weeks. Diabetes Obes Metab. 2011;13(6):567-76. [pmid: 21342412].
Pratley RE, Kipnes MS, Fleck PR, Wilson C, Mekki Q, Alogliptin Study G. Efficacy and safety of the dipeptidyl peptidase-4 inhibitor alogliptin in patients with type 2 diabetes inadequately controlled by glyburide monotherapy. Diabetes Obes Metab. 2009;11(2):167-76. [pmid: 19125778].
Pratley RE, Reusch JEB, Fleck PR, Wilson CA, Mekki Q, Alogliptin Study G. Efficacy and safety of the dipeptidyl peptidase-4 inhibitor alogliptin added to pioglitazone in patients with type 2 diabetes: a randomized, double-blind, placebo-controlled study. Curr Med Res Opin. 2009;25(10):2361-71. [pmid: 19650752].
Rajamani K, Colman PG, Li LP, Best JD, Voysey M, D'Emden MC, et al. Effect of fenofibrate on amputation events in people with type 2 diabetes mellitus (FIELD study): a prespecified analysis of a randomised controlled trial. Lancet. 2009;373(9677):1780-8. [pmid: 19465233].
Raz I, Fonseca V, Kipnes M, Durrwell L, Hoekstra J, Boldrin M, et al. Efficacy and safety of taspoglutide monotherapy in drug-naive type 2 diabetic patients after 24 weeks of treatment: results of a randomized, double-blind, placebo-controlled phase 3 study (T-emerge 1). Diabetes Care. 2012;35(3):485-7. [pmid: 22301126].
Riddle MC, Ambrosius WT, Brillon DJ, Buse JB, Byington RP, Cohen RM, et al. Epidemiologic relationships between A1C and all-cause mortality during a median 3.4-year follow-up of glycemic treatment in the ACCORD trial. Diabetes Care. 2010;33(5):983-90. [pmid: 20427682].
Rosenstock J, Aguilar-Salinas C, Klein E, Nepal S, List J, Chen R, et al. Effect of saxagliptin monotherapy in treatment-naive patients with type 2 diabetes. Curr Med Res Opin. 2009;25(10):2401-11. [pmid: 19650754].
Shibayama T, Kobayashi K, Takano A, Kadowaki T, Kazuma K. Effectiveness of lifestyle counseling by certified expert nurse of Japan for non-insulin-treated diabetic outpatients: a 1-year randomized controlled trial. Diabetes Res Clin Pract. 2007;76(2):265-8. [pmid: 17049662].
Sone H, Tanaka S, Iimuro S, Oida K, Yamasaki Y, Oikawa S, et al. Long-term lifestyle intervention lowers the incidence of stroke in Japanese patients with type 2 diabetes: a nationwide multicentre randomised controlled trial (the Japan Diabetes Complications Study). Diabetologia. 2010;53(3):419-28. [pmid: 20054522].
Trento M, Basile M, Borgo E, Grassi G, Scuntero P, Trinetta A, et al. A randomised controlled clinical trial of nurse-, dietitian- and pedagogist-led Group Care for the management of Type 2 diabetes. J Endocrinol Invest. 2008;31(11):1038-42. [pmid: 19169063].
Trento M, Gamba S, Gentile L, Grassi G, Miselli V, Morone G, et al. Rethink Organization to iMprove Education and Outcomes (ROMEO): a multicenter randomized trial of lifestyle intervention by group care to manage type 2 diabetes. Diabetes Care. 2010;33(4):745-7. [pmid: 20103547].
Tseng C-H. Insulin use is not significantly predictive for prostate cancer mortality in diabetic patients: a 12-year follow-up study. BJU Int. 2012;110(5):668-73. [pmid: 22300458].
Williamson DA, Rejeski J, Lang W, Van Dorsten B, Fabricatore AN, Toledo K, et al. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med. 2009;169(2):163-71. [pmid: 19171813].
Woodward A, Wallymahmed M, Wilding JP, Gill GV. Nurse-led clinics for strict hypertension control are effective long term: a 7 year follow-up study. Diabet Med. 2010;27(8):933-7. [pmid: 20653752].

### In systematic review, not directly used

Asche CV, McAdam-Marx C, Shane-McWhorter L, Sheng X, Plauschinat CA. Association between oral antidiabetic use, adverse events and outcomes in patients with type 2 diabetes. Diabetes Obes Metab. 2008;10(8):638-45. [pmid: 17645555].
Aubert RE, Herrera V, Chen W, Haffner SM, Pendergrass M. Rosiglitazone and pioglitazone increase fracture risk in women and men with type 2 diabetes. Diabetes Obes Metab. 2010;12(8):716-21. [pmid: 20590749].
Azoulay L, Schneider-Lindner V, Dell'aniello S, Filion KB, Suissa S. Thiazolidinediones and the risk of incident strokes in patients with type 2 diabetes: a nested case-control study. Pharmacoepidemiol Drug Saf. 2010;19(4):343-50. [pmid: 19998318].
Azoulay L, Schneider-Lindner V, Dell'aniello S, Schiffrin A, Suissa S. Combination therapy with sulfonylureas and metformin and the prevention of death in type 2 diabetes: a nested case-control study. Pharmacoepidemiol Drug Saf. 2010;19(4):335-42. [pmid: 20052677].
Azoulay L, Yin H, Filion KB, Assayag J, Majdan A, Pollak MN, et al. The use of pioglitazone and the risk of bladder cancer in people with type 2 diabetes: nested case-control study. BMJ. 2012;344:e3645. [pmid: 22653981].
Bazelier MT, Gallagher AM, van Staa T-P, Cooper C, Leufkens HGM, Vestergaard P, et al. Use of thiazolidinediones and risk of osteoporotic fracture: disease or drugs?. Pharmacoepidemiol Drug Saf. 2012;21(5):507-14. [pmid: 22392882].
Berthet S, Olivier P, Montastruc J-L, Lapeyre-Mestre M. Drug safety of rosiglitazone and pioglitazone in France: a study using the French PharmacoVigilance database. BMC Clin Pharml. 2011;11:5.
Bilik D, McEwen LN, Brown MB, Pomeroy NE, Kim C, Asao K, et al. Thiazolidinediones and fractures: evidence from translating research into action for diabetes. J Clin Endocrinol Metab. 2010;95(10):4560-5. [pmid: 20631021].
Bo S, Ciccone G, Rosato R, Villois P, Appendino G, Ghigo E, et al. Cancer mortality reduction and metformin: a retrospective cohort study in type 2 diabetic patients. Diabetes Obes Metab. 2012;14(1):23-9. [pmid: 21812892].
Bonds DE, Miller ME, Bergenstal RM, Buse JB, Byington RP, Cutler JA, et al. The association between symptomatic, severe hypoglycaemia and mortality in type 2 diabetes: retrospective epidemiological analysis of the ACCORD study. BMJ. 2010;340:b4909. [pmid: 20061358].
Chang C-H, Lin J-W, Wu L-C, Lai M-S, Chuang L-M, Chan KA. Association of thiazolidinediones with liver cancer and colorectal cancer in type 2 diabetes mellitus. Hepatology. 2012;55(5):1462-72. [pmid: 22135104].
Dormuth CR, Carney G, Carleton B, Bassett K, Wright JM. Thiazolidinediones and fractures in men and women. Arch Intern Med. 2009;169(15):1395-402. [pmid: 19667303].
Dormuth CR, Maclure M, Carney G, Schneeweiss S, Bassett K, Wright JM. Rosiglitazone and myocardial infarction in patients previously prescribed metformin. [Erratum appears in PLoS ONE. 2010;5(7). doi: 10.1371/annotation/3330720e-5520-4211-91f3-d3b3d20e9804]. PLoS ONE. [Electronic Resource]. 2009;4(6):e6080. [pmid: 19562036].
Ferrara A, Lewis JD, Quesenberry CP Jr., Peng T, Strom BL, Van Den Eeden SK, et al. Cohort study of pioglitazone and cancer incidence in patients with diabetes. Diabetes Care. 2011;34(4):923-9. [pmid: 21447664].
Fong DS, Contreras R. Glitazone use associated with diabetic macular edema. Am J Ophthalmol. 2009;147(4):583-6.e1. [pmid: 19181303].
Graham DJ, Ouellet-Hellstrom R, MaCurdy TE, Ali F, Sholley C, Worrall C, et al. Risk of acute myocardial infarction, stroke, heart failure, and death in elderly Medicare patients treated with rosiglitazone or pioglitazone. JAMA. 2010;304(4):411-8. [pmid: 20584880].
Horsdal HT, Sondergaard F, Johnsen SP, Rungby J. Antidiabetic treatments and risk of hospitalisation with myocardial infarction: a nationwide case-control study. Pharmacoepidemiol Drug Saf. 2011;20(4):331-7. [pmid: 21442682].
Hsiao F-Y, Huang W-F, Wen Y-W, Chen P-F, Kuo KN, Tsai Y-W. Thiazolidinediones and cardiovascular events in patients with type 2 diabetes mellitus: a retrospective cohort study of over 473,000 patients using the National Health Insurance database in Taiwan. Drug Saf. 2009;32(8):675-90. [pmid: 19591532].
Hsieh M-C, Lee T-C, Cheng S-M, Tu S-T, Yen M-H, Tseng C-H. The influence of type 2 diabetes and glucose-lowering therapies on cancer risk in the Taiwanese. Exp Diabetes Res. 2012;2012:413782. [pmid: 22719752].
Idris I, Warren G, Donnelly R. Association between thiazolidinedione treatment and risk of macular edema among patients with type 2 diabetes. Arch Intern Med. 2012;172(13):1005-11. [pmid: 22688528].
Ismail-Beigi F, Craven T, Banerji MA, Basile J, Calles J, Cohen RM, et al. Effect of intensive treatment of hyperglycaemia on microvascular outcomes in type 2 diabetes: an analysis of the ACCORD randomised trial. [Erratum appears in Lancet. 2010 Oct 30;376(9751):1466]. Lancet. 2010;376(9739):419-30. [pmid: 20594588].
Koro CE, Fu Q, Stender M. An assessment of the effect of thiazolidinedione exposure on the risk of myocardial infarction in type 2 diabetic patients. Pharmacoepidemiol Drug Saf. 2008;17(10):989-96. [pmid: 18759378].
Koro CE, Sowell MO, Stender M, Qizilbash N. The risk of myopathy associated with thiazolidinediones and statins in patients with type 2 diabetes: a nested case-control analysis. Clin Ther. 2008;30(3):535-42. [pmid: 18405791].
Landman GWD, Kleefstra N, van Hateren KJJ, Groenier KH, Gans ROB, Bilo HJG. Metformin associated with lower cancer mortality in type 2 diabetes: ZODIAC-16. Diabetes Care. 2010;33(2):322-6. [pmid: 19918015].
Lee M-S, Hsu C-C, Wahlqvist ML, Tsai H-N, Chang Y-H, Huang Y-C. Type 2 diabetes increases and metformin reduces total, colorectal, liver and pancreatic cancer incidences in Taiwanese: a representative population prospective cohort study of 800,000 individuals. BMC Cancer. 2011;11:20. [pmid: 21241523].
Lehman DM, Lorenzo C, Hernandez J, Wang C-P. Statin use as a moderator of metformin effect on risk for prostate cancer among type 2 diabetic patients. Diabetes Care. 2012;35(5):1002-7. [pmid: 22456867].
Lewis JD, Ferrara A, Peng T, Hedderson M, Bilker WB, Quesenberry CP Jr., et al. Risk of bladder cancer among diabetic patients treated with pioglitazone: interim report of a longitudinal cohort study. Diabetes Care. 2011;34(4):916-22. [pmid: 21447663].
Libby G, Donnelly LA, Donnan PT, Alessi DR, Morris AD, Evans JMM. New users of metformin are at low risk of incident cancer: a cohort study among people with type 2 diabetes. Diabetes Care. 2009;32(9):1620-5. [pmid: 19564453].
Mamtani R, Haynes K, Bilker WB, Vaughn DJ, Strom BL, Glanz K, et al. Association between longer therapy with thiazolidinediones and risk of bladder cancer: a cohort study. J Natl Cancer Inst. 2012;104(18):1411-21. [pmid: 22878886].
McAlister FA, Eurich DT, Majumdar SR, Johnson JA. The risk of heart failure in patients with type 2 diabetes treated with oral agent monotherapy. Eur J Heart Fail. 2008;10(7):703-8. [pmid: 18571471].
Schramm TK, Gislason GH, Vaag A, Rasmussen JN, Folke F, Hansen ML, et al. Mortality and cardiovascular risk associated with different insulin secretagogues compared with metformin in type 2 diabetes, with or without a previous myocardial infarction: a nationwide study. [Erratum appears in Eur Heart J. 2012 May;33(10):1183]. Eur Heart J. 2011;32(15):1900-8. [pmid: 21471135].
Stockl KM, Le L, Zhang S, Harada ASM. Risk of acute myocardial infarction in patients treated with thiazolidinediones or other antidiabetic medications. Pharmacoepidemiol Drug Saf. 2009;18(2):166-74. [pmid: 19109802].
Tseng C-H. Diabetes, insulin use, and non-Hodgkin lymphoma mortality in Taiwan. Metabolism. 2012;61(7):1003-9. [pmid: 22237115].

### Wrong comparison

Alssema M, Vistisen D, Heymans MW, Nijpels G, Glumer C, Zimmet PZ, et al. The Evaluation of Screening and Early Detection Strategies for Type 2 Diabetes and Impaired Glucose Tolerance (DETECT-2) update of the Finnish diabetes risk score for prediction of incident type 2 diabetes. Diabetologia. 2011;54(5):1004-12. [pmid: 21153531].
Blin P, Lassalle R, Dureau-Pournin C, Ambrosino B, Bernard MA, Abouelfath A, et al. Insulin glargine and risk of cancer: a cohort study in the French National Healthcare Insurance Database. Diabetologia. 2012;55(3):644-53. [pmid: 22222504].
Boyko EJ, Gerstein HC, Mohan V, Yusuf S, Sheridan P, Anand S, et al. Effects of ethnicity on diabetes incidence and prevention: results of the Diabetes REduction Assessment with ramipril and rosiglitazone Medication (DREAM) trial. Diabet Med. 2010;27(11):1226-32. [pmid: 20950379].
Burke TA, Sturkenboom MC, Ohman-Strickland PA, Wentworth CE, Rhoads GG. The effect of antihypertensive drugs and drug combinations on the incidence of new-onset type-2 diabetes mellitus. Pharmacoepidemiol Drug Saf. 2007;16(9):979-87. [pmid: 17605137].
Casscells SW, Granger E, Swedorske J, Goldhammer R, Shaheen M, Dorris J, et al. A comparison of select cardiovascular outcomes by antidiabetic prescription drug classes used to treat type 2 diabetes among Military Health System beneficiaries, fiscal year 2003-2006. Am J Ther. 2008;15(3):198-205. [pmid: 18496256].
Chang C-H, Toh S, Lin J-W, Chen S-T, Kuo C-W, Chuang L-M, et al. Cancer risk associated with insulin glargine among adult type 2 diabetes patients--a nationwide cohort study. PLoS ONE. [Electronic Resource]. 2011;6(6):e21368. [pmid: 21738645].
Currie CJ, Peters JR, Tynan A, Evans M, Heine RJ, Bracco OL, et al. Survival as a function of HbA(1c) in people with type 2 diabetes: a retrospective cohort study. Lancet. 2010;375(9713):481-9. [pmid: 20110121].
Douglas IJ, Evans SJ, Pocock S, Smeeth L. The risk of fractures associated with thiazolidinediones: a self-controlled case-series study. PLoS Med. 2009;6(9):e1000154. [pmid: 19787025].
Gosmanova EO, Canada RB, Mangold TA, Rawls WN, Wall BM. Effect of metformin-containing antidiabetic regimens on all-cause mortality in veterans with type 2 diabetes mellitus. Am J Med Sci. 2008;336(3):241-7. [pmid: 18794619].
Greenfield S, Billimek J, Pellegrini F, Franciosi M, De Berardis G, Nicolucci A, et al. Comorbidity affects the relationship between glycemic control and cardiovascular outcomes in diabetes: a cohort study. [Summary for patients in Ann Intern Med. 2009 Dec 15;151(12):I54; PMID: 20008745]. Ann Intern Med. 2009;151(12):854-60. [pmid: 20008761].
Hayashi T, Kawashima S, Nomura H, Itoh H, Watanabe H, Ohrui T, et al. Age, gender, insulin and blood glucose control status alter the risk of ischemic heart disease and stroke among elderly diabetic patients. Cardiovasc Diabetol. 2011;10:86. [pmid: 21978180].
Home PD, Pocock SJ, Beck-Nielsen H, Curtis PS, Gomis R, Hanefeld M, et al. Rosiglitazone evaluated for cardiovascular outcomes in oral agent combination therapy for type 2 diabetes (RECORD): a multicentre, randomised, open-label trial. Lancet. 2009;373(9681):2125-35. [pmid: 19501900].
Houlden R, Ross S, Harris S, Yale J-F, Sauriol L, Gerstein HC. Treatment satisfaction and quality of life using an early insulinization strategy with insulin glargine compared to an adjusted oral therapy in the management of Type 2 diabetes: the Canadian INSIGHT Study. Diabetes Res Clin Pract. 2007;78(2):254-8. [pmid: 17490781].
Iwamoto Y, Tajima N, Kadowaki T, Nonaka K, Taniguchi T, Nishii M, et al. Efficacy and safety of sitagliptin monotherapy compared with voglibose in Japanese patients with type 2 diabetes: a randomized, double-blind trial. Diabetes Obes Metab. 2010;12(7):613-22. [pmid: 20590736].
Jadzinsky M, Pfutzner A, Paz-Pacheco E, Xu Z, Allen E, Chen R, et al. Saxagliptin given in combination with metformin as initial therapy improves glycaemic control in patients with type 2 diabetes compared with either monotherapy: a randomized controlled trial. Diabetes Obes Metab. 2009;11(6):611-22. [pmid: 19515181].
Karyekar C, Donovan M, Allen E, Fleming D, Ravichandran S, Chen R. Efficacy and safety of saxagliptin combination therapy in US patients with type 2 diabetes. Postgrad Med. 2011;123(4):63-70. [pmid: 21680990].
Komajda M, McMurray JJV, Beck-Nielsen H, Gomis R, Hanefeld M, Pocock SJ, et al. Heart failure events with rosiglitazone in type 2 diabetes: data from the RECORD clinical trial. Eur Heart J. 2010;31(7):824-31. [pmid: 20118174].
Lingvay I, Legendre JL, Kaloyanova PF, Zhang S, Adams-Huet B, Raskin P. Insulin-based versus triple oral therapy for newly diagnosed type 2 diabetes: which is better?. Diabetes Care. 2009;32(10):1789-95. [pmid: 19592630].
Loebstein R, Dushinat M, Vesterman-Landes J, Silverman B, Friedman N, Katzir I, et al. Database evaluation of the effects of long-term rosiglitazone treatment on cardiovascular outcomes in patients with type 2 diabetes. J Clin Pharmacol. 2011;51(2):173-80. [pmid: 20484611].
Loebstein R, Katzir I, Vasterman-Landes J, Halkin H, Lomnicky Y. Database assessment of the effectiveness of brand versus generic rosiglitazone in patients with type 2 diabetes mellitus. Med Sci Monit. 2008;14(6):CR323-6. [pmid: 18509276].
Monami M, Marchionni N, Masotti G, Mannucci E. Effect of combined secretagogue/biguanide treatment on mortality in type 2 diabetic patients with and without ischemic heart disease. Int J Cardiol. 2008;126(2):247-51. [pmid: 17512619].
Muramatsu T, Matsushita K, Yamashita K, Kondo T, Maeda K, Shintani S, et al. Comparison between valsartan and amlodipine regarding cardiovascular morbidity and mortality in hypertensive patients with glucose intolerance: NAGOYA HEART Study. Hypertension. 2012;59(3):580-6. [pmid: 22232134].
Pantalone KM, Kattan MW, Yu C, Wells BJ, Arrigain S, Jain A, et al. Increase in overall mortality risk in patients with type 2 diabetes receiving glipizide, glyburide or glimepiride monotherapy versus metformin: a retrospective analysis. Diabetes Obes Metab. 2012;14(9):803-9. [pmid: 22486923].
Redon J, Mancia G, Sleight P, Schumacher H, Gao P, Pogue J, et al. Safety and efficacy of low blood pressures among patients with diabetes: subgroup analyses from the ONTARGET (ONgoing Telmisartan Alone and in combination with Ramipril Global Endpoint Trial). J Am Coll Cardiol. 2012;59(1):74-83. [pmid: 22192672].
Rosenstock J, Chou HS, Matthaei S, Seidel DK, Hamann A. Potential benefits of early addition of rosiglitazone in combination with glimepiride in the treatment of type 2 diabetes. Diabetes Obes Metab. 2008;10(10):862-73. [pmid: 18201206].
Saaristo T, Moilanen L, Korpi-Hyövälti E, Vanhala M, Saltevo J, Niskanen L, et al. Lifestyle Intervention for Prevention of Type 2 Diabetes in Primary Health Care: One-year follow-up of the Finnish National Diabetes Prevention Program (FIN-D2D). Diabetes Care. 2010;33(10):2146-51. [pmid: 20664020].
Schwarz PE, Li J, Reimann M, Schutte AE, Bergmann A, Hanefeld M, et al. The Finnish Diabetes Risk Score is associated with insulin resistance and progression towards type 2 diabetes. J Clin Endocrinol Metab. 2009;94(3):920-6. [pmid: 19106274].
Singh KP, Periyandavar I, Rajadhyaksha GC, Jayaram S, Mishra AB, Kinagi S, et al. Evaluation of the efficacy, safety and tolerability of miglitol in adult Indian patients with uncomplicated type 2 diabetes mellitus. J Indian Med Assoc. 2007;105(6):344. 6. 50. [pmid: 18232183].
Song R, Ahn S, Roberts BL, Lee EO, Ahn YH. Adhering to a t'ai chi program to improve glucose control and quality of life for individuals with type 2 diabetes. J Altern Complement Med. 2009;15(6):627-32. [pmid: 19500007].
Suissa S, Azoulay L, Dell'Aniello S, Evans M, Vora J, Pollak M. Long-term effects of insulin glargine on the risk of breast cancer. Diabetologia. 2011;54(9):2254-62. [pmid: 21614572].
Toprani A, Fonseca V. Thiazolidinediones and congestive heart failure in veterans with type 2 diabetes. [Erratum appears in Diabetes Obes Metab. 2012 Apr;14(4):386]. Diabetes Obes Metab. 2011;13(3):276-80. [pmid: 21205120].
Tzoulaki I, Molokhia M, Curcin V, Little MP, Millett CJ, Ng A, et al. Risk of cardiovascular disease and all cause mortality among patients with type 2 diabetes prescribed oral antidiabetes drugs: retrospective cohort study using UK general practice research database. BMJ. 2009;339:b4731. [pmid: 19959591].

### Duplicate data, used another source

Diabetes Prevention Program Research Group, Knowler WC, Fowler SE, Hamman RF, Christophi CA, Hoffman HJ, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009;374(9702):1677-86. [pmid: 19878986].
Hemmingsen B, Lund SS, Gluud C, Vaag A, Almdal T, Hemmingsen C, et al. Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2011;(6). CD008143.
Ramachandran A, Arun N, Shetty AS, Snehalatha C. Efficacy of primary prevention interventions when fasting and postglucose dysglycemia coexist: analysis of the Indian Diabetes Prevention Programmes (IDPP-1 and IDPP-2). Diabetes Care. 2010;33(10):2164-8. [pmid: 20519663].
Rasmussen SS, Glumer C, Sandbaek A, Lauritzen T, Borch-Johnsen K. Progression from impaired fasting glucose and impaired glucose tolerance to diabetes in a high-risk screening programme in general practice: the ADDITION Study, Denmark. Diabetologia. 2007;50(2):293-7. [pmid: 17143605].
Reboldi G, Gentile G, Manfreda VM, Angeli F, Verdecchia P. Tight blood pressure control in diabetes: evidence-based review of treatment targets in patients with diabetes. Curr Cardiol Rep. 2012;14(1):89-96. [pmid: 22139528].
Woodward M, Patel A, Zoungas S, Liu L, Pan C, Poulter N, et al. Does glycemic control offer similar benefits among patients with diabetes in different regions of the world? Results from the ADVANCE trial. Diabetes Care. 2011;34(12):2491-5. [pmid: 21972410].
Wright JT, Probstfield JL, Cushman WC, Pressel SL, Cutler JA, Davis BR, et al. ALLHAT findings revisited in the context of subsequent analyses, other trials, and meta-analyses. Arch Intern Med. 2009;169(9):832-42. [pmid: 19433694].
Zoungas S, Chalmers J, Ninomiya T, Li Q, Cooper ME, Colagiuri S, et al. Association of HbA1c levels with vascular complications and death in patients with type 2 diabetes: evidence of glycaemic thresholds. Diabetologia. 2012;55(3):636-43. [pmid: 22186981].

### Systematic review, used as source document only

Ahmed AA, Alsharief E, Alsharief A. Intensive versus conventional glycemic control: what is best for patients with type 2 diabetes?. Diabetes Metab Syndr. 2013;7(1):48-51. [pmid: 23517797].
Baker MK, Simpson K, Lloyd B, Bauman AE, Singh MAF. Behavioral strategies in diabetes prevention programs: a systematic review of randomized controlled trials. Diabetes Res Clin Pract. 2011;91(1):1-12. [pmid: 20655610].
Chatterjee S, Sharma A, Lichstein E, Mukherjee D. Intensive glucose control in diabetics with an acute myocardial infarction does not improve mortality and increases risk of hypoglycemia-a meta-regression analysis. Curr Vasc Pharmacol. 2013;11(1):100-4. [pmid: 22724474].
Chen YH, Feng B, Chen ZW. Statins for primary prevention of cardiovascular and cerebrovascular events in diabetic patients without established cardiovascular diseases: a meta-analysis. Exp Clin Endocrinol Diabetes. 2012;120(2):116-20. [pmid: 22187291].
Colmers IN, Bowker SL, Majumdar SR, Johnson JA. Use of thiazolidinediones and the risk of bladder cancer among people with type 2 diabetes: a meta-analysis. CMAJ. 2012;184(12):E675-83. [pmid: 22761478].
Hemmingsen B, Schroll JB, Lund SS, Wetterslev J, Gluud C, Vaag A, et al. Sulphonylurea monotherapy for patients with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013;4. CD009008.
Hopper I, Billah B, Skiba M, Krum H. Prevention of diabetes and reduction in major cardiovascular events in studies of subjects with prediabetes: meta-analysis of randomised controlled clinical trials. Eur J Cardiovasc Prev Rehabil. 2011;18(6):813-23. [pmid: 21878448].
Mannucci E, Monami M, Lamanna C, Gensini GF, Marchionni N. Pioglitazone and cardiovascular risk. A comprehensive meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2008;10(12):1221-38. [pmid: 18505403].
Monami M, Lamanna C, Marchionni N, Mannucci E. Rosiglitazone and risk of cancer: a meta-analysis of randomized clinical trials. Diabetes Care. 2008;31(7):1455-60. [pmid: 18375416].
Orozco LJ, Buchleitner AM, Gimenez-Perez G, Roque i Figuls M, Richter B, Mauricio D. Exercise or exercise and diet for preventing type 2 diabetes mellitus. Cochrane Database Syst Rev. 2008;(3).
Phung OJ, Sood NA, Sill BE, Coleman CI. Oral anti-diabetic drugs for the prevention of Type 2 diabetes. Diabet Med. 2011;28(8):948-64. [pmid: 21429006].
Yuen A, Sugeng Y, Weiland TJ, Jelinek GA. Lifestyle and medication interventions for the prevention or delay of type 2 diabetes mellitus in prediabetes: a systematic review of randomised controlled trials. Aust N Z J Public Health. 2010;34(2):172-8. [pmid: 23331362].

## Appendix A5 U.S. Preventive Services Task Force Quality Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

### Case-Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variables.

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

Source: U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF, July 2008. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm.