# REFERENCES

1 U.S. Preventive Services Task Force. Screening for Gonorrhea: Recommendation Statement. Rockville, MD. Agency for Healthcare Research and Quality. 2005.
2 U.S. Preventive Services Task Force. Screening for chlamydial infection: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2007;147(2):128-34. [pmid: 17576996].
3 Nelson HD, Helfand M. Screening for chlamydial infection. Am J Prev Med. 2001;20(3 Suppl):95-107. [pmid: 11306238].
4 Glass N, Nelson HD, Villemyer K. Screening for Gonorrhea: Update of the Evidence for the U.S. Preventive Services Task Force. Rockville, MD. Agency for Healthcare Research and Quality. 2005.
5 Meyers DS, Halvorson H, Luckhaupt S. U.S. Preventive Services Task Force. Screening for chlamydial infection: an evidence update for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;147(2):135-42. [pmid: 17576995].
6 Merz AJ, So M. Interactions of pathogenic Neisseriae with epithelial cell membranes. Annu Rev Cell Dev Biol. 2000;16:423-57. [pmid: 11031243].
7 Edwards JL, Apicella MA. The molecular mechanisms used by Neisseria gonorrhoeae to initiate infection differ between men and women. Clin Microbiol Rev. 2004;17(4):965-81. [pmid: 15489357].
8 Centers for Disease Control and Prevention. 2012 Sexually Transmitted Disease Surveillance. Atlanta. Centers for Disease Control and Prevention. 2014. Accessed at http://www.cdc.gov/std/stats12/default.htm. 3 September 2014.
9 Stephens RS. The cellular paradigm of chlamydial pathogenesis. Trends Microbiol. 2003;11(1):44-51. [pmid: 12526854].
10 Centers for Disease Control and Prevention. Recommendations for the laboratory-based detection of Chlamydia trachomatis and Neisseria gonorrhoeae--2014. MMWR Recomm Rep. 2014;63(RR-02):1-19.
11 Brocklehurst P. Antibiotics for gonorrhoea in pregnancy. Cochrane Database Syst Rev. 2002;(2):CD000098. [pmid: 12076381].
12 Workowski KA, Levine WC. Centers for Disease Control and Prevention. Sexually transmitted disease treatment guidelines--2002. MMWR Recomm Rep. 2002;51(RR-06):1-78.
13 Workowski KA, Berman S. Centers for Disease Control and Prevention. Sexually transmitted diseases treatment guidelines, 2010. MMWR Recomm Rep. 2010;59(RR-12):1-113. [pmid: 21160459].
14 Workowski KA, Berman SM. Centers for Disease Control and Prevention. Sexually transmitted diseases treatment guidelines, 2006. MMWR Recomm Rep. 2006;55(RR-11):1-94. [pmid: 16888612].
15 Centers for Disease Control and Prevention. CDC Grand Rounds: chlamydia prevention: challenges and strategies for reducing disease burden and sequelae. MMWR Morb Mortal Wkly Rep. 2011;60(12):370-3. [pmid: 21451447].
16 Arya R, Mannion PT, Woodcock K, Haddad NG. Incidence of genital Chlamydia trachomatis infection in the male partners attending an infertility clinic. J Obstet Gynaecol. 2005;25(4):364-6. [pmid: 16091321].
17 Røttingen JA, Cameron WD, Garnett GP. A systematic review of the epidemiologic interactions between classic sexually transmitted diseases and HIV: how much really is known?. Sex Transm Dis. 2001;28(10):579-97. [pmid: 11689757].
18 Baeten JM, Overbaugh J. Measuring the infectiousness of persons with HIV-1: opportunities for preventing sexual HIV-1 transmission. Curr HIV Res. 2003;1(1):69-86. [pmid: 15043213].
19 Centers for Disease Control and Prevention. Update to CDC's sexually transmitted diseases treatment guidelines, 2010: oral cephalosporins no longer a recommended treatment for gonococcal infections. MMWR Morb Mortal Wkly Rep. 2012;61(31):590-4. [pmid: 22874837].
20 Tao G, Irwin KL. Receipt of HIV and STD testing services during routine general medical or gynecological examinations: variations by patient sexual risk behaviors. Sex Transm Dis. 2008;35(2):167-71. [pmid: 18090177].
21 Centers for Disease Control and Prevention. Chlamydia screening among sexually active young female enrollees of health plans--United States, 2000-2007. MMWR Morb Mortal Wkly Rep. 2009;58(14):362-5. [pmid: 19373196].
22 Blatt AJ, Lieberman JM, Hoover DR, Kaufman HW. Chlamydial and gonococcal testing during pregnancy in the United States. Am J Obstet Gynecol. 2012;207(1):55.e1-8. [pmid: 22621817].
23 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
24 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 3 September 2014.
25 Centers for Disease Control and Prevention. Recall of LCx® Neisseria gonorrhoeae assay and implicatons for laboratory testing for N. gonorrhoeae and Chlamydia trachomatis. MMWR Morb Mortal Wkly Rep. 2002;51(32):709. [pmid: 12206288].
26 Oakeshott P, Kerry S, Aghaizu A, Atherton H, Hay S, Taylor-Robinson D, et al. Randomised controlled trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: the POPI (Prevention of Pelvic Infection) trial. BMJ. 2010;340:c1642. [pmid: 20378636].
27 Scholes D, Stergachis A, Heidrich FE, Andrilla H, Holmes KK, Stamm WE. Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996;334(21):1362-6. [pmid: 8614421].
28 Ostergaard L, Andersen B, Møller JK, Olesen F. Home sampling versus conventional swab sampling for screening of Chlamydia trachomatis in women: a cluster-randomized 1-year follow-up study. Clin Infect Dis. 2000;31(4):951-7. [pmid: 11049776].
29 Götz HM, Veldhuijzen IK, Habbema JD, Boeke AJ, Richardus JH, Steyerberg EW. Prediction of Chlamydia trachomatis infection: application of a scoring rule to other populations. Sex Transm Dis. 2006;33(6):374-80. [pmid: 16505746].
30 Miller WC, Hoffman IF, Owen-O'Dowd J, McPherson JT, Privette A, Schmitz JL, et al. Selective screening for chlamydial infection: which criteria to use?. Am J Prev Med. 2000;18(2):115-22. [pmid: 10698241].
31 Chernesky MA, Martin DH, Hook EW, Willis D, Jordan J, Wang S, et al. Ability of new APTIMA CT and APTIMA GC assays to detect Chlamydia trachomatis and Neisseria gonorrhoeae in male urine and urethral swabs. J Clin Microbiol. 2005;43(1):127-31. [pmid: 15634960].
32 Taylor SN, Liesenfeld O, Lillis RA, Body BA, Nye M, Williams J, et al. Evaluation of the Roche cobas® CT/NG test for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in male urine. Sex Transm Dis. 2012;39(7):543-9. [pmid: 22706217].
33 Van Der Pol B, Liesenfeld O, Williams JA, Taylor SN, Lillis RA, Body BA, et al. Performance of the cobas CT/NG test compared to the APTIMA AC2 and Viper CTQ/GCQ assays for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2012;50(7):2244-9. [pmid: 22518864].
34 Van Der Pol B, Taylor SN, Lebar W, Davis T, Fuller D, Mena L, et al. Clinical evaluation of the BD ProbeTec™ Neisseria gonorrhoeae Qx amplified DNA assay on the BD Viper™ system with XTR™ technology. Sex Transm Dis. 2012;39(2):147-53. [pmid: 22249304].
35 Stewart CM, Schoeman SA, Booth RA, Smith SD, Wilcox MH, Wilson JD. Assessment of self taken swabs versus clinician taken swab cultures for diagnosing gonorrhoea in women: single centre, diagnostic accuracy study. BMJ. 2012;345:e8107. [pmid: 23236033].
36 Gaydos CA, Van Der Pol B, Jett-Goheen M, Barnes M, Quinn N, Clark C, et al. Performance of the Cepheid CT/NG Xpert rapid PCR test for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2013;51(6):1666-72. [pmid: 23467600].
37 Schachter J, McCormack WM, Chernesky MA, Martin DH, Van Der Pol B, Rice PA, et al. Vaginal swabs are appropriate specimens for diagnosis of genital tract infection with Chlamydia trachomatis. J Clin Microbiol. 2003;41(8):3784-9. [pmid: 12904390].
38 Shrier LA, Dean D, Klein E, Harter K, Rice PA. Limitations of screening tests for the detection of Chlamydia trachomatis in asymptomatic adolescent and young adult women. Am J Obstet Gynecol. 2004;190(3):654-62. [pmid: 15041995].
39 Taylor SN, Van Der Pol B, Lillis R, Hook EW 3rd, Lebar W, Davis T, et al. Clinical evaluation of the BD ProbeTec™ Chlamydia trachomatis Qx amplified DNA assay on the BD Viper™ system with XTR™ technology. Sex Transm Dis. 2011;38(7):603-9. [pmid: 21301389].
40 Schoeman SA, Stewart CM, Booth RA, Smith SD, Wilcox MH, Wilson JD. Assessment of best single sample for finding chlamydia in women with and without symptoms: a diagnostic test study. BMJ. 2012;345:e8013. [pmid: 23236032].
41 Pimenta JM, Catchpole M, Rogers PA, Hopwood J, Randall S, Mallinson H, et al. Opportunistic screening for genital chlamydial infection, II: prevalence among healthcare attenders, outcome, and evaluation of positive cases. Sex Transm Infect. 2003;79(1):22-7. [pmid: 12576608].
42 Burstein G, Jacobs A, Kissin D, Workowski K. Changes in the 2010 STD Treatment Guidelines: What Adolescent Health Care Providers Should Know. Washington, DC. American Congress of Obstetricians and Gynecologists. 2011. Accessed at http://www.acog.org/About-ACOG/ACOG-Departments/Adolescent-Health-Care/Changes-in-the-2010-STD-Treatment-Guidelines--What-Adolescent-Health-Care-Providers-Should-Know. 3 September 2014.
43 Moyer CS. STDs increasing among young women; more prevention urged. American Medical News. December. 7. 2009. Accessed at http://www.amednews.com/article/20091207/profession/312079972/6/. 3 September 2014.
44 Burstein G, Workowski K. What's new with 2010 STD treatment guidelines from the CDC?. AAP News. 2011;32:7.
45 American Academy of Family Physicians. Clinical Preventive Services Recommendation: Chlamydia. Leawood, KS. American Academy of Family Physicians. 2007. Accessed at http://www.aafp.org/patient-care/clinical-recommendations/all/chlamydia.html. 3 September 2014.
46 American College of Physicians. Clinical Practice Guidelines. Philadelphia. American College of Physicians. 2014. Accessed at http://www.acponline.org/clinical_information/guidelines/guidelines/. 8 September 2014.
47 Andersen B, van Valkengoed I, Sokolowski I, Møller JK, Østergaard L, Olesen F. Impact of intensified testing for urogenital Chlamydia trachomatis infections: a randomised study with 9-year follow-up. Sex Transm Infect. 2011;87(2):156-61. [pmid: 21097811].
48 Low N, Egger M, Sterne JA, Harbord RM, Ibrahim F, Lindblom B, et al. Incidence of severe reproductive tract complications associated with diagnosed genital chlamydial infection: the Uppsala Women's Cohort Study. Sex Transm Infect. 2006;82(3):212-8. [pmid: 16731670].
49 van den Broek IV, van Bergen JE, Brouwers EE, Fennema JS, Götz HM, Hoebe CJ, et al. Effectiveness of yearly, register based screening for chlamydia in the Netherlands: controlled trial with randomised stepped wedge implementation. BMJ. 2012;345:e4316. [pmid: 22767614].
50 Scholes D, Satterwhite CL, Yu O, Fine D, Weinstock H, Berman S. Long-term trends in Chlamydia trachomatis infections and related outcomes in a U.S. managed care population. Sex Transm Dis. 2012;39(2):81-8. [pmid: 22249294].
51 Gaydos CA, Barnes M, Jett-Goheen M, Quinn N, Whittle P, Hogan T, et al. Characteristics and predictors of women who obtain rescreening for sexually transmitted infections using the www.iwantthekit.org screening programme. Int J STD AIDS. 2013;24(9):736-44. [pmid: 23970594].
52 Gottlieb SL, Stoner BP, Zaidi AA, Buckel C, Tran M, Leichliter JS, et al. A prospective study of the psychosocial impact of a positive Chlamydia trachomatis laboratory test. Sex Transm Dis. 2011;38(11):1004-11. [pmid: 21992975].
53 Kangas I, Andersen B, Olesen F, Møller JK, Østergaard L. Psychosocial impact of Chlamydia trachomatis testing in general practice. Br J Gen Pract. 2006;56(529):587-93. [pmid: 16882376].
54 Campbell R, Mills N, Sanford E, Graham A, Low N, Peters TJ. Chlamydia Screening Studies (ClaSS) Group. Does population screening for Chlamydia trachomatis raise anxiety among those tested? Findings from a population based chlamydia screening study. BMC Public Health. 2006;6:106. [pmid: 16638147].
55 Low N, McCarthy A, Macleod J, Salisbury C, Campbell R, Roberts TE, et al. Epidemiological, social, diagnostic and economic evaluation of population screening for genital chlamydial infection. Health Technol Assess. 2007;11(8):iii-iv. ix. xii. 1. 165. [pmid: 17311735].
56 Hood EE, Nerhood RC. The utility of screening for chlamydia at 34-36 weeks gestation. W V Med J. 2010;106(6):10-1. [pmid: 21928555].
57 Miller JM, Maupin RT, Nsuami M. Initial and repeat testing for chlamydia during pregnancy. J Matern Fetal Neonatal Med. 2005;18(4):231-5. [pmid: 16318972].
58 Blas MM, Canchihuaman FA, Alva IE, Hawes SE. Pregnancy outcomes in women infected with Chlamydia trachomatis: a population-based cohort study in Washington State. Sex Transm Infect. 2007;83(4):314-8. [pmid: 17344249].
59 Alexander S, Ison C, Parry J, Llewellyn C, Wayal S, Richardson D, et al. Self-taken pharyngeal and rectal swabs are appropriate for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in asymptomatic men who have sex with men. Sex Transm Infect. 2008;84(6):488-92. [pmid: 19028953].
60 Marcus JL, Bernstein KT, Kohn RP, Liska S, Philip SS. Infections missed by urethral-only screening for chlamydia or gonorrhea detection among men who have sex with men. Sex Transm Dis. 2011;38(10):922-4. [pmid: 21934565].
61 Schachter J, Moncada J, Liska S, Shayevich C, Klausner JD. Nucleic acid amplification tests in the diagnosis of chlamydial and gonococcal infections of the oropharynx and rectum in men who have sex with men. Sex Transm Dis. 2008;35(7):637-42. [pmid: 18520976].
62 Bissessor M, Tabrizi SN, Fairley CK, Danielewski J, Whitton B, Bird S. Differing Neisseria gonorrhoeae bacterial loads in the pharynx and rectum in men who have sex with men: implications for gonococcal detection, transmission, and control. J Clin Microbiol. 2011;49(12):4304-6. [pmid: 21956992].
63 Kent CK, Chaw JK, Wong W, Liska S, Gibson S, Hubbard G, et al. Prevalence of rectal, urethral, and pharyngeal chlamydia and gonorrhea detected in 2 clinical settings among men who have sex with men: San Francisco, California, 2003. Clin Infect Dis. 2005;41(1):67-74. [pmid: 15937765].
64 Public Health Agency of Canada. Canadian Guidelines on Sexually Transmitted Infections. Ottawa, Ontario, Canada. Public Health Agency of Canada. 2010. Accessed at http://www.phac-aspc.gc.ca/std-mts/sti-its/. 8 September 2014.