# METHODS

## Key Questions and Analytic Framework

This review followed a standard protocol consistent with the Agency for Healthcare Research and Quality's (AHRQ's) methods for systematic reviews.23,24 Based on evidence gaps identified from prior reviews,3-5 the USPSTF and AHRQ determined the scope and Key Questions of the review. A research plan was externally reviewed and modified. Investigators created two analytic frameworks incorporating the Key Questions and outlining the patient populations, interventions, outcomes, and potential adverse effects. The first analytic framework is for asymptomatic, sexually active men and nonpregnant women, including adolescents (Figure 1). The second analytic framework is for pregnant women (Figure 2).

Figure 1 Analytic Framework: Screening in Men and Nonpregnant Women, Including Adolescents

Key Questions
1. How effective is screening for gonorrhea and chlamydia in reducing complications of infection and transmission or acquisition of disease in asymptomatic, sexually active men and nonpregnant women, including adolescents?
2. How effective are different screening strategies in identifying persons with gonorrhea and chlamydia?
3. How accurate are screening tests for detecting gonorrhea and chlamydia?
4. What are the harms of screening for gonorrhea and chlamydia?

Figure 1 is an analytic framework that depicts the events involved in the screening of asymptomatic, sexually active men and nonpregnant women including adolescents for gonorrhea and chlamydia. The figure shows that screening asymptomatic individuals can lead to the detection of an infection and subsequent treatment for the infection. The figure indicates that by treating the infection there may be reduced complications from gonococcal or chlamydial infection as well as reduced transmission or acquisition of the disease. Additionally the figure indicates that there may be potential adverse effects of screening asymptomatic individuals.

Figure 2 Analytic Framework: Screening in Pregnant Women

Key Questions
1. How effective is screening for gonorrhea and chlamydia in reducing maternal complications, adverse pregnancy and infant outcomes, and transmission or acquisition of disease in asymptomatic pregnant women?
2. What are the harms of screening for gonorrhea and chlamydia in asymptomatic pregnant women?

Figure 2 is an analytic framework that depicts the events involved in the screening of asymptomatic, pregnant women for gonorrhea and chlamydia. The figure shows that screening asymptomatic individuals can lead to the detection of an infection and subsequent treatment for the infection. The figure depicts two pathways for treatment outcomes. In the first, treatment of gonococcal or chlamydial infection may reduce the maternal complications, which in turn may reduce adverse pregnancy outcomes. In the second pathway treatment of gonococcal or chlamydial infection may reduce the transmission to the newborn, which in turn may reduce adverse infant outcomes. Additionally, the figure indicates the possibility for adverse effects of both screening for and treatment of gonococcal or chlamydial infection in pregnant women.

The review includes studies published since prior USPSTF reviews of these topics.3-5 Studies were included if they were applicable to clinical settings and practices in the United States, as determined by the similarity of participants and health care services to real-world situations and the use of screening tests that are available and FDA-cleared for clinical use. The conditions of interest are gonococcal and chlamydial infections in asymptomatic persons.

The Key Questions for men and nonpregnant women are:

1. How effective is screening for gonorrhea and chlamydia in reducing complications of infection and transmission or acquisition of disease in asymptomatic, sexually active men and nonpregnant women, including adolescents?
2. How effective are different screening strategies in identifying persons with gonorrhea and chlamydia?
3. How accurate are screening tests in detecting gonorrhea and chlamydia?
4. What are the harms of screening for gonorrhea and chlamydia?

The Key Questions for pregnant women are:

1. How effective is screening for gonorrhea and chlamydia in reducing maternal complications, adverse pregnancy and infant outcomes, and transmission or acquisition of disease in asymptomatic pregnant women?
2. What are the harms of screening for gonorrhea and chlamydia in asymptomatic pregnant women?

## Search Strategies

The investigators worked with a research librarian to conduct searches of electronic databases, including MEDLINE (2004 to June 13, 2014), Cochrane Central Register of Controlled Trials (through May 2014), Cochrane Database of Systematic Reviews (through May 2014), Health Technology Assessment Database (through May 2014), Database of Abstracts of Reviews of Effects (through May 2014), and clinicaltrials.gov (through May 2014) (search strategies are available in Appendix B1). Search dates were selected to update prior USPSTF systematic reviews of these topics. In addition, investigators manually reviewed reference lists of relevant articles.

## Study Selection

Abstracts were selected for full-text review if they included asymptomatic, sexually active men and women, including pregnant women and adolescents; were relevant to a Key Question; and met additional prespecified inclusion criteria for each Key Question. Although this update was intended to evaluate studies published since prior USPSTF reviews, the scope, Key Questions, and inclusion criteria differ across reviews, resulting in the inclusion of some apparently older studies that had not been previously reviewed. Two reviewers independently evaluated each study to determine its inclusion eligibility based on prespecified inclusion and exclusion criteria developed for each Key Question (Appendix B2). Non-English–language articles and studies published as abstracts were not included.

Studies of screening effectiveness (Key Questions 1 and 2 for general populations and Key Question 1 for pregnant women) were included if they compared health outcomes of screened and nonscreened asymptomatic persons. Outcomes included reduced complications of gonococcal or chlamydial infections and reduced transmission or acquisition of disease, and for pregnant women, reduced maternal complications, adverse pregnancy outcomes, and adverse infant outcomes. Only randomized, controlled trials (RCTs) and controlled observational studies were included to evaluate the effectiveness of screening. Studies of screening strategies were included if they described the study population (number screened, sex, age range, setting, and absence of symptoms), features of the screening program (duration, type of strategy, and followup), and outcome measures. Inclusion criteria for effectiveness studies were less restrictive than for diagnostic accuracy studies because the main comparison concerned outcomes related to the overall approach of screening versus not screening, not the individual tests themselves. Uncontrolled observational studies were included to determine adverse effects of screening (Key Question 4 for general populations and Key Question 2 for pregnant women).

Studies of diagnostic accuracy (Key Question 3) were included if they evaluated the performance of tests in asymptomatic persons using technologies and methods cleared by the FDA and available for clinical practice in the United States. Based on these criteria, rectal, pharyngeal, and self-collected vaginal specimens obtained in nonclinical settings, as well as point-of-care or in-house tests, were excluded. Tests that were previously cleared by the FDA and subsequently removed from the U.S. market were also excluded.25 Included studies of diagnostic accuracy used credible reference standards, described the study population (number screened, sex, age range, setting, and absence of symptoms), defined positive screening test results, and reported performance characteristics (sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios) or provided data to calculate them.

The selection of studies is summarized in Appendix B3. Appendix B4 lists studies excluded at the full-text level with reasons for exclusion.

## Data Abstraction and Quality Rating

One investigator abstracted details about study design, patient population, comparison groups, setting, screening method, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. By using prespecified criteria developed by the USPSTF for RCTs, cohort, and diagnostic accuracy studies,24 two investigators independently rated the quality of studies (good, fair, or poor) and resolved discrepancies by consensus (Appendix B5).

## Data Synthesis

Two independent reviewers assessed the internal validity (quality) of new studies for each Key Question using methods developed by the USPSTF, based on the number, quality, and size of studies; consistency of results between studies; and directness of evidence.23,24 Statistical meta-analysis was not performed because of methodological limitations of the studies and heterogeneity in study designs, interventions, populations, and other factors. Studies included in prior reviews were reviewed for consistency with current results; however, lack of studies and differences in scope, Key Questions, and inclusion criteria limited aggregate synthesis with the updated evidence.

## External Review

The draft report was reviewed by six content experts and scientists at the CDC during October 2013 and by USPSTF members, AHRQ Project Officers, collaborative partners, and the public during May 2014 (Appendix B6).

## Response to Public Comments

This systematic review was posted for public comment from April 29 to May 26, 2014. The investigators reviewed and considered relevant comments. No comments identified missing studies that met inclusion criteria or errors in the evidence reviewed, resulting in no changes to the findings or the conclusion of this report.