# Evidence and Quality Tables

Appendix C1 Randomized, Controlled Trial of Effectiveness of Screening for Chlamydia

Author, year, title | Population characteristics | Eligibility criteria | Number approached, eligible, enrolled, & analyzed | Country & setting | Duration of followup | Attrition | Interventions | Outcomes | Adverse events/ harms | Sponsor | Quality rating
Oakeshott et al, 2010^26^ (with data from personal communication) Prevention of Pelvic Infection (POPI) trial | Age (mean): 20.9 y 100% Female 61.1% White 27.2% Black 3.6% Asian 7.5% Other | Sexually active women age ≤27 y. Excluded those who have never had sexual intercourse, have been tested for chlamydial infection in the past 3 months, or were pregnant. | Approached: 3528 Eligible: 2563 Enrolled: 2529 Analyzed: 2377 (1648 asymptomatic women) | UK General population | 1 y | Screened: 5% Deferred: 7% | Immediate screening vs. deferred screening after 1 y | Incidence of PID in asymptomatic women: Screened: 0.6% (5/787) Deferred: 1.6% (14/861) RR, 0.39 (95% CI, 0.14 to 1.08) In all women: Screened: 1.3% (15/1191) Deferred: 1.9% (23/1186) RR, 0.65 (95% CI, 0.34 to 1.22) | Not reported | Grant from the Bupa Foundation | Good

Abbreviations: CI = confidence interval; PID = pelvic inflammatory disease; RR = relative risk; UK = United Kingdom.

Appendix C2 Quality Rating of Randomized, Controlled Trial

Author, Year | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition, crossovers, adherence, and contamination reported? | Loss to followup differential /high? | Patients analyzed in the groups to which they were randomized? | Post-randomization exclusions? | Outcomes pre-specified? | Funding source | External validity | Quality Rating
Oakeshott et al, 2010^26^ | Yes | Yes | Yes | Yes | Yes | Screener: Yes Treatment: No | Yes | Yes | No/No | Yes | No | Yes | Grant from the Bupa Foundation | High | Good

Appendix C3 Observational Study of Screening Strategies for Chlamydia

Author, year, title | Study design | Country & setting | Interventions | Study duration Mean followup | Baseline demographics
Gotz et al, 2006^29^ “Prediction of Chlamydia trachomatis infection: application of a scoring rule to other populations” | Observational Population-based setting | Amsterdam/ Rotterdam | Self-administered questionnaire to develop a prediction rule for probability of infection in participants A: CT pilot study, 2002 to 2003, n=6303 [underlined: Validation study] B: Amsterdam, 1996 to 1997, n=1788 C: Rotterdam, n=172 (high-risk youth) | 1 year | A, B, C [underlined: CT result] Neg: 5997 (98%), 1361 (96%), 133 (88%) Pos: 144 (2%), 52 (4%), 19 (13%) [underlined: Sex] F: 4195 (68%), 913 (65%), 91 (60%) M: 1946 (32%), 500 (35%), 61 (40%) [underlined: Age] 15 to 19: 1386 (23%), 118 (8%), 87 (58%) 20 to 24: 2307 (38%), 440 (31%), 51 (34%) 25 to 29: 2448 (40%), 855 (61%), 12 (85%) [underlined: Urogenital symptoms, women] No: 4017 (96%), 870 (95%), 84 (92%) Yes: 178 (4%), 43 (5%), 7 (8%) [underlined: Urogenital symptoms, men] No: 1851 (95%), 480 (96%), 59 (97%) Yes: 95 (5%), 20 (4%), 2 (3%) [underlined: Lifetime sexual partners] 1: 2160 (35%), 248 (18%), 34 (22%) 2 to 5: 2904 (47%), 529 (37%), 66 (43%) ≥6: 1077 (18%), 636 (45%), 52 (34%)

Author, year, title | Eligibility criteria | Number enrolled Number analyzed Withdrawals Loss to followup | Adjusted variables for statistical analysis | Intermediate/clinical health outcome results | Adverse events/ harms | Sponsor | Quality rating
See above | Men and women ages 15 to 40 y; sexually active in the past 6 mo | Eligible: 21,000 [underlined: Enrolled] A: 6303 (41% participation rate) B: 1788 C: 172 Excluded: NR [underlined: Analyzed] A: 6141 B: 1413 C: 152 Withdrawals: NR Lost: NR | Discriminatory score AUC used as a model | Performance of predictor score at development and external validation: [underlined: AUC^*^ (95% CI)] A: 0.79 (0.76 to 0.84) B: 0.66 (0.58 to 0.74) C: 0.68 (0.58 to 0.79) [underlined: Predicted mean prevalence] A: 2.3 B: 4.7 C: 8.9 [underlined: Actual mean prevalence] A: 2.3 B: 3.7 C: 12.5 | NR | Rotterdam public health service | Good

* Results reflect higher homogeneity in risk factors.

Note: a model with an AUC of 0.5 has no discriminative power, whereas an AUC of 1 reflects perfect discrimination.

Abbreviations: AUC = area under curve; CI = confidence Interval; CT = Chlamydia trachomatis; F = female; M = male; n = number; Neg = negative; NNI = number needed to invite; NNS = number needed to screen; NR = not reported; Pos = positive.

Appendix C4 Quality Rating of Observational Study

Author, year | Did the study attempt to enroll all patients meeting inclusion criteria, or a random sample? | Were the groups comparable at baseline on key prognostic factors? | Did the study use accurate methods for ascertaining exposures and potential confounders? | Were outcome assessors and/or data analysts blinded to the exposure being studied? | Did the study maintain comparable groups? | Did the study perform appropriate statistical analyses on potential confounders? | Is there important differential or overall high loss to followup? | Were outcomes prespecified, defined, and ascertained using accurate methods? | Quality rating
Gotz et al, 2006^29^ | Yes | Yes | Unclear | No | Yes | Yes | No | Yes | Good

Appendix C5 Diagnostic Accuracy Studies of Gonorrhea Tests

Study, year | Screening test | Definition of a positive screening exam | Reference standard | Country, Setting, Prevalence | Population characteristics
Chernesky et al, 2005^31^ | AGC Site: urethral swab, FCU | Positive result from ≥1 NAAT in both urethral swab and FCU; or 1 specimen positive on both NAATs | AC2 PTGC | Canada, U.S. STI clinics | Age (mean): 28.5 y 100% male 62.2% non-Hispanic black, 24.6% white
Gaydos et al, 2013^36^ | Xpert Site: self-collected vaginal, cervix, female FCU, male FCU | Positive result from at least 1 of the 2 reference NAATs | AC2 PTGC | U.S. STI clinics | Age: ≥14 y (range or mean NR) 45% male (full sample, asymptomatic information NR separately) Race: NR
Stewart et al, 2012^35^ | AC2 Site: endocervical, self-collected vaginal | Positive culture with biochemical confirmation or positive result from 1 NAAT confirmed by second NAAT | Culture Aptima GC | United Kingdom Sexual health clinic Prevalence: NR | Age (mean): 25 y 100% female Ethnicity: 80% white, 9% black, 7% mixed, 4% other
Taylor et al, 2012^32^ | c4800 Site: FCU AC2, CT/GC Q^X^ Site: FCU, urethral swab | Positive result from ≥2 NAATs with different target regions in urethral swab and/or FCU | AC2 CT/GC Q^X^ | U.S. Obstetrics/gynecology, family planning, and STI clinics Prevalence: ≥1% | Age: 55% ≤30 y 100% male Race: 64.7% black, 32.9% white, 0.4% Asian, 0.4% American Indian/Alaskan Native, 0.1% Hawaiian/Pacific Islander, 1.3% other, 0.1% unknown Ethnicity: 82.7% non-Hispanic, 15.1% Hispanic, 2.2% unknown
Van Der Pol et al, 2012^33^ | c4800, AC2, CT/GC Q^X^ Site: endocervical, FCU | Positive result from ≥2 NAATs with different target regions in endocervical swab and/or FCU; each NAAT was evaluated based on results of other 2 NAATS | AC2 CT/GC Q^X^ | U.S. Family planning, obstetrics/gynecology, and STI clinics Prevalence NR | Age: ≥14 y 100% female Race: 43.1% black, 48.4% white, 2.8% Asian/Pacific Islander, 5.7% other Ethnicity: 22.1% Hispanic
Van Der Pol et al, 2012^34^ | GCQ, PTNG, AC2 Site: endocervical, female FCU, urethral swab, male FCU,all female sites, all male sites, overall | ≥1 positive result from each reference NAAT; for assay comparison, positive result required from each of other 2 assays | AC2 PTNG | U.S. NG prevalence across sites (range): 1.4% to 19.2% in females; 4.8% to 40.5% in males | Age (range): 16 to 64 y 44% male Race: NR Note: 2.7% of females were pregnant

Study, year | Eligibility Criteria | Sample size Proportion with condition | Proportion unexaminable by screening test | Number of indeterminate results
Chernesky et al, 2005^31^ | Men ages 15 to 77 y. Excluded if could not concurrently provide all samples, had urinated within 1 hour, had taken antibiotics in the last 21 days, or if they could not provide informed consent. | 1322 enrolled 17.9% CT 13.8% NG | NR | NR
Gaydos et al, 2013^36^ | Age ≥14 y, sexually active in the last 6 months, and attending a participating clinic. Excluded if enrolled in previous trial, received antimicrobial therapy within 21 days of study, or history of hysterectomy. | 2,270 asymptomatic 3.5% CT 0.7% NG | NR | 0.25% (total sample) were invalid and unreadable
Stewart et al, 2012^35^ | Women age ≥16 y presenting to study clinic for a new visit. Excluded if used antibiotics in the last 28 days, were unable or unwilling to perform self-taken swab or have the standard examination and swabs performed by clinicians. | 3973 enrolled 2.5% with NG | 0.8% | None
Taylor et al, 2012^32^ | Men age ≥14 y. Excluded if they had been previously enrolled in the study or used antimicrobials effective against CT or NG in the last 21 days. | 768 enrolled 16.4% CT 9.2% NG | 2.9% | NR
Van Der Pol et al, 2012^33^ | Women age ≥14 y who were eligible for routine CT/NG screening as per standard practice at each enrollment site. Excluded if they had been previously enrolled, used antimicrobial agents active against CT or NG in last 21 days, used Raplense (a vaginal lubricant) within past 3 days, or had a history of hysterectomy or contraindication to Pap test/cervical sampling. | 4479 enrolled 6.3% CT 1.5% NG | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR
Van Der Pol et al, 2012^34^ | Men and women ages 16 to 64 y who presented with urogenital symptoms or were being screened for CT and NG. Excluded if they had urinated within 1 hour of specimen collection, used antibiotics within last 21 days, had prior study enrollment, failed to provide consent, or were younger than the age required by the sites' IRB. | 1846 enrolled 6.5% of females with NG 14.5% of males with NG | 4.2% 12% of males had only 2 urethral swabs collected, rather than 3 | 21 indeterminate from PTNG; 9/21 resolved negative with repeat testing, 12 remained indeterminate. All were negative by GCQ and AC2.

Study, year | Screening test | Proportion with reference standard & included in analysis | True positives | False positives | False negatives | True negatives | Sensitivity (95% CI) | Specificity (95% CI)
Chernesky et al, 2005^31^ | AGC Site: urethral swab | 100% | 110 | 21 | 0 | 710 | 100.0% (71.5 to 100) Calculated CI: 96.7 to 100 | 97.1% (95.6 to 98.2)
Chernesky et al, 2005^31^ | AGC Site: FCU | 100% | 100 | 4 | 10 | 730 | 90.9% (58.7 to 99.8) Calculated CI: 83.9 to 95.6 | 99.5% (98.6 to 99.9)
Gaydos et al, 2013^36^ | Xpert Site: self-collected vaginal | 99.6% | 12 | 1 | 0 | 1119 | 100% (77.9 to 100) | 99.9% (99.5 to 100)
Gaydos et al, 2013^36^ | Xpert Site: cervix | 99.6% | 12 | 0 | 0 | 1116 | 100% (77.9 to 100) | 100% (99.7 to 100)
Gaydos et al, 2013^36^ | Xpert Site: female FCU | 99.6% | 11 | 1 | 1 | 1123 | 91.7% (61.5 to 99.8) | 99.9% (99.5 to 100)
Gaydos et al, 2013^36^ | Xpert Site: male FCU | 99.6% | 5 | 1 | 0 | 1126 | 100% (54.9 to 100) | 99.9% (99.5 to 100)
Stewart et al, 2012^35^ | AC2 Site: endocervical | 97% | 36 | 0 | 4 | 2194 | 90.0% (77.0 to 96.0) | 100.0% (99.8 to 100.0)^*^
Stewart et al, 2012^35^ | AC2 Site: self-collected vaginal | 97% | 39 | 0 | 1 | 2194 | 98.0% (87.0 to 100.0) | 100.0% (99.8 to 100.0)^*^
Taylor et al, 2012^32^ | c4800 Site: FCU | 97.1% | 7 | 0 | 0 | 465 | 100.0% (64.6 to 100.0) Calculated CI: 58.9 to 100 | 100.0% (99.2 to 100.0)
Taylor et al, 2012^32^ | AC2 Site: FCU | 97.1% | 7 | 0 | 0 | 465 | 100.0% (64.6 to 100.0) Calculated CI: 58.9 to 100 | 100.0% (99.2 to 100.0)
Taylor et al, 2012^32^ | AC2 Site: urethral swab | 97.1% | 7 | 0 | 0 | 465 | 100.0% (64.6 to 100.0) Calculated CI: 58.9 to 100 | 100.0% (99.2 to 100.0)
Taylor et al, 2012^32^ | CT/GC Q^X^ Site: FCU | 97.1% | 7 | 1 | 0 | 464 | 100.0% (64.6 to 100.0) Calculated CI: 58.9 to 100 | 99.8% (98.8 to 100.0)
Taylor et al, 2012^32^ | CT/GC Q^X^ Site: urethral swab | 97.1% | 7 | 0 | 0 | 465 | 100.0% (64.6 to 100.0) Calculated CI: 58.9 to 100 | 100.0% (99.2 to 100.0)
Van Der Pol et al, 2012^33^ | c4800 Site: endocervical | 96.4% | 22 | 0 | 1 | 2246 | 95.7% (79.0 to 99.2) | 100.0% (99.8 to 100.0)
Van Der Pol et al, 2012^33^ | c4800 Site: FCU | 96.4% | 23 | 1 | 0 | 2255 | 100.0% (85.7 to 100.0) | 100.0% (99.7 to 100.0)
Van Der Pol et al, 2012^33^ | AC2 Site: endocervical | 96.4% | 23 | 0 | 0 | 2266 | 100.0% (85.7 to 100.0) | 100.0% (99.8 to 100.0)
Van Der Pol et al, 2012^33^ | AC2 Site: FCU | 96.4% | 22 | 1 | 1 | 2268 | 95.7% (79.0 to 99.2) | 100.0% (99.8 to 100.0)
Van Der Pol et al, 2012^33^ | CT/GC Q^X^ Site: endocervical | 96.4% | 21 | 4 | 2 | 2241 | 91.3% (73.2 to 97.6) | 99.8% (99.5 to 99.9)
Van Der Pol et al, 2012^33^ | CT/GC Q^X^ Site: FCU | 96.4% | 23 | 3 | 0 | 2246 | 100.0% (85.7 to 100.0) | 99.9% (99.6 to 100.0)
Van Der Pol et al, 2012^34^ | GCQ Site: endocervical | 95.8% | 26 | 2 | 1 | 421 | 96.3% (81.0 to 99.9) | 99.5% (98.3 to 99.9)
Van Der Pol et al, 2012^34^ | GCQ Site: female FCU | 95.8% | 27 | 2 | 0 | 421 | 100.0% (87.2 to 100.0) | 99.5% (98.3 to 99.9)
Van Der Pol et al, 2012^34^ | GCQ Site: urethral swab | 95.8% | 12 | 4 | 0 | 492 | 100.0% (73.5 to 100.0) | 99.2% (97.9 to 99.8)
Van Der Pol et al, 2012^34^ | GCQ Site: male FCU | 95.8% | 12 | 4 | 0 | 501 | 100.0% (73.5 to 100.0%) | 99.2% (98.0 to 99.8%)
Van Der Pol et al, 2012^34^ | GCQ All female sites | 95.8% | 106 | 13 | 2 | 1678 | 98.1% (93.5 to 99.8) | 99.2% (98.7 to 99.6)
Van Der Pol et al, 2012^34^ | GCQ All male sites | 95.8% | 36 | 12 | 0 | 1494 | 100.0% (90.3 to 100.0) | 99.2% (98.6 to 99.6)
Van Der Pol et al, 2012^34^ | GCQ Overall | 95.8% | 142 | 25 | 2 | 3172 | 98.6% (95.1 to 99.8) | 99.2% (98.8 to 99.5)
Van Der Pol et al, 2012^34^ | PTNG Site: endocervical | 95.8% | 26 | 3 | 2 | 407 | 92.9% (76.5 to 99.1) | 99.3% (97.9 to 99.8)
Van Der Pol et al, 2012^34^ | PTNG Site: female FCU | 95.8% | 23 | 2 | 5 | 414 | 82.1% (63.1 to 93.9) | 99.5% (98.3 to 99.9)
Van Der Pol et al, 2012^34^ | PTNG Site: urethral swab | 95.8% | 12 | 0 | 0 | 480 | 100.0% (73.5 to 100.0) | 100.0% (99.2 to 100.0)
Van Der Pol et al, 2012^34^ | PTNG Site: male FCU | 95.8% | 12 | 1 | 1 | 497 | 92.3% (64.0 to 99.8) | 99.8% (98.9 to 100.0)
Van Der Pol et al, 2012^34^ | PTNG All female sites | 95.8% | 49 | 5 | 7 | 821 | 87.5% (75.9 to 94.8) | 99.4% (98.6 to 99.8)
Van Der Pol et al, 2012^34^ | PTNG All male sites | 95.8% | 24 | 1 | 1 | 977 | 96.0% (79.6 to 99.9) | 99.9% (99.4 to 100.0)
Van Der Pol et al, 2012^34^ | PTNG Overall | 95.8% | 73 | 6 | 8 | 1798 | 90.1% (81.5 to 95.6) | 99.7% (99.3 to 99.9)
Van Der Pol et al, 2012^34^ | AC2 Site: endocervical | 95.8% | 27 | 2 | 1 | 418 | 96.4% (81.7 to 99.9) | 99.5% (98.3 to 99.9)
Van Der Pol et al, 2012^34^ | AC2 Site: female FCU | 95.8% | 22 | 0 | 6 | 422 | 78.6% (59.0 to 91.7) | 100.0% (99.1 to 100.0)
Van Der Pol et al, 2012^34^ | AC2 Site: urethral swab | 95.8% | 11 | 4 | 0 | 469 | 100.0% (71.5 to 100.0) | 99.2% (97.8 to 99.8)
Van Der Pol et al, 2012^34^ | AC2 Site: male FCU | 95.8% | 12 | 3 | 0 | 502 | 100.0% (73.5 to 100.0) | 99.4% (98.3 to 99.9)
Van Der Pol et al, 2012^34^ | AC2 All female sites | 95.8% | 49 | 2 | 7 | 840 | 87.5% (75.9 to 94.8) | 99.8% (99.1 to 100.0)
Van Der Pol et al, 2012^34^ | AC2 All male sites | 95.8% | 23 | 7 | 0 | 971 | 100.0% (85.2 to 100.0) | 99.3% (98.5 to 99.7)
| AC2 Overall | | 72 | 9 | 7 | 1811 | 91.1% (82.6 to 96.4) | 99.5% (99.1 to 99.8)

Study, year | Screening test | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Sponsor | Quality rating
Chernesky et al, 2005^31^ | AGC Site: urethral swab | 34.8 (22.8 to 53.1)^*^ | 0.00^*^ | 84.0% (76.5 to 89.8)^*^ | 100% (99.5 to 100.0)^*^ | NR | Fair
Chernesky et al, 2005^31^ | AGC Site: FCU | 166.8 (62.7 to 444.1)^*^ | 0.09 (0.05 to 0.17)^*^ | 96.2% (90.4 to 98.9)^*^ | 98.7% (97.5 to 99.4)^*^ | NR | Fair
Gaydos et al, 2013^36^ | Xpert Site: self-collected vaginal | 1120.0 (157.90 to 7944.29)^*^ | 0.00^*^ | 92.3% (63.9 to 98.7) | 100% (99.7 to 100) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Gaydos et al, 2013^36^ | Xpert Site: cervix | Unable to calculate | 0.00^*^ | 100.0% (73.4 to 100) | 100.0% (99.7 to 100) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Gaydos et al, 2013^36^ | Xpert Site: female FCU | 1030.3 (144.2 to 7362.7)^*^ | 0.08 (0.01 to 0.54)^*^ | 91.7% (61.5 to 98.6) | 99.9% (99.5 to 99.9) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Gaydos et al, 2013^36^ | Xpert Site: male FCU | 1127.0 (158.9 to 7993.9)^*^ | 0.00^*^ | 83.3% (36.1 to 97.2) | 100.0% (99.7 to 100) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Stewart et al, 2012^35^ | AC2 Site: endocervical | Unable to calculate | 0.10 (0.04 to 0.25)^*^ | 100.0% (90.2 to 100.0)^*^ | 99.8% (99.5 to 100.0)^*^ | None reported (GenProbe provided supplies) | Good
Stewart et al, 2012^35^ | AC2 Site: self-collected vaginal | Unable to calculate | 0.03 (0.00 to 0.17)^*^ | 100.0% (90.9 to 100.0)^*^ | 100.0% (99.8 to 100.0)^*^ | None reported (GenProbe provided supplies) | Good
Taylor et al, 2012^32^ | c4800 Site: FCU | Unable to calculate | 0.00^*^ | 100% (58.9 to 100.0)^*^ | 100.0% (99.2 to 100.0)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | AC2 Site: FCU | Unable to calculate | 0.00^*^ | 100% (58.9 to 100.0)^*^ | 100.0% (99.2 to 100.0)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | AC2 Site: urethral swab | Unable to calculate | 0.00^*^ | 100% (58.9 to 100.0)^*^ | 100.0% (99.2 to 100.0)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | CT/GC Q^X^ Site: FCU | 465.0 (65.6 to 3294.2)^*^ | 0.00^*^ | 87.5% (47.4 to 97.9)^*^ | 100.0% (99.2 to 100.0)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | CT/GC Q^X^ Site: urethral swab | Unable to calculate | 0.00^*^ | 100% (58.9 to 100.0)^*^ | 100.0% (99.2 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | c4800 Site: endocervical | Unable to calculate | 0.04 (0.01 to 0.30)^*^ | 100.0% (84.4 to 100.0)^*,†^ | 100.0% (99.8 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | c4800 Site: FCU | 2256.0 (317.9 to 16009.1)^*^ | 0.00^*^ | 95.8% (78.8 to 99.3)^*^ | 100.0% (99.8 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | AC2 Site: endocervical | Unable to calculate | 0.00^*^ | 100.0% (85.1 to 100.0) | 100.0% (99.8 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | AC2 Site: FCU | 2170.4 (305.3 to 15431.2)^*^ | 0.04 (0.01 to 0.30)^*^ | 95.7% (78.0 to 99.3)^*^ | 100.0% (99.8 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | CT/GC Q^X^ Site: endocervical | 512.5 (190.9 to 1375.3)^*^ | 0.09 (0.02 to 0.33)^*^ | 84.0% (63.9 to 95.4)^*^ | 99.9% (99.7 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | CT/GC Q^X^ Site: FCU | 749.7 (242.0 to 2322.7)^*^ | 0.00^*^ | 88.5% (69.8 to 97.4)^*^ | 100.0% (99.8 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^34^ | GCQ Site: endocervical | 203.7 (51.0 to 813.3)^*^ | 0.04 (0.01 to 0.25)^*^ | 92.9% (76.5 to 98.9)^*^ | 99.8% (98.7 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | GCQ Site: female FCU | 211.5 (53.1 to 842.9)^*^ | 0.00^*^ | 93.1% (77.2 to 99.0)^*^ | 100.0% (99.1 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | GCQ Site: urethral swab | 124.0 (46.7 to 329.1)^*^ | 0.00^*^ | 75.0% (47.6 to 92.6)^*^ | 100.0% (99.3 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | GCQ Site: male FCU | 126.3 (47.6 to 335.1)^*^ | 0.00^*^ | 75.0% (47.6 to 92.6)^*^ | 100.0% (99.3 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | GCQ All female sites | 127.7 (74.2 to 219.6)^*^ | 0.02 (0.00 to 0.07)^*^ | 89.1% (82.0 to 94.1)^*^ | 99.9% (99.6 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | GCQ All male sites | 125.5 (71.4 to 220.5)^*^ | 0.00^*^ | 75.0% (60.4 to 86.4)^*^ | 100.0% (99.8 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | GCQ Overall | 126.1 (85.3 to 186.4)^*^ | 0.01 (0.00 to 0.06)^*^ | 85.0% (78.7 to 90.1)^*^ | 99.9% (99.8 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG Site: endocervical | 126.9 (40.9 to 393.7)^*^ | 0.07 (0.02 to 0.27)^*^ | 89.7% (72.6 to 97.7)^*^ | 99.5% (98.2 to 99.9)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG Site: female FCU | 170.9 (42.4 to 688.3)^*^ | 0.18 (0.08 to 0.40)^*^ | 92.0% (73.9 to 98.8)^*^ | 98.8% (97.2 to 99.6)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG Site: urethral swab | Unable to calculate | 0.00^*^ | 100.0% (73.4 to 100.0)^*^ | 100.0% (99.2 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG Site: male FCU | 459.7 (64.5 to 3277.6)^*^ | 0.08 (0.01 to 0.51)^*^ | 92.3% (63.9 to 98.7)^*^ | 99.8% (98.9 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG All female sites | 144.6 (60.0 to 348.3)^*^ | 0.13 (0.06 to 0.25)^*^ | 90.7% (79.7 to 96.9)^*^ | 99.2% (98.3 to 99.7)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG All male sites | 938.9 (132.2 to 6669.6)^*^ | 0.04 (0.01 to 0.27)^*^ | 96.0% (79.6 to 99.3)^*^ | 99.9% (99.4 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | PTNG Overall | 271.0 (121.5 to 604.3) | 0.10 (0.05 to 0.19)^*^ | 92.4% (84.2 to 97.1)^*^ | 99.6% (99.1 to 99.8)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 Site: endocervical | 202.5 (50.7 to 808.5)^*^ | 0.04 (0.01 to 0.25)^*^ | 93.1% (77.2 to 99.0)^*^ | 99.8% (98.7 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 Site: female FCU | Unable to calculate | 0.21 (0.11 to 0.44)^*^ | 100.0% (84.4 to 100.0)^*^ | 98.6% (97.0 to 99.5)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 Site: urethral swab | 118.3 (44.6 to 313.8)^*^ | 0.00^*^ | 73.3% (44.9 to 92.1)^*^ | 100.0% (99.2 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 Site: male FCU | 168.3 (54.5 to 520.2)^*^ | 0.00^*^ | 80.0% (51.9 to 95.4)^*^ | 100.0% (99.3 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 All female sites | 368.4 (92.0 to 1475.8)^*^ | 0.13 (0.06 to 0.25)^*^ | 96.1% (86.5 to 99.4)^*^ | 99.2% (98.3 to 99.7)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 All male sites | 139.7 (66.8 to 292.3)^*^ | 0.00^*^ | 76.7% (57.7 to 90.0)^*^ | 100.0% (99.6 to 100.0)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^34^ | AC2 Overall | 184.3 (95.7 to 354.9)^*^ | 0.09 (0.04 to 0.18)^*^ | 88.9% (80.0 to 94.8)^*^ | 99.6% (99.2 to 99.8)^*^ | BD Diagnostics | Fair

* Calculated.

† Authors estimate PPV = 93.8% to 99.9% (based on hypothetical prevalence range of 1% to 50%).

Abbreviations: AC2 = Aptima Combo 2; AGC = Aptima NG test; BD = Becton Dickinson; c4800= cobas 4800 CT and NG test; CI = confidence interval; CT = Chlamydia trachomatis; CT/GC Q^x^ = BD ProbeTech CT and NG Q^x^ amplified DNA assay; FCU = first-catch urine; GCQ = BD ProbeTec NG Q^x^ amplified DNA assay on Viper system; IRB = institutional review board; NAAT = nucleic acid amplification test; NG = Neisseria gonorrhea; NR = not reported; PPV = positive predictive value; PTGC = BD ProbeTech ET for CT and NG; PTNG = BD ProbeTech ET NG amplified DNA assay; STI = sexually transmited infection.

Appendix C6 Diagnostic Accuracy Studies of Chlamydia Tests

Study, year | Screening test(s) | Definition of a positive screening exam | Reference standard(s) | Country Setting Prevalence
NAATs vs. NAATs
Chernesky et al, 2005^31^ | ACT Site: urethral swab, FCU | Positive result from at least 1 NAAT in both urethral swab and FCU; or one specimen positive on both NAATs | AC2 PTGC | Canada, U.S. STI clinics
Gaydos et al, 2013^36^ | Xpert Site: self-collected vaginal, cervix, female FCU, male FCU | Positive result from at least 1 of the reference NAATs | AC2 PTGC | U.S. STI clinics
Schachter et al, 2003^37^ | ACT, Amplicor Site: FCU, cervix, clinician-collected vaginal, self-collected vaginal | Agreement between positive results with vaginal swab and cervical swab or FCU | Culture | U.S., Canada Family planning, obstetrics/gynecology, and STI clinics CT prevalence across sites: 5.4% to 10.2% by culture
Schoeman et al, 2012^40^ | AC2 Site: endocervix, self-collected vaginal | Positive result from 1 NAAT confirmed by second NAAT | Aptima CT | United Kingdom Sexual health clinic Prevalence: NR
Shrier et al, 2004^38^ | Amplicor Site: endocervix, FCU, clinician-collected vaginal, self-collected vaginal | 1 positive culture or 2 positive nonculture tests or 1 positive nonculture test confirmed by nested PCR | Culture Amplicor Abbot LCx assay | U.S. University medical center and children's hospital 21.6% positive for CT at any site
Taylor et al, 2012^32^ | c4800 Site: FCU AC2, CT/GC Q^x^ Site: FCU, urethral swab | Positive result from ≥2 NAATs with different target regions in urethral swab and/or FCU | AC2 CT/GC Q^x^ | U.S. Obstetrics/gynecology, family planning, and STI clinics Prevalence ≥1%
Taylor et al, 2011^39^ | CTQ, PTCT, AC2 Site: endocervical, female FCU, urethral swab, male FCU, all female sites, all male sites | ≥1 positive result from each reference NAAT; for assay comparison, positive result required from each of other 2 assays | AC2 PTCT | U.S. Family planning, obstetrics/gynecology, and STI clinics CT prevalence across sites: 11.6% in females, 21.4% in males
Van Der Pol et al, 2012^33^ | c4800, AC2, CT/GC Q^x^ Site: endocervical, FCU | Positive result from ≥2 NAATs with different target regions in endocervical swab and/or FCU; each NAAT was evaluated based on results of other 2 NAATs | AC2 CT/GC Q^x^ | U.S. Family planning, obstetrics/gynecology, and STI clinics Prevalence NR

Study, year | Population Characteristics | Eligibility Criteria | Sample size Proportion with condition
NAATs vs. NAATs
Chernesky et al, 2005^31^ | Age (mean): 28.5 y 100% male 62.2% non-Hispanic black, 24.6% white | Men ages 15 to 77 y. Excluded if they could not concurrently provide all samples, had urinated within 1 hour, had taken antibiotics in the last 21 days, or if they could not provide informed consent. | 1322 enrolled 17.9% CT 13.8% NG
Gaydos et al, 2013^36^ | Age: ≥14 y (range or mean NR) 45% male (full sample, asymptomatic information NR separately) Race: NR | Age ≥14 y, sexually active in the last 6 months, and attending a participating clinic. Excluded if enrolled in previous trial, received antimicrobial therapy within 21 days of study, or history of hysterectomy. | 2,270 asymptomatic 3.5% CT 0.7% NG
Schachter et al, 2003^37^ | Age (range): 16 to 25 y 100% female Race: NR | Females ages 16 to 25 y who were not pregnant and attending a study clinic for routine exam or birth control advice. Excluded if they had been treated with antibiotics within the last 30 days, were attending the clinic because of symptoms, or had a male partner treated for genital symptoms. | 2517 tested 9.6% of women with CT by culture of 1 specimen
Schoeman et al, 2012^40^ | Age (mean): 25 y 100% female Ethnicity: 80% white, 9% black, 7% mixed, 4% other | Women age ≥16 y presenting to study clinic for a new visit. Excluded if used antibiotics in the preceding 28 days, were unable or unwilling to perform self-taken swab, or have the standard exam and swabs performed by clinicians. | 3973 enrolled 10.3% with CT
Shrier et al, 2004^38^ | Age (mean): 19 y 100% female 22% history of CT Median time since previous CT infection: 539 days (range, 43 to 2738) 8% with history of other STI | Females ages 16 to 25 y who had ever had sexual intercourse, did not report symptoms of an STI, and were being seen at clinic for routine gynecologic care. Excluded if they were pregnant, had taken antibiotics in the previous 21 days, were diagnosed with CT in the previous 6 weeks, or had sexual contact with a partner diagnosed with an STI. | 139 eligible 126 analyzed 21.6% CT 2% NG or trichomoniasis (1 participant had CT and NG)
Taylor et al, 2012^32^ | Age: 55% ≤30 y 100% male Race: 64.7% black, 32.9% white, 0.4% Asian, 0.4% American Indian/Alaskan Native, 0.1% Hawaiian/Pacific Islander, 1.3% other, 0.1% unknown Ethnicity: 82.7% non-Hispanic, 15.1% Hispanic, 2.2% unknown ethnicity | Men age ≥14 y. Excluded if they had been previously enrolled in the study or used antimicrobials effective against CT or NG in the preceding 21 days. | 768 enrolled 16.4% CT 9.2% NG
Taylor et al, 2011^39^ | Age (range): 17 to 64 y 32% male Race: NR Note: 2.7% of females were pregnant | Men and women ages 17 to 64 y who presented with urogenital symptoms or were being screened for CT and NG. Excluded if they had taken antibiotics in the previous 21 days, urinated in the previous hour, had sample collection issues, did not provide informed consent, or were younger than the age required by the site's IRB. | 1538 enrolled 11.6% of females with CT 21.4% of males with CT
Van Der Pol et al, 2012^33^ | Age: ≥14 y 100% female 43.1% black, 48.4% white, 22.1% Hispanic, 2.8% Asian/Pacific Islander, 5.7% other | Women age ≥14 y who were eligible for routine CT/NG screening as per standard practice at each enrollment site. Excluded if they had been previously enrolled, used antimicrobial agents active against CT or NG in preceding 21 days, used Raplense, a vaginal lubricant, within the past 3 days, or had a history of hysterectomy or contraindication to Pap test/cervical sampling. | 4479 enrolled 6.3% CT 1.5% NG

Study, year | Screening test(s) | Proportion unexaminable by screening test | Number of indeterminate results | Proportion who underwent reference standard and included in analysis | True positives | False positives | False negatives | True negatives | Sensitivity (95% CI)
NAATs vs. NAATs
Chernesky et al, 2005^31^ | ACT Site: urethral swab | NR | NR | 100% | 94 | 16 | 1 | 634 | 98.9% (94.3 to 100)
Chernesky et al, 2005^31^ | Site: FCU | NR | NR | 100% | 94 | 19 | 1 | 638 | 98.9% (94.3 to 100)
Gaydos et al, 2013^36^ | Xpert Site: self-collected vaginal | NR | 0.25% (total sample) were invalid and unreadable | 99.6% | 48 | 7 | 1 | 1076 | 98.0% (89.1 to 99.9)
Gaydos et al, 2013^36^ | Site: cervix | NR | 0.25% (total sample) were invalid and unreadable | 99.6% | 46 | 6 | 2 | 1074 | 95.8% (85.7 to 99.5)
Gaydos et al, 2013^36^ | Site: female FCU | NR | 0.25% (total sample) were invalid and unreadable | 99.6% | 49 | 2 | 2 | 1083 | 96.1% (86.5 to 99.5)
Gaydos et al, 2013^36^ | Site: male FCU | NR | 0.25% (total sample) were invalid and unreadable | 99.6% | 29 | 1 | 0 | 1102 | 100% (90.2 to 100)
Schachter et al, 2003^37^ | ACT Site: FCU | Not reported | Not reported | Unclear | 86^*^ | 7 | 33^*^ | 1265^*^ | 72.0%
Schachter et al, 2003^37^ | Site: cervix | Not reported | Not reported | Unclear | 106^*^ | 10 | 13^*^ | 1262^*^ | 89.1%
Schachter et al, 2003^37^ | Site: clinician-collected vaginal | Not reported | Not reported | Unclear | 107^*^ | 9 | 12^*^ | 1263^*^ | 89.9%
Schachter et al, 2003^37^ | Site: self-collected vaginal | Not reported | Not reported | Unclear | 111^*^ | 6 | 8^*^ | 1266^*^ | 93.3%
Schachter et al, 2003^37^ | Amplicor Site: FCU | Not reported | Not reported | Unclear | 63^*^ | 5 | 12^*^ | 501^*^ | 84.0%
Schachter et al, 2003^37^ | Site: cervix | Not reported | Not reported | Unclear | 68^*^ | 3 | 7^*^ | 503^*^ | 90.7%
Schachter et al, 2003^37^ | Site: clinician-collected vaginal | Not reported | Not reported | Unclear | 70^*^ | 6 | 5^*^ | 500^*^ | 93.3%
Schachter et al, 2003^37^ | Site: self-collected vaginal | Not reported | Not reported | Unclear | 68^*^ | 5 | 7^*^ | 501^*^ | 90.7%
Schoeman et al, 2012^40^ | AC2 Site: endocervix | 0.7% | 4 | 97.3% | 163 | 0 | 20 | 2050 | 89.0% (84.0 to 93.0)
Schoeman et al, 2012^40^ | Site: self-collected vaginal | 0.7% | 4 | 97.3% | 178 | 1 | 5 | 2049 | 97.0% (94.0 to 99.0)
Shrier et al, 2004^38^ | Amplicor Site: endocervix | 1 participant excluded because no samples were collected by physician | None reported; 8 participants had a single positive result that needed confirmation by nested PCR | 90.6% (analysis only included eligible participants with results on all tests) | 14 | 0 | 13 | 99 | 51.9% (32.0 to 71.3)
Shrier et al, 2004^38^ | Site: FCU | 1 participant excluded because no samples were collected by physician | None reported; 8 participants had a single positive result that needed confirmation by nested PCR | 90.6% (analysis only included eligible participants with results on all tests) | 12 | 0 | 15 | 99 | 44.4% (26.9 to 63.6)
Shrier et al, 2004^38^ | clinician-collected vaginal | 1 participant excluded because no samples were collected by physician | None reported; 8 participants had a single positive result that needed confirmation by nested PCR | 90.6% (analysis only included eligible participants with results on all tests) | 15 | 0 | 12 | 99 | 55.6% (36.4 to 73.1)
Shrier et al, 2004^38^ | self-collected vaginal | 1 participant excluded because no samples were collected by physician | None reported; 8 participants had a single positive result that needed confirmation by nested PCR | 90.6% (analysis only included eligible participants with results on all tests) | 14 | 1 | 13 | 98 | 51.9% (32.0 to 71.3)
Taylor et al, 2012^32^ | c4800 Site: FCU | 2.9% | NR | 97.1% | 51 | 2 | 1 | 418 | 98.1% (89.9 to 99.7)
Taylor et al, 2012^32^ | AC2 Site: FCU | 2.9% | NR | 97.1% | 50 | 4 | 1 | 417 | 98.0% (89.7 to 99.7)
Taylor et al, 2012^32^ | Site: urethral swab | 2.9% | NR | 97.1% | 48 | 5 | 3 | 416 | 94.1% (84.1 to 98.0)
Taylor et al, 2012^32^ | CT/GC Q^x^ Site: FCU | 2.9% | NR | 97.1% | 50 | 2 | 2 | 418 | 96.2% (87.0 to 98.9)
Taylor et al, 2012^32^ | Site: urethral swab | 2.9% | NR | 97.1% | 45 | 1 | 7 | 419 | 86.5% (74.7 to 93.3)
Taylor et al, 2011^39^ | CTQ Site: endocervical | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 53 | 8 | 4 | 385 | 93.0% (83.0 to 98.1)
Taylor et al, 2011^39^ | Site: female FCU | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 54 | 2 | 3 | 391 | 94.7% (85.4 to 98.9)
Taylor et al, 2011^39^ | Site: urethral swab | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 31 | 2 | 4 | 178 | 88.6% (73.3 to 96.8)
Taylor et al, 2011^39^ | Site: Male FCU | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 35 | 2 | 0 | 178 | 100.0% (90.0 to 100.0)
Taylor et al, 2011^39^ | All female sites | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 216 | 12 | 12 | 1559 | 94.7% (91.0 to 97.3)
Taylor et al, 2011^39^ | All male sites | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 101 | 6 | 4 | 534 | 96.2% (90.5 to 99.0)
Taylor et al, 2011^39^ | PTCT Site: endocervical | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 51 | 0 | 8 | 379 | 86.4% (75.0 to 94.0)
Taylor et al, 2011^39^ | Site: female FCU | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 53 | 1 | 6 | 384 | 89.8% (79.2 to 96.2)
Taylor et al, 2011^39^ | Site: urethral swab | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 31 | 2 | 5 | 173 | 86.1% (70.5 to 95.3)
Taylor et al, 2011^39^ | Site: male FCU | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 35 | 1 | 1 | 173 | 97.2% (85.5 to 99.9)
Taylor et al, 2011^39^ | All female sites | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 104 | 1 | 14 | 763 | 88.1% (80.9 to 93.4)
Taylor et al, 2011^39^ | All male sites | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 66 | 3 | 6 | 346 | 91.7% (82.7 to 96.9%)
Taylor et al, 2011^39^ | AC2 Site: endocervical | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 52 | 4 | 4 | 389 | 92.9% (82.7 to 98.0)
Taylor et al, 2011^39^ | Site: female FCU | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 55 | 2 | 1 | 392 | 98.2% (90.4 to 100.0)
Taylor et al, 2011^39^ | Site: urethral swab | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 30 | 2 | 3 | 166 | 90.9% (75.7 to 98.1)
Taylor et al, 2011^39^ | Site: male FCU | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 35 | 0 | 1 | 179 | 97.2% (85.5 to 99.9)
Taylor et al, 2011^39^ | All female sites | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 107 | 6 | 5 | 781 | 95.5% (89.9 to 98.5)
Taylor et al, 2011^39^ | All male sites | 4.7%; 13% of men had only 2 urethral swabs collected rather than 3 | 19 unable to calculate from PTCT; 7/19 resolved negative All 19 were negative by CTQ and AC2 | 95.3% | 65 | 2 | 4 | 345 | 94.2% (85.8 to 98.4)
Van Der Pol et al, 2012^33^ | c4800 Site: endocervical | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR | 96.4% | 94 | 1 | 11 | 2163 | 89.5% (82.2 to 94.0)
Van Der Pol et al, 2012^33^ | Site: FCU | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR | 96.4% | 98 | 4 | 12 | 2165 | 89.1% (81.9 to 93.6)
Van Der Pol et al, 2012^33^ | AC2 Site: endocervical | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR | 96.4% | 101 | 12 | 3 | 2173 | 97.1% (91.9 to 99.0)
Van Der Pol et al, 2012^33^ | Site: FCU | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR | 96.4% | 98 | 5 | 8 | 2181 | 92.5% (85.8 to 96.1)
Van Der Pol et al, 2012^33^ | CT/GC Q^x^ Site: endocervical | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR | 96.4% | 102 | 7 | 4 | 2155 | 96.2% (90.7 to 98.5)
Van Der Pol et al, 2012^33^ | Site: FCU | 3.6% of enrolled; 16.4% for primary analysis of particular specimen type | NR | 96.4% | 101 | 6 | 4 | 2161 | 96.2% (90.6 to 98.5)

Study, year | Screening test(s) | Specificity (95% CI) | Positive likelihood ratio (95% CI) | Negative likelihood ratio (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Sponsor | Quality rating
NAATs vs. NAATs
Chernesky et al, 2005^31^ | ACT Site: urethral swab | 97.5% (96.0 to 98.6) | 40.2 (24.8 to 65.3)^*^ | 0.01 (0.00 to 0.08)^*^ | 85.5% (77.5 to 91.5)^*^ | 99.8% (99.1 to 100)^*^ | NR | Fair
Chernesky et al, 2005^31^ | ACT Site: FCU | 98.0% (96.6 to 98.9) 97.1% (95.5 to 98.3)^*^ | 34.2 (22.0 to 53.3)^*^ | 0.01 (0 to 0.08)^*^ | 83.2% (75 to 89.6)^*^ | 99.8% (99.1 to 100)^*^ | NR | Fair
Gaydos et al, 2013^36^ | Xpert Site: self-collected vaginal | 99.4% (98.7 to 99.7) | 151.6 (72.3 to 317.5)^*^ | 0.02 (0.00 to 0.14)^*^ | 87.3% (75.5 to 94.7) | 99.9% (99.5 to 99.9) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Gaydos et al, 2013^36^ | Site: cervix | 99.4% (98.8 to 99.8) | 172.5 (77.5 to 383.9)^*^ | 0.04 (0.01 to 0.16)^*^ | 88.5% (76.5 to 95.6) | 99.8% (99.3 to 99.7) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Gaydos et al, 2013^36^ | Site: female FCU | 99.8% (99.3 to 100) | 521.2 (130.4 to 2083.8)^*^ | 0.04 (0.01 to 0.15)^*^ | 96.1% (86.5 to 99.4) | 99.8% (99.3 to 99.9) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Gaydos et al, 2013^36^ | Site: male FCU | 99.9% (99.5 to 100) | 1103.0 (155.5 to 7823.6)^*^ | 0.00^*^ | 96.7% (82.7 to 99.4) | 100% (99.6 to 100) | Cepheid, grant from National Insitute of Biomedical Imaging and Bioengineering | Fair
Schachter et al, 2003^37^ | ACT Site: FCU | 99.5% | 131.3 (62.2 to 277.2)^*^ | 0.28 (0.21 to 0.37)^*^ | 92.5% (85.1 to 96.9)^*^ | 97.5% (96.5 to 98.2)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Site: cervix | 99.3% | 113.3 (60.9 to 210.7)^*^ | 0.11 (0.07 to 0.18)^*^ | 91.4% (84.7 to 95.8)^*^ | 99.0% (98.3 to 99.5)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Site: clinician-collected vaginal | 99.4% | 127.1 (66.1 to 244.4)^*^ | 0.10 (0.06 to 0.17)^*^ | 92.2% (85.8 to 96.4)^*^ | 99.1% (98.4 to 99.5)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Site: self-collected vaginal | 99.6% | 197.8 (88.9 to 440.0)^*^ | 0.07 (0.03 to 0.13)^*^ | 94.9% (89.2 to 98.1) | 99.4% (98.8 to 99.7) | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Amplicor Site: FCU | 99.0% | 85.0 (35.3 to 204.5) | 0.16 (0.10 to 0.27)^*^ | 92.7% (83.7 to 97.5)^*^ | 97.7% (96.0 to 98.8)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Site: cervix | 99.4% | 152.9 (49.4 to 473.7)^*^ | 0.09 (0.05 to 0.19)^*^ | 95.8% (88.1 to 99.1)^*^ | 98.6% (97.2 to 99.4)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Site: clinician-collected vaginal | 98.8% | 78.7 (35.5 to 174.7)^*^ | 0.07 (0.03 to 0.16)^*^ | 92.1% (83.6 to 97.0)^*^ | 99.0% (97.7 to 99.7)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schachter et al, 2003^37^ | Site: self-collected vaginal | 99.0% | 91.8 (38.2 to 220.2)^*^ | 0.09 (0.05 to 0.19)^*^ | 93.2% (84.7 to 97.7)^*^ | 98.6% (97.2 to 99.4)^*^ | Roche Molecular Systems; Abbott Laboratories; GenProbe, Inc; CDC | Fair
Schoeman et al, 2012^40^ | AC2 Site: endocervix | 100% (99.8 to 100.0) | Unable to calculate | 0.11 (0.07 to 0.17)^*^ | 100.0% (97.7 to 100.0)^*^ | 99.0% (98.5 to 99.4)^*^ | None reported (GenProbe provided supplies) | Good
Schoeman et al, 2012^40^ | Site: self-collected vaginal | 99.9% (99.7 to 100.0) | 1994.0 (281.0 to 14151.3)^*^ | 0.03 (0.01 to 0.06)^*^ | 99.4% (96.9 to 99.9)^*^ | 99.8% (99.4 to 99.9)^*^ | None reported (GenProbe provided supplies) | Good
Shrier et al, 2004^38^ | Amplicor Site: endocervix | 100% (96.5 to 100) | Unable to calculate | 0.48 (0.33 to 0.71)^*^ | 100% (77.0 to 100) | 88.4% (81.1 to 93.6) | Roche Molecular Systems, Inc; CDC; NIMH, NIH | Good
Shrier et al, 2004^38^ | Site: FCU | 100% (96.5 to 100) | 0.56 (0.40 to 0.78) | Unable to calculate | 100% (76.4 to 100) | 86.8% (79.6 to 92.3) | Roche Molecular Systems, Inc; CDC; NIMH, NIH | Good
Shrier et al, 2004^38^ | Site: clinician-collected vaginal | 100% (96.5 to 100) | Unable to calculate | 0.44 (0.29 to 0.68)^*^ | 100% (78.7 to 100) | 89.2% (82.4 to 94.0) | Roche Molecular Systems, Inc; CDC; NIMH, NIH | Good
Shrier et al, 2004^38^ | Site: self-collected vaginal | 99.0% (95.0 to 100) | 51.3 (7.1 to 373.2)^*^ | 0.49 (0.33 to 0.72)^*^ | 93.3% (69.8 to 99.7) | 88.3% (81.0 to 93.5) | Roche Molecular Systems, Inc; CDC; NIMH, NIH | Good
Taylor et al, 2012^32^ | c4800 Site: FCU | 99.5% (98.3 to 99.9) | 206.0 (51.7 to 821.3)^*^ | 0.02 (0.00 to 0.13)^*^ | 96.2% (87.0 to 99.4)^*^ | 99.8% (98.7 to 100.0)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | AC2 Site: FCU | 99.0% (97.6 to 99.6) | 103.2 (38.9 to 273.9)^*^ | 0.02 (0.00 to 0.14)^*^ | 92.6% (82.1 to 97.9)^*^ | 99.8% (98.7 to 100.0)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | Site: urethral swab | 98.9% (97.3 to 99.5) | 79.3 (33.1 to 189.9)^*^ | 0.06 (0.02 to 0.18)^*^ | 90.6% (79.3 to 96.8)^*^ | 99.3% (97.9 to 99.8)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | CT/GC Q^x^ Site: FCU | 99.5% (98.3 to 99.9) | 201.9 (50.6 to 805.6)^*^ | 0.04 (0.01 to 0.15)^*^ | 96.2% (86.8 to 99.4)^*^ | 99.5% (98.3 to 99.9)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | Site: urethral swab | 99.8% (98.7 to 100.0) | 363.5 (51.2 to 2581.9)^*^ | 0.13 (0.07 to 0.27)^*^ | 97.8% (88.4 to 99.6)^*^ | 98.4% (96.6 to 99.3)^*^ | Roche Molecular Systems | Fair
Taylor et al, 2012^32^ | CTQ Site: endocervical | 98.0% (96.0 to 99.1) | 45.7 (22.3 to 91.0)^*^ | 0.07 (0.03 to 0.18)^*^ | 86.9% (75.8 to 94.2)^*^ | 99.0% (97.4 to 99.7)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: female FCU | 99.5% (98.2 to 99.9) | 186.2 (46.7 to 742.7)^*^ | 0.05 (0.02 to 0.16)^*^ | 96.4% (87.7 to 99.5)^*^ | 99.2% (97.8 to 99.8)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: urethral swab | 98.9% (96.0 to 99.9) | 79.7 (20.0 to 317.9)^*^ | 0.12 (0.05 to 0.29)^*^ | 93.9% (79.7 to 99.1)^*^ | 97.8% (94.5% to 99.4)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: Male FCU | 98.9% (96.0 to 99.9) | 90.0 (22.7 to 357.1)^*^ | 0.00^*^ | 94.6% (81.8 to 99.2)^*^ | 100.0% (97.9 to 100.0)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | All female sites | 99.2% (98.7 to 99.6) | 124.0 (70.5 to 218.1)^*^ | 0.05 (0.03 to 0.09)^*^ | 94.7% (91.0 to 97.3)^*^ | 99.2% (98.7 to 99.6)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | All male sites | 98.9% (97.6 to 99.6%) | 86.6 (39.0 to 192.0)^*^ | 0.04 (0.01 to 0.10)^*^ | 94.4% (88.2 to 97.9)^*^ | 99.3% (98.1 to 99.8)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | PTCT Site: endocervical | 100.0% (99.0 to 100.0) | Unable to calculate | 0.14 (0.07 to 0.26)^*^ | 100.0% (93.0 to 100.0)^*^ | 97.9% (96.0 to 99.1)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: female FCU | 99.7% (98.6 to 100.0) | 345.9 (48.8 to 2453.7)^*^ | 0.10 (0.05 to 0.22)^*^ | 98.2% (90.1 to 99.7)^*^ | 98.5% (96.7 to 99.4)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: urethral swab | 98.9% (95.9 to 99.9) | 75.4 (18.9 to 300.8)^*^ | 0.14 (0.06 to 0.32)^*^ | 93.9% (79.7 to 99.1)^*^ | 97.2% (93.6 to 99.1)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: male FCU | 99.4% (96.8 to 100.0) | 169.2 (23.9 to 1195.2)^*^ | 0.03 (0.00 to 0.19)^*^ | 97.2% (85.4 to 99.5)^*^ | 99.4% (96.8 to 99.9)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | All female sites | 99.9% (99.3 to 100.0) | 673.4 (94.9 to 4779.6)^*^ | 0.12 (0.07 to 0.19)^*^ | 99.1% (94.8 to 99.8)^*^ | 98.2% (97.0 to 99.0)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | All male sites | 99.1% (97.5 to 99.8) | 106.6 (34.5 to 329.8)^*^ | 0.08 (0.04 to 0.18)^*^ | 95.6% (87.8 to 99.0)^*^ | 98.3% (96.3 to 99.4)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | AC2 Site: endocervical | 99.0% (97.4 to 99.7) | 91.2 (34.3 to 242.5)^*^ | 0.07 (0.03 to 0.19)^*^ | 92.9% (82.7 to 98.0)^*^ | 99.0% (97.4 to 99.7)^*^ | BD Diagnostics | Fair
Taylor et al, 2012^32^ | Site: female FCU | 99.5% (98.2 to 99.9) | 193.5 (48.5 to 771.3)^*^ | 0.02 (0.00 to 0.13)^*^ | 96.5% (87.9 to 99.5)^*^ | 99.8% (98.6 to 100.0)^*^ | BD Diagnostics | Fair
Taylor et al, 2011^39^ | AC2 Site: urethral swab | 98.8% (95.8 to 99.9) | 76.4 (19.2 to 304.1)^*^ | 0.09 (0.03 to 0.27)^*^ | 93.8% (79.2 to 99.1)^*^ | 98.2% (94.9 to 99.6)^*^ | BD Diagnostics | Fair
Taylor et al, 2011^39^ | Site: male FCU | 100.0% (98.0 to 100.0) | Unable to calculate | 0.03 (0.00 to 0.19)^*^ | 100.0% (89.9 to 100.0)^*^ | 99.4% (96.9 to 99.9)^*^ | BD Diagnostics | Fair
Taylor et al, 2011^39^ | All female sites | 99.2% (98.3 to 99.7) | 125.3 (56.4 to 278.4)^*^ | 0.04 (0.02 to 0.11)^*^ | 94.7% (88.8 to 98.0)^*^ | 99.4% (98.5 to 99.8)^*^ | BD Diagnostics | Fair
Taylor et al, 2011^39^ | All male sites | 99.4% (97.9 to 99.9) | 163.4 (41.0 to 651.7)^*^ | 0.06 (0.02 to 0.15)^*^ | 97.0% (89.6 to 99.6)^*^ | 98.9% (97.1 to 99.7)^*^ | BD Diagnostics | Fair
Van Der Pol et al, 2012^33^ | c4800 Site: endocervical | 100.0% (99.7 to 100.0) | 1937.3 (272.7 to 13762.3)^*^ | 0.10 (0.06 to 0.18)^*^ | 99.0% (94.3 to 99.8)^*^ Note: authors estimate PPV of 77.3% to 99.7% (based on hypothetical prevalence range of 1% to 50%) | 99.5% (99.1 to 99.8)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | Site: FCU | 99.8% (99.5 to 99.9) | 483.1 (181.1 to 1288.8)^*^ | 0.11 (0.06 to 0.19)^*^ | 96.1% (90.3 to 98.9)^*^ | 99.5% (99.0 to 99.7)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | AC2 Site: endocervical | 99.5% (99.0 to 99.7) | 176.8 (100.5 to 311.2)^*^ | 0.03 (0.01 to 0.09)^*^ | 89.4% (82.2 to 94.4)^*^ | 99.9% (99.6 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | Site: FCU | 99.8% (99.5 to 99.9) | 404.2 (168.1 to 971.8)^*^ | 0.08 (0.04 to 0.15)^*^ | 95.2% (89.0 to 98.4)^*^ | 99.6% (99.3 to 99.8)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | CT/GC Q^x^ Site: endocervical | 99.7% (99.3 to 99.8) | 297.2 (141.7 to 623.3)^*^ | 0.04 (0.01 to 0.10)^*^ | 93.6% (87.2 to 97.3)^*^ | 99.8% (99.5 to 100.0)^*^ | Roche Molecular Systems | Fair
Van Der Pol et al, 2012^33^ | Site: FCU | 99.7% (99.4 to 99.9) | 347.4 (156.1 to 773.1)^*^ | 0.04 (0.01 to 0.10)^*^ | 94.4% (88.2 to 97.9)^*^ | 99.8% (99.5 to 100.0)^*^ | Roche Molecular Systems | Fair

* Calculated.

Abbreviations: AC2 = Aptima Combo 2; ACT = Aptima Chlamydia trachomatis test; Amplicor = Roche cobas Amplicor test; BD = Becton Dickinson; c4800= Roche cobas 4800 CT and NG test; CDC = Centers for Disease Control and Prevention; CI = confidence interval; CT = Chlamydia trachomatis; CTQ = BD ProbeTec CT Qx amplified DNA assay on the Viper system; CT/GC Qx = BD ProbeTec CT and NG Qx amplified DNA assay; EIA = enzyme immunoassay; FCU = first-catch urine; IRB = institutional review board; NAAT = nucleic acid amplification test; NG = Neisseria gonorrhea; NIH = National Institutes of Health; NIMH = National Institute for Mental Health; NR = not reported; PCR = polymerase chain reaction; PT = ProbeTech; PTCT = BD ProbeTech ET CT amplified DNA assay; PTGC = BD ProbeTech ET amplified DNA assay for CT and NG; STI = sexually transmitted infection.

Appendix C7 Quality Ratings of Diagnostic Accuracy Studies

Study, year | Representative spectrum | Random or consecutive sample | Screening test adequately described | Screening cutoffs predefined | Credible reference standard | Reference standard applied to and analysis includes all patients, or a random subset | Same reference standard applied to all patients | Reference standard and screening examination interpreted independently | High rate of uninterpretable results or noncompliance with screening test | Analysis includes patients with uninterpretable results or noncompliance | Quality Rating
Chernesky et al, 2005^31^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Fair
Schacter et al, 2003^37^ | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Fair
Schoeman et al, 2012^40^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | Yes | Good
Shrier et al, 2004^38^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | No | Fair
Stewart et al, 2012^35^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | Yes | Good
Taylor et al, 2011^39^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | Unclear | Fair
Taylor et al, 2012^32^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | No | Fair
Van Der Pol et al, 2012^33^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | Unclear | Fair
Van Der Pol et al, 2012^34^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | Unclear | Fair
Gaydos et al, 2013^36^ | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | No | Unclear | Fair