# Detailed Methods

## Appendix B1 Search Strategies

### Screening in Pregnant Women: Maternal and Neonatal Outcomes

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp GONORRHEA/
2. exp NEISSERIA GONORRHOEAE/
3. gonorrh$.mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
4. 1 or 2 or 3
5. exp mass screening/ or screen$.mp.
6. 4 and 5
7. exp GONORRHEA/di
8. 6 or 7
9. neonat$.mp. or exp Infant, Newborn/
10. 8 and 9
11. maternal fetal transmission.mp. or exp Disease Transmission, Vertical/
12. exp GONORRHEA/tm [Transmission]
13. 4 and 11
14. 7 and 11
15. 9 and 12
16. 13 or 15
17. limit 16 to human
18. 10 or 17

### Risks

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp gonorrhea/
2. exp Neisseria gonorrhoeae/
3. 1 or 2
4. exp Risk/
5. exp Risk Reduction Behavior/
6. exp Risk-Taking/
7. exp Risk Management/
8. 4 or 5 or 6 or 7
9. 3 or 8

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. gonorrh$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. risk$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2

### Test Performance

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp gonorrhea/
2. exp Neisseria gonorrhoeae/
3. 1 or 2
4. exp “Sensitivity and Specificity”/
5. exp Diagnostic Errors/
6. 4 or 5
7. 3 and 6

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. gonorrh$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (sensitiv$ or accurate$ or accuracy or predict$ or misdiagnos$ or misinterpret$ or ((diagnos$ or detect$ or discover$) adj5 (error$ or erroneous$ or fail$ or bias$)) or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2

### Searches Conducted for Chlamydia Only

#### Overall

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. risk$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2
4. screen$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. 1 and 4
6. (sensitiv$ or accurate$ or accuracy or predict$ or misdiagnos$ or misinterpret$ or ((diagnos$ or detect$ or discover$) adj5 (error$ or erroneous$ or fail$ or bias$)) or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7. 1 and 6
8. 3 or 5 or 7

Database: EBM Reviews – Cochrane Database of Systematic Reviews

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, abstract, full text, keywords, caption text]
2. risk$.mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 and 2
4. screen$.mp. [mp=title, abstract, full text, keywords, caption text]
5. 1 and 4
6. (sensitiv$ or accurate$ or accuracy or predict$ or misdiagnos$ or misinterpret$ or ((diagnos$ or detect$ or discover$) adj5 (error$ or erroneous$ or fail$ or bias$)) or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, abstract, full text, keywords, caption text]
7. 1 and 6
8. 3 or 5 or 7

Database: EBM Reviews – Database of Abstracts of Reviews of Effects

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, full text, keywords]
2. (cost or costs or costing or fund or funding or funded or economic$ or expenditur$ or insuran$ or dollar$).mp. [mp=title, full text, keywords]
3. 1 and 2
4. risk$.mp. [mp=title, full text, keywords]
5. 1 and 4
6. screen$.mp. [mp=title, full text, keywords]
7. 1 and 6
8. (sensitiv$ or accurate$ or accuracy or predict$ or misdiagnos$ or misinterpret$ or ((diagnos$ or detect$ or discover$) adj5 (error$ or erroneous$ or fail$ or bias$)) or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, full text, keywords]
9. 1 and 8
10. 3 or 5 or 7 or 9

Database: EBM Reviews – Health Technology Assessment

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, text, subject heading word]
2. risk$.mp. [mp=title, text, subject heading word]
3. 1 and 2
4. screen$.mp. [mp=title, text, subject heading word]
5. 1 and 4
6. (sensitiv$ or accurate$ or accuracy or predict$ or misdiagnos$ or misinterpret$ or ((diagnos$ or detect$ or discover$) adj5 (error$ or erroneous$ or fail$ or bias$)) or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, text, subject heading word]
7. 1 and 6
8. 3 or 5 or 7

#### Screening

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp chlamydia infections/
2. exp chlamydia trachomatis/
3. 1 or 2
4. exp Mass Screening/
5. 3 and 4

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. screen$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2

#### Screening in Pregnant Women – Maternal Outcomes

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp chlamydia infections/
2. exp chlamydia trachomatis/
3. 1 or 2
4. exp mass screening/ or screen$.mp.
5. 3 and 4
6. exp chlamydia infections/di
7. 5 or 6
8. exp PREGNANCY/ or exp PREGNANCY COMPLICATIONS/
9. (septic$ adj3 abort$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
10. exp Fetal Death/
11. (stillborn or stillbirth$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
12. (preterm$ or prematur$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
13. exp Infant, Low Birth Weight/
14. (low adj3 birth weight$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
15. ((low or lower$ or reduc$) adj3 (weight$ or birthweight$)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
16. chorioamnionit$.mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
17. 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16
18. 7 and 17

#### Screening in Pregnant Women – Neonatal Outcomes

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp chlamydia infections/
2. exp chlamydia trachomatis/
3. 1 or 2
4. exp mass screening/ or screen$.mp.
5. 3 and 4
6. exp chlamydia infections/di
7. 5 or 6
8. neonat$.mp. or exp Infant, Newborn/
9. 7 and 8
10. maternal fetal transmission.mp. or exp Disease Transmission, Vertical/
11. exp chlamydia infection/tm
12. 7 and 10
13. 8 and 11
14. 12 or 13
15. limit 14 to human

#### Risks

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp chlamydia infections/
2. exp chlamydia trachomatis/
3. 1 or 2
4. exp Risk/
5. exp Risk Reduction Behavior/
6. exp Risk-Taking/
7. exp Risk Management/
8. 8 or 9 or 10 or 11
9. 3 and 12

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. risk$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2

#### Test Performance

Database: Ovid MEDLINE(R) without Revisions

Search Strategy:

--------------------------------------------------------------------------------

1. exp chlamydia infections/
2. exp chlamydia trachomatis/
3. 1 or 2
4. exp “Sensitivity and Specificity”/
5. exp Diagnostic Errors/
6. 4 or 5
7. 3 and 6

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

Search Strategy:

--------------------------------------------------------------------------------

1. chlamyd$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (sensitiv$ or accurate$ or accuracy or predict$ or misdiagnos$ or misinterpret$ or ((diagnos$ or detect$ or discover$) adj5 (error$ or erroneous$ or fail$ or bias$)) or (false$ adj3 (positiv$ or negativ$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2

## Appendix B2 Inclusion and Exclusion Criteria

| Include | Exclude
Population | Asymptomatic, sexually active men and women (pregnant and nonpregnant), including adolescents | Symptomatic patients, children age <13 years, persons with other STIs
Interventions | [underlined: Nonpregnant population:] Screening effectiveness; screening strategies to detect infection, including selective screening of high-risk groups, sampling from various anatomical sites, cotesting for concurrent STIs, and use of different screening intervals; tests that detect chlamydia or gonorrhea in biological specimens from various anatomical sites (urine, endocervix, urethra, vagina, anus, pharynx) [underlined: Pregnant population:] Screening effectiveness | Tests that are not approved by the FDA
Outcomes | [underlined: Nonpregnant population:] Reduction in pelvic inflammatory disease, ectopic pregnancy, infertility, chronic pelvic pain, disease transmission, epididymitis, and other clinical outcomes; detection of infection and diagnostic accuracy; and harms from screening, such as labeling and false-negative or false-positive results [underlined: Pregnant population:] Reduction in disease transmission, preterm birth, neonatal clinical outcomes, and other pregnancy clinical outcomes | Intermediate outcomes
Study types and designs | [underlined: All key questions:] Good-quality systematic reviews [underlined: Benefits:] Randomized, control trials; controlled observational trials [underlined: Harms:] Randomized, control trials; controlled observational trials; and uncontrolled observational trials | [underlined: Benefits:] Uncontrolled observational trials, case studies [underlined: Harms:] Small uncontrolled observational trials, case studies

Abbreviations: FDA = U.S. Food and Drug Administration; STI = sexually transmitted infection.

## Appendix B3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Identified from reference lists, hand searching, and suggestions from experts.

‡ Studies that provided data and contributed to the body of evidence were considered “included.”

§ Studies may have provided data for more than one Key Question.

Appendix B3 is a flow diagram that summarizes the search and selection of articles. There were 3,236 citations identified by searching MEDLINE, Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and other sources including reference lists, hand searching, and suggestions by experts. Of these 2,452 were excluded at the abstract level because they did not address a Key Question. The remaining 784 articles were pulled for review at the full-text level to further review for inclusion. There were 772 full-text articles excluded for the following reasons: did not address a Key Question or meet inclusion criteria, but pulled to provide background information only; wrong population; wrong intervention; wrong outcomes; wrong study design; wrong publication type; foreign language; wrong comparison; no or inadequate reference standard used or a review not meeting our requirements. Twelve studies were included in the final report and may have provided data for more than one Key Question. For studies of asymptomatic, sexually active men and nonpregnant women including adolescents there was 1 study for Key Question 1, 1 study for Key Question 2, 10 studies for Key Question 3, and 10 studies for Key Question 4. There were no applicable studies for either question regarding asymptomatic pregnant women.

## Appendix B4 Excluded Studies

Key to exclusion codes

2 | Excluded because it does not address a Key Question or meet inclusion criteria, but pulled to provide background information
3 | Wrong population
4 | Wrong intervention
5 | Wrong outcomes
6 | Wrong study design for Key Question
7 | Wrong publication type
8 | Foreign language
9 | Appears in an included systematic review, no original data
10 | Wrong comparison
11 | No or inadequate reference standard used
12 | Review did not meet our requirements

Molecular Diagnostics: LCR, the ligase chain reaction. 2003. http://chlamydiae.com/twiki/bin/view/Diagnostics/LcrTest. 22 May, 2013. Exclusion code: 2.
Adderley-Kelly B, Stephens EM. Chlamydia: A major health threat to adolescents and young adults. Abnf J. 2005;16(3):52-55. Exclusion code: 6. [pmid: 16092734].
Aghaizu A, Adams EJ, Turner K, et al. What is the cost of pelvic inflammatory disease and how much could be prevented by screening for chlamydia trachomatis? Cost analysis of the Prevention of Pelvic Infection (POPI) trial. Sex Transm Infect. 2011;87(4):312-317. Exclusion code: 5. [pmid: 21444333].
Agrawal T, Vats V, Salhan S, Mittal A. Local markers for prediction of women at higher risk of developing sequelae to Chlamydia trachomatis infection. Am J Reprod Immunol. 2007;57(2):153-159. Exclusion code: 5. [pmid: 17217370].
Akande V, Turner C, Horner P, Horne A, Pacey A, British Fertility S. Impact of Chlamydia trachomatis in the reproductive setting: British Fertility Society Guidelines for practice. Hum Fertil (Camb). 2010;13(3):115-125. Exclusion code: 6. [pmid: 20849196].
Alary M, Poulin C, Bouchard C, et al. Evaluation of a modified sanitary napkin as a sample self-collection device for the detection of genital chlamydial infection in women. J Clin Microbiol. 2001;39(7):2508-2512. Exclusion code: 4. [pmid: 11427561].
Aldeen T, Jacobs J, Powell R. Screening university students for genital chlamydial infection: another lesson to learn. Sex Health. 2010;7(4):491-494. Exclusion code: 5. [pmid: 21062592].
Alexander S, Ison C. Evaluation of commercial kits for the identification of Neisseria gonorrhoeae. J Med Microbiol. 2005;54(Pt 9):827-831. Exclusion code: 10. [pmid: 16091433].
Alexander S, Ison C, Parry J, et al. Self-taken pharyngeal and rectal swabs are appropriate for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in asymptomatic men who have sex with men. Sex Transm Infect. 2008;84(6):488-492. Exclusion code: 4. [pmid: 19028953].
Alexander S, Martin I, Ison C. Confirming the Chlamydia trachomatis status of referred rectal specimens. Sex Transm Infect. 2007;83(4):327-329. Exclusion code: 5. [pmid: 17475685].
Al-Tayyib AA, Miller WC, Rogers SM, et al. Evaluation of risk score algorithms for detection of chlamydial and gonococcal infections in an emergency department setting. Acad Emerg Med. 2008;15(2):126-135. Exclusion code: 10. [pmid: 18275441].
Althaus CL, Heijne JCM, Roellin A, Low N. Transmission dynamics of Chlamydia trachomatis affect the impact of screening programmes. Epidemics. 2010;2(3):123-131. Exclusion code: 6. [pmid: 21352783].
American Academy of Family Physicians. USPSTF Screening for Chlamydial Infection: Recommendation Statement. 2007. http://www.aafp.org/afp/2007/1201/p1695.html. 5 Dec, 2012. Exclusion code: 2.
American Academy of Pediatrics. What's new with 2010 STD treatment guidelines from the CDC?. 2011. http://aapnews.aappublications.org/content/32/2/7.full. 5 Dec, 2012. Exclusion code: 2.
American College of Obstetricians and Gynecologists. Committee opinion no. 506: expedited partner therapy in the management of gonorrhea and chlamydia by obstetrician-gynecologists. Obstet Gynecol. 2011;118(3):761-766. Exclusion code: 7. [pmid: 21860319].
American College of Physicians. ACP Pocket Guide to Selected Preventive Services for Adults: Gonorrhea. 2012. http://www.acponline.org/mobile/cyppocketguide/gonorrhea_screening.html. 5 Dec, 2012. Exclusion code: 2.
American College of Physicians. ACP Pocket Guide to Selected Preventive Services for Adults: Chlamydia. 2012. http://www.acponline.org/mobile/cyppocketguide/chlamydia_screening.html. 5 Dec 2012. Exclusion code: 2.
American Medical Association, Moyer CS. STDs increasing among young women; more prevention urged. 2009. http://www.ama-assn.org/amednews/2009/12/07/prsb1207.htm. 5 Dec, 2012. Exclusion code: 2.
Amortegui AJ, Meyer MP. Enzyme immunoassay for detection of Chlamydia trachomatis from the cervix. Obstet Gynecol. 1985;65(4):523-526. Exclusion code: 4. [pmid: 3885103].
Anagrius C, Mjornberg PA. Gathering round the Chlamydia infection problems: tests and contact tracing necessary--changed sexual behavior is also needed!. Lakartidningen. 2006;103(28-29):2158. discussion 2160-2151 Exclusion code: 8. [pmid: 16895103].
Andersen B, Gundgaard J, Kretzschmar M, Olsen J, Welte R, Oster-Gaard L. Prediction of costs, effectiveness, and disease control of a population-based program using home sampling for diagnosis of urogenital Chlamydia trachomatis Infections. Sex Transm Dis. 2006;33(7):407-415. Exclusion code: 3. [pmid: 16601656].
Andersen B, Olesen F. Screening for Chlamydia trachomatis. BMJ. 2012;345:e4231. Exclusion code: 7. [pmid: 22767613].
Andersen B, Olesen F, Moller JK, Ostergaard L. Population-based strategies for outreach screening of urogenital Chlamydia trachomatis infections: a randomized, controlled trial. J Infect Dis. 2002;185(2):252-258. Exclusion code: 3. [pmid: 11807700].
Andersen B, Ostergaard L, Olesen F. Lack of evidence to support chlamydia infection screening. Ugeskr Laeger. 2010;172(28):2059-2061. Exclusion code: 7. [pmid: 20615375].
Andersen B, Ostergaard L, Puho E, Skriver MV, Schonheyder HC. Ectopic pregnancies and reproductive capacity after Chlamydia trachomatis positive and negative test results: a historical follow-up study. Sex Transm Dis. 2005;32(6):377-381. Exclusion code: 4. [pmid: 15912085].
Andersen B, Ostergaard L, Thomsen RW, Schonheyder H. Chlamydia trachomatis infection and risk of ectopic pregnancy. Sex Transm Dis. 2007;34(1):59. author reply 60. Exclusion code: 7. [pmid: 17195757].
Andersen B, van Valkengoed I, Sokolowski I, Moller JK, Ostergaard L, Olesen F. Impact of intensified testing for urogenital Chlamydia trachomatis infections: a randomised study with 9-year follow-up. Sex Transm Infect. 2011;87(2):156-161. Exclusion code: 3. [pmid: 21097811].
Anderson C, Thornley T. A pharmacy-based private chlamydia screening programme: results from the first 2 years of screening and treatment. Int J Clin Pharm. 2011;33(1):88-91. Exclusion code: 4. [pmid: 21365400].
Andrews WW, Klebanoff MA, Thom EA, et al. Midpregnancy genitourinary tract infection with Chlamydia trachomatis: association with subsequent preterm delivery in women with bacterial vaginosis and Trichomonas vaginalis. Am J Obstet Gynecol. 2006;194(2):493-500. Exclusion code: 5. [pmid: 16458652].
Angles d'Auriac M, Refseth UH, Espelund M, Moi H, Storvold G, Jeansson S. A new automated method for isolation of Chlamydia trachomatis from urine eliminates inhibition and increases robustness for NAAT systems. J Microbiol Methods. 2007;70(3):416-423. Exclusion code: 4. [pmid: 17610971].
Annan NT, Sullivan AK, Nori A, et al. Rectal chlamydia--a reservoir of undiagnosed infection in men who have sex with men. Sex Transm Infect. 2009;85(3):176-179. Exclusion code: 10. [pmid: 19176570].
Anschuetz GL, Asbel L, Spain CV, et al. Association between enhanced screening for Chlamydia trachomatis and Neisseria gonorrhoeae and reductions in sequelae among women. J Adolesc Health. 2012;51(1):80-85. Exclusion code: 10. [pmid: 22727081].
Anttila T, Tenkanen L, Lumme S, et al. Chlamydial antibodies and risk of prostate cancer. Cancer Epidemiol Biomarkers Prev. 2005;14(2):385-389. Exclusion code: 6. [pmid: 15734962].
Arcari CM, Gaydos JC, Howell MR, McKee KT, Gaydos CA. Feasibility and short-term impact of linked education and urine screening interventions for Chlamydia and gonorrhea in male army recruits. Sex Transm Dis. 2004;31(7):443-447. Exclusion code: 4. [pmid: 15215702].
Arustamian KK. Risk factors of urogenital chlamydiosis in women of reproductive age. Georgian Med. 2006;(139):76-78. Exclusion code: 8.
Arustamian KK. Comparative analysis of methods for diagnostics of chlamydial infection in women of reproductive age. Georgian Med. 2006;(139):73-75. Exclusion code: 8.
Arya R, Mannion PT, Woodcock K, Haddad NG. Incidence of genital Chlamydia trachomatis infection in the male partners attending an infertility clinic. J Obstet Gynaecol. 2005;25(4):364-366. Exclusion code: 2. [pmid: 16091321].
Asbel LE, Newbern EC, Salmon M, Spain CV, Goldberg M. School-based screening for Chlamydia trachomatis and Neisseria gonorrhoeae among Philadelphia public high school students. Sex Transm Dis. 2006;33(10):614-620. Exclusion code: 10. [pmid: 16614587].
Atherton H, Oakeshott P, Aghaizu A, Hay P, Kerry S. Use of an online questionnaire for follow-up of young female students recruited to a randomised controlled trial of chlamydia screening. J Epidemiol Community Health. 2010;64(7):580-584. Exclusion code: 4. [pmid: 20547698].
Auerswald CL, Sugano E, Ellen JM, Klausner JD. Street-based STD testing and treatment of homeless youth are feasible, acceptable and effective. J Adolesc Health. 2006;38(3):208-212. Exclusion code: 10. [pmid: 16488817].
Azariah S, McKernon S, Werder S. Large increase in opportunistic testing for chlamydia during a pilot project in a primary health organisation. J Prim Health Care. 2013;5(2):141-145. Exclusion code: 6. [pmid: 23748396].
Bachmann LH, Johnson RE, Cheng H, et al. Nucleic acid amplification tests for diagnosis of Neisseria gonorrhoeae and Chlamydia trachomatis rectal infections. J Clin Microbiol. 2010;48(5):1827-1832. Exclusion code: 3. [pmid: 20335410].
Bachmann LH, Johnson RE, Cheng H, Markowitz LE, Papp JR, Hook EW 3rd. Nucleic acid amplification tests for diagnosis of Neisseria gonorrhoeae oropharyngeal infections. J Clin Microbiol. 2009;47(4):902-907. Exclusion code: 3. [pmid: 19193848].
Bacon L. Chlamydia testing in contraceptive clinics: who, where, how and why?. J Fam Plann Reprod Health Care. 2004;30(2):82-83. Exclusion code: 7. [pmid: 15086988].
Baeten JM, Overbaugh J. Measuring the infectiousness of persons with HIV-1: opportunities for preventing sexual HIV-1 transmission. Curr HIV Res. 2003;1(1):69-86. Exclusion code: 2. [pmid: 15043213].
Bakken IJ. Chlamydia trachomatis and ectopic pregnancy: recent epidemiological findings. Curr Opin Infect Dis. 2008;21(1):77-82. Exclusion code: 6. [pmid: 18192790].
Bakken IJ, Bratt H, Skjeldestad FE, Nordbo SA. Detection of chlamydia trachomatis in urine, vulval and cervical swabs. Tidsskr Nor Laegeforen. 2005;125(12):1629-1630. Exclusion code: 8. [pmid: 15976824].
Bakken IJ, Ghaderi S. Incidence of pelvic inflammatory disease in a large cohort of women tested for Chlamydia trachomatis: a historical follow-up study. BMC Infect Dis. 2009;9:130. Exclusion code: 6. [pmid: 19678959].
Bakken IJ, Skjeldestad FE, Halvorsen TF, Thomassen T, Storvold G, Nordbo SA. Chlamydia trachomatis among young Norwegian men: sexual behavior and genitourinary symptoms. Sex Transm Dis. 2007;34(4):245-249. Exclusion code: 6. [pmid: 16924179].
Bakken IJ, Skjeldestad FE, Lydersen S, Nordbo SA. Births and ectopic pregnancies in a large cohort of women tested for Chlamydia trachomatis. Sex Transm Dis. 2007;34(10):739-743. Exclusion code: 3. [pmid: 17479068].
Bakken IJ, Skjeldestad FE, Nordbo SA. Chlamydia trachomatis infections increase the risk for ectopic pregnancy: a population-based, nested case-control study. Sex Transm Dis. 2007;34(3):166-169. Exclusion code: 3. [pmid: 16837829].
Bakken IJ, Skjeldestad FE, Ovreness T, Nordbo SA, Storvold G. Chlamydia infections and sexual behavior among young women. Tidsskr Nor Laegeforen. 2004;124(12):1633-1635. Exclusion code: 8. [pmid: 15229708].
Baldwin SB, Djambazov B, Papenfuss M, et al. Chlamydial infection in women along the US-Mexico border. Int J STD AIDS. 2004;15(12):815-821. Exclusion code: 5. [pmid: 15601488].
Balfe M, Brugha R, O'Connell E, Vaughan D, O'Donovan D. Men's attitudes towards chlamydia screening: a narrative review. Sex Health. 2012;9(2):120-130. Exclusion code: 5. [pmid: 22498155].
Balla E. Chlamydia trachomatis infections in neonates--overview of current laboratory diagnostics. Orv Hetil. 2009;150(17):805-809. Exclusion code: 8. [pmid: 19362937].
Bandea CI, Koumans EH, Sawyer MK, et al. Evaluation of the rapid BioStar optical immunoassay for detection of Chlamydia trachomatis in adolescent women. J Clin Microbiol. 2009;47(1):215-216. Exclusion code: 4. [pmid: 19005149].
Bangor-Jones RD. Sexual health in general practice: do practitioners comply with the sexually transmitted infections guidelines for management of suspected chlamydial infections?. Int J STD AIDS. 2011;22(9):523-524. Exclusion code: 3. [pmid: 21890552].
Barabasi Z. Treatment of conjunctivitis. Orv Hetil. 2004;145(41):2107-2110. Exclusion code: 8. [pmid: 15586586].
Baraitser P, Alexander S, Sheringham J. Chlamydia trachomatis screening in young women. Curr Opin Obstet Gynecol. 2011;23(5):315-320. Exclusion code: 7. [pmid: 21897235].
Barbee L, Dombrowski JC, Kerani R, Golden MR. Effect of nucleic acid amplification testing on detection of extragenital gonorrhea and chlamydial infections in men who have sex with men sexually transmitted disease clinic patients. Sex Transm Dis. 2014;41(3):168-172. Exclusion code: 4. [pmid: 24521722].
Barry PM, Kent CK, Klausner JD. Risk factors for gonorrhea among heterosexuals--San Francisco, 2006. Sex Transm Dis. 2009;36(2 Suppl):S62-66. Exclusion code: 5. [pmid: 18418303].
Barry PM, Kent CK, Philip SS, Klausner JD. Results of a program to test women for rectal chlamydia and gonorrhea. Obstet Gynecol. 2010;115(4):753-759. Exclusion code: 3. [pmid: 20308835].
Barry PM, Kent CK, Scott KC, Goldenson J, Klausner JD. Is jail screening associated with a decrease in Chlamydia positivity among females seeking health services at community clinics?-San Francisco, 1997-2004. Sex Transm Dis. 2009;36(2 Suppl):S22-28. Exclusion code: 10. [pmid: 18418298].
Barry PM, Kent CK, Scott KC, Snell A, Goldenson J, Klausner JD. Optimising sexually transmitted infection screening in correctional facilities: San Francisco, 2003-2005. Sex Transm Infect. 2007;83(5):416-418. Exclusion code: 10. [pmid: 17567685].
Barry PM, Scott KC, McCright J, et al. Stay in school? Results of a sexually transmitted diseases screening program in San Francisco high schools-2007. Sex Transm Dis. 2008;35(6):550-552. Exclusion code: 10. [pmid: 18356770].
Baseviciene I, Sumskas L. Use of contraceptives among adolescent girls and its relation with the Chlamydia trachomatis infection. Medicina (Kaunas). 2004;40(10):997-1003. Exclusion code: 5. [pmid: 15516825].
Baud D, Regan L, Greub G. Comparison of five commercial serological tests for the detection of anti-Chlamydia trachomatis antibodies. Eur J Clin Microbiol Infect Dis. 2010;29(6):669-675. Exclusion code: 4. [pmid: 20349260].
Beebe JL, Masters H, Jungkind D, Heltzel DM, Weinberg A. Confirmation of the Syva MicroTrak enzyme immunoassay for chlamydia trachomatis by Syva Direct Fluorescent Antibody Test. Sex Transm Dis. 1996;23(6):465-470. Exclusion code: 3. [pmid: 8946630].
Bekler C, Kultursay N, Ozacar T, Sayiner A, Yalaz M, Akisu M. Chlamydial infections in term and preterm neonates. Jpn J Infect Dis. 2012;65(1):1-6. Exclusion code: 3. [pmid: 22274150].
Benn PD, Rooney G, Carder C, et al. Chlamydia trachomatis and Neisseria gonorrhoeae infection and the sexual behaviour of men who have sex with men. Sex Transm Infect. 2007;83(2):106-112. Exclusion code: 3. [pmid: 17020893].
Benzaken AS, Galban EG, Antunes W, et al. Diagnosis of gonococcal infection in high risk women using a rapid test. Sex Transm Infect. Suppl 5. 2006;82:v26-28. Exclusion code: 4. [pmid: 17118954].
Berger RE. Comparison of three nucleic acid amplification tests for detection of Chlamydia trachomatis in urine specimens. J Urol. 2005;173(6):1989-1990. Exclusion code: 7.
Berger RE. Comparison of first void urine and urogenital swab specimens for detection of Mycoplasma genitalium and Chlamydia trachomatis by polymerase chain reaction in patients attending a sexually transmitted disease clinic. J Urol. 2005;173(6):1989-1990. Exclusion code: 7.
Berman SM, Satterwhite CL. A paradox: overscreening of older women for Chlamydia while too few younger women are being tested. Sex Transm Dis. 2011;38(2):130-132. Exclusion code: 7. [pmid: 21173722].
Bernstein KT, Marcus JL, Nieri G, Philip SS, Klausner JD. Rectal gonorrhea and chlamydia reinfection is associated with increased risk of HIV seroconversion. J Acquir Immune Defic Syndr. 2010;53(4):537-543. Exclusion code: 5. [pmid: 19935075].
Bernstein KT, Marcus JL, Snell A, Liska S, Rauch L, Philip SS. Reduction in unnecessary Chlamydia screening among older women at title X-funded family planning sites following a structural intervention--San Francisco, 2009. Sex Transm Dis. 2011;38(2):127-129. Exclusion code: 6. [pmid: 21139515].
Bernstein KT, Mehta SD, Rompalo AM, Erbelding EJ. Cost-effectiveness of screening strategies for Gonorrhea among females in private sector care. Obstet Gynecol. 2006;107(4):813-821. Exclusion code: 6. [pmid: 16582117].
Berry SA, Ghanem KG, Page KR, et al. Increased gonorrhoea and chlamydia testing did not increase case detection in an HIV clinical cohort 1999-2007. Sex Transm Infect. 2011;87(6):469-475. Exclusion code: 3. [pmid: 21745834].
Berwald N, Cheng S, Augenbraun M, Abu-Lawi K, Lucchesi M, Zehtabchi S. Self-administered vaginal swabs are a feasible alternative to physician-assisted cervical swabs for sexually transmitted infection screening in the emergency department. Acad Emerg Med. 2009;16(4):360-363. Exclusion code: 3. [pmid: 19220203].
Bhalla P, Baveja UK, Chawla R, et al. Simultaneous detection of Neisseria gonorrhoeae and Chlamydia trachomatis by PCR in genitourinary specimens from men and women attending an STD clinic. J Commun Dis. 2007;39(1):1-6. Exclusion code: 3. [pmid: 18338709].
Bialasiewicz S, Whiley DM, Buhrer-Skinner M, et al. A novel gel-based method for self-collection and ambient temperature postal transport of urine for PCR detection of Chlamydia trachomatis. Sex Transm Infect. 2009;85(2):102-105. Exclusion code: 4. [pmid: 19004866].
Bielecki R, Zdrodowska-Stefanow B, Ostaszewska-Puchalska I, Kozlowski R, Pucilo K. Role of Chlamydia trachomatis infection in the pathology of male urogenital tract. Przegl Lek. 2004;61(3):170-176. Exclusion code: 8. [pmid: 15518327].
Bignell C, Ison CA, Jungmann E. Gonorrhoea. Sex Transm Infect. Suppl 4. 2006;82:iv6-9. Exclusion code: 7. [pmid: 17151055].
Bilardi JE, Sanci LA, Fairley CK, et al. The experience of providing young people attending general practice with an online risk assessment tool to assess their own sexual health risk. BMC Infect Dis. 2009;9:29. Exclusion code: 5. [pmid: 19284635].
Biro FM, Reising SF, Doughman JA, Kollar LM, Rosenthal SL. A comparison of diagnostic methods in adolescent girls with and without symptoms of Chlamydia urogenital infection. Pediatrics. 1994;93(3):476-480. Exclusion code: 4. [pmid: 8115208].
Biros E, Bodnar J, Biros I, et al. Nucleic acid amplification technique for detection of Chlamydia trachomatis infection from clinical urogenital swabs. Folia Microbiol (Praha). 2007;52(4):437-442. Exclusion code: 4. [pmid: 18062194].
Bissessor M, Tabrizi SN, Fairley CK, et al. Differing Neisseria gonorrhoeae bacterial loads in the pharynx and rectum in men who have sex with men: Implications for gonococcal detection, transmission, and control. J Clin Microbiol. 2011;49(12):4304-4306. Exclusion code: 2. [pmid: 21956992].
Bjartling C, Persson K. Chlamydia and genital mycoplasma: epidemiology and risks. Lakartidningen. 2010;107(6):341-345. Exclusion code: 8. [pmid: 20297583].
Blake DR. Approaches to Chlamydia screening: one size does not fit all. Arch Pediatr Adolesc Med. 2009;163(6):585-586. Exclusion code: 7. [pmid: 19487617].
Blake DR, Lemay CA, Gaydos CA, Quinn TC. Performance of urine leukocyte esterase in asymptomatic male youth: another look with nucleic acid amplification testing as the gold standard for Chlamydia detection. J Adolesc Health. 2005;36(4):337-341. Exclusion code: 4. [pmid: 15780789].
Blas MM, Canchihuaman FA, Alva IE, Hawes SE. Pregnancy outcomes in women infected with Chlamydia trachomatis: a population-based cohort study in Washington State. Sex Transm Infect. 2007;83(4):314-318. Exclusion code: 5. [pmid: 17344249].
Blatt AJ, Lieberman JM, Hoover DR, Kaufman HW. Chlamydial and gonococcal testing during pregnancy in the United States. Am J Obstet Gynecol. 2012;207(1):55.e51-58. Exclusion code: 5. [pmid: 22621817].
Bloom MS, Hu Z, Gaydos JC, Brundage JF, Tobler SK. Incidence rates of pelvic inflammatory disease diagnoses among Army and Navy recruits potential impacts of Chlamydia screening policies. Am J Prev Med. 2008;34(6):471-477. Exclusion code: 5. [pmid: 18471582].
Boeke AJP, van Bergen JEAM, Morre SA, van Everdingen JJE. The risk of pelvic inflammatory disease associated with urogenital infection with Chlamydia trachomatis; literature review. Ned Tijdschr Geneeskd. 2005;149(16):878-884. Exclusion code: 8. [pmid: 15868993].
Boel CHE, van Herk CMC, Berretty PJM, Onland GHW, van den Brule AJC. Evaluation of conventional and real-time PCR assays using two targets for confirmation of results of the COBAS AMPLICOR Chlamydia trachomatis/Neisseria gonorrhoeae test for detection of Neisseria gonorrhoeae in clinical samples. J Clin Microbiol. 2005;43(5):2231-2235. Exclusion code: 4. [pmid: 15872247].
Bohm I, Groning A, Sommer B, Muller HW, Krawczak M, Glaubitz R. A German Chlamydia trachomatis screening program employing semi-automated real-time PCR: results and perspectives. J Clin Virol. Suppl 3. 2009;46:S27-32. Exclusion code: 5. [pmid: 20129071].
Bone A, Soldan K, Woodhall S, Clarke J, Gill ON. Opportunistic or population register based programmes for chlamydia screening?. BMJ. 2012;345:e5887. Exclusion code: 7. [pmid: 22951560].
Bongaerts M, van de Bovenkamp JHB, Morre SA, Manders MELM, Heddema ER. Evaluation of the Siemens VERSANT[REGISTERED] CT/GC DNA 1.0 assay (kPCR) for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Microbiol Methods. 2011;87(2):139-142. Exclusion code: 4. [pmid: 21925547].
Borborema-Alfaia APBd, Freitas NSdL, Astolfi Filho S, Borborema-Santos CM. Chlamydia trachomatis infection in a sample of northern Brazilian pregnant women: prevalence and prenatal importance. Braz J Infect Dis. 2013;17(5):545-550. Exclusion code: 5. [pmid: 23831212].
Borel N, Kempf E, Hotzel H, et al. Direct identification of chlamydiae from clinical samples using a DNA microarray assay: a validation study. Mol Cell Probes. 2008;22(1):55-64. Exclusion code: 3. [pmid: 17714911].
Borges-Costa J, Matos C, Pereira F. Sexually transmitted infections in pregnant adolescents: prevalence and association with maternal and foetal morbidity. J Eur Acad Dermatol Venereol. 2012;26(8):972-975. Exclusion code: 5. [pmid: 21797933].
Bott M, Bixby T, Castillo M. APTIMA Combo 2 analytical performance with C. trachomatis and N. gonorrhoeae. Kohl P, Jodl S, editors. Sexually Transmitted Infections. Bologna, Italy. Monduzzi Editore SPA. 2001:55-60. Exclusion code:Exclusion code: 7.
Bowden FJ, Currie MJ, Toyne H, et al. Screening for Chlamydia trachomatis at the time of routine Pap smear in general practice: a cluster randomised controlled trial. Med J Aust. 2008;188(2):76-80. Exclusion code: 5. [pmid: 18205578].
Bowden FJ, Tabrizi SN, Paterson BA, Garland SM, Fairley CK. Determination of genital human papillomavirus genotypes in women in Northern Australia using a novel, self-administered tampon technique. Int J Gynaecol Cancer. 1998;8(6):471-475. Exclusion code: 5.
Boyadzhyan B, Yashina T, Yatabe JH, Patnaik M, Hill CS. Comparison of the APTIMA CT and GC assays with the APTIMA combo 2 assay, the Abbott LCx assay, and direct fluorescent-antibody and culture assays for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2004;42(7):3089-3093. Exclusion code: 3. [pmid: 15243065].
Bozicevic I, Grgic I, Zidovec-Lepej S, et al. Urine-based testing for Chlamydia trachomatis among young adults in a population-based survey in Croatia: feasibility and prevalence. BMC Public Health. 2011;11:230. Exclusion code: 5. [pmid: 21489313].
Brabin L, Thomas G, Hopkins M, O'Brien K, Roberts SA. Delivery of chlamydia screening to young women requesting emergency hormonal contraception at pharmacies in Manchester, UK: a prospective study. BMC Womens Health. 2009;9:7. Exclusion code: 5. [pmid: 19323804].
Bracebridge S, Bachmann MO, Ramkhelawon K, Woolnough A. Evaluation of a systematic postal screening and treatment service for genital Chlamydia trachomatis, with remote clinic access via the internet: a cross-sectional study, East of England. Sex Transm Infect. 2012;88(5):375-381. Exclusion code: 10. [pmid: 22375045].
Bradley H, Satterwhite CL. Prevalence of Neisseria gonorrhoeae infections among men and women entering the National Job Training Program--United States, 2004-2009. Sex Transm Dis. 2012;39(1):49-54. Exclusion code: 2. [pmid: 22183847].
Braun RA, Provost JM. Bridging the gap: using school-based health services to improve chlamydia screening among young women. Am J Public Health. 2010;100(9):1624-1629. Exclusion code: 4. [pmid: 20634446].
Broad J, Cox T, Rodriguez S, et al. The impact of discontinuation of male STD screening services at a large urban county jail: Chicago, 2002-2004. Sex Transm Dis. 2009;36(2 Suppl):S49-52. Exclusion code: 2. [pmid: 19131909].
Brocklehurst P. Antibiotics for gonorrhoea in pregnancy. Cochrane database of systematic reviews (Online). 2002;(2). Exclusion code: 2.
Bromhead C, Miller A, Jones M, Whiley D. Comparison of the cobas 4800 CT/NG test with culture for detecting Neisseria gonorrhoeae in genital and nongenital specimens in a low-prevalence population in New Zealand. J Clin Microbiol. 2013;51(5):1505-1509. Exclusion code: 3. [pmid: 23467604].
Brugha R, Balfe M, Conroy RM, et al. Young adults' preferred options for receiving chlamydia screening test results: a cross-sectional survey of 6085 young adults. Int J STD AIDS. 2011;22(11):635-639. Exclusion code: 5. [pmid: 22096047].
Brugha R, Balfe M, Jeffares I, et al. Where do young adults want opportunistic chlamydia screening services to be located?. J Public Health (Oxf). 2011;33(4):571-578. Exclusion code: 5. [pmid: 21486871].
Bruine de Bruin W, Downs JS, Murray P, Fischhoff B. Can female adolescents tell whether they will test positive for Chlamydia infection?. Med Decis Making. 2010;30(2):189-193. Exclusion code: 5. [pmid: 19706879].
Buhrer-Skinner M, Muller R, Bialasiewicz S, et al. The check is in the mail: piloting a novel approach to Chlamydia trachomatis testing using self-collected, mailed specimen. Sex Health. 2009;6(2):163-169. Exclusion code: 5. [pmid: 19457297].
Buhrer-Skinner M, Muller R, Buettner PG, Gordon R, Debattista J. Improving Chlamydia trachomatis retesting rates by mailed self-collection kit. Sex Health. 2011;8(2):248-250. Exclusion code: 5. [pmid: 21592441].
Buhrer-Skinner M, Muller R, Menon A, Gordon R. Novel approach to an effective community-based chlamydia screening program within the routine operation of a primary healthcare service. Sex Health. 2009;6(1):51-56. Exclusion code: 5. [pmid: 19254492].
Burstein G, Jacobs A, Kissin D, Workowski K. Changes in the 2010 STD Treatment Guidelines What Adolescent Health Care Providers Should Know. 2010. The American Congress of Obstetricians and Gynecologists. http://www.acog.org/About-ACOG/ACOG-Departments/Adolescent-Health-Care/Changes-in-the-2010-STD-Treatment-Guidelines--What-Adolescent-Health-Care-Providers-Should-Know. 4 Dec, 2012. Exclusion code: 2.
Caan W. Preterm delivery in primiparous women at low risk: could epidemic chlamydia contribute to rise in preterm births?. BMJ. 2006;332(7549):1094. Exclusion code: 7. [pmid: 16675824].
Campbell R, Mills N, Sanford E, et al. Does population screening for Chlamydia trachomatis raise anxiety among those tested? Findings from a population based chlamydia screening study. BMC Public Health. 2006;6:106. Exclusion code: 2. [pmid: 16638147].
Cano S, Fuentes M, Ballesteros J, Clavo P, Menendez B, Del Romero J. Gonorrhea diagnoses in a center for sexually transmitted disease (STD) and their relationship with HIV and other STD, Madrid, 2005. Enferm Infecc Microbiol Clin. 2009;27(6):338-341. Exclusion code: 5. [pmid: 19427079].
Carder C, Mercey D, Benn P. Chlamydia trachomatis. Sex Transm Infect. Suppl 4. 2006;82:iv10-12. Exclusion code: 7. [pmid: 17151043].
Carre H, Lindstrom R, Boman J, Janlert U, Lundqvist L, Nylander E. Asking about condom use: a key to individualized care when screening for chlamydia. Int J STD AIDS. 2011;22(8):436-441. Exclusion code: 5. [pmid: 21795417].
Carvalho Gomes Hd, Velasco-Garrido M, Busse R. Screening on urogenital Chlamydia trachomatis. GMS Health Technology Assessment. 2005;1. http://www.ncbi.nlm.nih.gov/pmc/articles/PMC3011323/. Exclusion code: 6.
Cassell JA, Mercer CH, Fenton KA, et al. A comparison of the population diagnosed with chlamydia in primary care with that diagnosed in sexual health clinics: implications for a national screening programme. Public Health. 2006;120(10):984-988. Exclusion code: 5. [pmid: 16949114].
Castellsague X, Peeling RW, Franceschi S, et al. Chlamydia trachomatis infection in female partners of circumcised and uncircumcised adult men. Am J Epidemiol. 2005;162(9):907-916. Exclusion code: 4. [pmid: 16177149].
Centers for Disease C, Prevention. Chlamydia screening among sexually active young female enrollees of health plans--United States, 1999-2001. MMWR Morb Mortal Wkly Rep. 2004;53(42):983-985. Exclusion code: 7. [pmid: 15514579].
Centers for Disease C, Prevention. Chlamydia screening among sexually active young female enrollees of health plans--United States, 2000-2007. [Erratum appears in MMWR Morb Mortal Wkly Rep. 2009 Jun 12;58(22):623]. MMWR Morb Mortal Wkly Rep. 2009;58(14):362-365. Exclusion code: 7. [pmid: 19373196].
Centers for Disease C, Prevention. Clinic-based testing for rectal and pharyngeal Neisseria gonorrhoeae and Chlamydia trachomatis infections by community-based organizations--five cities, United States, 2007. MMWR Morb Mortal Wkly Rep. 2009;58(26):716-719. Exclusion code: 7. [pmid: 19590491].
Centers for Disease C, Prevention. CDC Grand Rounds: Chlamydia prevention: challenges and strategies for reducing disease burden and sequelae. MMWR Morb Mortal Wkly Rep. 2011;60(12):370-373. Exclusion code: 7. [pmid: 21451447].
Centers for Disease C, Prevention. Recall of LCx Neisseria gonorrhoeae Assay and Implicatons for Laboratory Testing for N. gonorrhoeae and Chlamydia trachomatis. MMWR. 2002;51(32):709. Exclusion code: 2. [pmid: 12206288].
Centers for Disease Control and Prevention. Male Chlamydia Screening Consultation. Atlanta, GA. March 28-29 2006. Exclusion code: 7.
Centers for Disease Control and Prevention. Sexually Transmitted Diseases Surveillance 2010. 2011. 2012. October. 18. http://www.cdc.gov/std/stats10/default.htm. Exclusion code: 2.
Centers for Disease Control and Prevention. Gonorrhea - CDC Fact Sheet. 2012. Department of Health and Human Services. Atlanta, GA. Available at: http://www.cdc.gov/std/gonorrhea/STDFact-Gonorrhea.htm. October 18, 2012. Exclusion code: 2.
Centers for Disease Control and Prevention. del Rio C, Hall G, et al. Update to CDC's sexually transmitted diseases treatment guidelines, 2010: Oral cephalosporins no longer a recommended treatment for gonococcal infections. MMWR Recomm Rep. 2012;61(31):590-594. Exclusion code: 2.
Centers for Disease Control and Prevention. Workowski KA, Berman SM. Sexually transmitted diseases treatment guidelines, 2006. MMWR Recomm Rep. 2006;55(RR-11):1-94. Exclusion code: 2. [pmid: 16888612].
Centers for Disease Control and Prevention. Workowski KA, Levine WC. Sexually Transmitted Disease Treatment Guidelines--2002. MMWR. 2002;51(RR06):1-80. Exclusion code: 2.
Chacko MR, Von Sternberg K, Velasquez MM. Gonorrhea and chlamydia screening in sexually active young women: the processes of change. J Adolesc Health. 2004;34(5):424-427. Exclusion code: 5. [pmid: 15093798].
Chacko MR, Wiemann CM, Smith PB. Chlamydia and gonorrhea screening in asymptomatic young women. J Pediatr Adolesc Gynecol. 2004;17(3):169-178. Exclusion code: 5. [pmid: 15125902].
Chai SJ, Aumakhan B, Barnes M, et al. Internet-based screening for sexually transmitted infections to reach nonclinic populations in the community: risk factors for infection in men. Sex Transm Dis. 2010;37(12):756-763. Exclusion code: 5. [pmid: 20644498].
Chandeying V, Lamlertkittikul S, Skov S. A comparison of first-void urine, self-administered low vaginal swab, self-inserted tampon, and endocervical swab using PCR tests for the detection of infection with Chlamydia trachomatis. Sex Health. 2004;1(1):51-54. Exclusion code: 3. [pmid: 16335296].
Chapin KC. Molecular tests for detection of the sexually-transmitted pathogens Neisseria gonorrhoeae and Chlamydia trachomatis. Med Health R I. 2006;89(6):202-204. Exclusion code: 7. [pmid: 16875007].
Chen CS, Baeumner AJ, Durst RA. Protein G-liposomal nanovesicles as universal reagents for immunoassays. Talanta. 2005;67(1):205-211. Exclusion code: 4. [pmid: 18970156].
Chen CS, Durst RA. Simultaneous detection of Escherichia coli O157:H7, Salmonella spp. and Listeria monocytogenes with an array-based immunosorbent assay using universal protein G-liposomal nanovesicles. Talanta. 2006;69(1):232-238. Exclusion code: 4. [pmid: 18970559].
Chen CS, Korobkova E, Chen H, et al. A proteome chip approach reveals new DNA damage recognition activities in Escherichia coli. Nat Methods. 2008;5(1):69-74. Exclusion code: 4. [pmid: 18084297].
Chen CS, Zhu H. Protein microarrays. Biotechniques. 2006;40(4):423. 425. 427. passim Exclusion code: 8. [pmid: 16629388].
Chen MY, Fairley CK, De Guingand D, et al. Screening pregnant women for chlamydia: what are the predictors of infection?. Sex Transm Infect. 2009;85(1):31-35. Exclusion code: 5. [pmid: 18708481].
Chen MY, Rohrsheim R, Donovan B. The differing profiles of symptomatic and asymptomatic Chlamydia trachomatis-infected men in a clinical setting. Int J STD AIDS. 2007;18(6):384-388. Exclusion code: 5. [pmid: 17609026].
Chen S, Li J, van den Hoek A. Universal screening or prophylactic treatment for Chlamydia trachomatis infection among women seeking induced abortions: which strategy is more cost-effective?. Sex Transm Dis. 2007;34(4):230-236. Exclusion code: 6. [pmid: 17414068].
Cheney K, Wray L. Chlamydia and associated factors in an under 20s antenatal population. Aust N Z J Obstet Gynaecol. 2008;48(1):40-43. Exclusion code: 6. [pmid: 18275570].
Cheng A, Kirby JE. Evaluation of the Hologic gen-probe PANTHER, APTIMA Combo 2 assay in a tertiary care teaching hospital. Am J Clin Pathol. 2014;141(3):397-403. Exclusion code: 4. [pmid: 24515768].
Cheng A, Qian Q, Kirby JE. Evaluation of the Abbott RealTime CT/NG assay in comparison to the Roche Cobas Amplicor CT/NG assay. J Clin Microbiol. 2011;49(4):1294-1300. Exclusion code: 3. [pmid: 21325546].
Chernesky M, Castriciano S, Jang D, Smieja M. Use of flocked swabs and a universal transport medium to enhance molecular detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2006;44(3):1084-1086. Exclusion code: 4. [pmid: 16517899].
Chernesky M, Castriciano S, Sellors J, et al. Detection of Chlamydia trachomatis antigens in urine as an alternative to swabs and cultures. J Infect Dis. 1990;161(1):124-126. Exclusion code: 3. [pmid: 2404073].
Chernesky M, Freund GG, Hook E 3rd, Leone P, D'Ascoli P, Martens M. Detection of Chlamydia trachomatis and Neisseria gonorrhoeae infections in North American women by testing SurePath liquid-based Pap specimens in APTIMA assays. J Clin Microbiol. 2007;45(8):2434-2438. Exclusion code: 4. [pmid: 17581931].
Chernesky M, Jang D, Luinstra K, et al. High analytical sensitivity and low rates of inhibition may contribute to detection of Chlamydia trachomatis in significantly more women by the APTIMA Combo 2 assay. J Clin Microbiol. 2006;44(2):400-405. Exclusion code: 3. [pmid: 16455891].
Chernesky M, Jang D, Portillo E, et al. Abilities of APTIMA, AMPLICOR, and ProbeTec assays to detect Chlamydia trachomatis and Neisseria gonorrhoeae in PreservCyt ThinPrep Liquid-based Pap samples. J Clin Microbiol. 2007;45(8):2355-2358. Exclusion code: 4. [pmid: 17537943].
Chernesky M, Jang D, Portillo E, et al. Comparison of three assays for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in SurePath Pap samples and the role of pre- and postcytology testing. J Clin Microbiol. 2012;50(4):1281-1284. Exclusion code: 4. [pmid: 22259215].
Chernesky M, Jang D, Smieja M, et al. Validation of the APTIMA Combo 2 assay for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in SurePath liquid-based pap test samples taken with different collection devices. Sex Transm Dis. 2009;36(9):581-583. Exclusion code: 4. [pmid: 19661842].
Chernesky MA, Hook EW 3rd, Martin DH, et al. Women find it easy and prefer to collect their own vaginal swabs to diagnose Chlamydia trachomatis or Neisseria gonorrhoeae infections. Sex Transm Dis. 2005;32(12):729-733. Exclusion code: 5. [pmid: 16314768].
Chernesky MA, Jang DE. APTIMA transcription-mediated amplification assays for Chlamydia trachomatis and Neisseria gonorrhoeae. Expert Rev Mol Diagn. 2006;6(4):519-525. Exclusion code: 7. [pmid: 16824026].
Chesson HW, Bernstein KT, Gift TL, Marcus JL, Pipkin S, Kent CK. The cost-effectiveness of screening men who have sex with men for rectal chlamydial and gonococcal infection to prevent HIV Infection. Sex Transm Dis. 2013;40(5):366-371. Exclusion code: 5. [pmid: 23588125].
Chiaradonna C. The Chlamydia cascade: enhanced STD prevention strategies for adolescents. J Pediatr Adolesc Gynecol. 2008;21(5):233-241. Exclusion code: 7. [pmid: 18794017].
Chidambaram JD, Melese M, Alemayehu W, et al. Mass antibiotic treatment and community protection in trachoma control programs. Clin Infect Dis. 2004;39(9):e95-97. Exclusion code: 3. [pmid: 15494901].
Chojnacka K, Szczapa J, Kedzia W. Perinatal transmission of Chlamydia trachomatis and its complication in preterm infants. Ginekol Pol. 2012;83(2):116-121. Exclusion code: 8. [pmid: 22568356].
Chow JM. Measuring the uptake and impact of Chlamydia screening programs--easier said than done. Sex Transm Dis. 2012;39(2):89-91. Exclusion code: 7. [pmid: 22249295].
Chrisoulidou A, Goulis DG, Iliadou PK, et al. Acute and chronic Chlamydia pneumoniae infection in pregnancy complicated with preeclampsia. Hypertens. 2011;30(2):164-168. Exclusion code: 5.
Church DL, Amante L, Semeniuk H, Gregson DB. Selective testing of women based on age for genital Chlamydia trachomatis and Neisseria gonorrhoeae infection in a centralized regional microbiology laboratory. Diagn Microbiol Infect Dis. 2007;57(4):379-385. Exclusion code: 5. [pmid: 17240104].
Clarke J, White KAJ, Turner K. Exploring short-term responses to changes in the control strategy for Chlamydia trachomatis. Comput. 2012;2012:803097. Exclusion code: 6.
Coble BI, Nordahl-Akesson E, Vinnerberg A, Kihlstrom E. Urine-based testing for Chlamydia trachomatis using polymerase chain reaction, leucocyte esterase and urethral and cervical smears. Scand J Clin Lab Invest. 2006;66(4):269-277. Exclusion code: 3. [pmid: 16777755].
Cohen DA, Nsuami M, Martin DH, Farley TA. Repeated school-based screening for sexually transmitted diseases: a feasible strategy for reaching adolescents. Pediatrics. 1999;104(6):1281-1285. Exclusion code: 10. [pmid: 10585978].
Cook RL, Ostergaard L, Hillier SL, et al. Home screening for sexually transmitted diseases in high-risk young women: randomised controlled trial. Sex Transm Infect. 2007;83(4):286-291. Exclusion code: 3. [pmid: 17301105].
Cornetta MdCdM, Goncalves AKdS, Bertini AM. Efficacy of cytology for the diagnosis of Chlamydia trachomatis in pregnant women. Braz J Infect Dis. 2006;10(5):337-340. Exclusion code: 5. [pmid: 17293922].
Cosentino LA, Campbell T, Jett A, et al. Use of nucleic acid amplification testing for diagnosis of anorectal sexually transmitted infections. J Clin Microbiol. 2012;50(6):2005-2008. Exclusion code: 4. [pmid: 22493338].
Costa AM, Fairley CK, Garland SM, Tabrizi SN. Evaluation of self-collected urine dip swab method for detection of Chlamydia trachomatis. Sex Health. 2009;6(3):213-216. Exclusion code: 3. [pmid: 19653958].
Coughlan E, Bagshaw S. Chlamydia--the problem that just won't go away. N Z Med J. 2005;118(1220):U1605. Exclusion code: 7. [pmid: 16132067].
Coughlan E, Young S. Screening for pharyngeal Chlamydia trachomatis in asymptomatic men who have sex with men. N Z Med J. 2006;119(1232):U1948. Exclusion code: 6. [pmid: 16633402].
Coulson R, Rao N, Freeman M. Disseminated GC infection without urogenital symptoms. Jaapa. 2007;20(9):29-31. Exclusion code: 6. [pmid: 17902539].
Creighton S, Revell B, Barrow A. Concordance between nucleic acid amplification technique and culture for the diagnosis of gonorrhoea. Int J STD AIDS. 2009;20(5):358-359. Exclusion code: 3. [pmid: 19386976].
Crouch SR. Opportunistic evidence: evidence-based policy in the setting of the Australian Government's chlamydia screening pilot. Aust Health Rev. 2012;36(1):57-60. Exclusion code: 4. [pmid: 22513021].
Crucitti T, De Deken B, Smet H, Cuylaerts V, Abdellati S, Vuylsteke B. Evaluation of the APTIMA Combo 2 Assay using self-administered vaginal swabs for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae. Diagn Microbiol Infect Dis. 2013;76(3):385-386. Exclusion code: 3. [pmid: 23598167].
Culler EE, Caliendo AM, Nolte FS. Reproducibility of positive test results in the BDProbeTec ET system for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2003;41(8):3911-3914. Exclusion code: 5. [pmid: 12904416].
Curran G. Universal antenatal chlamydia screening by rural midwives. Aust Nurs J. 2012;19(7):30-32. Exclusion code: 7. [pmid: 22390013].
Currie MJ, McNiven M, Yee T, Schiemer U, Bowden FJ. Pooling of clinical specimens prior to testing for Chlamydia trachomatis by PCR is accurate and cost saving. J Clin Microbiol. 2004;42(10):4866-4867. Exclusion code: 4. [pmid: 15472365].
Currie MJ, Schmidt M, Davis BK, et al. ‘Show me the money’: financial incentives increase chlamydia screening rates among tertiary students: a pilot study. Sex Health. 2010;7(1):60-65. Exclusion code: 4. [pmid: 20152098].
Dabrera G, Pinson D, Whiteman S. Chlamydia screening by community pharmacists: a qualitative study. J Fam Plann Reprod Health Care. 2011;37(1):17-21. Exclusion code: 3. [pmid: 21367698].
Dabrera G, Pinson D, Whiteman S. Missed opportunities for chlamydia screening by community pharmacists. Sex Health. 2012;9(3):297. Exclusion code: 6. [pmid: 22697148].
Dadamessi I, Eb F, Betsou F. Combined detection of Chlamydia trachomatis-specific antibodies against the 10 and 60-kDa heat shock proteins as a diagnostic tool for tubal factor infertility: Results from a case-control study in Cameroon. FEMS Immunol Med Microbiol. 2005;45(1):31-35. Exclusion code: 5. [pmid: 15985220].
Dajek Z, Seliborska Z, Wiecko-Jankowska E. Assessment of direct fluorescent antibody technique in detecting Chlamydia trachomatis in sexually transmitted infections clinics. Med Wieku Rozwoj. 2005;9(1):111-115. Exclusion code: 4. [pmid: 16082072].
Das S, Sabin C, Allan S. Higher vaginal pH is associated with Chlamydia trachomatis infection in women: a prospective case-controlled study. Int J STD AIDS. 2005;16(4):290-293. Exclusion code: 5. [pmid: 15899081].
Das S, Sabin C, Wade A, Allan S. Sociodemography of genital co-infection with Neisseria gonorrhoeae and Chlamydia trachomatis in Coventry, UK. Int J STD AIDS. 2005;16(4):318-322. Exclusion code: 5. [pmid: 15899087].
Datta SD, Sternberg M, Johnson RE, et al. Gonorrhea and Chlamydia in the United States among Persons 14 to 39 Years of Age, 1999 to 2002. Ann Intern Med. 2007;147(2):89-96. Exclusion code: 2. [pmid: 17638719].
Datta SD, Torrone E, Kruszon-Moran D, et al. Chlamydia trachomatis Trends in the United States Among Persons 14 to 39 Years of Age, 1999–2008. Sex Transm Dis. 2012;39(2):92-96. Exclusion code: 2. [pmid: 22249296].
Davies SC, Shepherd B, Wiig R, Kaan I. Unsupervised screening for chlamydia and gonorrhoea in backpacker hostels in Manly, Sydney. Sex Health. 2013;10(2):185-187. Exclusion code: 4. [pmid: 23158843].
De Backer E, Verhelst R, Verstraelen H, et al. Quantitative determination by real-time PCR of four vaginal Lactobacillus species, Gardnerella vaginalis and Atopobium vaginae indicates an inverse relationship between L. gasseri and L. iners. BMC Microbiol. 2007;7:115. Exclusion code: 3. [pmid: 18093311].
De Martino SJ, de Barbeyrac B, Piemont Y, Barthel C, Monteil H, Jaulhac B. Detection of Chlamydia trachomatis DNA using MagNA Pure DNA extraction and Cobas Amplicor CT/NG amplification. Clin Microbiol Infect. 2006;12(6):576-579. Exclusion code: 4. [pmid: 16700708].
de Silva T, Kudesia G, Joall A, Whittaker D, Davies S, Ryan C. Significance of low positive scores obtained with a method other than acceleration in the BDProbeTec-Strand displacement amplification test for detection of Neisseria gonorrhoeae. J Clin Microbiol. 2006;44(12):4628-4629. Exclusion code: 5. [pmid: 17035486].
de Vries HJC, Smelov V, Ouburg S, et al. Anal lymphogranuloma venereum infection screening with IgA anti-Chlamydia trachomatis-specific major outer membrane protein serology. Sex Transm Dis. 2010;37(12):789-795. Exclusion code: 5. [pmid: 20625350].
de Vries HJC, van der Bij AK, Fennema JSA, et al. Lymphogranuloma venereum proctitis in men who have sex with men is associated with anal enema use and high-risk behavior. Sex Transm Dis. 2008;35(2):203-208. Exclusion code: 5. [pmid: 18091565].
de Vries R, van Bergen JEAM, de Jong-van den Berg LTW, Postma MJ, Group PCS. Systematic screening for Chlamydia trachomatis: estimating cost-effectiveness using dynamic modeling and Dutch data. Value Health. 2006;9(1):1-11. Exclusion code: 5. [pmid: 16441519].
Dean D, Turingan RS, Thomann HU, et al. A multiplexed microfluidic PCR assay for sensitive and specific point-of-care detection of Chlamydia trachomatis. PLoS ONE. 2012;7(12):e51685. Exclusion code: 4. [pmid: 23272140].
Deluca GD, Marin HM, Schelover E, et al. Chlamydia trachomatis and papillomavirus infection in women with cytohistological abnormalities in uterine cervix. Medicina (B Aires). 2006;66(4):303-306. Exclusion code: 5. [pmid: 16977964].
den Hartog JE, Land JA, Stassen FRM, Kessels AGH, Bruggeman CA. Serological markers of persistent C. trachomatis infections in women with tubal factor subfertility. Hum Reprod. 2005;20(4):986-990. Exclusion code: 5. [pmid: 15640255].
Dicker LW, Mosure DJ, Kay RS, Shelby L, Cheek JE, Region VIPP. An ongoing burden: chlamydial infections among young American Indian women. Matern Child Health J. Suppl 1. 2008;12:25-29. Exclusion code: 5. [pmid: 17968641].
DiClemente RJ, Wingood GM, Rose ES, et al. Efficacy of sexually transmitted disease/human immunodeficiency virus sexual risk-reduction intervention for african american adolescent females seeking sexual health services: a randomized controlled trial. Arch Pediatr Adolesc Med. 2009;163(12):1112-1121. Exclusion code: 4. [pmid: 19996048].
Dietrich W, Rath M, Stanek G, Apfalter P, Huber JC, Tempfer C. Multiple site sampling does not increase the sensitivity of Chlamydia trachomatis detection in infertility patients. Fertil Steril. 2010;93(1):68-71. Exclusion code: 3. [pmid: 18990379].
Dize L, Agreda P, Quinn N, Barnes MR, Hsieh YH, Gaydos CA. Comparison of self-obtained penile-meatal swabs to urine for the detection of C. trachomatis, N. gonorrhoeae and T. vaginalis. Sex Transm Infect. 2013;89(4):305-307. Exclusion code: 4. [pmid: 23093735].
Dodge B, Van Der Pol B, Rosenberger JG, et al. Field collection of rectal samples for sexually transmitted infection diagnostics among men who have sex with men. Int J STD AIDS. 2010;21(4):260-264. Exclusion code: 5. [pmid: 20378897].
Doherty IA, Adimora AA, Schoenbach VJ, Aral SO. Correlates of gonorrhoea among African Americans in North Carolina. Int J STD AIDS. 2007;18(2):114-117. Exclusion code: 5. [pmid: 17331284].
Domeika M, Oscarsson L, Hallen A, Hjelm E, Sylvan S. Mailed urine samples are not an effective screening approach for Chlamydia trachomatis case finding among young men. J Eur Acad Dermatol Venereol. 2007;21(6):789-794. Exclusion code: 5. [pmid: 17567309].
Donaldson AA, Burns J, Bradshaw CP, Ellen JM, Maehr J. Screening juvenile justice-involved females for sexually transmitted infection: a pilot intervention for urban females in community supervision. J. 2013;19(4):258-268. Exclusion code: 6.
Doseeva V, Forbes T, Wolff J, et al. Multiplex isothermal helicase-dependent amplification assay for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. Diagn Microbiol Infect Dis. 2011;71(4):354-365. Exclusion code: 10. [pmid: 22000085].
Downey L, Tyree PT, Lafferty WE. Preventive screening of women who use complementary and alternative medicine providers. J Womens Health (Larchmt). 2009;18(8):1133-1143. Exclusion code: 4. [pmid: 19630554].
Du P, Lemkin A, Kluhsman B, et al. The roles of social domains, behavioral risk, health care resources, and chlamydia in spatial clusters of US cervical cancer mortality: not all the clusters are the same. Cancer Causes Control. 2010;21(10):1669-1683. Exclusion code: 5. [pmid: 20532608].
Durber L, Oakeshott P, Prime K, Hay P. Chlamydia screening in non-clinical settings. Int J STD AIDS. 2010;21(6):449-450. Exclusion code: 5. [pmid: 20606230].
Edwards JL, Apicella MA. The molecular mechanisms used by Neisseria gonorrhoeae to initiate infection differ between men and women. Clin Microbiol Rev. 2004;17(4):965-981. Exclusion code: 2. [pmid: 15489357].
Eugene JM, Hoover KW, Tao G, Kent CK. Higher yet suboptimal chlamydia testing rates at community health centers and outpatient clinics compared with physician offices. Am J Public Health. 2012;102(8):e26-29. Exclusion code: 5. [pmid: 22698048].
Evans C, Das C, Kinghorn G. A retrospective study of recurrent chlamydia infection in men and women: is there a role for targeted screening for those at risk?. Int J STD AIDS. 2009;20(3):188-192. Exclusion code: 10. [pmid: 19255268].
Fairley CK, Chen MY, Bradshaw CS, Tabrizi SN. Is it time to move to nucleic acid amplification tests screening for pharyngeal and rectal gonorrhoea in men who have sex with men to improve gonorrhoea control?. Sex Health. 2011;8(1):9-11. Exclusion code: 7. [pmid: 21371376].
Fairley CK, Chen S, Tabrizi S, Quinn M, Garland S. Influence of quartile of menstrual cycle on pellet volume of specimens from tampons and isolation of human papillomavirus. J Infect Dis. 1992;166(5):1199-1200. Exclusion code: 5. [pmid: 1328407].
Fairley CK, Chen S, Tabrizi SN, Leeton K, Quinn MA, Garland SM. The absence of genital human papillomavirus DNA in virginal women. Int J STD AIDS. 1992;3(6):414-417. Exclusion code: 3. [pmid: 1337472].
Fairley CK, Chen S, Tabrizi SN, Quinn MA, McNeil JJ, Garland SM. Tampons: a novel patient-administered method for the assessment of genital human papillomavirus infection. J Infect Dis. 1992;165(6):1103-1106. Exclusion code: 5. [pmid: 1316411].
Falk L, Coble BI, Mjornberg PA, Fredlund H. Sampling for Chlamydia trachomatis infection - a comparison of vaginal, first-catch urine, combined vaginal and first-catch urine and endocervical sampling. Int J STD AIDS. 2010;21(4):283-287. Exclusion code: 11. [pmid: 20378903].
Falk L, Fredlund H, Jensen JS. Symptomatic urethritis is more prevalent in men infected with Mycoplasma genitalium than with Chlamydia trachomatis. Sex Transm Infect. 2004;80(4):289-293. Exclusion code: 5. [pmid: 15295128].
Fang J, Husman C, DeSilva L, Chang R, Peralta L. Evaluation of self-collected vaginal swab, first void urine, and endocervical swab specimens for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in adolescent females. J Pediatr Adolesc Gynecol. 2008;21(6):355-360. Exclusion code: 3. [pmid: 19064231].
Farrell DJ. Evaluation of AMPLICOR Neisseria gonorrhoeae PCR using cppB nested PCR and 16S rRNA PCR. J Clin Microbiol. 1999;37(2):386-390. Exclusion code: 3. [pmid: 9889224].
Fedorova VA, Bannikova VA, Alikberov SA, Eliseev II, Grashkin VA. Comparative efficiency of detection of the causative agent of urogenital chlamydiasis by immunofluorescence, polymerase chain reaction, and dot immunoassay. Klin Lab Diagn. 2007;(7):30-35. Exclusion code: 8. [pmid: 17802805].
Filipp E, Raczynski P, El Midaoui A, et al. Chlamydia trachomatis infection in sexually active adolescents and young women. Med Wieku Rozwoj. 2005;9(1):57-64. Exclusion code: 5. [pmid: 16082066].
Finan RR, Musharrafieh U, Almawi WY. Detection of Chlamydia trachomatis and herpes simplex virus type 1 or 2 in cervical samples in human papilloma virus (HPV)-positive and HPV-negative women. Clin Microbiol Infect. 2006;12(9):927-930. Exclusion code: 3. [pmid: 16882302].
Fine D, Dicker L, Mosure D, Berman S, Region XIPP. Increasing chlamydia positivity in women screened in family planning clinics: do we know why?. Sex Transm Dis. 2008;35(1):47-52. Exclusion code: 5. [pmid: 17700377].
Fine D, Thomas KK, Nakatsukasa-Ono W, Marrazzo J. Chlamydia positivity in women screened in family planning clinics: racial/ethnic differences and trends in the northwest U.S., 1997-2006. Public Health Rep. 2012;127(1):38-51. Exclusion code: 5. [pmid: 22298921].
Fisman DN, Spain CV, Salmon ME, Goldberg M. The Philadelphia High-School STD Screening Program: key insights from dynamic transmission modeling. Sex Transm Dis. 2008;35(11 Suppl):S61-65. Exclusion code: 6. [pmid: 18607306].
Forbes KM, Vaze U, Wheeler HL. Rationalization of microscopy in the detection of Neisseria gonorrhoeae in women. Int J STD AIDS. 2007;18(10):705-706. Exclusion code: 4. [pmid: 17945050].
Ford CA, Pence BW, Miller WC, et al. Predicting adolescents' longitudinal risk for sexually transmitted infection: results from the National Longitudinal Study of Adolescent Health. Arch Pediatr Adolesc Med. 2005;159(7):657-664. Exclusion code: 5. [pmid: 15997000].
Ford CA, Viadro CI, Miller WC. Testing for chlamydial and gonorrheal infections outside of clinic settings: a summary of the literature. Sex Transm Dis. 2004;31(1):38-51. Exclusion code: 4. [pmid: 14695957].
Forni J, Miles K, Hamill M. Microscopy detection of rectal gonorrhoea in asymptomatic men. Int J STD AIDS. 2009;20(11):797-798. Exclusion code: 4. [pmid: 19833693].
Forsbach-Birk V, Simnacher U, Pfrepper KI, et al. Identification and evaluation of a combination of chlamydial antigens to support the diagnosis of severe and invasive Chlamydia trachomatis infections. Clin Microbiol Infect. 2010;16(8):1237-1244. Exclusion code: 5. [pmid: 19723133].
Forslin L, Kamwendo F, Bodin L, Danielsson D. The Chlamydia infection epidemic threatens women's reproductive health. A longitudinal study points out the need of effective strategy to break the trend. Lakartidningen. 2006;103(39):2848-2853. Exclusion code: 8. [pmid: 17128917].
Foulkes HBS, Pettigrew MM, Livingston KA, Niccolai LM. Comparison of sexual partnership characteristics and associations with inconsistent condom use among a sample of adolescents and adult women diagnosed with Chlamydia trachomatis. J Womens Health (Larchmt). 2009;18(3):393-399. Exclusion code: 3. [pmid: 19245304].
Fowler T, Caley M, Johal R, Brown R, Ross JDC. Previous history of gonococcal infection as a risk factor in patients presenting with gonorrhoea. Int J STD AIDS. 2010;21(4):277-278. Exclusion code: 5. [pmid: 20378901].
Fowler T, Edeghere O, Inglis N, Bradshaw S. Estimating the positive predictive value of opportunistic population testing for gonorrhoea as part of the English Chlamydia Screening Programme. Int J STD AIDS. 2013;24(3):185-191. Exclusion code: 10. [pmid: 23514834].
Franklin WB, Katyal M, Mahajan R, Parvez FM. Chlamydia and gonorrhea screening using urine-based nucleic acid amplification testing among males entering New York City jails: a pilot study. J. 2012;18(2):120-130. Exclusion code: 10.
Fredlund H, Falk L, Jurstrand M, Unemo M. Molecular genetic methods for diagnosis and characterisation of Chlamydia trachomatis and Neisseria gonorrhoeae: impact on epidemiological surveillance and interventions. Apmis. 2004;112(11-12):771-784. Exclusion code: 7. [pmid: 15638837].
Freeman AH, Bernstein KT, Kohn RP, Philip S, Rauch LM, Klausner JD. Evaluation of self-collected versus clinician-collected swabs for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae pharyngeal infection among men who have sex with men. Sex Transm Dis. 2011;38(11):1036-1039. Exclusion code: 4. [pmid: 21992980].
Friedek D, Ekiel A, Chelmicki Z, Romanik M. HPV, Chlamydia trachomatis and genital mycoplasmas infections in women with low-grade squamous intraepithelial lesions (LSIL). Ginekol Pol. 2004;75(6):457-463. Exclusion code: 8. [pmid: 15524422].
Friedek D, Ekiel A, Romanik M, Chelmicki Z, Chelmicki A, Martirosian G. Chlamydia trachomatis and human papillomavirus (HPV) infections in teenage sexually active girls. Ginekol Pol. 2005;76(11):879-883. Exclusion code: 8. [pmid: 16566362].
Fruchtman Y, Greenberg D, Shany E, Melamed R, Peled N, Lifshitz M. Ophthalmia neonatorum caused by multidrug-resistant Neisseria gonorrhoeae. Isr Med Assoc J. 2004;6(3):180-181. Exclusion code: 3. [pmid: 15055278].
Garland SM, Tabrizi S, Hallo J, Chen S. Assessment of Chlamydia trachomatis prevalence by PCR and LCR in women presenting for termination of pregnancy. Sex Transm Infect. 2000;76(3):173-176. Exclusion code: 3. [pmid: 10961192].
Garland SM, Tabrizi SN. Diagnosis of sexually transmitted infections (STI) using self-collected non-invasive specimens. Sex Health. 2004;1(2):121-126. Exclusion code: 12. [pmid: 16334994].
Garland SM, Tabrizi SN, Chen S, Byambaa C, Davaajav K. Prevalence of sexually transmitted infections (Neisseria gonorrhoeae, Chlamydia trachomatis, Trichomonas vaginalis and human papillomavirus) in female attendees of a sexually transmitted diseases clinic in Ulaanbaatar, Mongolia. Infect Dis Obstet Gynecol. 2001;9(3):143-146. Exclusion code: 5. [pmid: 11516062].
Garland SM, Tabrizi SN, Fairley CK, Bowden FJ. Tampons could be used to diagnose sexually transmitted diseases. BMJ. 2001;322(7287):676. Exclusion code: 7. [pmid: 11291656].
Garrow SC, Smith DW, Harnett GB. The diagnosis of chlamydia, gonorrhoea, and trichomonas infections by self obtained low vaginal swabs, in remote northern Australian clinical practice. Sex Transm Infect. 2002;78(4):278-281. Exclusion code: 3. [pmid: 12181467].
Garvey LJ, Roberts C, Smith A. Confirmed new HIV diagnoses in men who have sex with men after episodes of rectal gonorrhoea. Int J STD AIDS. 2009;20(2):144. Exclusion code: 5. [pmid: 19182068].
Gaydos CA. Nucleic acid amplification tests for gonorrhea and chlamydia: practice and applications. Infect Dis Clin North. 2005;19(2):367-386. Exclusion code: 2.
Gaydos CA, Barnes M, Aumakhan B, et al. Chlamydia trachomatis age-specific prevalence in women who used an internet-based self-screening program compared to women who were screened in family planning clinics. Sex Transm Dis. 2011;38(2):74-78. Exclusion code: 5. [pmid: 21173720].
Gaydos CA, Barnes M, Dwyer K. Use of an internet program to facilitate screening for Chlamydia trachomatis. Proc American Society of Microbiology 105th General Meeting. 2005. Exclusion code: 7.
Gaydos CA, Cartwright CP, Colaninno P, et al. Performance of the Abbott RealTime CT/NG for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2010;48(9):3236-3243. Exclusion code: 3. [pmid: 20668135].
Gaydos CA, Crotchfelt KA, Shah N, et al. Evaluation of dry and wet transported intravaginal swabs in detection of Chlamydia trachomatis and Neisseria gonorrhoeae infections in female soldiers by PCR. J Clin Microbiol. 2002;40(3):758-761. Exclusion code: 4. [pmid: 11880389].
Gaydos CA, Dwyer K, Barnes M, et al. Internet-based screening for Chlamydia trachomatis to reach non-clinic populations with mailed self-administered vaginal swabs. [Erratum appears in Sex Transm Dis. 2007 Aug;34(8):625]. Sex Transm Dis. 2006;33(7):451-457. Exclusion code: 4. [pmid: 16652069].
Gaydos CA, Farshy C, Barnes M, et al. Can mailed swab samples be dry-shipped for the detection of Chlamydia trachomatis, Neisseria gonorrhoeae, and Trichomonas vaginalis by nucleic acid amplification tests?. Diagn Microbiol Infect Dis. 2012;73(1):16-20. Exclusion code: 5. [pmid: 22578934].
Gaydos CA, McKee KT Jr., Quinn TC, Gaydos JC. Prevalence of chlamydial and gonococcal infections among young adults. [Erratum appears in JAMA. 2004 Oct 13;292(14):1686]. Jama. 2004;292(7):801. author reply 801-802. Exclusion code: 7. [pmid: 15315990].
Gaydos CA, Rizzo-Price PA, Barnes M, Dwyer K, Wood BJ, Hogan MT. The use of focus groups to design an internet-based program for chlamydia screening with self-administered vaginal swabs: what women want. Sex Health. 2006;3(4):209-215. Exclusion code: 5. [pmid: 17112429].
Gaydos CA, Theodore M, Dalesio N, Wood BJ, Quinn TC. Comparison of three nucleic acid amplification tests for detection of Chlamydia trachomatis in urine specimens. J Clin Microbiol. 2004;42(7):3041-3045. Exclusion code: 3. [pmid: 15243057].
Gaydos CA, Wright C, Wood BJ, Waterfield G, Hobson S, Quinn TC. Chlamydia trachomatis reinfection rates among female adolescents seeking rescreening in school-based health centers. Sex Transm Dis. 2008;35(3):233-237. Exclusion code: 3. [pmid: 18490866].
Geelen TH, Rossen JW, Beerens AM, et al. Performance of cobas 4800 and m2000 real-time assays for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in rectal and self-collected vaginal specimen. Diagnostic microbiology and infectious disease. 2013;77(2):101-105. Exclusion code: 3. [pmid: 23891224].
Geertsen R, Friderich P, Dobec M, Emler S. Evaluation of an automated extraction method for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae by Cobas Amplicor PCR from different sample materials. Scand J Infect Dis. 2007;39(5):405-408. Exclusion code: 4. [pmid: 17464862].
Geisler WM. Duration of untreated, uncomplicated Chlamydia trachomatis genital infection and factors associated with chlamydia resolution: a review of human studies. J Infect Dis. Suppl 2. 2010;201:S104-113. Exclusion code: 7. [pmid: 20470048].
Geisler WM. Diagnosis and management of uncomplicated Chlamydia trachomatis infections in adolescents and adults: summary of evidence reviewed for the 2010 Centers for Disease Control and Prevention Sexually Transmitted Diseases Treatment Guidelines. Clin Infect Dis. Suppl 3. 2011;53:S92-98. Exclusion code: 7. [pmid: 22080274].
Geisler WM, Chyu L, Kusunoki Y, Upchurch DM, Hook EW 3rd. Health insurance coverage, health care-seeking behaviors, and genital chlamydial infection prevalence in sexually active young adults. Sex Transm Dis. 2006;33(6):389-396. Exclusion code: 5. [pmid: 16505745].
Geisler WM, Tang J, Wang C, Wilson CM, Kaslow RA. Epidemiological and genetic correlates of incident Chlamydia trachomatis infection in North American adolescents. J Infect Dis. 2004;190(10):1723-1729. Exclusion code: 3. [pmid: 15499525].
Geraats-Peters CWM, Brouwers M, Schneeberger PM, et al. Specific and sensitive detection of Neisseria gonorrhoeae in clinical specimens by real-time PCR. J Clin Microbiol. 2005;43(11):5653-5659. Exclusion code: 3. [pmid: 16272500].
Ghanem KG, Koumans EH, Johnson RE, et al. Effect of specimen order on Chlamydia trachomatis and Neisseria gonorrhoeae test performance and adequacy of Papanicolaou smear. J Pediatr Adolesc Gynecol. 2006;19(1):23-30. Exclusion code: 4. [pmid: 16472725].
Ghanem M, Radcliffe K, Allan P. The role of urethral samples in the diagnosis of gonorrhoea in women. Int J STD AIDS. 2004;15(1):45-47. Exclusion code: 4. [pmid: 14769171].
Giertz G, Kallings I, Nordenvall M, Fuchs T. A prospective study of Chlamydia trachomatis infection following legal abortion. Acta Obstet Gynecol Scand. 1987;66(2):107-109. Exclusion code: 3. [pmid: 3618133].
Gift TL, Gaydos CA, Kent CK, et al. The program cost and cost-effectiveness of screening men for Chlamydia to prevent pelvic inflammatory disease in women. Sex Transm Dis. 2008;35(11 Suppl):S66-75. Exclusion code: 6. [pmid: 18830137].
Glass N, Nelson HD, Villemyer K. Screening for Gonorrhea: Update of the Evidence. Rockville, MD. Quality AfHRa. 2005. Exclusion code: 2.
Gokral JS, Mania-Pramanik J, Meherji PK, Mali BN. Introital swab testing for Chlamydia trachomatis in a resource-poor setting: an Indian perspective. Int J Fertil Womens Med. 2005;50(3):140-143. Exclusion code: 3. [pmid: 16279508].
Golden MR, Hughes JP, Cles LE, et al. Positive predictive value of Gen-Probe APTIMA Combo 2 testing for Neisseria gonorrhoeae in a population of women with low prevalence of N. gonorrhoeae infection. Clin Infect Dis. 2004;39(9):1387-1390. Exclusion code: 3. [pmid: 15494917].
Goldenberg SD, Finn J, Sedudzi E, White JA, Tong CYW. Performance of the GeneXpert CT/NG assay compared to that of the Aptima AC2 assay for detection of rectal Chlamydia trachomatis and Neisseria gonorrhoeae by use of residual Aptima Samples. J Clin Microbiol. 2012;50(12):3867-3869. Exclusion code: 4. [pmid: 22993183].
Golparian D, Tabrizi SN, Unemo M. Analytical specificity and sensitivity of the APTIMA Combo 2 and APTIMA GC assays for detection of commensal Neisseria species and Neisseria gonorrhoeae on the Gen-Probe Panther instrument. Sex Transm Dis. 2013;40(2):175-178. Exclusion code: 3. [pmid: 23324980].
Gopal Rao G, Bacon L, Evans J, et al. Can culture confirmation of gonococcal infection be improved in female subjects found to be positive by nucleic acid amplification tests in community clinics?. Sex Transm Infect. 2009;85(7):531-533. Exclusion code: 3. [pmid: 19703846].
Gorbunov EF, Tsinzerling VA, Semenov NV. Characteristics of perinatal visceral lesions caused by chlamydia trachomatis. Arkh Patol. 2007;69(3):33-36. Exclusion code: 8. [pmid: 17722593].
Gorgos L, Fine D, Marrazzo J. Chlamydia positivity in American Indian/Alaska Native women screened in family planning clinics, 1997-2004. Sex Transm Dis. 2008;35(8):753-757. Exclusion code: 5. [pmid: 18449068].
Gorozpe Calvillo JI, Gomez Arzapalo E, Castaneda Vivar JJ, Santoyo Haro S, Herrera Avalos I. Search of Chlamydia trachomatis in 159 women from private consultation. Ginecol Obstet Mex. 2005;73(3):124-127. Exclusion code: 8. [pmid: 21961349].
Gottlieb SL, Berman SM, Low N. Screening and treatment to prevent sequelae in women with Chlamydia trachomatis genital infection: how much do we know?. J Infect Dis. Suppl 2. 2010;201:S156-167. Exclusion code: 12. [pmid: 20470051].
Gottlieb SL, Stoner BP, Zaidi AA, et al. A prospective study of the psychosocial impact of a positive Chlamydia trachomatis laboratory test. Sex Transm Dis. 2011;38(11):1004-1011. Exclusion code: 2. [pmid: 21992975].
Gottlieb SL, Xu F, Brunham RC. Screening and treating Chlamydia trachomatis genital infection to prevent pelvic inflammatory disease: interpretation of findings from randomized controlled trials. Sex Transm Dis. 2013;40(2):97-102. Exclusion code: 12. [pmid: 23324973].
Gotz HM, van Bergen JEAM, Veldhuijzen IK, et al. A prediction rule for selective screening of Chlamydia trachomatis infection. Sex Transm Infect. 2005;81(1):24-30. Exclusion code: 5. [pmid: 15681717].
Gotz HM, van den Broek IVF, Hoebe CJPA, et al. High yield of reinfections by home-based automatic rescreening of Chlamydia positives in a large-scale register-based screening programme and determinants of repeat infections. Sex Transm Infect. 2013;89(1):63-69. Exclusion code: 3. [pmid: 22728910].
Graseck AS, Secura GM, Allsworth JE, Madden T, Peipert JF. Home screening compared with clinic-based screening for sexually transmitted infections. Obstet Gynecol. 2010;115(4):745-752. Exclusion code: 5. [pmid: 20308834].
Greaves A, Lonsdale S, Whinney S, Hood E, Mossop H, Olowokure B. University undergraduates' knowledge of chlamydia screening services and chlamydia infection following the introduction of a National Chlamydia Screening Programme. Eur J Contracept Reprod Health Care. 2009;14(1):61-68. Exclusion code: 5. [pmid: 19241303].
Greenland KE, Op de Coul ELM, van Bergen JEAM, et al. Acceptability of the internet-based Chlamydia screening implementation in the Netherlands and insights into nonresponse. Sex Transm Dis. 2011;38(6):467-474. Exclusion code: 5. [pmid: 21217416].
Griffith WF, Stuart GS, Gluck KL, Heartwell SF. Vaginal speculum lubrication and its effects on cervical cytology and microbiology. Contraception. 2005;72(1):60-64. Exclusion code: 4. [pmid: 15964294].
Grover D, Prime KP, Prince MV, Ridgway G, Gilson RJC. Rectal gonorrhoea in men -- is microscopy still a useful tool?. Int J STD AIDS. 2006;17(4):277-279. Exclusion code: 4. [pmid: 16595053].
Gunn RA, O'Brien CJ, Lee MA, Gilchick RA. Gonorrhea screening among men who have sex with men: value of multiple anatomic site testing, San Diego, California, 1997-2003. Sex Transm Dis. 2008;35(10):845-848. Exclusion code: 3. [pmid: 18607315].
Guy R, Hocking J, Low N, et al. Interventions to increase rescreening for repeat chlamydial infection. Sex Transm Dis. 2012;39(2):136-146. Exclusion code: 3. [pmid: 22249303].
Guy R, Wand H, Franklin N, et al. Re-testing for chlamydia at sexual health services in Australia, 2004-08. Sex Health. 2011;8(2):242-247. Exclusion code: 3. [pmid: 21592440].
Guy RJ, Ali H, Liu B, et al. Efficacy of interventions to increase the uptake of chlamydia screening in primary care: a systematic review. BMC Infect Dis. 2011;11:211. Exclusion code: 5. [pmid: 21816113].
Guy RJ, Kong F, Goller J, et al. A new national Chlamydia Sentinel Surveillance System in Australia: evaluation of the first stage of implementation. Commun Dis Intell. 2010;34(3):319-328. Exclusion code: 5.
Haasnoot A, Koedijk FDH, Op De Coul ELM, et al. Comparing two definitions of ethnicity for identifying young persons at risk for chlamydia. Epidemiol Infect. 2012;140(5):951-958. Exclusion code: 5. [pmid: 21767454].
Hackett KM. Chlamydia screening. Increased efforts needed for asymptomatic women. Adv Nurse Pract. 2010;18(2):16. Exclusion code: 6. [pmid: 20481029].
Hadad R, Fredlund H, Unemo M. Evaluation of the new COBAS TaqMan CT test v2.0 and impact on the proportion of new variant Chlamydia trachomatis by the introduction of diagnostics detecting new variant C trachomatis in Orebro county, Sweden. Sex Transm Infect. 2009;85(3):190-193. Exclusion code: 4. [pmid: 19060034].
Haggerty CL, Gottlieb SL, Taylor BD, Low N, Xu F, Ness RB. Risk of sequelae after Chlamydia trachomatis genital infection in women. J Infect Dis. Suppl 2. 2010;201:S134-155. Exclusion code: 3. [pmid: 20470050].
Hamasuna R, Hoshina S, Imai H, Jensen JS, Osada Y. Usefulness of oral wash specimens for detecting Chlamydia trachomatis from high-risk groups in Japan. Int J Urol. 2007;14(5):473-475. Exclusion code: 4. [pmid: 17511741].
Hammerschlag MR. Chlamydia trachomatis and Chlamydia pneumoniae infections in children and adolescents. Pediatr Rev. 2004;25(2):43-51. Exclusion code: 7. [pmid: 14754926].
Hampton T. Lymphogranuloma venereum targeted: those at risk identified; diagnostic test developed. Jama. 2006;295(22):2592. Exclusion code: 7. [pmid: 16772616].
Hardwick C, White D, Osman H. An audit of the results of the Roche Amplicor gonorrhoea test on female genital samples--a cheaper and more sensitive method than culture in an urban English population. Int J STD AIDS. 2007;18(5):347-348. Exclusion code: 3. [pmid: 17524199].
Harper DM, Noll WW, Belloni DR, Cole BF. Randomized clinical trial of PCR-determined human papillomavirus detection methods: self-sampling versus clinician-directed--biologic concordance and women's preferences. Am J Obstet Gynecol. 2002;186(3):365-373. Exclusion code: 5. [pmid: 11904593].
Harper DM, Raymond M, Noll WW, Belloni DR, Duncan LT, Cole BF. Tampon samplings with longer cervicovaginal cell exposures are equivalent to two consecutive swabs for the detection of high-risk human papillomavirus. Sex Transm Dis. 2002;29(11):628-636. Exclusion code: 5. [pmid: 12438897].
Harris DI. Implementation of chlamydia screening in a general practice setting: a 6-month pilot study. J Fam Plann Reprod Health Care. 2005;31(2):109-112. Exclusion code: 5. [pmid: 15921545].
Harryman L, Scofield S, Macleod J, et al. Comparative performance of culture using swabs transported in Amies medium and the Aptima Combo 2 nucleic acid amplification test in detection of Neisseria gonorrhoeae from genital and extra-genital sites: a retrospective study. Sex Transm Infect. 2012;88(1):27-31. Exclusion code: 3. [pmid: 22034496].
Haugland S, Thune T, Fosse B, Wentzel-Larsen T, Hjelmevoll SO, Myrmel H. Comparing urine samples and cervical swabs for Chlamydia testing in a female population by means of Strand Displacement Assay (SDA). BMC Womens Health. 2010;10:9. Exclusion code: 3. [pmid: 20338058].
Hawthorne CM, Farber PJ, Bibbo M. Chlamydia/gonorrhea combo and HR HPV DNA testing in liquid-based pap. Diagn Cytopathol. 2005;33(3):177-180. Exclusion code: 5. [pmid: 16078250].
Hay PE, Pittrof RUJ. Has the effectiveness of a single chlamydia test in preventing pelvic inflammatory disease over 12 months been overestimated?. Womens Health (Lond Engl). 2010;6(5):627-630. Exclusion code: 7. [pmid: 20887160].
Heijne JCM, Low N. Differential selection processes in opportunistic chlamydia screening. Sex Transm Infect. 2011;87(6):454-455. Exclusion code: 7. [pmid: 21705377].
Heijne JCM, Tao G, Kent CK, Low N. Uptake of regular chlamydia testing by U.S. women: a longitudinal study. Am J Prev Med. 2010;39(3):243-250. Exclusion code: 5. [pmid: 20709256].
Hennrikus E, Oberto D, Linder JM, Rempel JML, Hennrikus N. Sports preparticipation examination to screen college athletes for Chlamydia trachomatis. Med Sci Sports Exerc. 2010;42(4):683-688. Exclusion code: 10. [pmid: 21099757].
Herring A, Ballard R, Mabey D, Peeling RW. Initiative WTSTDD. Evaluation of rapid diagnostic tests: chlamydia and gonorrhoea. Nature Reviews Microbiology. 2006;4(12 Suppl):S41-48. Exclusion code: 7.
Hince D, Brett T, Mak D, Bulsara M, Moorhead R, Arnold-Reed D. Opportunistic screening for chlamydia in young men. Aust Fam Physician. 2009;38(9):734-737. Exclusion code: 10. [pmid: 19893805].
Hislop J, Quayyum Z, Flett G, Boachie C, Fraser C, Mowatt G. Systematic review of the clinical effectiveness and cost-effectiveness of rapid point-of-care tests for the detection of genital chlamydia infection in women and men. Health Technol Assess. 2010;14(29):1-97. iii. iv. Exclusion code: 4.
Hjelmevoll SO, Olsen ME, Sollid JUE, et al. Clinical validation of a real-time polymerase chain reaction detection of Neisseria gonorrheae porA pseudogene versus culture techniques. Sex Transm Dis. 2008;35(5):517-520. Exclusion code: 3. [pmid: 18434945].
Hjelmevoll SO, Olsen ME, Sollid JUE, Haaheim H, Unemo M, Skogen V. A fast real-time polymerase chain reaction method for sensitive and specific detection of the Neisseria gonorrhoeae porA pseudogene. J Mol Diagn. 2006;8(5):574-581. Exclusion code: 3. [pmid: 17065426].
Ho MK, Lo JYC, Lo ACT, Cheng FK, Chan FK. Evaluation of replacing the existing diagnostic strategy for Neisseria gonorrhoeae and Chlamydia trachomatis infections with sole molecular testing of urine specimens in a sexually transmitted infection clinic setting. Sex Transm Infect. 2009;85(5):322-325. Exclusion code: 3. [pmid: 19406739].
Hocking J, Fairley CK. Do the characteristics of sexual health centre clients predict chlamydia infection sufficiently strongly to allow selective screening?. Sex Health. 2005;2(3):185-192. Exclusion code: 5. [pmid: 16335546].
Hodgins S, Peeling RW, Dery S, et al. The value of mass screening for chlamydia control in high prevalence communities. Sex Transm Infect. Suppl 1. 2002;78:i64-68. Exclusion code: 3. [pmid: 12083449].
Hogan AH, Howell-Jones RS, Pottinger E, Wallace LM, McNulty CA. “…they should be offering it”: a qualitative study to investigate young peoples' attitudes towards chlamydia screening in GP surgeries. BMC Public Health. 2010;10:616. Exclusion code: 4. [pmid: 20955570].
Holden AEC, Shain RN, Miller WB, et al. The influence of depression on sexual risk reduction and STD infection in a controlled, randomized intervention trial. Sex Transm Dis. 2008;35(10):898-904. Exclusion code: 3. [pmid: 18607311].
Holland D. Chlamydia screening: making a case for including men. Nurs Times. 2006;102(13):44-46. Exclusion code: 7. [pmid: 16605152].
Hollegaard S, Vogel I, Thorsen P, Jensen IP, Mordhorst CH, Jeune B. Chlamydia trachomatis C-complex serovars are a risk factor for preterm birth. In Vivo. 2007;21(1):107-112. Exclusion code: 3. [pmid: 17354622].
Hood EE, Nerhood RC. The utility of screening for chlamydia at 34-36 weeks gestation. W V Med J. 2010;106(6):10-11. Exclusion code: 5. [pmid: 21928555].
Hook EW 3rd, Ching SF, Stephens J, Hardy KF, Smith KR, Lee HH. Diagnosis of Neisseria gonorrhoeae infections in women by using the ligase chain reaction on patient-obtained vaginal swabs. J Clin Microbiol. 1997;35(8):2129-2132. Exclusion code: 3. [pmid: 9230396].
Hook EW 3rd, Smith K, Mullen C, et al. Diagnosis of genitourinary Chlamydia trachomatis infections by using the ligase chain reaction on patient-obtained vaginal swabs. J Clin Microbiol. 1997;35(8):2133-2135. Exclusion code: 3. [pmid: 9230397].
Hopkins MJ, Ashton LJ, Alloba F, Alawattegama A, Hart IJ. Validation of a laboratory-developed real-time PCR protocol for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in urine. Sex Transm Infect. 2010;86(3):207-211. Exclusion code: 3. [pmid: 20522633].
Hopkins MJ, Smith G, Hart IJ, Alloba F. Screening tests for Chlamydia trachomatis or Neisseria gonorrhoeae using the cobas 4800 PCR system do not require a second test to confirm: an audit of patients issued with equivocal results at a sexual health clinic in the Northwest of England, U.K. Sex Transm Infect. 2012;88(7):495-497. Exclusion code: 5. [pmid: 22661631].
Hopwood J, Mallinson H, Hodgson E, Hull L. Liquid based cytology: examination of its potential in a chlamydia screening programme. Sex Transm Infect. 2004;80(5):371-373. Exclusion code: 4. [pmid: 15459404].
Horner P, Skidmore S, Herring A, et al. Enhanced enzyme immunoassay with negative-gray-zone testing compared to a single nucleic Acid amplification technique for community-based chlamydial screening of men. J Clin Microbiol. 2005;43(5):2065-2069. Exclusion code: 3. [pmid: 15872223].
Horner PJ. Should we still be testing for asymptomatic non-specific urethritis in departments of genitourinary medicine?. Int J STD AIDS. 2005;16(4):273-277. Exclusion code: 7. [pmid: 15899076].
Hu D, Hook EW 3rd, Goldie SJ. The impact of natural history parameters on the cost-effectiveness of Chlamydia trachomatis screening strategies. Sex Transm Dis. 2006;33(7):428-436. Exclusion code: 6. [pmid: 16572038].
Huppert JS, Biro F, Lan D, Mortensen JE, Reed J, Slap GB. Urinary symptoms in adolescent females: STI or UTI?. J Adolesc Health. 2007;40(5):418-424. Exclusion code: 3. [pmid: 17448399].
Huppert JS, Mortensen JE, Reed JL, Kahn JA, Rich KD, Hobbs MM. Mycoplasma genitalium detected by transcription-mediated amplification is associated with Chlamydia trachomatis in adolescent women. Sex Transm Dis. 2008;35(3):250-254. Exclusion code: 5. [pmid: 18490867].
Hurly DS, Buhrer-Skinner M, Badman SG, et al. Field evaluation of the CRT and ACON chlamydia point-of-care tests in a tropical, low-resource setting. Sex Transm Infect. 2014;90(3):179-184. Exclusion code: 4. [pmid: 24337733].
Hwang LY, Tebb KP, Shafer MAB, Pantell RH. Examination of the treatment and follow-up care for adolescents who test positive for Chlamydia trachomatis infection. Arch Pediatr Adolesc Med. 2005;159(12):1162-1166. Exclusion code: 3. [pmid: 16330741].
Imai H, Shinohara H, Nakao H, Tsukino H, Hamasuna R, Katoh T. Prevalence and risk factors of asymptomatic chlamydial infection among students in Japan. Int J STD AIDS. 2004;15(6):408-414. Exclusion code: 5. [pmid: 15186587].
Irvin CB, Nowak B, Moore M, Flynn K, Vretta C. Emergency department Chlamydia screening through partnership with the public health department. Acad Emerg Med. 2009;16(11):1217-1220. Exclusion code: 10. [pmid: 19814759].
Irwig L, Tosteson ANA, Gatsonis C, et al. Guidelines for Meta-analyses Evaluating Diagnostic Tests. Ann Intern Med. 1994;120(8):667-676. Exclusion code: 2. [pmid: 8135452].
Iur'ev SI, Krotov SA, Degteva SS, et al. Perinatal aspects of serological diagnosis in urogenital chlamydiosis. Klin Lab Diagn. 2005;(3):20-23. Exclusion code: 8. [pmid: 15881128].
Jalal H, Al-Suwaine A, Stephen H, Carne C, Sonnex C. Comparative performance of the Roche COBAS Amplicor assay and an in-house real-time PCR assay for diagnosis of Chlamydia trachomatis infection. J Med Microbiol. 2007;56(Pt 3):320-322. Exclusion code: 4. [pmid: 17314360].
Jalal H, Stephen H, Al-Suwaine A, Sonnex C, Carne C. The superiority of polymerase chain reaction over an amplified enzyme immunoassay for the detection of genital chlamydial infections. Sex Transm Infect. 2006;82(1):37-40. Exclusion code: 3. [pmid: 16461600].
Jalkh AP, Miranda AE, Hurtado-Guerreiro JC, et al. Chlamydia trachomatis in human immunodeficiency virus-infected men treated at a referral hospital for sexually transmitted diseases in the Amazonas, Brazil. Braz J Infect Dis. 2014;18(2):158-163. Exclusion code: 3. [pmid: 24216156].
Jamil MS, Hocking JS, Bauer HM, et al. Home-based chlamydia and gonorrhoea screening: a systematic review of strategies and outcomes. BMC Public Health. 2013;13:189. Exclusion code: 5. [pmid: 23496833].
Jaton K, Bille J, Greub G. A novel real-time PCR to detect Chlamydia trachomatis in first-void urine or genital swabs. J Med Microbiol. 2006;55(Pt 12):1667-1674. Exclusion code: 4. [pmid: 17108270].
Jenkins WD, Kovach R, Wold BJ, Zahnd WE. Using patient-provided information to refine sexually transmitted infection screening criteria among women presenting in the emergency department. Sex Transm Dis. 2012;39(12):965-967. Exclusion code: 5. [pmid: 23191951].
Jenkins WD, Kruse J. Chlamydia screening: how we can better serve patients. J. 2010;59(2):E2. Exclusion code: 7.
Jenkins WD, Nessa LL, Clark T. Cross-sectional study of pharyngeal and genital chlamydia and gonorrhoea infections in emergency department patients. Sex Transm Infect. 2014;90(3):246-249. Exclusion code: 5. [pmid: 24366777].
Jenkins WD, Weis R, Campbell P, Barnes M, Barnes P, Gaydos C. Comparative effectiveness of two self-collected sample kit distribution systems for chlamydia screening on a university campus. Sex Transm Infect. 2012;88(5):363-367. Exclusion code: 4. [pmid: 22399277].
Jenkins WD, Zahnd W, Kovach R, Kissinger P. Chlamydia and gonorrhea screening in United States emergency departments. J Emerg Med. 2013;44(2):558-567. Exclusion code: 2. [pmid: 23102593].
Jensen JS, Bjornelius E, Dohn B, Lidbrink P. Comparison of first void urine and urogenital swab specimens for detection of Mycoplasma genitalium and Chlamydia trachomatis by polymerase chain reaction in patients attending a sexually transmitted disease clinic. Sex Transm Dis. 2004;31(8):499-507. Exclusion code: 3. [pmid: 15273584].
Jespersen DJ, Flatten KS, Jones MF, Smith TF. Prospective comparison of cell cultures and nucleic acid amplification tests for laboratory diagnosis of Chlamydia trachomatis Infections. J Clin Microbiol. 2005;43(10):5324-5326. Exclusion code: 3. [pmid: 16208009].
Joesoef MR, Mosure DJ. Prevalence of Chlamydia in young men in the United States from newly implemented universal screening in a national job training program. Sex Transm Dis. 2006;33(10):636-639. Exclusion code: 5. [pmid: 16641824].
Joesoef MR, Weinstock HS, Johnson RE. Factors associated with recurrent chlamydial infection and failure to return for retesting in young women entering national job training program, 1998--2005. Sex Transm Dis. 2008;35(4):368-371. Exclusion code: 3. [pmid: 18192930].
Joffe A, Rietmeijer CA, Chung SE, et al. Screening asymptomatic adolescent men for Chlamydia trachomatis in school-based health centers using urine-based nucleic acid amplification tests. Sex Transm Dis. 2008;35(11 Suppl):S19-23. Exclusion code: 5. [pmid: 18716568].
Johnson CC, Jones EH, Goldberg M, Asbel LE, Salmon ME, Waller CL. Screening for Chlamydia trachomatis and Neisseria gonorrhoeae among adolescents in Family Court, Philadelphia, Pennsylvania. Sex Transm Dis. 2008;35(11 Suppl):S24-27. Exclusion code: 10. [pmid: 18607316].
Johnson RE, Green TA, Schachter J, et al. Evaluation of nucleic acid amplification tests as reference tests for Chlamydia trachomatis infections in asymptomatic men. J Clin Microbiol. 2000;38(12):4382-4386. Exclusion code: 10. [pmid: 11101568].
Johnson SA, Simms I, Sheringham J, et al. The implementation of chlamydia screening: a cross-sectional study in the south east of England. Sex Transm Infect. 2010;86(3):217-221. Exclusion code: 6. [pmid: 20460264].
Jones HE, Altini L, de Kock A, Young T, van de Wijgert JH. Home-based versus clinic-based self-sampling and testing for sexually transmitted infections in Gugulethu, South Africa: randomised controlled trial. Sex Transm Infect. 2007;83(7):552-557. Exclusion code: 5. [pmid: 17901084].
Jones K, Baldwin KA, Lewis PR. The potential influence of a social media intervention on risky sexual behavior and Chlamydia incidence. J Community Health Nurs. 2012;29(2):106-120. Exclusion code: 4. [pmid: 22536914].
Jordan NN, Clemmons NS, Gaydos JC, Lee HCS, Yi SH, Klein TA. Chlamydia trachomatis screening initiative among U.S. Army soldiers assigned to Korea. Msmr. 2013;20(2):15-16. Exclusion code: 5. [pmid: 23461305].
Joyee AG, Thyagarajan SP, Reddy EV, Venkatesan C, Ganapathy M. Genital chlamydial infection in STD patients: its relation to HIV infection. Indian J. 2005;23(1):37-40. Exclusion code: 3.
Jumping-Eagle S, Sheeder J, Kelly LS, Stevens-Simon C. Feasibility and utility of screening adolescent mothers for Chlamydia at their children's health care visits. Matern Child Health J. 2007;11(6):586-594. Exclusion code: 10. [pmid: 17549616].
Kadzhaia D, Merabishvili N. Prevalence and risk factors for Chlamydia trachomatis infection in pregnant women. Georgian Med. 2005;(129):33-36. Exclusion code: 5.
Kalwij S, Macintosh M, Baraitser P. Screening and treatment of Chlamydia trachomatis infections. BMJ. 2010;340:c1915. Exclusion code: 7. [pmid: 20410164].
Kalwij SA. Opportunistic chlamydia screening in a general practice consultation. BMJ. 2011;343:d5108. Exclusion code: 7. [pmid: 21844158].
Kangas I, Andersen B, Olesen F, Moller JK, Ostergaard L. Psychosocial impact of Chlamydia trachomatis testing in general practice. Br J Gen Pract. 2006;56(529):587-593. Exclusion code: 3. [pmid: 16882376].
Kanno MB, Nguyen RHN, Lee EM, Zenilman JM, Erbelding EJ. The prevalence of abnormal cervical cytology in a sexually transmitted diseases clinic. Int J STD AIDS. 2005;16(8):549-552. Exclusion code: 3. [pmid: 16105189].
Kapala J, Biers K, Cox M, et al. Aptima Combo 2 testing detected additional cases of Neisseria gonorrhoeae infection in men and women in community settings. J Clin Microbiol. 2011;49(5):1970-1971. Exclusion code: 3. [pmid: 21411585].
Karinen L, Pouta A, Bloigu A, et al. Serum C-reactive protein and Chlamydia trachomatis antibodies in preterm delivery. Obstet Gynecol. 2005;106(1):73-80. Exclusion code: 5. [pmid: 15994620].
Karowicz-Biliniska A, Kus E, Kazimiera W, et al. Chlamydia trachomatis infection and bacterial analysis in pregnant women in II and III trimester of pregnancy. Ginekol Pol. 2007;78(10):787-791. Exclusion code: 8. [pmid: 18200970].
Kasowitz AR, McCusker M, Coury-Doniger P, et al. Stage of change behavioral assessment tool fails to predict the prevalence of chlamydia in an urban adolescent health clinic. J Pediatr Adolesc Gynecol. 2006;19(4):277-283. Exclusion code: 5. [pmid: 16873032].
Keegan H, Malkin A, Griffin M, Ryan F, Lambkin H. Validation of a multiplex PCR assay for the simultaneous detection of human papillomavirus and Chlamydia trachomatis in cervical PreservCyt samples. Clin Chem. 2005;51(7):1301-1302. Exclusion code: 3. [pmid: 15976120].
Kehl SC, Georgakas K, Swain GR, et al. Evaluation of the abbott LCx assay for detection of Neisseria gonorrhoeae in endocervical swab specimens from females. J Clin Microbiol. 1998;36(12):3549-3551. Exclusion code: 3. [pmid: 9817871].
Keltz MD, Sauerbrun-Cutler MT, Durante MS, Moshier E, Stein DE, Gonzales E. Positive Chlamydia trachomatis serology result in women seeking care for infertility is a negative prognosticator for intrauterine pregnancy. Sex Transm Dis. 2013;40(11):842-845. Exclusion code: 5. [pmid: 24113404].
Kent CK, Chaw JK, Wong W, et al. Prevalence of rectal, urethral, and pharyngeal chlamydia and gonorrhea detected in 2 clinical settings among men who have sex with men: San Francisco, California, 2003. Clin Infect Dis. 2005;41(1):67-74. Exclusion code: 3. [pmid: 15937765].
Kerndt PR, Ferrero DV, Aynalem G, et al. First report of performance of the Versant CT/GC DNA 1.0 assay (kPCR) for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2011;49(4):1347-1353. Exclusion code: 4. [pmid: 21307209].
Khan A, Hussain R, Schofield M. Correlates of sexually transmitted infections in young Australian women. Int J STD AIDS. 2005;16(7):482-487. Exclusion code: 5. [pmid: 16004627].
Khan ER, Hossain MA, Paul SK, et al. Comparison between ICT and PCR for diagnosis of Chlamydia trachomatis. Mymensingh Med J. 2012;21(2):190-194. Exclusion code: 4. [pmid: 22561757].
Khandhadia S, Foster S, Cree A, et al. Chlamydia infection status, genotype, and age-related macular degeneration. Mol Vis. 2012;18:29-37. Exclusion code: 5. [pmid: 22259222].
Khryanin AA, Reshetnikov OV, Vlaspolder F. Comparison of APTIMA COMBO 2 assay with polymerase chain reaction Roche assay for detection of Chlamydia trachomatis in endocervical swabs. Int J STD AIDS. 2007;18(12):871-872. Exclusion code: 3. [pmid: 18073027].
Killick V, Kell P, Plumb H, Hurd N, Turner P. Screening for Neisseria gonorrhoeae using the BD ProbeTec nucleic acid amplification test in a low prevalence genitourinary medicine clinic. Int J STD AIDS. 2012;23(6):e1-3. Exclusion code: 3. [pmid: 22807549].
Kimmitt PT, Tabrizi SN, Crosatti M, et al. Pilot study of the utility and acceptability of tampon sampling for the diagnosis of Neisseria gonorrhoeae and Chlamydia trachomatis infections by duplex realtime polymerase chain reaction in United Kingdom sex workers. Int J STD AIDS. 2010;21(4):279-282. Exclusion code: 5. [pmid: 20378902].
Kirk E, Bora S, Van Calster B, et al. Chlamydia trachomatis infection in patients attending an Early Pregnancy Unit: prevalence, symptoms, pregnancy location and viability. Acta Obstet Gynecol Scand. 2008;87(6):601-607. Exclusion code: 5. [pmid: 18568458].
Klovstad H, Natas O, Tverdal A, Aavitsland P. Systematic screening with information and home sampling for genital Chlamydia trachomatis infections in young men and women in Norway: a randomized controlled trial. BMC Infect Dis. 2013;13:30. Exclusion code: 5. [pmid: 23343391].
Knesel BW, Dry JC, Wald-Scott C, Aftab A. Preliminary evaluation of a cervical self-sampling device with liquid-based cytology and multiparameter molecular testing. [Erratum appears in J Reprod Med. 2005 May;50(5):376 Note: Aftoh, Asma [corrected to Aftab, Asma]]. J Reprod Med. 2005;50(4):256-260. Exclusion code: 5. [pmid: 15916209].
Knox J, Tabrizi SN, Miller P, et al. Evaluation of self-collected samples in contrast to practitioner-collected samples for detection of Chlamydia trachomatis, Neisseria gonorrhoeae, and Trichomonas vaginalis by polymerase chain reaction among women living in remote areas. Sex Transm Dis. 2002;29(11):647-654. Exclusion code: 3. [pmid: 12438900].
Koffi SK, Faye-Kette H, Kacou-N'douba A, Kouassi-M'bengue A, Dosso M. Evaluation of first void urine in the detection of Neisseria gonorrhoeae in patients less symptomatic in Abidjan (Cote d'Ivoire). Med Trop (Mars). 2009;69(3):275-277. Exclusion code: 8. [pmid: 19702151].
Korenromp EL, White RG, Orroth KK, et al. Determinants of the impact of sexually transmitted infection treatment on prevention of HIV infection: a synthesis of evidence from the Mwanza, Rakai, and Masaka intervention trials. J Infect Dis. Suppl 1. 2005;191:S168-178. Exclusion code: 4. [pmid: 15627227].
Koumans EH, Black CM, Markowitz LE, et al. Comparison of methods for detection of Chlamydia trachomatis and Neisseria gonorrhoeae using commercially available nucleic acid amplification tests and a liquid pap smear medium. J Clin Microbiol. 2003;41(4):1507-1511. Exclusion code: 3. [pmid: 12682137].
Koumans EHA, Rosen J, van Dyke MK, et al. Prevention of mother-to-child transmission of infections during pregnancy: implementation of recommended interventions, United States, 2003-2004. Am J Obstet Gynecol. 2012;206(2):158.e151-158.e111. Exclusion code: 5. [pmid: 22030318].
Kouyoumdjian FG, Leto D, John S, Henein H, Bondy S. A systematic review and meta-analysis of the prevalence of chlamydia, gonorrhoea and syphilis in incarcerated persons. Int J STD AIDS. 2012;23(4):248-254. Exclusion code: 5. [pmid: 22581947].
Krech T, Castriciano S, Jang D, Smieja M, Enders G, Chernesky M. Detection of high risk HPV and Chlamydia trachomatis in vaginal and cervical samples collected with flocked nylon and wrapped rayon dual swabs transported in dry tubes. J Virol Methods. 2009;162(1-2):291-293. Exclusion code: 4. [pmid: 19703493].
Kretzschmar M, Satterwhite C, Leichliter J, Berman S. Effects of screening and partner notification on Chlamydia positivity in the United States: a modeling study. Sex Transm Dis. 2012;39(5):325-331. Exclusion code: 6. [pmid: 22504590].
Kretzschmar M, Turner KME, Barton PM, Edmunds WJ, Low N. Predicting the population impact of chlamydia screening programmes: comparative mathematical modelling study. Sex Transm Infect. 2009;85(5):359-366. Exclusion code: 6. [pmid: 19454407].
Kwan B, Ryder N, Knight V, et al. Sensitivity of 20-minute voiding intervals in men testing for Chlamydia trachomatis. Sex Transm Dis. 2012;39(5):405-406. Exclusion code: 5. [pmid: 22504609].
La Montagne DS, Patrick LE, Fine DN, Marrazzo JM, Region XIPP. Re-evaluating selective screening criteria for chlamydial infection among women in the U S Pacific Northwest. Sex Transm Dis. 2004;31(5):283-289. Exclusion code: 3. [pmid: 15107630].
LaMontagne DS, Fenton KA, Randall S, Anderson S, Carter P. Establishing the National Chlamydia Screening Programme in England: results from the first full year of screening. Sex Transm Infect. 2004;80(5):335-341. Exclusion code: 10. [pmid: 15459399].
Langille DB, Proudfoot K, Rigby J, Aquino-Russell C, Strang R, Forward K. A pilot project for chlamydia screening in adolescent females using self-testing: characteristics of participants and non-participants. Can J Public Health. 2008;99(2):117-120. Exclusion code: 5. [pmid: 18457285].
Lardenoije CMJG, Land JA. Chlamydia antibody testing for tubal factor subfertility. Ned Tijdschr Geneeskd. 2007;151(36):1981-1985. Exclusion code: 8. [pmid: 17953171].
Lavelle SJ, Jones KE, Mallinson H, Webb AMC. Finding, confirming, and managing gonorrhoea in a population screened for chlamydia using the Gen-Probe Aptima Combo2 assay. Sex Transm Infect. 2006;82(3):221-224. Exclusion code: 3. [pmid: 16731672].
Lawless S. Sustaining chlamydia screening is difficult. J Prim Health Care. 2010;2(4):347. Exclusion code: 7. [pmid: 21125080].
Lawton B, Rose S, Bromhead C, Brown S, MacDonald J, Shepherd J. Rates of Chlamydia trachomatis testing and chlamydial infection in pregnant women. N Z Med J. 2004;117(1194):U889. Exclusion code: 5. [pmid: 15156207].
Lawton BA, Rose SB, Elley CR, Bromhead C, MacDonald EJ, Baker MG. Increasing the uptake of opportunistic chlamydia screening: a pilot study in general practice. J Prim Health Care. 2010;2(3):199-207. Exclusion code: 5. [pmid: 21069115].
Lawung R, Cherdtrakulkiat R, Charoenwatanachokchai A, Nabu S, Suksaluk W, Prachayasittikul V. One-step PCR for the identification of multiple antimicrobial resistance in Neisseria gonorrhoeae. J Microbiol Methods. 2009;77(3):323-325. Exclusion code: 5. [pmid: 19341768].
Le Roy C, Le Hen I, Clerc M, et al. The first performance report for the Bio-Rad Dx CT/NG/MG assay for simultaneous detection of Chlamydia trachomatis, Neisseria gonorrhoeae and Mycoplasma genitalium in urogenital samples. J Microbiol Methods. 2012;89(3):193-197. Exclusion code: 3. [pmid: 22446590].
Lee JY, Lensing SY, Schwebke JR. Retention of clinical trial participants in a study of nongonococcal urethritis (NGU), a sexually transmitted infection in men. Contemp Clin Trials. 2012;33(4):606-610. Exclusion code: 5. [pmid: 22261236].
Lee SH, Vigliotti VS, Pappu S. DNA sequencing validation of Chlamydia trachomatis and Neisseria gonorrhoeae nucleic acid tests. Am J Clin Pathol. 2008;129(6):852-859. Exclusion code: 4. [pmid: 18480000].
Lee SH, Vigliotti VS, Pappu S. Molecular tests for human papillomavirus (HPV), Chlamydia trachomatis and Neisseria gonorrhoeae in liquid-based cytology specimen. BMC Womens Health. 2009;9:8. Exclusion code: 5. [pmid: 19358733].
Lee SJ, Park DC, Lee DS, Choe HS, Cho YH. Evaluation of Seeplex STD6 ACE Detection kit for the diagnosis of six bacterial sexually transmitted infections. J Infect Chemother. 2012;18(4):494-500. Exclusion code: 3. [pmid: 22252268].
Lee SR, Chung JM, Kim YG. Rapid one step detection of pathogenic bacteria in urine with sexually transmitted disease (STD) and prostatitis patient by multiplex PCR assay (mPCR). J. 2007;45(5):453-459. Exclusion code: 4.
Lee V, Tobin JM, Foley E. Relationship of cervical ectopy to chlamydia infection in young women. J Fam Plann Reprod Health Care. 2006;32(2):104-106. Exclusion code: 5. [pmid: 16824301].
Lee YM, Samaranayake A, Fairley CK, et al. Pelvic examination leads to changed clinical management in very few women diagnosed with asymptomatic chlamydia infection. Sex Health. 2010;7(4):498-499. Exclusion code: 10. [pmid: 21062594].
Lehtinen M, Ault KA, Lyytikainen E, et al. Chlamydia trachomatis infection and risk of cervical intraepithelial neoplasia. Sex Transm Infect. 2011;87(5):372-376. Exclusion code: 5. [pmid: 21471141].
Levett PN, Brandt K, Olenius K, Brown C, Montgomery K, Horsman GB. Evaluation of three automated nucleic acid amplification systems for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in first-void urine specimens. J Clin Microbiol. 2008;46(6):2109-2111. Exclusion code: 3. [pmid: 18400919].
Levi AW, Beckman D, Hui P, Schofield K, Harigopal M, Chhieng DC. Comparing two methods of detection for Chlamydia trachomatis in liquid-based Papanicolaou tests. Am J Clin Pathol. 2012;138(2):236-240. Exclusion code: 4. [pmid: 22904135].
Levy V, Blackmore CS, Klausner JD. Self-collection of specimens for nucleic acid-based diagnosis of pharyngeal, cervicovaginal, urethral, and rectal Neisseria gonorrhoeae and Chlamydia trachomatis infections. Methods Mol Biol. 2012;903:407-418. Exclusion code: 7. [pmid: 22782835].
Li JH, Yin YP, Zheng HP, et al. A high-resolution melting analysis for genotyping urogenital Chlamydia trachomatis. Diagn Microbiol Infect Dis. 2010;68(4):366-374. Exclusion code: 4. [pmid: 20889277].
Lin KW, Ramsey L. Screening for chlamydial infection. Am Fam Physician. 2008;78(12):1349-1350. Exclusion code: 7. [pmid: 19119552].
Lindan C, Mathur M, Kumta S, et al. Utility of pooled urine specimens for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in men attending public sexually transmitted infection clinics in Mumbai, India, by PCR. J Clin Microbiol. 2005;43(4):1674-1677. Exclusion code: 4. [pmid: 15814983].
Lister NA, Tabrizi SN, Fairley CK, Garland S. Validation of roche COBAS Amplicor assay for detection of Chlamydia trachomatis in rectal and pharyngeal specimens by an omp1 PCR assay. J Clin Microbiol. 2004;42(1):239-241. Exclusion code: 4. [pmid: 14715759].
Lloyd TDR, Malin G, Pugsley H, et al. Women presenting with lower abdominal pain: a missed opportunity for chlamydia screening?. Surg. 2006;4(1):15-19. Exclusion code: 6.
Lofy KH, Hofmann J, Mosure DJ, Fine DN, Marrazzo JM. Chlamydial infections among female adolescents screened in juvenile detention centers in Washington State, 1998-2002. Sex Transm Dis. 2006;33(2):63-67. Exclusion code: 5. [pmid: 16432475].
Logan S, Browne J, McKenzie H, Templeton A, Bhattacharya S. Evaluation of endocervical, first-void urine and self-administered vulval swabs for the detection of Chlamydia trachomatis in a miscarriage population. [Erratum appears in BJOG. 2005 Apr;112(4):528]. Bjog. 2005;112(1):103-106. Exclusion code: 3. [pmid: 15663407].
Lorimer K. Pilot qualitative analysis of the psychosocial factors which drive young people to decline chlamydia testing in the UK: implications for health promotion and screening. Int J STD AIDS. 2010;21(5):379. Exclusion code: 7. [pmid: 20498116].
Lorimer K, Hart GJ. Knowledge of Chlamydia trachomatis among men and women approached to participate in community-based screening, Scotland, UK. BMC Public Health. 2010;10:794. Exclusion code: 5. [pmid: 21192793].
Low N. Current status of Chlamydia screening in Europe. Euro Surveill. 2004;8(41). Exclusion code: 7.
Low N. Evaluating novel interventions for chlamydia screening. Sex Transm Infect. 2006;82(2):97-98. Exclusion code: 7. [pmid: 16581729].
Low N, Bender N, Nartey L, Shang A, Stephenson JM. Effectiveness of chlamydia screening: systematic review. Int J Epidemiol. 2009;38(2):435-448. Exclusion code: 12. [pmid: 19060033].
Low N, Egger M, Sterne JAC, et al. Incidence of severe reproductive tract complications associated with diagnosed genital chlamydial infection: the Uppsala Women's Cohort Study. Sex Transm Infect. 2006;82(3):212-218. Exclusion code: 3. [pmid: 16731670].
Low N, Harbord RM, Egger M, Sterne JA, Herrmann B. Screening for chlamydia. Lancet. 2005;365(9470):1539. Exclusion code: 5.
Low N, McCarthy A, Macleod J, et al. Epidemiological, social, diagnostic and economic evaluation of population screening for genital chlamydial infection. Health Technol Assess. 2007;11(8):iii-iv. ix. xii. 1. 165. Exclusion code: 3. [pmid: 17311735].
Low N, McCarthy A, Macleod J, et al. The chlamydia screening studies: rationale and design. Sex Transm Infect. 2004;80(5):342-348. Exclusion code: 2. [pmid: 15459400].
Lowe P, O'Loughlin P, Evans K, White M, Bartley PB, Vohra R. Comparison of the Gen-Probe APTIMA Combo 2 assay to the AMPLICOR CT/NG assay for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in urine samples from Australian men and women. J Clin Microbiol. 2006;44(7):2619-2621. Exclusion code: 3. [pmid: 16825397].
Luijt DS, Bos PAJ, van Zwet AA, van Voorst Vader PC, Schirm J. Comparison of COBAS AMPLICOR Neisseria gonorrhoeae PCR, including confirmation with N. gonorrhoeae-specific 16S rRNA PCR, with traditional culture. J Clin Microbiol. 2005;43(3):1445-1447. Exclusion code: 3. [pmid: 15750129].
Lum G, Garland SM, Tabrizi S, et al. Supplemental testing is still required in australia for samples positive for Neisseria gonorrhoeae by nucleic acid detection tests. J Clin Microbiol. 2006;44(11):4292-4294. author reply 4293-4294. Exclusion code: 7. [pmid: 17088373].
Luostarinen T, Lehtinen M, Bjorge T, et al. Joint effects of different human papillomaviruses and Chlamydia trachomatis infections on risk of squamous cell carcinoma of the cervix uteri. Eur J Cancer. 2004;40(7):1058-1065. Exclusion code: 4. [pmid: 15093583].
MacDonald N, Mailman T, Desai S. Gonococcal infections in newborns and in adolescents. Adv Exp Med Biol. 2008;609:108-130. Exclusion code: 7. [pmid: 18193661].
Machado ACS, Guimaraes EMB, Sakurai E, Fioravante FCR, Amaral WN, Alves MFC. High titers of Chlamydia trachomatis antibodies in Brazilian women with tubal occlusion or previous ectopic pregnancy. Infect Dis Obstet Gynecol. 2007;2007:24816. Exclusion code: 5. [pmid: 17541464].
Madeleine MM, Anttila T, Schwartz SM, et al. Risk of cervical cancer associated with Chlamydia trachomatis antibodies by histology, HPV type and HPV cofactors. Int J Cancer. 2007;120(3):650-655. Exclusion code: 5. [pmid: 17096345].
Magnus M, Schillinger JA, Fortenberry JD, Berman SM, Kissinger P. Partner age not associated with recurrent Chlamydia trachomatis infection, condom use, or partner treatment and referral among adolescent women. J Adolesc Health. 2006;39(3):396-403. Exclusion code: 5. [pmid: 16919802].
Mahilum-Tapay L, Laitila V, Wawrzyniak JJ, et al. New point of care Chlamydia Rapid Test--bridging the gap between diagnosis and treatment: performance evaluation study. BMJ. 2007;335(7631):1190-1194. Exclusion code: 4. [pmid: 18055487].
Mahmud NU, Hossain MA, Nahar K, et al. Non-culture diagnosis of Chlamydia trachomatis genital infection in sexually active women. Mymensingh Med J. 2012;21(1):8-12. Exclusion code: 11. [pmid: 22314447].
Mahony JB, Jang D, Chong S, et al. Detection of Chlamydia trachomatis, Neisseria gonorrhoeae, Ureaplasma urealyticum, and Mycoplasma genitalium in First-void Urine Specimens by Multiplex Polymerase Chain Reaction. Mol Diagn. 1997;2(3):161-168. Exclusion code: 3. [pmid: 10462605].
Mahto M, Mallinson H. Should we consider alternatives to combined cervical and urethral swabs for detection of Chlamydia trachomatis in females?. Sex Transm Infect. 2007;83(4):335-336. Exclusion code: 3. [pmid: 17611234].
Malenie R, Joshi PJ, Mathur MD. Chlamydia trachomatis antigen detection in pregnancy and its verification by antibody blocking assay. Indian J. 2006;24(2):97-100. Exclusion code: 5.
Malik A, Jain S, Rizvi M, Shukla I, Hakim S. Chlamydia trachomatis infection in women with secondary infertility. Fertil Steril. 2009;91(1):91-95. Exclusion code: 3. [pmid: 18635168].
Mangin D, Murdoch D, Wells JE, et al. Chlamydia trachomatis testing sensitivity in midstream compared with first-void urine specimens. Ann Fam Med. 2012;10(1):50-53. Exclusion code: 5. [pmid: 22230830].
Manhart LE, Aral SO, Holmes KK, et al. Influence of study population on the identification of risk factors for sexually transmitted diseases using a case-control design: the example of gonorrhea. Am J Epidemiol. 2004;160(4):393-402. Exclusion code: 5. [pmid: 15286025].
Manhas A, Sethi S, Sharma M, et al. Association of genital mycoplasmas including Mycoplasma genitalium in HIV infected men with nongonococcal urethritis attending STD & HIV clinics. Indian J Med Res. 2009;129(3):305-310. Exclusion code: 3. [pmid: 19491424].
Mann JR, McDermott S, Gill T. Sexually transmitted infection is associated with increased risk of preterm birth in South Carolina women insured by Medicaid. J Matern Fetal Neonatal Med. 2010;23(6):563-568. Exclusion code: 5. [pmid: 19903113].
Marangoni A, Foschi C, Nardini P, et al. Evaluation of the new test VERSANT CT/GC DNA 1.0 assay for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in urine specimens. J Clin Lab Anal. 2012;26(2):70-72. Exclusion code: 4. [pmid: 22467321].
Marcus JL, Bernstein KT, Kohn RP, Liska S, Philip SS. Infections missed by urethral-only screening for chlamydia or gonorrhea detection among men who have sex with men. Sex Transm Dis. 2011;38(10):922-924. Exclusion code: 2. [pmid: 21934565].
Marin Gabriel MA, de las Heras Ibarra S, Bergon Sendin E, et al. Respiratory infection due to Chlamydia trachomatis in infants. Clinical presentation and outcome in 18 patients. An Pediatr (Barc). 2004;60(4):349-353. Exclusion code: 5. [pmid: 15033113].
Markos AR. Testing asymptomatic heterosexual men for gonorrhoea. Int J STD AIDS. 2010;21(4):302. Exclusion code: 7. [pmid: 20378910].
Marrazzo JM, Johnson RE, Green TA, et al. Impact of patient characteristics on performance of nucleic acid amplification tests and DNA probe for detection of Chlamydia trachomatis in women with genital infections. J Clin Microbiol. 2005;43(2):577-584. Exclusion code: 3. [pmid: 15695648].
Marrazzo JM, Scholes D. Acceptability of urine-based screening for Chlamydia trachomatis in asymptomatic young men: a systematic review. Sex Transm Dis. 2008;35(11 Suppl):S28-33. Exclusion code: 5. [pmid: 18418291].
Marshall R, Chernesky M, Jang D, et al. Characteristics of the m2000 automated sample preparation and multiplex real-time PCR system for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2007;45(3):747-751. Exclusion code: 4. [pmid: 17202273].
Martens MG, Fine P, Fuller D, et al. Clinical evaluation of a new Pap test-based method for screening of Chlamydia trachomatis and Neisseria gonorrhoeae using liquid-based cytology media. South Med J. 2013;106(9):506-512. Exclusion code: 3. [pmid: 24002555].
Martin DH, Nsuami M, Schachter J, et al. Use of multiple nucleic acid amplification tests to define the infected-patient “gold standard” in clinical trials of new diagnostic tests for Chlamydia trachomatis infections. J Clin Microbiol. 2004;42(10):4749-4758. Exclusion code: 5. [pmid: 15472336].
Masek BJ, Arora N, Quinn N, et al. Performance of three nucleic acid amplification tests for detection of Chlamydia trachomatis and Neisseria gonorrhoeae by use of self-collected vaginal swabs obtained via an Internet-based screening program. J Clin Microbiol. 2009;47(6):1663-1667. Exclusion code: 4. [pmid: 19386838].
Mayor S. Chlamydia screening in young people fails to reduce prevalence. BMJ. 2009;339:b4736. Exclusion code: 7. [pmid: 19914952].
McClure JB, Scholes D, Grothaus L, et al. Chlamydia screening in at-risk adolescent females: an evaluation of screening practices and modifiable screening correlates. J Adolesc Health. 2006;38(6):726-733. Exclusion code: 3. [pmid: 16730602].
McDonnell DD, Levy V, Morton TJM. Risk factors for Chlamydia among young women in a northern california juvenile detention facility: implications for community intervention. Sex Transm Dis. 2009;36(2 Suppl):S29-33. Exclusion code: 5. [pmid: 18209687].
McGowin CL, Whitlock GC, Pyles RB. High-throughput multistrain polymerase chain reaction quantification of Chlamydia trachomatis from clinical and preclinical urogenital specimens. Diagn Microbiol Infect Dis. 2009;64(2):117-123. Exclusion code: 4. [pmid: 19345037].
McGrath CM, Katz AR, Lee MVC, Rochat RW. Chlamydia screening of adolescent females: a survey of providers in Hawaii. J Community Health. 2011;36(2):274-280. Exclusion code: 3. [pmid: 20824312].
McMillan A, Manavi K, Young H. Concurrent gonococcal and chlamydial infections among men attending a sexually transmitted diseases clinic. Int J STD AIDS. 2005;16(5):357-361. Exclusion code: 5. [pmid: 15949065].
McMillan HM, O'Carroll H, Lambert JS, et al. Screening for Chlamydia trachomatis in asymptomatic women attending outpatient clinics in a large maternity hospital in Dublin, Ireland. Sex Transm Infect. 2006;82(6):503-505. Exclusion code: 5. [pmid: 16854994].
McNally LP, Templeton DJ, Jin F, et al. Low positive predictive value of a nucleic acid amplification test for nongenital Neisseria gonorrhoeae infection in homosexual men. Clin Infect Dis. 2008;47(2):e25-27. Exclusion code: 4. [pmid: 18549310].
McNulty CAM, Freeman E, Howell-Jones R, et al. Overcoming the barriers to chlamydia screening in general practice--a qualitative study. Fam Pract. 2010;27(3):291-302. Exclusion code: 3. [pmid: 20308246].
McNulty CAM, Hogan AH, Ricketts EJ, et al. Increasing chlamydia screening tests in general practice: a modified Zelen prospective Cluster Randomised Controlled Trial evaluating a complex intervention based on the Theory of Planned Behaviour. Sex Transm Infect. 2014;90(3):188-194. Exclusion code: 4. [pmid: 24005256].
Meader E, Waters J, Sillis M. Chlamydia trachomatis RNA in the environment: is there potential for false-positive nucleic acid amplification test results?. Sex Transm Infect. 2008;84(2):107-110. Exclusion code: 5. [pmid: 17971374].
Merz AJ, So M. Interactions of pathogenic Neisseriae with epithelial cell membranes. Annu Rev Cell Dev Biol. 2000;16:423-457. Exclusion code: 2. [pmid: 11031243].
Mevissen FEF, Meertens RM, Ruiter RAC, Feenstra H, Schaalma HP. HIV/STI risk communication: the effects of scenario-based risk information and frequency-based risk information on perceived susceptibility to chlamydia and HIV. J Health Psychol. 2009;14(1):78-87. Exclusion code: 4. [pmid: 19129340].
Meyers D, Wolff T, Gregory K, et al. USPSTF recommendations for STI screening. Am Fam Physician. 2008;77(6):819-824. Exclusion code: 2. [pmid: 18386598].
Meyers DS, Halvorson H, Luckhaupt S. Screening for Chlamydial Infection: A Focused Evidence Update for the U.S. Preventive Services Task Force. Rockville (MD). Agency for Healthcare Research and Quality. Jun Preventive Services Task Force. 2007. Exclusion code: 2.
Meyers DS, Halvorson H, Luckhaupt S. Force USPST. Screening for chlamydial infection: an evidence update for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;147(2):135-142. Exclusion code: 2. [pmid: 17576995].
Michaud DS, Platz EA, Giovannucci E. Gonorrhoea and male bladder cancer in a prospective study. Br J Cancer. 2007;96(1):169-171. Exclusion code: 5. [pmid: 17164760].
Michel CEC, Sonnex C, Carne CA, et al. Chlamydia trachomatis load at matched anatomic sites: implications for screening strategies. J Clin Microbiol. 2007;45(5):1395-1402. Exclusion code: 5. [pmid: 17376879].
Miller JM, Maupin RT, Nsuami M. Initial and repeat testing for chlamydia during pregnancy. J Matern Fetal Neonatal Med. 2005;18(4):231-235. Exclusion code: 5. [pmid: 16318972].
Miller KE. Diagnosis and treatment of Neisseria gonorrhoeae infections. Am Fam Physician. 2006;73(10):1779-1784. Exclusion code: 7. [pmid: 16734055].
Miller KE. Diagnosis and treatment of Chlamydia trachomatis infection. Am Fam Physician. 2006;73(8):1411-1416. Exclusion code: 7. [pmid: 16669564].
Miller WC. Screening for chlamydial infection: are we doing enough?. Lancet. 2005;365(9458):456-458. Exclusion code: 7. [pmid: 15705443].
Miller WC, Hoffman IF, Owen-O'Dowd J, et al. Selective screening for chlamydial infection: which criteria to use?. Am J Prev Med. 2000;18(2):115-122. Exclusion code: 2. [pmid: 10698241].
Mills N, Daker-White G, Graham A, Campbell R. Population screening for Chlamydia trachomatis infection in the UK: a qualitative study of the experiences of those screened. Fam Pract. 2006;23(5):550-557. Exclusion code: 6. [pmid: 16790452].
Miranda AE, Szwarcwald CL, Peres RL, Page-Shafer K. Prevalence and risk behaviors for chlamydial infection in a population-based study of female adolescents in Brazil. Sex Transm Dis. 2004;31(9):542-546. Exclusion code: 5. [pmid: 15480115].
Mitka M. CDC: improve targeted screening for chlamydia. Jama. 2012;307(14):1472. Exclusion code: 7. [pmid: 22496252].
Molano M, Meijer CJLM, Morre SA, Pol R, van den Brule AJC. Combination of PCR targeting the VD2 of omp1 and reverse line blot analysis for typing of urogenital Chlamydia trachomatis serovars in cervical scrape specimens. J Clin Microbiol. 2004;42(7):2935-2939. Exclusion code: 4. [pmid: 15243041].
Moller JK, Pedersen LN, Persson K. Comparison of Gen-probe transcription-mediated amplification, Abbott PCR, and Roche PCR assays for detection of wild-type and mutant plasmid strains of Chlamydia trachomatis in Sweden. J Clin Microbiol. 2008;46(12):3892-3895. Exclusion code: 5. [pmid: 18842934].
Moller JK, Pedersen LN, Persson K. Comparison of the Abbott RealTime CT new formulation assay with two other commercial assays for detection of wild-type and new variant strains of Chlamydia trachomatis. J Clin Microbiol. 2010;48(2):440-443. Exclusion code: 3. [pmid: 20007394].
Moncada J, Donegan E, Schachter J. Evaluation of CDC-recommended approaches for confirmatory testing of positive Neisseria gonorrhoeae nucleic acid amplification test results. J Clin Microbiol. 2008;46(5):1614-1619. Exclusion code: 4. [pmid: 18322062].
Moncada J, Schachter J, Liska S, Shayevich C, Klausner JD. Evaluation of self-collected glans and rectal swabs from men who have sex with men for detection of Chlamydia trachomatis and Neisseria gonorrhoeae by use of nucleic acid amplification tests. J Clin Microbiol. 2009;47(6):1657-1662. Exclusion code: 4. [pmid: 19369445].
Morgan J, Donnell A, Bell A. Does a clinical guideline change chlamydia testing? Report from the Waikato Chlamydia Project. J Prim Health Care. 2012;4(1):45-51. Exclusion code: 5. [pmid: 22377549].
Morris SR, Bauer HM, Chartier M, et al. Relative efficiency of chlamydia screening in non-clinical settings in two California counties. Int J STD AIDS. 2010;21(1):52-56. Exclusion code: 5. [pmid: 20029065].
Morris W, Omokanye S. Chlamydia rates in postcoital IUD recipients. J Fam Plann Reprod Health Care. 2006;32(3):204. Exclusion code: 7. [pmid: 16857092].
Morton AN, Wakefield T, Tabrizi SN, Garland SM, Fairley CK. An outreach programme for sexually transmitted infection screening in street sex workers using self-administered samples. Int J STD AIDS. 1999;10(11):741-743. Exclusion code: 5. [pmid: 10563563].
Moss S, Mallinson H. The contribution of APTIMA Combo 2 assay to the diagnosis of gonorrhoea in genitourinary medicine setting. Int J STD AIDS. 2007;18(8):551-554. Exclusion code: 3. [pmid: 17686218].
Moss TR, Van Der Pol B. Dual infection with Neisseria gonorrhoeae and Chlamydia trachomatis. Int J STD AIDS. 2009;20(2):143-144. Exclusion code: 7. [pmid: 19182067].
Mossenson A, Algie K, Olding M, Garton L, Reeve C. ‘Yes wee can’ - a nurse-driven asymptomatic screening program for chlamydia and gonorrhoea in a remote emergency department. Sex Health. 2012;9(2):194-195. Exclusion code: 10. [pmid: 22498167].
Mukherjee A, Sood S, Bala M, et al. The role of a commercial enzyme immuno assay antigen detection system for diagnosis of C. trachomatis in genital swab samples. Indian J. 2011;29(4):411-413. Exclusion code: 3.
Mundy L, Hiller J. Rapid point-of-care test for the detection of Chlamydia in individuals at risk of trachoma. National Horizon Scanning Unit. 2006;13(1). Exclusion code: 7.
Opportunistic screening of symptomatic individuals for Chlamydia Commonwealth of Australia. 2007. Exclusion code: 7.
Munson E, Boyd V, Czarnecka J, et al. Evaluation of Gen-Probe APTIMA-based Neisseria gonorrhoeae and Chlamydia trachomatis confirmatory testing in a metropolitan setting of high disease prevalence. J Clin Microbiol. 2007;45(9):2793-2797. Exclusion code: 4. [pmid: 17581933].
Murphy PA, Jacobson J, Turok DK. Criterion-based screening for sexually transmitted infection: sensitivity, specificity, and predictive values of commonly used questions. J Midwifery Womens Health. 2012;57(6):622-628. Exclusion code: 4. [pmid: 23050734].
Mushanski LM, Brandt K, Coffin N, Levett PN, Horsman GB, Rank EL. Comparison of the BD Viper System with XTR Technology to the Gen-Probe APTIMA COMBO 2 Assay using the TIGRIS DTS system for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in urine specimens. Sex Transm Dis. 2012;39(7):514-517. Exclusion code: 3. [pmid: 22706212].
Myziuk L, Romanowski B, Brown M. Endocervical Gram stain smears and their usefulness in the diagnosis of Chlamydia trachomatis. Sex Transm Infect. 2001;77(2):103-106. Exclusion code: 3. [pmid: 11287687].
Nadala EC, Goh BT, Magbanua JP, et al. Performance evaluation of a new rapid urine test for chlamydia in men: prospective cohort study. BMJ. 2009;339:b2655. Exclusion code: 4. [pmid: 19638650].
Nagasawa Z, Ikeda-Dantsuji Y, Niwa T, Miyakoshi H, Nagayama A. Evaluation of APTIMA Combo 2 for cross-reactivity with oropharyngeal Neisseria species and other microorganisms. Clin Chim Acta. 2010;411(9-10):776-778. Exclusion code: 5. [pmid: 20138032].
Nasution TA, Cheong SF, Lim CT, Leong EWK, Ngeow YF. Multiplex PCR for the detection of urogenital pathogens in mothers and newborns. Malays J Pathol. 2007;29(1):19-24. Exclusion code: 3. [pmid: 19105324].
Naucler P, Chen HC, Persson K, et al. Seroprevalence of human papillomaviruses and Chlamydia trachomatis and cervical cancer risk: nested case-control study. J Gen Virol. 2007;88(Pt 3):814-822. Exclusion code: 5. [pmid: 17325353].
Nelson H, Cantor A, Zakher B, Fraenkel M, Pappas M. Screening for Gonorhea and Chlamydia: Systematic Review to Update the U.S. Preventive Services Task Force Recommendations [in press]. Rockvile, MD. Agency for Healthcare Research and Quality. 2014. Exclusion code: 2.
Nelson HD, Helfand M. Screening for chlamydial infection. Am J Prev Med. 2001;20(3 SUPPL):95-107. Exclusion code: 2. [pmid: 11306238].
Ness RB, Shen C, Bass D, et al. Chlamydia trachomatis serology in women with and without ovarian cancer. Infect Dis Obstet Gynecol. 2008;2008:219672. Exclusion code: 5. [pmid: 19125176].
Ness RB, Smith KJ, Chang CCH, Schisterman EF, Bass DC. Gynecologic Infection Follow-Through GI. Prediction of pelvic inflammatory disease among young, single, sexually active women. Sex Transm Dis. 2006;33(3):137-142. Exclusion code: 5. [pmid: 16505735].
Nogales MC, Castro C, Ramirez M, et al. Diagnosis of Chlamydia trachomatis infection in a clinic for sexually transmitted disease: evaluation of cervical, urethral and rectal swab samples by polymerase chain reaction. Enferm Infecc Microbiol Clin. 2007;25(1):11-15. Exclusion code: 3. [pmid: 17261241].
Noguchi Y, Kanyama A, Fujita M, et al. Evaluation of the new nucleic acid amplification system for direct detection of Chlamydia trachomatis and Neisseria gonorrhoeae in women. Kansenshogaku Zasshi. 2006;80(3):251-256. Exclusion code: 8. [pmid: 16780132].
Noone A, Spiers A, Allardice G, et al. Opportunistic screening for genital Chlamydia trachomatis infection and partner follow-up in family planning clinics in three Scottish cities. J Fam Plann Reprod Health Care. 2004;30(2):84-85. Exclusion code: 10. [pmid: 15086989].
Novak D, Novak M. Use of the Internet for home testing for Chlamydia trachomatis in Sweden: who are the users?. Int J STD AIDS. 2012;23(2):83-87. Exclusion code: 4. [pmid: 22422680].
Novak DP, Karlsson RB. Simplifying chlamydia testing: an innovative Chlamydia trachomatis testing approach using the internet and a home sampling strategy: population based study. Sex Transm Infect. 2006;82(2):142-147. discussion 152-143. Exclusion code: 10. [pmid: 16581742].
Oakeshott P, Aghaizu A, Reid F, et al. Frequency and risk factors for prevalent, incident, and persistent genital carcinogenic human papillomavirus infection in sexually active women: community based cohort study. BMJ. 2012;344:e4168. Exclusion code: 5. [pmid: 22730542].
Oakeshott P, Kerry S, Atherton H, et al. Community-based trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: The POPI (Prevention Of Pelvic Infection) Trial. Trials. 2008;9. Exclusion code: 7.
Okuda H, Ohya K, Shiota Y, Kato H, Fukushi H. Detection of Chlamydophila psittaci by using SYBR green real-time PCR. J Vet Med Sci. 2011;73(2):249-254. Exclusion code: 3. [pmid: 20948172].
Oliveira MdL, Amorim MMRd, Souza ASRd, Albuquerque LCBd, Costa AARd. Chlamydia infection in patients with and without cervical intra-epithelial lesions. Rev Assoc Med Bras. 2008;54(6):506-512. Exclusion code: 5. [pmid: 19197527].
Oliveira MdL, Amorim MMRd, Souza PREd, Albuquerque LCBd, Brandao LAC, Guimaraes RL. Chlamydia infection in patients with and without cervical intra-epithelial lesions tested by real-time PCR vs. direct immunofluorescence. Braz J Infect Dis. 2008;12(4):324-328. Exclusion code: 5. [pmid: 19030735].
Olshen E, Shrier LA. Diagnostic tests for chlamydial and gonorrheal infections. Semin Pediatr Infect Dis. 2005;16(3):192-198. Exclusion code: 7. [pmid: 16044393].
O'Mahony C, Gupta M, Edirisinghe D, Worthen E. One-year experience of APTIMA COMBO 2 Transcription Mediated Assay (TMA) for chlamydia and gonorrhoea in a district general hospital. Int J STD AIDS. 2006;17(4):283. Exclusion code: 6. [pmid: 16595056].
O'Mahony C, Reeve-Fowkes A, Worthen E, Mallinson H. Three years of using Aptima Combo 2 (AC2) transcription-mediated amplification for gonorrhoea in a district hospital genitourinary medicine clinic shows it to be superior to culture and has a specificity of almost 100%. Int J STD AIDS. 2008;19(1):67-69. Exclusion code: 7. [pmid: 18275655].
O'Neil D, Doseeva V, Rothmann T, Wolff J, Nazarenko I. Evaluation of Chlamydia trachomatis and Neisseria gonorrhoeae detection in urine, endocervical, and vaginal specimens by a multiplexed isothermal thermophilic helicase-dependent amplification (tHDA) assay. J Clin Microbiol. 2011;49(12):4121-4125. Exclusion code: 4. [pmid: 21956990].
Oppelt P, Renner SP, Strick R, et al. Correlation of high-risk human papilloma viruses but not of herpes viruses or Chlamydia trachomatis with endometriosis lesions. Fertil Steril. 2010;93(6):1778-1786. Exclusion code: 5. [pmid: 19200955].
Ostergaard L, Andersen B, Moller JK, Olesen F. Home sampling versus conventional swab sampling for screening of Chlamydia trachomatis in women: a cluster-randomized 1-year follow-up study. Clin Infect Dis. 2000;31(4):951-957. Exclusion code: 3. [pmid: 11049776].
Ostergaard L, Andersen B, Olesen F, Moller JK. Efficacy of home sampling for screening of Chlamydia trachomatis: randomised study. BMJ. 1998;317(7150):26-27. Exclusion code: 3. [pmid: 9651263].
Ostergaard L, Moller JK, Andersen B, Olesen F. Diagnosis of urogenital Chlamydia trachomatis infection in women based on mailed samples obtained at home: multipractice comparative study. BMJ. 1996;313(7066):1186-1189. Exclusion code: 3. [pmid: 8916753].
Ota KV, Tamari IE, Smieja M, et al. Detection of Neisseria gonorrhoeae and Chlamydia trachomatis in pharyngeal and rectal specimens using the BD Probetec ET system, the Gen-Probe Aptima Combo 2 assay and culture. Sex Transm Infect. 2009;85(3):182-186. Exclusion code: 3. [pmid: 19126571].
Ouden DD, Derouin A, Silva S, Khan A. Screening for chlamydia: are you doing it?. Nurse Pract. 2014;39(4):41-47. Exclusion code: 7. [pmid: 24633638].
Owusu-Edusei K, Bohm MK, Kent CK. Diagnostic methodologies for chlamydia screening in females aged 15 to 25 years from private insurance claims data in the United States, 2001 to 2005. Sex Transm Dis. 2009;36(7):419-421. Exclusion code: 10. [pmid: 19556935].
Paavonen J. Chlamydia carrier--symptomless or unfaithful?. Duodecim. 2012;128(13):1351-1356. Exclusion code: 8. [pmid: 22880369].
Palmer HM, Gilroy CB, Thomas BJ, Hay PE, Gilchrist C, Taylor-Robinson D. Detection of Chlamydia trachomatis by the polymerase chain reaction in swabs and urine from men with non-gonococcal urethritis. J Clin Pathol. 1991;44(4):321-325. Exclusion code: 3. [pmid: 2030152].
Panknin HT. How frequently are chlamydia responsible for newborn conjunctivitis? A study in Holland reveals current prevalence. Kinderkrankenschwester. 2009;28(7):294-295. Exclusion code: 8. [pmid: 19731760].
Papp JR, Ahrens K, Phillips C, Kent CK, Philip S, Klausner JD. The use and performance of oral-throat rinses to detect pharyngeal Neisseria gonorrhoeae and Chlamydia trachomatis infections. Diagn Microbiol Infect Dis. 2007;59(3):259-264. Exclusion code: 4. [pmid: 17662554].
Park J, Marcus JL, Pandori M, Snell A, Philip SS, Bernstein KT. Sentinel surveillance for pharyngeal chlamydia and gonorrhea among men who have sex with men--San Francisco, 2010. Sex Transm Dis. 2012;39(6):482-484. Exclusion code: 5. [pmid: 22592836].
Parra-Sanchez M, Palomares JC, Bernal S, et al. Evaluation of the cobas 4800 CT/NG Test for detecting Chlamydia trachomatis and Neisseria gonorrhoeae DNA in urogenital swabs and urine specimens. Diagn Microbiol Infect Dis. 2012;74(4):338-342. Exclusion code: 3. [pmid: 22995365].
Pathela P, Hennessy RR, Blank S, Parvez F, Franklin W, Schillinger JA. The contribution of a urine-based jail screening program to citywide male Chlamydia and gonorrhea case rates in New York City. Sex Transm Dis. 2009;36(2 Suppl):S58-61. Exclusion code: 5. [pmid: 17989586].
Pearce DM, Shenton DP, Holden J, Gaydos CA. Evaluation of a novel electrochemical detection method for Chlamydia trachomatis: application for point-of-care diagnostics. IEEE Trans Biomed Eng. 2011;58(3):755-758. Exclusion code: 4. [pmid: 21118757].
Peng Xb, Zeng K. Ligase chain reaction for Chlamydia trachomatis detection in urine specimens from symptomatic and asymptomatic men. Di Yi Jun Yi Da Xue Xue Bao. 2004;24(5):485-488. Exclusion code: 4. [pmid: 15151813].
Penney GC, Thomson M, Norman J, et al. A randomised comparison of strategies for reducing infective complications of induced abortion. Br J Obstet Gynaecol. 1998;105(6):599-604. Exclusion code: 4. [pmid: 9647149].
Perlik M, Drews K, Pienskowski W. Is it justifiable to perform screening tests for Chlamydia trachomatis in pregnant women?. Med Wieku Rozwoj. 2005;9(1):117-125. Exclusion code: 7. [pmid: 16082073].
Perquin DAM, Beersma MFC, de Craen AJM, Helmerhorst FM. The value of Chlamydia trachomatis-specific IgG antibody testing and hysterosalpingography for predicting tubal pathology and occurrence of pregnancy. Fertil Steril. 2007;88(1):224-226. Exclusion code: 5. [pmid: 17296194].
Peterman TA, Newman DR, Goldberg M, et al. Screening male prisoners for Chlamydia trachomatis: impact on test positivity among women from their neighborhoods who were tested in family planning clinics. Sex Transm Dis. 2009;36(7):425-429. Exclusion code: 5. [pmid: 19525892].
Petersen RW, Tabrizi SN, Garland S, Quinlivan JA. Prevalence of Chlamydia trachomatis in a public colposcopy clinic population. Sex Health. 2007;4(2):133-136. Exclusion code: 5. [pmid: 17524292].
Pientong C, Ekalaksananan T, Wonglikitpanya N, Swadpanich U, Kongyingyoes B, Kleebkaow P. Chlamydia trachomatis infections and the risk of ectopic pregnancy in Khon Kaen women. J Obstet Gynaecol Res. 2009;35(4):775-781. Exclusion code: 5. [pmid: 19751341].
Pittaras TE, Papaparaskevas J, Houhoula DP, et al. Comparison of penile skin swab with intra-urethral swab and first void urine for polymerase chain reaction-based diagnosis of Chlamydia trachomatis urethritis in male patients. Sex Transm Dis. 2008;35(12):999-1001. Exclusion code: 4. [pmid: 18665017].
Pope CF, Hay P, Alexander S, et al. Positive predictive value of the Becton Dickinson VIPER system and the ProbeTec GC Q x assay, in extracted mode, for detection of Neisseria gonorrhoeae. Sex Transm Infect. 2010;86(6):465-469. Exclusion code: 3. [pmid: 20940160].
Porter KA, Thomas JC, Emch ME. Variations in the effect of incarceration on community gonorrhoea rates, Guilford County, North Carolina, 2005-2006. Int J STD AIDS. 2010;21(1):34-38. Exclusion code: 5. [pmid: 19884357].
Potterat JJ. Active detection of men with asymptomatic chlamydial or gonorrhoeal urethritis. Int J STD AIDS. 2005;16(6):458. Exclusion code: 7. [pmid: 15969789].
Powers ME, Adekeye T, Volny R. Chlamydia screening: what about the men?. Am J Public Health. 2011;101(4):583-584. author reply 584-585. Exclusion code: 7. [pmid: 21389286].
Public Health Agency of Canada. Canadian Guidelines on Sexually Transmitted Infections. 2010. Exclusion code: 2.
Public Health Agency of Canada. Canadian Guidelines on Sexually Transmitted Infections. Section 5 - Management and Treatment of Specific Infections; Gonococcal Infections. 2013. Revised July 2013 http://www.phac-aspc.gc.ca/std-mts/sti-its/cgsti-ldcits/section-5-6-eng.php#toc361210448. Exclusion code: 2.
Quint KD, Bom RJM, Bruisten SM, et al. Comparison of three genotyping methods to identify Chlamydia trachomatis genotypes in positive men and women. Mol Cell Probes. 2010;24(5):266-270. Exclusion code: 4. [pmid: 20457248].
Radouani F, Maile J, Betsou F. Serological profiling with Chlamycheck, a commercial multiplex recombinant antigen Western blot assay of chlamydial infections. Can J Microbiol. 2007;53(12):1360-1368. Exclusion code: 3. [pmid: 18059568].
Rahman MS, Beever W, Skov S, Boffa J. Using urinary leucocyte esterase tests as an indicator of infection with gonorrhoea or chlamydia in asymptomatic males in a primary health care setting. Int J STD AIDS. 2014;25(2):138-144. Exclusion code: 4. [pmid: 23970638].
Rank EL, Sautter RL, Beavis KG, et al. A two-site analytical evaluation of the BD Viper System with XTR Technology in Nonextracted Mode and Extracted Mode with seeded simulated specimens. J Lab Autom. 2011;16(4):271-275. Exclusion code: 4. [pmid: 21764022].
Raychaudhuri M, Birley HDL. Audit of routine rectal swabs for gonorrhoea culture in women. Int J STD AIDS. 2010;21(2):143-144. Exclusion code: 5. [pmid: 20090002].
Razali MF, Fairley CK, Hocking J, Bradshaw CS, Chen MY. Sampling technique and detection rates for pharyngeal gonorrhea using culture. Sex Transm Dis. 2010;37(8):522-524. Exclusion code: 5. [pmid: 20661116].
Reagan MM, Xu H, Shih SL, Secura GM, Peipert JF. A randomized trial of home versus clinic-based sexually transmitted disease screening among men. Sex Transm Dis. 2012;39(11):842-847. Exclusion code: 5. [pmid: 23064532].
Regua-Mangia AH, Brito CMMd, Rosa RS, Correa MA, Santos-Perisse AR. Molecular diagnosis and genotyping of Neisseria gonorrhoeae in urine samples from women at low-income communities in Rio de Janeiro, Brazil. Braz J Infect Dis. 2012;16(1):105-106. Exclusion code: 3. [pmid: 22358368].
Reid RJ, Scholes D, Grothaus L, et al. Is provider continuity associated with chlamydia screening for adolescent and young adult women?. Prev Med. 2005;41(5-6):865-872. Exclusion code: 5. [pmid: 16169069].
Renton A, Filatova E, Ison C, et al. Performance of direct fluorescent antibody tests for routine diagnosis of Chlamydia trachomatis in Russian sexually transmitted disease clinics. Int J STD AIDS. 2008;19(12):851-855. Exclusion code: 4. [pmid: 19050218].
Renton A, Filatova E, Ison C, et al. A trial of the validity of genital smears and cultures with gonococcal vaccine provocation in diagnosing genital gonorrhoea in women. Int J STD AIDS. 2009;20(1):24-29. Exclusion code: 4. [pmid: 19103889].
Renton A, Thomas BM, Gill S, Lowndes C, Taylor-Robinson D, Patterson K. Chlamydia trachomatis in cervical and vaginal swabs and urine specimens from women undergoing termination of pregnancy. Int J STD AIDS. 2006;17(7):443-447. Exclusion code: 3. [pmid: 16820072].
Richardus JH, Gotz HM. Risk selection and targeted interventions in community-based control of chlamydia. Curr Opin Infect Dis. 2007;20(1):60-65. Exclusion code: 6. [pmid: 17197883].
Rietmeijer CA, Hopkins E, Geisler WM, Orr DP, Kent CK. Chlamydia trachomatis positivity rates among men tested in selected venues in the United States: a review of the recent literature. Sex Transm Dis. 2008;35(11 Suppl):S8-S18. Exclusion code: 5. [pmid: 18449072].
Roberts CH, Last A, Molina-Gonzalez S, et al. Development and evaluation of a next-generation digital PCR diagnostic assay for ocular Chlamydia trachomatis infections. J Clin Microbiol. 2013;51(7):2195-2203. Exclusion code: 4. [pmid: 23637300].
Roberts SW, Sheffield JS, McIntire DD, Alexander JM. Urine screening for Chlamydia trachomatis during pregnancy. Obstet Gynecol. 2011;117(4):883-885. Exclusion code: 3. [pmid: 21422860].
Rockett R, Goire N, Limnios A, et al. Evaluation of the cobas 4800 CT/NG test for detecting Chlamydia trachomatis and Neisseria gonorrhoeae. Sex Transm Infect. 2010;86(6):470-473. Exclusion code: 3. [pmid: 20719957].
Rompalo AM, Gaydos CA, Shah N, et al. Evaluation of use of a single intravaginal swab to detect multiple sexually transmitted infections in active-duty military women. Clin Infect Dis. 2001;33(9):1455-1461. Exclusion code: 3. [pmid: 11568849].
Rose SB, Lawton BA, Bromhead C, MacDonald EJ, Elley CR. Poor uptake of self-sample collection kits for Chlamydia testing outside primary care. Aust N Z J Public Health. 2010;34(5):517-520. Exclusion code: 5. [pmid: 21040182].
Rosenthal DA, Fairley CK, Garland SM, et al. Homeless young people: an important risk group for sexually transmitted infections. Med J Aust. 2000;172(5):244. Exclusion code: 5. [pmid: 10776403].
Ross JDC, Radcliffe KW. Why do those using illicit drugs have higher rates of sexually transmitted infection?. Int J STD AIDS. 2006;17(4):247-253. Exclusion code: 5. [pmid: 16595047].
Roth A, Van Der Pol B, Dodge B, Fortenberry JD, Zimet G. Future chlamydia screening preferences of men attending a sexually transmissible infection clinic. Sex Health. 2011;8(3):419-426. Exclusion code: 4. [pmid: 21851785].
Røttingen JA, Cameron WD, Garnett GP. A systematic review of the epidemiologic interactions between classic sexually transmitted diseases and HIV: How much really is known?. Sex Transm Dis. 2001;28(10):579-597. Exclusion code: 2. [pmid: 11689757].
Rours GIJG, Duijts L, Moll HA, et al. Chlamydia trachomatis infection during pregnancy associated with preterm delivery: a population-based prospective cohort study. Eur J Epidemiol. 2011;26(6):493-502. Exclusion code: 10. [pmid: 21538042].
Rours GIJG, Verkooyen RP, Willemse HFM, et al. Use of pooled urine samples and automated DNA isolation to achieve improved sensitivity and cost-effectiveness of large-scale testing for Chlamydia trachomatis in pregnant women. J Clin Microbiol. 2005;43(9):4684-4690. Exclusion code: 4. [pmid: 16145127].
Rowhani-Rahbar A, Niccolai LM, Dunne DW, Green S, Jenkins H, Khoshnood K. Comparative epidemiology of Chlamydia trachomatis infection among men attending sexually transmitted disease clinics with and without indication for testing. Int J STD AIDS. 2006;17(7):453-458. Exclusion code: 5. [pmid: 16820074].
Ruhl C. Update on Chlamydia and gonorrhea screening during pregnancy. Nurs Womens Health. 2013;17(2):143-146. Exclusion code: 7. [pmid: 23594327].
Ryan C, Kudesia G, McIntyre S, Davies S, Zadik P, Kinghorn GR. BD ProbeTec ET assay for the diagnosis of gonorrhoea in a high-risk population: a protocol for replacing traditional microscopy and culture techniques. Sex Transm Infect. 2007;83(3):175-179. discussion 179-180. Exclusion code: 3. [pmid: 17202199].
Ryder N, Lockart IG, Bourne C. Is screening asymptomatic men who have sex with men for urethral gonorrhoea worthwhile?. Sex Health. 2010;7(1):90-91. Exclusion code: 5. [pmid: 20152104].
Sabido M, Hernandez G, Gonzalez V, et al. Clinic-based evaluation of a rapid point-of-care test for detection of Chlamydia trachomatis in specimens from sex workers in Escuintla, Guatemala. J Clin Microbiol. 2009;47(2):475-476. Exclusion code: 4. [pmid: 19052178].
Sachse K, Hotzel H, Slickers P, Ehricht R. The use of DNA microarray technology for detection and genetic characterisation of chlamydiae. Dev Biol (Basel). 2006;126:203-210. discussion 326-207. Exclusion code: 5. [pmid: 17058496].
Sachse K, Hotzel H, Slickers P, Ellinger T, Ehricht R. DNA microarray-based detection and identification of Chlamydia and Chlamydophila spp. Mol Cell Probes. 2005;19(1):41-50. Exclusion code: 3. [pmid: 15652219].
Safaeian M, Quint K, Schiffman M, et al. Chlamydia trachomatis and risk of prevalent and incident cervical premalignancy in a population-based cohort. J Natl Cancer Inst. 2010;102(23):1794-1804. Exclusion code: 5. [pmid: 21098758].
Salazar LF, Crosby RA, Diclemente RJ. Exploring the mediating mechanism between gender-based violence and biologically confirmed Chlamydia among detained adolescent girls. Violence Against Women. 2009;15(3):258-275. Exclusion code: 5. [pmid: 19139491].
Salerno J, Darling-Fisher C, Hawkins NM, Fraker E. Identifying relationships between high-risk sexual behaviors and screening positive for chlamydia and gonorrhea in school-wide screening events. J Sch Health. 2013;83(2):99-104. Exclusion code: 5. [pmid: 23331269].
Samarawickrama A, Alexander S, Ison C. A laboratory-based evaluation of the BioStar Optical ImmunoAssay point-of-care test for diagnosing Neisseria gonorrhoeae infection. J Med Microbiol. 2011;60(Pt 12):1779-1781. Exclusion code: 4. [pmid: 21835969].
Samra Z, Rosenberg S, Madar-Shapiro L. Direct simultaneous detection of 6 sexually transmitted pathogens from clinical specimens by multiplex polymerase chain reaction and auto-capillary electrophoresis. Diagn Microbiol Infect Dis. 2011;70(1):17-21. Exclusion code: 3. [pmid: 21392925].
Sarlangue J, Castella C. Chlamydia infection in neonates and infants. Arch Pediatr. 2005;12(Suppl 1):S32-34. Exclusion code: 8. [pmid: 15893235].
Satterwhite CL, Gray AM, Berman S, Weinstock H, Kleinbaum D, Howards PP. Chlamydia trachomatis infections among women attending prenatal clinics: United States, 2004-2009. Sex Transm Dis. 2012;39(6):416-420. Exclusion code: 5. [pmid: 22592825].
Satterwhite CL, Grier L, Patzer R, Weinstock H, Howards PP, Kleinbaum D. Chlamydia positivity trends among women attending family planning clinics: United States, 2004-2008. Sex Transm Dis. 2011;38(11):989-994. Exclusion code: 8. [pmid: 21992972].
Savage EJ, Hughes G, Ison C, Lowndes CM. European Surveillance of Sexually Transmitted Infections n. Syphilis and gonorrhoea in men who have sex with men: a European overview. Euro Surveill. 2009;14(47). Exclusion code: 5.
Schachter J, Chernesky MA, Willis DE, et al. Vaginal swabs are the specimens of choice when screening for Chlamydia trachomatis and Neisseria gonorrhoeae: results from a multicenter evaluation of the APTIMA assays for both infections. Sex Transm Dis. 2005;32(12):725-728. Exclusion code: 3. [pmid: 16314767].
Schachter J, Chow JM, Howard H, Bolan G, Moncada J. Detection of Chlamydia trachomatis by nucleic acid amplification testing: our evaluation suggests that CDC-recommended approaches for confirmatory testing are ill-advised. J Clin Microbiol. 2006;44(7):2512-2517. Exclusion code: 4. [pmid: 16825373].
Schachter J, Hook EW, Martin DH, et al. Confirming positive results of nucleic acid amplification tests (NAATs) for Chlamydia trachomatis: all NAATs are not created equal. J Clin Microbiol. 2005;43(3):1372-1373. Exclusion code: 4. [pmid: 15750110].
Schachter J, Moncada J, Liska S, Shayevich C, Klausner JD. Nucleic acid amplification tests in the diagnosis of chlamydial and gonococcal infections of the oropharynx and rectum in men who have sex with men. Sex Transm Dis. 2008;35(7):637-642. Exclusion code: 2. [pmid: 18520976].
Schembri G, Schober P. Risk factors for chlamydial infection in chlamydia contacts: a questionnaire-based study. J Fam Plann Reprod Health Care. 2011;37(1):10-16. Exclusion code: 3. [pmid: 21367697].
Scholes D, Satterwhite CL, Yu O, Fine D, Weinstock H, Berman S. Long-term trends in Chlamydia trachomatis infections and related outcomes in a U.S. managed care population. Sex Transm Dis. 2012;39(2):81-88. Exclusion code: 10. [pmid: 22249294].
Scholes D, Stergachis A, Heidrich FE, Andrilla H, Holmes KK, Stamm WE. Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996;334(21):1362-1366. Exclusion code: 2. [pmid: 8614421].
Schwartz RM, Hogben M, Liddon N, et al. Coping with a diagnosis of C trachomatis or N gonorrhoeae: psychosocial and behavioral correlates. J Health Psychol. 2008;13(7):921-929. Exclusion code: 3. [pmid: 18809643].
Scott G. Chlamydia and male fertility. J R Soc Promot Health. 2004;124(5):211-212. Exclusion code: 7. [pmid: 15493777].
Scragg S, Bingham A, Mallinson H. Should Chlamydia trachomatis confirmation make you cross? Performance of collection kits tested across three nucleic acid amplification test platforms. Sex Transm Infect. 2006;82(4):295-297. Exclusion code: 4. [pmid: 16877577].
Sellors JW, Lorincz AT, Mahony JB, et al. Comparison of self-collected vaginal, vulvar and urine samples with physician-collected cervical samples for human papillomavirus testing to detect high-grade squamous intraepithelial lesions. Cmaj. 2000;163(5):513-518. Exclusion code: 5. [pmid: 11006761].
Senior K. Chlamydia: a much underestimated STI. Lancet Infect Dis. 2012;12(7):517-518. Exclusion code: 7. [pmid: 22930827].
Seth P, Wingood GM, DiClemente RJ, Robinson LS. Alcohol use as a marker for risky sexual behaviors and biologically confirmed sexually transmitted infections among young adult African-American women. Womens Health Issues. 2011;21(2):130-135. Exclusion code: 4. [pmid: 21276736].
Sethupathi M, Blackwell A. Chlamydia trachomatis infection: the efficacy and safety of a fast-track referral and treatment system. Int J STD AIDS. 2009;20(3):184-187. Exclusion code: 5. [pmid: 19255267].
Sexton ME, Baker JJ, Nakagawa K, et al. How reliable is self-testing for gonorrhea and chlamydia among men who have sex with men?. J Fam Pract. 2013;62(2):70-78. Exclusion code: 5. [pmid: 23405376].
Sharqi AA, Thompson C, Clutterbuck DJ. How many sexually transmitted infections (STIs) will we miss?--an algorithm to assess risk factors for STI. Int J STD AIDS. 2006;17(8):558-559. Exclusion code: 3. [pmid: 16925905].
She RC, Welch R, Wilson AR, Davis D, Litwin CM. Correlation of Chlamydia and Chlamydophila spp. IgG and IgM antibodies by microimmunofluorescence with antigen detection methods. J Clin Lab Anal. 2011;25(4):305-308. Exclusion code: 5. [pmid: 21786334].
Sheffield JS, Andrews WW, Klebanoff MA, et al. Spontaneous resolution of asymptomatic Chlamydia trachomatis in pregnancy. Obstet Gynecol. 2005;105(3):557-562. Exclusion code: 5. [pmid: 15738024].
Sheringham J. Screening for Chlamydia. BMJ. 2010;340:c1698. Exclusion code: 7. [pmid: 20378637].
Sherley M, Kennedy KJ, Martin SJ. Screening with nucleic acid amplification tests for gonorrhoea in men who have sex with men. Med J Aust. 2012;197(6):332. Exclusion code: 7. [pmid: 22994826].
Shields SA, Wong T, Mann J, et al. Prevalence and correlates of Chlamydia infection in Canadian street youth. J Adolesc Health. 2004;34(5):384-390. Exclusion code: 5. [pmid: 15093792].
Shrier LA, Schillinger JA, Aneja P, et al. Depressive symptoms and sexual risk behavior in young, chlamydia-infected, heterosexual dyads. J Adolesc Health. 2009;45(1):63-69. Exclusion code: 3. [pmid: 19541251].
Siemer J, Theile O, Larbi Y, et al. Chlamydia trachomatis infection as a risk factor for infertility among women in Ghana, West Africa. Am J Trop Med Hyg. 2008;78(2):323-327. Exclusion code: 5. [pmid: 18256439].
Silva LCF, Miranda AE, Batalha RS, et al. Chlamydia trachomatis infection among HIV-infected women attending an AIDS clinic in the city of Manaus, Brazil. Braz J Infect Dis. 2012;16(4):335-338. Exclusion code: 3. [pmid: 22846120].
Silva MJPMdA, Florencio GLD, Gabiatti JRE, Amaral RLd, Eleuterio Junior J, Goncalves AKdS. Perinatal morbidity and mortality associated with chlamydial infection: a meta-analysis study. Braz J Infect Dis. 2011;15(6):533-539. Exclusion code: 3. [pmid: 22218511].
Silveira MF, Ghanem KG, Erbelding EJ, et al. Chlamydia trachomatis infection during pregnancy and the risk of preterm birth: a case-control study. Int J STD AIDS. 2009;20(7):465-469. Exclusion code: 4. [pmid: 19541887].
Singh D, Fine DN, Marrazzo JM. Chlamydia trachomatis infection among women reporting sexual activity with women screened in Family Planning Clinics in the Pacific Northwest, 1997 to 2005. Am J Public Health. 2011;101(7):1284-1290. Exclusion code: 5. [pmid: 20724697].
Sirmatel F, Sahin N, Sirmatel O, Telli E, Kececi S. Chlamydia trachomatis antigen positivity in women in risk groups and its relationship with the use of antibiotics. Jpn J Infect Dis. 2005;58(1):41-43. Exclusion code: 4. [pmid: 15728992].
Skidmore S, Horner P, Herring A, et al. Vulvovaginal-swab or first-catch urine specimen to detect Chlamydia trachomatis in women in a community setting?. J Clin Microbiol. 2006;44(12):4389-4394. Exclusion code: 3. [pmid: 17065268].
Skjeldestad FE, Marsico MA, Sings HL, Nordbo SA, Storvold G. Incidence and risk factors for genital Chlamydia trachomatis infection: a 4-year prospective cohort study. Sex Transm Dis. 2009;36(5):273-279. Exclusion code: 5. [pmid: 19265733].
Skovgaard S, Larsen HK, Sand C, et al. Genital and extra-genital screening for gonorrhoea using the BD Probetec ET system with an in-house PCR method targeting the porA pseudogene as confirmatory test. Acta Derm Venereol. 2012;92(1):45-49. Exclusion code: 3. [pmid: 22002460].
Sparrow M, Lewis H, Brown P, Bromhead C, Fernando D, Maitra A. Chlamydia screening in Wellington Family Planning Association (FPA) clinics: a demonstration project. N Z Med J. 2007;120(1252):U2490. Exclusion code: 3. [pmid: 17460740].
Spaulding AC, Clarke JG, Jongco AM, Flanigan TP. Small reservoirs: jail screening for gonorrhea and Chlamydia in low prevalence areas. J. 2009;15(1):28-34. quiz 80-21. Exclusion code: 10.
Spauwen LWL, Hoebe CJPA, Brouwers EEHG, Dukers-Muijrers NHTM. Improving STD testing behavior among high-risk young adults by offering STD testing at a vocational school. BMC Public Health. 2011;11:750. Exclusion code: 10. [pmid: 21961932].
Spence D. Bad medicine: chlamydia. BMJ. 2010;340:c2547. Exclusion code: 7. [pmid: 20462923].
Spigarelli MG. Urine gonococcal/Chlamydia testing in adolescents. Curr Opin Obstet Gynecol. 2006;18(5):498-502. Exclusion code: 6. [pmid: 16932043].
Stampler KM, Lieberman A, Fraga M, Cohen A, Herman A. Vaginal wet mounts on asymptomatic adolescent females; are they beneficial?. J Pediatr Adolesc Gynecol. 2008;21(4):227-230. Exclusion code: 4. [pmid: 18656077].
Stanley B, Todd A. Testing for Neisseria gonorrhoeae by nucleic acid amplification testing of chlamydia samples using Roche Cobas Amplicor in a rural area in the north of England does not find more gonorrhoea in primary care. Sex Transm Infect. 2005;81(6):518. Exclusion code: 7. [pmid: 16326859].
Stary A, Najim B, Lee HH. Vulval swabs as alternative specimens for ligase chain reaction detection of genital chlamydial infection in women. J Clin Microbiol. 1997;35(4):836-838. Exclusion code: 4. [pmid: 9157137].
Stefanski P, Hafner JW, Riley SL, Sunga KLY, Schaefer TJ. Diagnostic utility of the genital Gram stain in ED patients. Am J Emerg Med. 2010;28(1):13-18. Exclusion code: 3. [pmid: 20006195].
Stein CR, Kaufman JS, Ford CA, Leone PA, Feldblum PJ, Miller WC. Screening young adults for prevalent chlamydial infection in community settings. Ann Epidemiol. 2008;18(7):560-571. Exclusion code: 3. [pmid: 18504140].
Stenqvist K, Lindqvist A, Almerson P, Jonsson L, Lander R. Chlamydia test via Internet a good alternative to testing in clinics. Lakartidningen. 2010;107(6):350-353. Exclusion code: 8. [pmid: 20297585].
Stephens RS. The cellular paradigm of chlamydial pathogenesis. Trends Microbiol. 2003;11(1):44-51. Exclusion code: 2. [pmid: 12526854].
Stevens MP, Twin J, Fairley CK, et al. Development and evaluation of an ompA quantitative real-time PCR assay for Chlamydia trachomatis serovar determination. J Clin Microbiol. 2010;48(6):2060-2065. Exclusion code: 4. [pmid: 20392903].
Stewart R. Opportunistic chlamydia testing: improving nursing practice through self-audit and reflection. Nurs Prax N Z. 2005;21(1):43-52. Exclusion code: 7. [pmid: 16764172].
Stolte IG, de Wit JBF, Kolader M, Fennema H, Coutinho RA, Dukers NHTM. Association between ‘safer sex fatigue’ and rectal gonorrhea is mediated by unsafe sex with casual partners among HIV-positive homosexual men. Sex Transm Dis. 2006;33(4):201-208. Exclusion code: 5. [pmid: 16505749].
Storm M, Gustafsson I, Herrmann B, Engstrand L. Real-time PCR for pharmacodynamic studies of Chlamydia trachomatis. J Microbiol Methods. 2005;61(3):361-367. Exclusion code: 3. [pmid: 15767012].
Stuart B, Hinde A. Identifying individuals engaging in risky sexual behaviour for chlamydia infection in the UK: a latent class approach. J Biosoc Sci. 2010;42(1):27-42. Exclusion code: 5. [pmid: 19793405].
Sturm PDJ, Connolly C, Khan N, Ebrahim S, Sturm AW. Vaginal tampons as specimen collection device for the molecular diagnosis of non-ulcerative sexually transmitted infections in antenatal clinic attendees. Int J STD AIDS. 2004;15(2):94-98. Exclusion code: 3. [pmid: 15006070].
Su WH, Tsou TS, Chen CS, et al. Are we satisfied with the tools for the diagnosis of gonococcal infection in females?. J Chin Med Assoc. 2011;74(10):430-434. Exclusion code: 7. [pmid: 22036133].
Su WH, Tsou TS, Chen CS, et al. Diagnosis of Chlamydia infection in women. Taiwan. 2011;50(3):261-267. Exclusion code: 12.
Sufrin CB, Postlethwaite D, Armstrong MA, Merchant M, Wendt JM, Steinauer JE. Neisseria gonorrhea and Chlamydia trachomatis screening at intrauterine device insertion and pelvic inflammatory disease. Obstet Gynecol. 2012;120(6):1314-1321. Exclusion code: 5. [pmid: 23168755].
Sullivan EA, Abel M, Tabrizi S, et al. Prevalence of sexually transmitted infections among antenatal women in Vanuatu, 1999-2000. Sex Transm Dis. 2003;30(4):362-366. Exclusion code: 5. [pmid: 12671560].
Suzuki K, Matsumoto T, Murakami H, Tateda K, Ishii N, Yamaguchi K. Evaluation of a rapid antigen detection test for Neisseria gonorrhoeae in urine sediment for diagnosis of gonococcal urethritis in males. J Infect Chemother. 2004;10(4):208-211. Exclusion code: 4. [pmid: 15365860].
Svenstrup HF, Fedder J, Kristoffersen SE, Trolle B, Birkelund S, Christiansen G. Mycoplasma genitalium, Chlamydia trachomatis, and tubal factor infertility--a prospective study. Fertil Steril. 2008;90(3):513-520. Exclusion code: 3. [pmid: 17548070].
Swain GR, McDonald RA, Pfister JR, Gradus MS, Sedmak GV, Singh A. Decision analysis: point-of-care Chlamydia testing vs. laboratory-based methods. Clin. 2004;2(1):29-35. Exclusion code: 3.
Swedish Council on Health Technology Assessment. Urine Specimens in Diagnosing Chlamydia in Women. SBU Alert. 052010. Exclusion code: 4.
Tabrizi S, Chen S, Fairley C, et al. Tampon-collected genital cells in the detection of Chlamydia trachomatis by polymerase chain reaction. J Infect Dis. 1993;168(3):796-797. Exclusion code: 4. [pmid: 8354930].
Tabrizi SN, Chen S, Tapsall J, Garland SM. Evaluation of opa-based real-time PCR for detection of Neisseria gonorrhoeae. Sex Transm Dis. 2005;32(3):199-202. Exclusion code: 4. [pmid: 15729160].
Tabrizi SN, Fairley CK, Cehn S, et al. Evaluation of patient-administered tampon specimens for Chlamydia trachomatis and Neisseria gonorrhoeae. Sex Transm Dis. 2000;27(3):133-137. Exclusion code: 4. [pmid: 10726644].
Tabrizi SN, Paterson B, Fairley CK, Bowden FJ, Garland SM. A self-administered technique for the detection of sexually transmitted diseases in remote communities. J Infect Dis. 1997;176(1):289-292. Exclusion code: 3. [pmid: 9207385].
Tabrizi SN, Paterson BA, Fairley CK, Bowden FJ, Garland SM. Comparison of tampon and urine as self-administered methods of specimen collection in the detection of Chlamydia trachomatis, Neisseria gonorrhoeae and Trichomonas vaginalis in women. Int J STD AIDS. 1998;9(6):347-349. Exclusion code: 4. [pmid: 9671249].
Tabrizi SN, Skov S, Chandeying V, Norpech J, Garland SM. Prevalence of sexually transmitted infections among clients of female commercial sex workers in Thailand. Sex Transm Dis. 2000;27(6):358-362. Exclusion code: 10. [pmid: 10907913].
Taha NSA, Focchi J, Ribalta JCL, Castelo A, Lorincz A, Dores GB. Universal Collection Medium (UCM) is as suitable as the Standard Transport Medium (STM) for Hybrid Capture II (HC-2) assay. J Clin Virol. 2006;36(1):32-35. Exclusion code: 4. [pmid: 16483839].
Tang J, Xu Z, Zhou L, Qin H, Wang Y, Wang H. Rapid and simultaneous detection of Ureaplasma parvum and Chlamydia trachomatis antibodies based on visual protein microarray using gold nanoparticles and silver enhancement. Diagn Microbiol Infect Dis. 2010;67(2):122-128. Exclusion code: 5. [pmid: 20207096].
Tao G, Hoover KW, Kent CK. Chlamydia testing patterns for commercially insured women, 2008. Am J Prev Med. 2012;42(4):337-341. Exclusion code: 5. [pmid: 22424245].
Tao G, Irwin KL. Receipt of HIV and STD testing services during routine general medical or gynecological examinations: Variations by patient sexual risk behaviors. Sex Transm Dis. 2008;35(2):167-171. Exclusion code: 2. [pmid: 18090177].
Tao G, Tian LH, Peterman TA. Estimating Chlamydia screening rates by using reported sexually transmitted disease tests for sexually active women aged 16 to 25 years in the United States. Sex Transm Dis. 2007;34(3):180-182. Exclusion code: 5. [pmid: 16865052].
Tebb K, Wibbelsman C, Ko T, Neuhaus JM, Shafer MA. Translating and sustaining a chlamydial screening intervention 4 years later. Arch Intern Med. 2011;171(19):1767-1768. Exclusion code: 5. [pmid: 22025436].
Tebb KP, Pantell RH, Wibbelsman CJ, et al. Screening sexually active adolescents for Chlamydia trachomatis: what about the boys?. Am J Public Health. 2005;95(10):1806-1810. Exclusion code: 5. [pmid: 16186459].
Tebb KP, Wibbelsman C, Neuhaus JM, Shafer MA. Screening for asymptomatic Chlamydia infections among sexually active adolescent girls during pediatric urgent care. Arch Pediatr Adolesc Med. 2009;163(6):559-564. Exclusion code: 5. [pmid: 19487613].
Templeton DJ, Jin F, Imrie J, et al. Prevalence, incidence and risk factors for pharyngeal chlamydia in the community based Health in Men (HIM) cohort of homosexual men in Sydney, Australia. Sex Transm Infect. 2008;84(5):361-363. Exclusion code: 5. [pmid: 18596068].
Templeton DJ, Manokaran N, O'Connor CC. Prevalence and predictors of chlamydia co-infection among patients infected with gonorrhoea at a sexual health clinic in Sydney. Sex Health. 2012;9(4):392-394. Exclusion code: 5. [pmid: 22877601].
Templeton DJ, Wang Y, Higgins AN, Manokaran N. Self-collected anal swabs in men who have sex with men: minimal benefit of routine peri-anal examination. Sex Transm Infect. 2011;87(3):204. Exclusion code: 10. [pmid: 21292689].
Thomas G, Humphris G, Ozakinci G, et al. A qualitative study of pharmacists' views on offering chlamydia screening to women requesting Emergency Hormonal Contraception. Bjog. 2010;117(1):109-113. Exclusion code: 5. [pmid: 19775305].
Thomas TL, Nandram B. Predicting incidence and asymptomatic rates for chlamydia in small domains. J Adv Nurs. 2010;66(12):2650-2658. Exclusion code: 5. [pmid: 20735497].
Tikkanen M, Surcel HM, Bloigu A, et al. Prediction of placental abruption by testing for C-reactive protein and chlamydial antibody levels in early pregnancy. Bjog. 2008;115(4):486-491. Exclusion code: 4. [pmid: 18271885].
Tinmouth J, Gilmour MW, Kovacs C, et al. Is there a reservoir of sub-clinical lymphogranuloma venereum and non-LGV Chlamydia trachomatis infection in men who have sex with men?. Int J STD AIDS. 2008;19(12):805-809. Exclusion code: 5. [pmid: 19050208].
Tipple C, Hill SC, Smith A. Is screening for pharyngeal Chlamydia trachomatis warranted in high-risk groups?. Int J STD AIDS. 2010;21(11):770-771. Exclusion code: 4. [pmid: 21187360].
Tomanovic S, Cukic I, Obradovic M, Curcic N, Petrovic-Milinkovic A, Djukic S. The diagnosis of Chlamydia trachomatis cervical infection among students by using classical and molecular methods. Srp Arh Celok Lek. 2013;141(3-4):187-191. Exclusion code: 8. [pmid: 23745341].
Tomanovic S, Dukic S. Classical and molecular methods for diagnosis of Chlamydia trachomatis infections. Med Pregl. 2011;64(9-10):477-480. Exclusion code: 7. [pmid: 22097114].
Toro MC. Closing in on Chlamydia. Nursing. 2008;38(9):61. Exclusion code: 7. [pmid: 18719500].
Tosun I, Cihanyurdu M, Kaklikkaya N, Topbas M, Aydin F, Erturk M. Asymptomatic Chlamydia trachomatis infection and predictive criteria among low-risk women in a primary care setting. Jpn J Infect Dis. 2008;61(3):216-218. Exclusion code: 5. [pmid: 18503174].
Toth M, Patton DL, Esquenazi B, Shevchuk M, Thaler H, Divon M. Association between Chlamydia trachomatis and abnormal uterine bleeding. Am J Reprod Immunol. 2007;57(5):361-366. Exclusion code: 4. [pmid: 17430500].
Tran K, Nkansah E. Urine based testing for Gonorrhea and Chlamydia: A review of diagnostic accuracy, cost-effectiveness, and compliance. Health Technology Inquiry Service. 2009. Exclusion code: 12.
Tran K, Nkansah E. Urine based testing for gonorrhea and chlamydia: a review of diagnostic accuracy, cost-effectiveness, and compliance (Structured abstract). Health Technology Assessment Database. 2013;(1). Exclusion code: 2.
Tsesliuk MV, Gushchin AE, Savochkina IA, Bykov AS, Shipulin GA. Comparison of methods for laboratory diagnosis of Neisseria gonorrhoeae by using the “extended gold standard”. Klin Lab Diagn. 2008;(7):48-52. Exclusion code: 8. [pmid: 18763330].
Tsuruoka N, Uzawa Y, Kikuchi K, Ohtsuka H, Todome Y, Ohkuni H. Evaluation of the GonoGen II kit for rapid identification of Neisseria gonorrhoeae using monoclonal antibody directed at gonococcal outer membrane protein 1. Kansenshogaku Zasshi. 2008;82(4):317-321. Exclusion code: 8. [pmid: 18697483].
U.S. Preventive Services Task Force. Screening for Gonorrhea: Recommendation Statement. American Academy of Family Physicians. 2005;3(3):263-267. Exclusion code: 2.
U.S. Preventive Services Task Force. Procedure Manual. 2011. U.S. Preventive Services Task Force. Rockvile, MD. Available at: http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 15 April, 2014. Exclusion code: 2.
U. S. Preventive Services Task Force, Calonge N, Petitti DB, et al. Screening for chlamydial infection: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2007;147(2):128-134. Exclusion code: 2. [pmid: 17576996].
Uuskula A, Kals M, McNutt LA. Assessing non-response to a mailed health survey including self-collection of biological material. Eur J Public Health. 2011;21(4):538-542. Exclusion code: 5. [pmid: 20457781].
van Bergen J. Chlamydia infection. Screening needs more answers. BMJ. 2010;340:c2502. Exclusion code: 7. [pmid: 20460319].
van Bergen JEAM, Fennema JSA, van den Broek IVF, et al. Rationale, design, and results of the first screening round of a comprehensive, register-based, Chlamydia screening implementation programme in the Netherlands. BMC Infect Dis. 2010;10:293. Exclusion code: 2. [pmid: 20925966].
van den Bos RR, van der Meijden WI. Persistent high-risk sexual behaviour in men who have sex with men after symptomatic lymphogranuloma venereum proctitis. Int J STD AIDS. 2007;18(10):715-716. Exclusion code: 3. [pmid: 17945053].
van den Broek IVF, Brouwers EEHG, Gotz HM, et al. Systematic selection of screening participants by risk score in a Chlamydia screening programme is feasible and effective. Sex Transm Infect. 2012;88(3):205-211. Exclusion code: 5. [pmid: 22215696].
van den Broek IVF, Hoebe CJPA, van Bergen JEAM, et al. Evaluation design of a systematic, selective, internet-based, Chlamydia screening implementation in the Netherlands, 2008-2010: implications of first results for the analysis. BMC Infect Dis. 2010;10:89. Exclusion code: 3. [pmid: 20374635].
van den Broek IVF, van Bergen JEAM, Brouwers EEHG, et al. Effectiveness of yearly, register based screening for chlamydia in the Netherlands: controlled trial with randomised stepped wedge implementation. BMJ. 2012;345:e4316. Exclusion code: 5. [pmid: 22767614].
Van der Bij AK, Spaargaren J, Morre SA, et al. Diagnostic and clinical implications of anorectal lymphogranuloma venereum in men who have sex with men: a retrospective case-control study. Clin Infect Dis. 2006;42(2):186-194. Exclusion code: 5. [pmid: 16355328].
van der Helm JJ, Hoebe CJPA, van Rooijen MS, et al. High performance and acceptability of self-collected rectal swabs for diagnosis of Chlamydia trachomatis and Neisseria gonorrhoeae in men who have sex with men and women. Sex Transm Dis. 2009;36(8):493-497. Exclusion code: 4. [pmid: 19617869].
van der Helm JJ, Sabajo LOA, Grunberg AW, Morre SA, Speksnijder AGCL, de Vries HJC. Point-of-care test for detection of urogenital chlamydia in women shows low sensitivity. A performance evaluation study in two clinics in Suriname. PLoS ONE. 2012;7(2):e32122. Exclusion code: 3. [pmid: 22393383].
Van Der Pol B, Kraft CS, Williams JA. Use of an adaptation of a commercially available PCR assay aimed at diagnosis of chlamydia and gonorrhea to detect Trichomonas vaginalis in urogenital specimens. J Clin Microbiol. 2006;44(2):366-373. Exclusion code: 5. [pmid: 16455885].
Van Der Pol B, Taylor SN, Liesenfeld O, Williams JA, Hook EW 3rd. Vaginal swabs are the optimal specimen for detection of genital Chlamydia trachomatis or Neisseria gonorrhoeae using the Cobas 4800 CT/NG test. Sex Transm Dis. 2013;40(3):247-250. Exclusion code: 3. [pmid: 23407470].
van Dommelen L, Dukers-Muijrers N, van Tiel FH, Brouwers EEHG, Hoebe CJPA. Evaluation of one-sample testing of self-obtained vaginal swabs and first catch urine samples separately and in combination for the detection of Chlamydia trachomatis by two amplified DNA assays in women visiting a sexually transmitted disease clinic. Sex Transm Dis. 2011;38(6):533-535. Exclusion code: 3. [pmid: 21217415].
van Dommelen L, van Tiel FH, Ouburg S, et al. Alarmingly poor performance in Chlamydia trachomatis point-of-care testing. Sex Transm Infect. 2010;86(5):355-359. Exclusion code: 4. [pmid: 20876754].
Van Dyck E, Ieven M, Pattyn S, Van Damme L, Laga M. Detection of Chlamydia trachomatis and Neisseria gonorrhoeae by enzyme immunoassay, culture, and three nucleic acid amplification tests. J Clin Microbiol. 2001;39(5):1751-1756. Exclusion code: 3. [pmid: 11325985].
Vaughan D, O'Connell E, Cormican M, et al. “Pee-in-a-Pot”: acceptability and uptake of on-site chlamydia screening in a student population in the Republic of Ireland. BMC Infect Dis. 2010;10:325. Exclusion code: 5. [pmid: 21070646].
Venkatesh KK, van der Straten A, Cheng H, et al. The relative contribution of viral and bacterial sexually transmitted infections on HIV acquisition in southern African women in the Methods for Improving Reproductive Health in Africa study. Int J STD AIDS. 2011;22(4):218-224. Exclusion code: 4. [pmid: 21515755].
Verhelst R, Verstraelen H, Claeys G, et al. Comparison between Gram stain and culture for the characterization of vaginal microflora: definition of a distinct grade that resembles grade I microflora and revised categorization of grade I microflora. BMC Microbiol. 2005;5:61. Exclusion code: 3. [pmid: 16225680].
Verhoeven V, Avonts D, Van Royen P, Denekens J. Implementation of a pilot programme for screening for chlamydial infection in general practice. Eur J Gen Pract. 2004;10(4):157-161. Exclusion code: 3. [pmid: 15724126].
Verhoeven V, Avonts D, Van Royen P, Weyler J, Wang X, Stalpaert M. Performance of a screening algorithm for chlamydial infection in 2 samples of patients in general practice. Scand J Infect Dis. 2004;36(11-12):873-875. Exclusion code: 3. [pmid: 15764176].
Verhoeven V, Baay M, Weyler J, et al. Concomitant Chlamydia trachomatis and human papilloma virus infection cannot be attributed solely to sexual behaviour. Eur J Clin Microbiol Infect Dis. 2004;23(9):735-737. Exclusion code: 5. [pmid: 15322933].
Verkooyen RP, Noordhoek GT, Klapper PE, et al. Reliability of nucleic acid amplification methods for detection of Chlamydia trachomatis in urine: results of the first international collaborative quality control study among 96 laboratories. J Clin Microbiol. 2003;41(7):3013-3016. Exclusion code: 4. [pmid: 12843035].
Verma R, Sood S, Bala M, et al. Diagnostic implications of 16S ribosomal assay for gonorrhoea. Sex Transm Infect. 2010;86(6):461-464. Exclusion code: 4. [pmid: 20542960].
Verma R, Sood S, Bala M, et al. Evaluation of an opa gene-based nucleic acid amplification test for detection of Neisseria gonorrhoeae in urogenital samples in North India. Epidemiol Infect. 2012;140(11):2110-2116. Exclusion code: 4. [pmid: 22244259].
Vernel-Pauillac F, Merien F. A novel real-time duplex PCR assay for detecting penA and ponA genotypes in Neisseria gonorrhoeae: Comparison with phenotypes determined by the E-test. Clin Chem. 2006;52(12):2294-2296. Exclusion code: 4. [pmid: 17053151].
Vickerman P, Watts C, Alary M, Mabey D, Peeling RW. Sensitivity requirements for the point of care diagnosis of Chlamydia trachomatis and Neisseria gonorrhoeae in women. Sex Transm Infect. 2003;79(5):363-367. Exclusion code: 5. [pmid: 14573829].
Voelker R. Experts reconsider wisdom of limiting Chlamydia screening only to women. Jama. 2010;303(9):823-824. Exclusion code: 7. [pmid: 20197522].
Walker J, Fairley CK, Walker SM, et al. Computer reminders for Chlamydia screening in general practice: a randomized controlled trial. Sex Transm Dis. 2010;37(7):445-450. Exclusion code: 4. [pmid: 20375930].
Wallace LA, Scoular A, Hart G, Reid M, Wilson P, Goldberg DJ. What is the excess risk of infertility in women after genital chlamydia infection? A systematic review of the evidence. Sex Transm Infect. 2008;84(3):171-175. Exclusion code: 3. [pmid: 18055580].
Wallin KL, Wiklund F, Luostarinen T, et al. A population-based prospective study of Chlamydia trachomatis infection and cervical carcinoma. Int J Cancer. 2002;101(4):371-374. Exclusion code: 2. [pmid: 12209962].
Walsh A, Rourke FO, Crowley B. Molecular detection and confirmation of Neisseria gonorrhoeae in urogenital and extragenital specimens using the Abbott CT/NG RealTime assay and an in-house assay targeting the porA pseudogene. Eur J Clin Microbiol Infect Dis. 2011;30(4):561-567. Exclusion code: 3. [pmid: 21170565].
Walsh A, Rourke FO, Laoi BN, Crowley B. Evaluation of the Abbott RealTime CT assay with the BD ProbeTec ET assay for the detection of Chlamydia trachomatis in a clinical microbiology laboratory. Diagn Microbiol Infect Dis. 2009;64(1):13-19. Exclusion code: 3. [pmid: 19362255].
Wand H, Ramjee G. The effects of injectable hormonal contraceptives on HIV seroconversion and on sexually transmitted infections. Aids. 2012;26(3):375-380. Exclusion code: 5. [pmid: 22156970].
Watchirs Smith LA, Hillman R, Ward J, et al. Point-of-care tests for the diagnosis of Neisseria gonorrhoeae infection: a systematic review of operational and performance characteristics. Sex Transm Infect. 2013;89(4):320-326. Exclusion code: 4. [pmid: 23093736].
Watson EJ, Templeton A, Russell I, et al. The accuracy and efficacy of screening tests for Chlamydia trachomatis: a systematic review. J Med Microbiol. 2002;51(12):1021-1031. Exclusion code: 12. [pmid: 12466399].
Watson V, Ryan M, Watson E. Valuing experience factors in the provision of Chlamydia screening: an application to women attending the family planning clinic. Value Health. 2009;12(4):621-623. Exclusion code: 5. [pmid: 18783389].
Webber MP, Schoenbaum EE, Farzadegan H, Klein RS. Tampons as a self-administered collection method for the detection and quantification of genital HIV-1. Aids. 2001;15(11):1417-1420. Exclusion code: 5. [pmid: 11504963].
Webley WC, Tilahun Y, Lay K, et al. Occurrence of Chlamydia trachomatis and Chlamydia pneumoniae in paediatric respiratory infections. Eur Respir J. 2009;33(2):360-367. Exclusion code: 5. [pmid: 19010996].
Weissenbacher TM, Kupka MS, Kainer F, Friese K, Mylonas I. Screening for Chlamydia trachomatis in pregnancy: a retrospective analysis in a German urban area. Arch Gynecol Obstet. 2011;283(6):1343-1347. Exclusion code: 5. [pmid: 20632183].
Weisz J, Lozyniak S, Lane SD, et al. It takes at least two: male partner factors, racial/ethnic disparity, and Chlamydia trachomatis among pregnant women. J Health Care Poor Underserved. 2011;22(3):871-885. Exclusion code: 5. [pmid: 21841284].
West ES, Munoz B, Mkocha H, et al. Mass treatment and the effect on the load of Chlamydia trachomatis infection in a trachoma-hyperendemic community. Invest Ophthalmol Vis Sci. 2005;46(1):83-87. Exclusion code: 4. [pmid: 15623758].
Wheeler HL, Skinner CJ, Khunda A, Aitken C, Perpanthan D, Staite E. Molecular testing (strand displacement assay) for identification of urethral gonorrhoea in men: can it replace culture as the gold standard?. Int J STD AIDS. 2005;16(6):430-432. Exclusion code: 3. [pmid: 15969778].
Whiley DM, Buda PJ, Bayliss J, Cover L, Bates J, Sloots TP. A new confirmatory Neisseria gonorrhoeae real-time PCR assay targeting the porA pseudogene. Eur J Clin Microbiol Infect Dis. 2004;23(9):705-710. Exclusion code: 3. [pmid: 15248092].
Whiley DM, Buda PP, Freeman K, Pattle NI, Bates J, Sloots TP. A real-time PCR assay for the detection of Neisseria gonorrhoeae in genital and extragenital specimens. Diagn Microbiol Infect Dis. 2005;52(1):1-5. Exclusion code: 3. [pmid: 15878435].
Whiley DM, Goire N, Ray ES, et al. Neisseria gonorrhoeae multi-antigen sequence typing using non-cultured clinical specimens. Sex Transm Infect. 2010;86(1):51-55. Exclusion code: 3. [pmid: 19843535].
Whiley DM, Sloots TP. Comparison of three in-house multiplex PCR assays for the detection of Neisseria gonorrhoeae and Chlamydia trachomatis using real-time and conventional detection methodologies. Pathology. 2005;37(5):364-370. Exclusion code: 4. [pmid: 16194847].
Whiley DM, Tapsall JW, Sloots TP. Nucleic acid amplification testing for Neisseria gonorrhoeae: an ongoing challenge. J Mol Diagn. 2006;8(1):3-15. Exclusion code: 7. [pmid: 16436629].
Wiehe SE, Rosenman MB, Wang J, Fortenberry JD. Disparities in chlamydia testing among young women with sexually transmitted infection symptoms. Sex Transm Dis. 2010;37(12):751-755. Exclusion code: 2. [pmid: 20644496].
Wiehe SE, Rosenman MB, Wang J, Katz BP, Fortenberry JD. Chlamydia screening among young women: individual- and provider-level differences in testing. Pediatrics. 2011;127(2):e336-344. Exclusion code: 5. [pmid: 21262889].
Wiesenfeld HC, Heine RP, Rideout A, Macio I, DiBiasi F, Sweet RL. The vaginal introitus: a novel site for Chlamydia trachomatis testing in women. Am J Obstet Gynecol. 1996;174(5):1542-1546. Exclusion code: 3. [pmid: 9065126].
Wilkinson A, El-Hayek C, Fairley CK, et al. Incidence and risk factors associated with chlamydia in men who have sex with men: a cohort analysis of Victorian Primary Care Network for Sentinel Surveillance data. Sex Transm Infect. 2012;88(5):319-324. Exclusion code: 5. [pmid: 22344714].
Wilkowska-Trojniel M, Zdrodowska-Stefanow B, Ostaszewska-Puchalska I, Redzko S, Przepiesc J, Zdrodowski M. The influence of Chlamydia trachomatis infection on spontaneous abortions. Adv Med Sci. 2009;54(1):86-90. Exclusion code: 5. [pmid: 19403438].
Wills GS, Horner PJ, Reynolds R, et al. Pgp3 antibody enzyme-linked immunosorbent assay, a sensitive and specific assay for seroepidemiological analysis of Chlamydia trachomatis infection. Clin Vaccine Immunol. 2009;16(6):835-843. Exclusion code: 3. [pmid: 19357314].
Winscott M, Taylor M, Kenney K. Sexually transmitted diseases among American Indians in Arizona: an important public health disparity. Public Health Rep. Suppl 4. 2010;125:51-60. Exclusion code: 5. [pmid: 20626193].
Wong A, Maclean AB, Furrows SJ, Ridgway GL, Hardiman PJ, Perrett CW. Could epithelial ovarian cancer be associated with chlamydial infection?. Eur J Gynaecol Oncol. 2007;28(2):117-120. Exclusion code: 5. [pmid: 17479672].
Wood BJ, Gaydos JC, McKee KT Jr., Gaydos CA. Comparison of the urine Leukocyte Esterase Test to a Nucleic Acid Amplification Test for screening non-health care-seeking male soldiers for Chlamydia trachomatis and Neisseria gonorrhoeae infections. Mil Med. 2007;172(7):770-772. Exclusion code: 4. [pmid: 17691693].
Workowski KA, Berman S. Sexually transmitted diseases treatment guidelines, 2010. MMWR Recomm Rep. 2010;59(12 RR):1-113. Exclusion code: 2. [pmid: 21160459].
Wozniakowska-Gesicka T, Wisniewska-Ligier M, Kicinski P, Gesicki T. Underestimated problem of Chlamydia infections. Przegl Epidemiol. Suppl 1. 2008;62:133-141. Exclusion code: 8. [pmid: 22320048].
Wright TC Jr., Denny L, Kuhn L, Pollack A, Lorincz A. HPV DNA testing of self-collected vaginal samples compared with cytologic screening to detect cervical cancer. Jama. 2000;283(1):81-86. Exclusion code: 5. [pmid: 10632284].
Xia QF, Xu SX, Wang DS, et al. Development of a novel quantitative real-time assay using duplex scorpion primer for detection of Chlamydia trachomatis. Exp Mol Pathol. 2007;83(1):119-124. Exclusion code: 4. [pmid: 17222821].
Xiong L, Kong F, Zhou H, Gilbert GL. Use of PCR and reverse line blot hybridization assay for rapid simultaneous detection and serovar identification of Chlamydia trachomatis. J Clin Microbiol. 2006;44(4):1413-1418. Exclusion code: 4. [pmid: 16597870].
Xu F, Stoner BP, Taylor SN, et al. Use of home-obtained vaginal swabs to facilitate rescreening for Chlamydia trachomatis infections: two randomized controlled trials. Obstet Gynecol. 2011;118(2 Pt 1):231-239. Exclusion code: 3. [pmid: 21775837].
Yang JL, Schachter J, Moncada J, et al. Comparison of an rRNA-based and DNA-based nucleic acid amplification test for the detection of Chlamydia trachomatis in trachoma. Br J Ophthalmol. 2007;91(3):293-295. Exclusion code: 3. [pmid: 17050583].
Yang JM, Liu HX, Hao YX, He C, Zhao DM. Development of a rapid real-time PCR assay for detection and quantification of four familiar species of Chlamydiaceae. J Clin Virol. 2006;36(1):79-81. Exclusion code: 4. [pmid: 16488188].
Yeung A, Bush M, Cummings R, et al. Use of computerized medical records to determine the feasibility of testing for chlamydia without patients seeing a practitioner. Int J STD AIDS. 2010;21(11):755-757. Exclusion code: 4. [pmid: 21187357].
Yip Pp, Chan Wh, Yip Kt, Que Tl, Kwong Ns, Ho Ck. The use of polymerase chain reaction assay versus conventional methods in detecting neonatal chlamydial conjunctivitis. J Pediatr Ophthalmol Strabismus. 2008;45(4):234-239. Exclusion code: 3. [pmid: 18705621].
Young F. Sexually transmitted infections. Genital chlamydia: practical management in primary care. J Fam Health Care. 2005;15(1):19-21. Exclusion code: 7. [pmid: 15819362].
Young H, Anderson J, Moyes A, McMillan A. Non-cultural detection of rectal and pharyngeal gonorrhoea by the Gen-Probe PACE 2 assay. Genitourin Med. 1997;73(1):59-62. Exclusion code: 2. [pmid: 9155558].
Zampini AN. Emergency prevention: the benefit of chlamydia and gonorrhea screening in urban emergency departments. J Emerg Nurs. 2010;36(3):246-247. Exclusion code: 7. [pmid: 20457322].
Zbroch T, Knapp P, Blonska E, Kobylec M, Knapp P. Life style, Chlamydia trachomatis infection, bacterial vaginosis and their impact on the frequency of cervical lesions. Ginekol Pol. 2004;75(7):538-544. Exclusion code: 8. [pmid: 15517774].
Zenner D, Molinar D, Nichols T, Riha J, Macintosh M, Nardone A. Should young people be paid for getting tested? A national comparative study to evaluate patient financial incentives for chlamydia screening. BMC Public Health. 2012;12:261. Exclusion code: 5. [pmid: 22471791].
Zhang Ld, Pei J, Zhang Hm, Sun Xf. Relationship between mycoplasma and chlamydia infection and lesions in the cervical tissue in high-risk HPV-positive patients. Chung Hua Shih Yen Ho Lin Chuang Ping Tu Hsueh. 2010;24(5):346-348. Exclusion code: 8.
Zheng Hp, Jiang Lf, Fang Dy, et al. Application of an oligonucleotide array assay for rapid detecting and genotyping of Chlamydia trachomatis from urogenital specimens. Diagn Microbiol Infect Dis. 2007;57(1):1-6. Exclusion code: 4. [pmid: 16872784].
Zhong XY, Yu JL, Wang J, et al. Genotyping of major outer membrane protein gene of Chlamydia trachomatis by cleavase fragment length polymorphism analysis. Zhonghua Er Ke Za Zhi. 2005;43(1):5-8. Exclusion code: 8. [pmid: 15796796].
Zou H, Fairley CK, Guy R, Chen MY. The efficacy of clinic-based interventions aimed at increasing screening for bacterial sexually transmitted infections among men who have sex with men: a systematic review. Sex Transm Dis. 2012;39(5):382-387. Exclusion code: 4. [pmid: 22504605].

## Appendix B5 Quality Rating Criteria

### Randomized, Controlled Trials (RCTs) and Cohort Studies

Criteria
- Initial assembly of comparable groups:
  ○ for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs.

Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: | Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat is lacking.

### Diagnostic Accuracy Studies

Criteria
- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test

Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: | Has fatal flaw such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

Source: USPSTF Procedure Manual24

## Appendix B6 Expert Reviewers

- Heidi Bauer, MD, MS, MPH
  Chief, Sexually Transmitted Disease, Control Branch, California Department of Public Health, CA; Adjunct Assistant Professor, Department of Epidemiology and Biostatistics, Division of Preventive Medicine and Public Health, University of California San Francisco, San Francisco, CA; Assistant Adjunct Professor, Division of Epidemiology, University of California Berkeley, Berkeley, CA
- David D. Celentano, ScD, MHS
  Professor, Charles Armstrong Chair, Department of Epidemiology, Johns Hopkins Bloomberg School of Public Health, Baltimore, MD
- Christopher Fairley, MBBS, PhD
  Melbourne Sexual Health Centre, Alfred Hospital, Carlton, Victoria, Australia; Sexual Health Unit, Melbourne School of Population Health, The University of Melbourne, Carlton, Victoria, Australia
- Khalil Ghanem, MD, PhD
  Johns Hopkins University School of Medicine, Baltimore MD
- Pippa Oakeshott, MA, MD
  Division of Population Health Sciences, St. George's, University of London, United Kingdom
- Stephanie N. Taylor, MD
  Professor of Medicine and Microbiology, Section of Infectious Disease, Louisiania State University Health Sciences Center, New Orleans, LA; Clinic Administrator and Medical Director, Delgado Personal Health Center Sexually Transmitted Disease Clinic, New Orleans, LA
- Rachel Gorwitz, MD, MPH
  Medical Epidemiologist, Centers for Disease Control and Prevention
- Sarah Kidd, MD, MPH
  Medical Epidemiologist, Centers for Disease Control and Prevention
- John Papp, PhD
  Team Lead, Chlamydia and Gonorrhea Reference Laboratory, Centers for Disease Control and Prevention
- Elizabeth Torrone, MSPH, PhD
  Epidemiologist, Centers for Disease Control and Prevention