# Terminology

Area under receiver operating curve (AUC): Measure of how well a parameter can distinguish between two diagnostic groups.
Enzyme immunoassay (EIA): Assay designed to detect antigens of antibodies by producing an enzyme-triggered color change.
First-catch urine (FCU): Urine sample collected from individuals. Individuals should not have passed urine for at least 3 hours before sample collection. Individual collects first 10 mL of urine.
Indeterminate test result: Test result was not clear.
Negative likelihood ratio (NLR): Ratio between the probability of a negative test result given the presence of the disease and the probability of a negative test result given the absence of the disease.
Negative predictive value (NPV): Proportion of people with a negative test who are free of disease.
Nucleic acid amplification test (NAAT): Nucleic acid amplification tests detect small amounts of DNA or RNA in a test sample by using a series of repeated reactions to make multiple copies of the DNA or RNA that is being detected, thereby amplifying the signal from that piece of DNA or RNA. Several different categories exist, including:
  - Transcription-mediated amplification (TMA)
  - Strand displacement amplification (SDA)
  - Polymerase chain reaction (PCR)
  - Ligase chain reaction (LCR)
Number needed to invite (NNI): Average number of people who need to be invited to screen to find one positive case of disease/infection.
Number needed to screen (NNS): Average number of people who need to be screened to find one positive case of disease/infection.
Positive likelihood ratio (PLR): Ratio between the probability of a positive test result given the presence of the disease and the probability of a positive test result given the absence of the disease.
Positive predictive value (PPV): Proportion of people with a positive test who have the disease.
Relative risk (RR): Ratio of the risk of an event among an exposed population to the risk among the unexposed.
Sensitivity: Proportion of truly diseased/infected persons in the screened population who are identified as diseased by the screening test—that is, the true-positive rate.
Specificity: Proportion of truly nondiseased/noninfected persons who are identified as such by the screening test—that is, the true-negative rate.