# REFERENCES

1 Centers for Disease Control and Prevention. Sexually transmitted diseases treatment guidelines, 2010. MMWR Recomm Rep. 2010;59(RR-12):1-110.
2 Centers for Disease Control and Prevention. Incidence, Prevalence, and Cost of Sexually Transmitted Infections in the United States. Atlanta, GA. Centers for Disease Control and Prevention. 2013.
3 Forhan SE, Gottlieb SL, Sternberg MR, et al. Prevalence of sexually transmitted infections among female adolescents aged 14 to 19 in the United States. Pediatrics. 2009;124(6):1505-12. [pmid: 19933728].
4 Chesson HW, Gift TL, Owusu-Edusei K Jr, et al. A brief review of the estimated economic burden of sexually transmitted diseases in the United States: inflation-adjusted updates of previously published cost studies. Sex Transm Dis. 2011;38(10):889-91. [pmid: 21934557].
5 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2011. Atlanta, GA. U.S. Department of Health and Human Services. 2012.
6 Centers for Disease Control and Prevention. HIV in the United States: At a Glance. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
7 Centers for Disease Control and Prevention. HIV Surveillance Report, 2009. Atlanta, GA. Centers for Disease Control and Prevention. 2011.
8 Centers for Disease Control and Prevention. The Role of STD Prevention and Treatment of HIV Prevention. Atlanta, GA. Centers for Disease Control and Prevention. 2010.
9 Centers for Disease Control and Prevention. HIV Prevention in the United States. Atlanta, GA. Centers for Disease Control and Prevention. 2009.
10 Centers for Disease Control and Prevention. Genital Herpes: CDC Fact Sheet. Atlanta, GA. Centers for Disease Control and Prevention. 2013.
11 Office of Population Affairs. Genital Herpes Fact Sheet. Washington, DC. U.S. Department of Health and Human Services. 2012.
12 Centers for Disease Control and Prevention. Disease Burden From Viral Hepatitis A, B, and C in the United States. Atlanta, GA. Centers for Disease Control and Prevention. 2009.
13 Centers for Disease Control and Prevention. Viral Hepatitis Surveillance: United States, 2010. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
14 Centers for Disease Control and Prevention. Trichomoniasis: CDC Fact Sheet. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
15 Chandra A, Martinez GM, Mosher WD, et al. Fertility, family planning, and reproductive health of U.S. women: data from the 2002 National Survey of Family Growth. Vital Health Stat. 2005;23(25):1-160. [pmid: 16532609].
16 Martinez GM, Chandra A, Abma JC, et al. Fertility, contraception, and fatherhood: data on men and women from cycle 6 (2002) of the 2002 National Survey of Family Growth. Vital Health Stat. 2006;23(26):1-142. [pmid: 16900800].
17 Copen CE, Chandra A, Martinez G. Prevalence and timing of oral sex with opposite-sex partners among female and males aged 15-24 years: United States, 2007-2010. Natl Health Stat Rep. 2012;(56):1-14.
18 Kaestle CE, Halpern CT, Miller WC, et al. Young age at first sexual intercourse and sexually transmitted infections in adolescents and young adults. Am J Epidemiol. 2005;161(8):774-80. [pmid: 15800270].
19 Tu W, Batteiger BE, Wiehe S, et al. Time from first intercourse to first sexually transmitted infection diagnosis among adolescent women. Arch Pediatr Adolesc Med. 2009;163(12):1106-11. [pmid: 19996047].
20 World Health Organization. Sexually Transmitted Infections. Geneva, Switzerland. World Health Organization. 2011.
21 Fung M, Scott KC, Kent CK, et al. Chlamydial and gonococcal reinfection among men: a systematic review of data to evaluate the need for retesting. Sex Transm Infect. 2007;83(4):304-9. [pmid: 17166889].
22 Hosenfeld CB, Workowski KA, Berman S, et al. Repeat infection with chlamydia and gonorrhea among females: a systematic review of the literature. Sex Transm Dis. 2009;36(8):478-89. [pmid: 19617871].
23 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2010. Atlanta, GA. Centers for Disease Control and Prevention. 2011.
24 Centers for Disease Control and Prevention. Vital signs: HIV infection, testing, and risk behaviors among youths--United States. MMWR Morb Mortal Wkly Rep. 2012;61(47):971-6. [pmid: 23190571].
25 Centers for Disease Control and Prevention. STDs in Men Who Have Sex With Men. Atlanta, GA. Centers for Disease Control and Prevention. 2011.
26 Chesson HW, Kent CK, Owusu-Edusei K Jr, et al. Disparities in sexually transmitted disease rates across the “eight Americas”. Sex Transm Dis. 2012;39(6):458-64. [pmid: 22592832].
27 Korzeniewski K. Sexually transmitted infections among army personnel in the military environment. Malla N, editor. Sexually Transmitted Infections. Croatia. InTech. 2012:165-82.
28 Carey MP, Weinhardt LS, Carey KB. Prevalence of infection with HIV among the seriously mentally ill: review of research and implications for practice. Prof Psychol Res Pract. 1995;26:262-8.
29 Hammett TM, Kennedy S, Kuck S. National Survey of Infectious Disease in Correctional Facilities: HIV and Sexually Transmitted Diseases. Washington, DC. U.S. Department of Justice. 2007.
30 Beltrami J, Wright-DeAguero L, Fullilove M, et al. Substance Abuse and the Spread of Sexually Transmitted Diseases. Washington, DC. Institute of Medicine Committee on Prevention and Control for Sexually Transmitted Diseases. 2012.
31 Homma Y, Wang N, Saewyc E, et al. The relationship between sexual abuse and risky sexual behavior among adolescent boys: a meta-analysis. J Adolesc Health. 2012;51(1):18-24. [pmid: 22727072].
32 Bobashev GV, Zule WA, Osilla KC, et al. Transactional sex among men and women in the south at high risk for HIV and other STIs. J Urban Health. 2009;86(Suppl 1):32-47. [pmid: 19513853].
33 Jones DL, Irwin KL, Inciardi J, et al. The high-risk sexual practices of crack-smoking sex workers recruited from the streets of three American cities. The Multicenter Crack Cocaine and HIV Infection Study Team. Sex Transm Dis. 1998;25(4):187-93. [pmid: 9564720].
34 Minichiello V, Rahman S, Hawkes G, et al. STI epidemiology in the global older population: emerging challenges. Perspect Public Health. 2012;132(4):178-81. [pmid: 22729008].
35 Centers for Disease Control and Prevention. HIV/AIDS Among Persons Aged 50 and Older. Atlanta, GA. Centers for Disease Control and Prevention. 2008.
36 Jameson M. Seniors' sex lives are up--and so are STD cases. Orlando, FL. Orlando Sentinal. 2011.
37 Wimberly YH, Hogben M, Moore-Ruffin J, et al. Sexual history-taking among primary care physicians. J Natl Med Assoc. 2006;98(12):1924-9. [pmid: 17225835].
38 Effective Interventions. HIV Prevention That Works. Silver Spring, MD. Effective Interventions. 2013. Accessed at http://www.effectiveinterventions.org/en/Home.aspx. 15 September 2014.
39 Miller KS, Wyckoff SC, Lin CY, et al. Pediatricians' role and practices regarding provision of guidance about sexual risk reduction to parents. J Prim Prev. 2008;29(3):279-91. [pmid: 18461458].
40 Millstein SG, Igra V, Gans J. Delivery of STD/HIV preventive services to adolescents by primary care physicians. J Adolesc Health. 1996;19(4):249-57. [pmid: 8897102].
41 Ashton MR, Cook RL, Wiesenfeld HC, et al. Primary care physician attitudes regarding sexually transmitted diseases. Sex Transm Dis. 2002;29(4):246-51. [pmid: 11912468].
42 Hansen L, Barnett J, Wong T, et al. STD and HIV counseling practices of British Columbia primary care physicians. AIDS Patient Care STDS. 2005;19(1):40-8. [pmid: 15665634].
43 Mark H, Irwin K, Sternberg M, et al. Providers' perceived barriers to sexually transmitted disease care in 2 large health maintenance organizations. Sex Transm Dis. 2008;35(2):184-9. [pmid: 18046264].
44 Bull SS, Rietmeijer C, Fortenberry JD, et al. Practice patterns for the elicitation of sexual history, education, and counseling among providers of STD services: results from the Gonorrhea Community Action Project (GCAP). Sex Transm Dis. 1999;26(10):584-9. [pmid: 10560723].
45 Langille DB, Mann KV, Gailiunas PN. Primary care physicians' perceptions of adolescent pregnancy and STD prevention practices in a Nova Scotia county. Am J Prev Med. 1997;13(4):324-30. [pmid: 9236972].
46 Chung PJ, Lee TC, Morrison JL, et al. Preventive care for children in the United States: quality and barriers. Annu Rev Public Health. 2006;27:491-515. [pmid: 16533127].
47 Kurth AE, Holmes KK, Hawkins R, et al. A national survey of clinic sexual histories for sexually transmitted infection and HIV screening. Sex Transm Dis. 2005;32(6):370-6. [pmid: 15912084].
48 Office of the Surgeon General. The Surgeon General's Call to Action to Promote Sexual Health and Responsible Sexual Behavior. Rockville, MD. Office of the Surgeon General, Office of Population Affairs. 2001. [pmid: 20669514].
49 Division of STD Prevention. Division of STD Prevention Strategic Plan, 2008-2013. Atlanta, GA. Centers for Disease Control and Prevention. 2008.
50 Centers for Disease Control and Prevention. Sexually Transmitted Diseases (STDs): Projects and Initiatives. Atlanta, GA. Centers for Disease Control and Prevention. 2010.
51 U.S. Department of Health and Human Services. Healthy People 2020 Summary of Objectives: Sexually Transmitted Diseases. Washington, DC. U.S. Department of Health and Human Services. 2012.
52 Meyers D, Wolff T, Gregory K, et al. USPSTF recommendations for STI screening. Am Fam Physician. 2008;77(6):819-24. [pmid: 18386598].
53 U.S. Preventive Services Task Force. Behavioral counseling to prevent sexually transmitted infections: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149(7):491-6. [pmid: 18838729].
54 Lin JS, Whitlock E, O'Connor E, et al. Behavioral counseling to prevent sexually transmitted infections: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2008;149(7):497-9. [pmid: 18838730].
55 World Health Organization. International Human Development Indicators. Geneva. World Health Organization. 2013. Accessed at http://hdr.undp.org/en/data. 15 September 2014.
56 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
57 Shain RN, Piper JM, Newton ER, et al. Even if you build it, we may not come: correlates of non-attendance at a sexual risk reduction workshop for STD clinic patients. N Engl J Med. 1999;340(2):93-100. [pmid: 9887160].
58 Kamb ML, Fishbein M, Douglas JM Jr, et al. Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. Project RESPECT Study Group. JAMA. 1998;280(13):1161-7. [pmid: 9777816].
59 Kershaw TS, Magriples U, Westdahl C, et al. Pregnancy as a window of opportunity for HIV prevention: effects of an HIV intervention delivered within prenatal care. Am J Public Health. 2009;99(11):2079-86. [pmid: 19762662].
60 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
61 Higgins JP, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. West Sussex, England. Cochrane Collaboration. 2012.
62 Borenstein M, Hedges LV, Higgins JP, Rothstein HR. Introduction to Meta-Analysis. West Sussex, England. Wiley & Sons. 2009.
63 Boekeloo BO, Schamus LA, Simmens SJ, et al. A STD/HIV prevention trial among adolescents in managed care. Pediatrics. 1999;103(1):107-15. [pmid: 9917447].
64 Carey MP, Carey KB, Maisto SA, et al. Reducing HIV-risk behavior among adults receiving outpatient psychiatric treatment: results from a randomized controlled trial. J Consult Clin Psychol. 2004;72(2):252-68. [pmid: 15065959].
65 Guilamo-Ramos V, Bouris A, Jaccard J, et al. A parent-based intervention to reduce sexual risk behavior in early adolescence: building alliances between physicians, social workers, and parents. J Adolesc Health. 2011;48(2):159-63. [pmid: 21257114].
66 Danielson R, Marcy S, Plunkett A, et al. Reproductive health counseling for young men: what does it do?. Fam Plann Perspect. 1990;22(3):115-21. [pmid: 2379568].
67 Jemmott JB III, Jemmott LS, Braverman PK, et al. HIV/STD risk reduction interventions for African American and Latino adolescent girls at an adolescent medicine clinic: a randomized controlled trial. Arch Pediatr Adolesc Med. 2005;159(5):440-9. [pmid: 15867118].
68 DiClemente RJ, Wingood GM, Harrington KF, et al. Efficacy of an HIV prevention intervention for African American adolescent girls: a randomized controlled trial. JAMA. 2004;292(2):171-9. [pmid: 15249566].
69 Champion JD, Collins JL. Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: results of a randomized controlled trial. Int J Nurs Stud. 2012;49(2):138-50. [pmid: 21937041].
70 Petersen R, Albright J, Garrett JM, et al. Pregnancy and STD prevention counseling using an adaptation of motivational interviewing: a randomized controlled trial. Perspect Sex Reprod Health. 2007;39(1):21-8. [pmid: 17355378].
71 Berenson AB, Rahman M. A randomized controlled study of two educational interventions on adherence with oral contraceptives and condoms. Contraception. 2012;86(6):716-24. [pmid: 22840278].
72 Peipert JF, Redding CA, Blume JD, et al. Tailored intervention to increase dual-contraceptive method use: a randomized trial to reduce unintended pregnancies and sexually transmitted infections. Am J Obstet Gynecol. 2008;198(6):630-8. [pmid: 18395692].
73 Shain RN, Piper JM, Holden AE, et al. Prevention of gonorrhea and chlamydia through behavioral intervention: results of a two-year controlled randomized trial in minority women. Sex Transm Dis. 2004;31(7):401-8. [pmid: 15215694].
74 Marrazzo JM, Thomas KK, Ringwood K. A behavioural intervention to reduce persistence of bacterial vaginosis among women who report sex with women: results of a randomised trial. Sex Transm Infect. 2011;87(5):399-405. [pmid: 21653935].
75 Cianelli R, Ferrer L, Norr KF, et al. Mano a Mano-Mujer: an effective HIV prevention intervention for Chilean women. Health Care Women Int. 2012;33(4):321-41. [pmid: 22420675].
76 Proude EM, D'Este C, Ward JE. Randomized trial in family practice of a brief intervention to reduce STI risk in young adults. Fam Pract. 2004;21(5):537-44. [pmid: 15367476].
77 Wenger NS, Greenberg JM, Hilborne LH, et al. Effect of HIV antibody testing and AIDS education on communication about HIV risk and sexual behavior. A randomized, controlled trial in college students. Ann Intern Med. 1992;117(11):905-11. [pmid: 1443951].
78 Warner L, Klausner JD, Rietmeijer CA, et al. Effect of a brief video intervention on incident infection among patients attending sexually transmitted disease clinics. PLoS Med. 2008;5(6):e135. [pmid: 18578564].
79 Jemmott LS, Jemmott JB III, O'Leary A. Effects on sexual risk behavior and STD rate of brief HIV/STD prevention interventions for African American women in primary care settings. Am J Public Health. 2007;97(6):1034-40. [pmid: 17463391].
80 Neumann MS, O'Donnell L, Doval AS, et al. Effectiveness of the VOICES/VOCES sexually transmitted disease/human immunodeficiency virus prevention intervention when administered by health department staff: does it work in the “real world”?. Sex Transm Dis. 2011;38(2):133-9. [pmid: 20729794].
81 Ehrhardt AA, Exner TM, Hoffman S, et al. A gender-specific HIV/STD risk reduction intervention for women in a health care setting: short- and long-term results of a randomized clinical trial. AIDS Care. 2002;14(2):147-61. [pmid: 11940275].
82 Berkman A, Pilowsky DJ, Zybert PA, et al. HIV prevention with severely mentally ill men: a randomised controlled trial. AIDS Care. 2007;19(5):579-88. [pmid: 17505917].
83 Scholes D, McBride CM, Grothaus L, et al. A tailored minimal self-help intervention to promote condom use in young women: results from a randomized trial. AIDS. 2003;17(10):1547-56. [pmid: 12824793].
84 Carey MP, Senn TE, Vanable PA, et al. Brief and intensive behavioral interventions to promote sexual risk reduction among STD clinic patients: results from a randomized controlled trial. AIDS Behav. 2010;14(3):504-17. [pmid: 19590947].
85 Marion LN, Finnegan L, Campbell RT, et al. The Well Woman Program: a community-based randomized trial to prevent sexually transmitted infections in low-income African American women. Res Nurs Health. 2009;32(3):274-85. [pmid: 19373824].
86 Cortes-Bordoy J, Vidart JA, Coll-Capdevila C, et al. Usefulness of an educational leaflet to modify sexual risk behaviour in women with external genital warts. Eur J Dermatol. 2010;20(3):339-44. [pmid: 20146965].
87 Crosby R, DiClemente RJ, Charnigo R, et al. A brief, clinic-based, safer sex intervention for heterosexual African American men newly diagnosed with an STD: a randomized controlled trial. Am J Public Health. 2009;99(Suppl 1):S96-103. [pmid: 19218185].
88 Boyer CB, Barrett DC, Peterman TA, et al. Sexually transmitted disease (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial. AIDS. 1997;11(3):359-67. [pmid: 9147428].
89 Wingood GM, DiClemente RJ, Robinson-Simpson L, et al. Efficacy of an HIV intervention in reducing high-risk human papillomavirus, nonviral sexually transmitted infections, and concurrency among African American women: a randomized-controlled trial. J Acquir Immune Defic Syndr. 2013;63(Suppl 1):S36-43. [pmid: 23673884].
90 Metsch LR, Feaster DJ, Gooden L, et al. Effect of risk-reduction counseling with rapid HIV testing on risk of acquiring sexually transmitted infections: the AWARE randomized controlled trial. JAMA. 2013;310(16):1701-10. [pmid: 24150466].
91 Alemagno SA, Stephens RC, Stephens P, et al. Brief motivational intervention to reduce HIV risk and to increase HIV testing among offenders under community supervision. J Correct Health Care. 2009;15(3):210-21. [pmid: 19477803].
92 Cohen DA, Dent C, MacKinnon D, et al. Condom skills education and sexually transmitted disease reinfection. J Sex Res. 1991;28(1):139-45.
93 Dancy BL, Dancy BL. African American adolescent females: mother-involved HIV risk-reduction intervention. J HIV AIDS Soc Serv. 2009;8(3):292-307. [pmid: 20090855].
94 DiClemente RJ, Wingood GM, Rose E, et al. Evaluation of an HIV/STD sexual risk-reduction intervention for pregnant African American adolescents attending a prenatal clinic in an urban public hospital: preliminary evidence of efficacy. J Pediatr Adolesc Gynecol. 2010;23(1):32-8. [pmid: 19643646].
95 Dilley JW, Woods WJ, Sabatino J, et al. Changing sexual behavior among gay male repeat testers for HIV: a randomized, controlled trial of a single-session intervention. J Acquir Immune Defic Syndr. 2002;30(2):177-86. [pmid: 12045680].
96 Grimley DM, Hook EW III. A 15-minute interactive, computerized condom use intervention with biological endpoints. Sex Transm Dis. 2009;36(2):73-8. [pmid: 19125141].
97 Howard MN, Howard MN. Improving low-income teen health behaviors with Internet-linked clinic interventions. Sex Res Social Policy. 2011;8(1).
98 Lindenberg CS, Solorzano RM, Bear D, et al. Reducing substance use and risky sexual behavior among young, low-income, Mexican-American women: comparison of two interventions. Appl Nurs Res. 2002;15(3):137-48. [pmid: 12173165].
99 Mallory C, Hesson-McInnis M. Pilot test results of an HIV prevention intervention for high-risk women. West J Nurs Res. 2013;35(3):313-29. [pmid: 21821725].
100 Morrison-Beedy D, Carey MP, Kowalski J, et al. Group-based HIV risk reduction intervention for adolescent girls: evidence of feasibility and efficacy. Res Nurs Health. 2005;28(1):3-15. [pmid: 15625713].
101 Roye C, Perlmutter SP, Krauss B. A brief, low-cost, theory-based intervention to promote dual method use by black and Latina female adolescents: a randomized clinical trial. Health Educ Behav. 2007;34(4):608-21. [pmid: 16740522].
102 Senn N, de Valliere S, Berdoz D, et al. Motivational brief intervention for the prevention of sexually transmitted infections in travelers: a randomized controlled trial. BMC Infect Dis. 2011;11:300. [pmid: 22044609].
103 Smith PB, Weinman ML, Parrilli J. The role of condom motivation education in the reduction of new and reinfection rates of sexually transmitted diseases among inner-city female adolescents. Patient Educ Couns. 1997;31(1):77-81. [pmid: 9197805].
104 Pealer LN, Peterman TA, Newman DR, et al. Are counselor demographics associated with successful human immunodeficiency virus/sexually transmitted disease prevention counseling?. Sex Transm Dis. 2004;31(1):52-6. [pmid: 14695958].
105 Melendez RM, Hoffman S, Exner T, et al. Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Arch Sex Behav. 2003;32(6):499-511. [pmid: 14574094].
106 DiClemente RJ, Crosby RA, Salazar LF, et al. Is male intent to be vaccinated against HPV a function of the promotion message?. Int J STD AIDS. 2011;22(6):332-4. [pmid: 21680669].
107 Eaton LA, Huedo-Medina TB, Kalichman SC, et al. Meta-analysis of single-session behavioral interventions to prevent sexually transmitted infections: implications for bundling prevention packages. Am J Public Health. 2012;102(11):e34-e44. [pmid: 22994247].
108 Chin HB, Sipe TA, Elder R, et al. The effectiveness of group-based comprehensive risk-reduction and abstinence education interventions to prevent or reduce the risk of adolescent pregnancy, human immunodeficiency virus, and sexually transmitted infections: two systematic reviews for the Guide to Community Preventive Services. Am J Prev Med. 2012;42(3):272-94. [pmid: 22341164].
109 Smoak ND, Scott-Sheldon LA, Johnson BT, et al. Sexual risk reduction interventions do not inadvertently increase the overall frequency of sexual behavior: a meta-analysis of 174 studies with 116,735 participants. J Acquir Immune Defic Syndr. 2006;41(3):374-84. [pmid: 16540941].
110 Catania JA, Kegeles SM, Coates TJ. Towards an understanding of risk behavior: an AIDS Risk Reduction Model (ARRM). Health Educ Q. 1990;17(1):53-72. [pmid: 2318652].
111 Fisher JD, Fisher WA. Changing AIDS-risk behavior. Psychol Bull. 1992;111(3):455-74. [pmid: 1594721].
112 Lawrence JS, Fortenberry JD. Behavorial Interventions for STDs: Theoretical Models and Intervention Methods. Aral SO, Douglas JM Jr, Lipshutz JA, editors. Behavioral Interventions for Prevention and Control of Sexually Transmitted Diseases. Atlanta, GA. Springer. 2007:23-59.
113 Noar SM. Behavioral interventions to reduce HIV-related sexual risk behavior: review and synthesis of meta-analytic evidence. AIDS Behav. 2008;12(3):335-53. [pmid: 17896176].
114 Risser WL, Bortot AT, Benjamins LJ, et al. The epidemiology of sexually transmitted infections in adolescents. Semin Pediatr Infect Dis. 2005;16(3):160-7. [pmid: 16044389].
115 Javanbakht M, Guerry S, Gorbach PM, et al. Prevalence and correlates of heterosexual anal intercourse among clients attending public sexually transmitted disease clinics in Los Angeles County. Sex Transm Dis. 2010;37(6):369-76. [pmid: 20514690].
116 Charania MR, Crepaz N, Guenther-Gray C, et al. Efficacy of structural-level condom distribution interventions: a meta-analysis of U.S. and international studies, 1998-2007. AIDS Behav. 2011;15(7):1283-97. [pmid: 20886277].
117 Barker DH, Swenson RR, Brown LK, et al. Blocking the benefit of group-based HIV-prevention efforts during adolescence: the problem of HIV-related stigma. AIDS Behav. 2012;16(3):571-7. [pmid: 22170381].
118 Hollis JF, Polen MR, Whitlock EP, et al. Teen reach: outcomes from a randomized, controlled trial of a tobacco reduction program for teens seen in primary medical care. Pediatrics. 2005;115(4):981-9. [pmid: 15805374].
119 Rose E, DiClemente RJ, Wingood GM, et al. The validity of teens' and young adults' self-reported condom use. Arch Pediatr Adolesc Med. 2009;163(1):61-4. [pmid: 19124705].
120 Herbst JH, Beeker C, Mathew A, et al. The effectiveness of individual-, group-, and community-level HIV behavioral risk-reduction interventions for adult men who have sex with men: a systematic review. Am J Prev Med. 2007;32(4 Suppl):S38-67. [pmid: 17386336].
121 Imrie J, Stephenson JM, Cowan FM, et al. A cognitive behavioural intervention to reduce sexually transmitted infections among gay men: randomised trial. BMJ. 2001;322(7300):1451-6. [pmid: 11408300].
122 Semaan S, Des Jarlais DC, Sogolow E, et al. A meta-analysis of the effect of HIV prevention interventions on the sex behaviors of drug users in the United States. J Acquir Immune Defic Syndr. 2002;30(Suppl 1):S73-93. [pmid: 12107362].
123 Meader N, Semaan S, Halton M, et al. An international systematic review and meta-analysis of multisession psychosocial interventions compared with educational or minimal interventions on the HIV sex risk behaviors of people who use drugs. AIDS Behav. 2013;17(6):1963-78. [pmid: 23386132].
124 Shepherd J, Kavanagh J, Picot J, et al. The effectiveness and cost-effectiveness of behavioural interventions for the prevention of sexually transmitted infections in young people aged 13-19: a systematic review and economic evaluation. Health Technol Assess. 2010;14(7):1-206. [pmid: 20178696].
125 Centers for Disease Control and Prevention. Compendium of Evidence-Based HIV Behavioral Interventions. Atlanta, GA. Centers for Disease Control and Prevention. 2013.
126 Jones R, Hoover DR, Lacroix LJ. A randomized controlled trial of soap opera videos streamed to smartphones to reduce risk of sexually transmitted human immunodeficiency virus (HIV) in young urban African American women. Nurs Outlook. 2013;61(4):205-15. [pmid: 23743482].
127 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. Leawood, KS. American Academy of Family Physicians. 2012.
128 Condom use by adolescents. Pediatrics. 2013;132(5):973-81.
129 Committee Opinion No. 460: the initial reproductive health visit. Obstet Gynecol. 2010;116(1):240-3. [pmid: 20567198].
130 Committee Opinion No. 534: well-woman visit. Obstet Gynecol. 2012;120(2 Pt 1):421-4. [pmid: 22825111].
131 ACOG Committee Opinion No. 423: motivational interviewing: a tool for behavioral change. Obstet Gynecol. 2009;113(1):243-6. [pmid: 19104391].
132 ACOG Committee Opinion No. 525: health care for lesbians and bisexual women. Obstet Gynecol. 2012;119(5):1077-80. [pmid: 22525932].
133 ACOG Committee Opinion No. 536: human immunodeficiency virus and acquired immunodeficiency syndrome and women of color. Obstet Gynecol. 2012;120(3):735-9. [pmid: 22914493].
134 ACOG Committee Opinion No. 582: addressing health risks of noncoital sexual activity. Obstet Gynecol. 2013;122(6):1378-82. [pmid: 24264716].
135 Centers for Disease Control and Prevention. Sexually Transmitted Diseases Treatment Guidelines. Atlanta, GA. Centers for Disease Control and Prevention. 2010.
136 Centers for Disease Control and Prevention. HIV Infection: Detection, Counseling, and Referral. Atlanta, GA. Centers for Disease Control and Prevention. 2010.
137 Wilkinson J, Bass C, Diem S, et al. Preventive Services for Children and Adolescents. Bloomington, MN. Institute for Clinical Systems Improvement. 2013.
138 Wilkinson J, Bass C, Diem S, et al. Preventive Services for Adults. Bloomington, MN. Institute for Clinical Systems Improvement. 2013.
139 Michigan Quality Improvement Consortium. Routine Preventive Services for Children and Adolescents (Ages 2–21). Southfield, MI. Michigan Quality Improvement Consortium. 2011.
140 Allen J, Bharel M, Brammer S, et al. Adapting Your Practice: Treatment and Recommendations on Reproductive Health Care for Homeless Patients. Nashville, TN. Health Care for the Homeless Clinicians' Network, National Health Care for the Homeless Council. 2008.
141 National Institute for Health and Care Excellence. One to One Interventions to Reduce the Transmission of Sexually Transmitted Infections (STIs) Including HIV, and to Reduce the Rate of Under 18 Conceptions, Especially Among Vulnerable and at Risk Groups. London. National Institute for Health and Care Excellence. 2007.
142 University of Michigan Health System. Adult Clinical Preventive Care. Ann Arbor, MI. University of Michigan. 2011.
143 Akers DD. ASSESS: for adolescent risk reduction. Card JJ, Benner TA, editors. Model Programs for Adolescent Sexual Health: Evidence-Based HIV, STI, and Pregnancy Prevention Interventions. New York. Springer. 2008:375-82.
144 Gottlieb SL, Douglas JM Jr, Foster M, et al. Incidence of herpes simplex virus type 2 infection in 5 sexually transmitted disease (STD) clinics and the effect of HIV/STD risk-reduction counseling. J Infect Dis. 2004;190(6):1059-67. [pmid: 15319854].
145 Bolu OO, Lindsey C, Kamb ML, et al. Is HIV/sexually transmitted disease prevention counseling effective among vulnerable populations? A subset analysis of data collected for a randomized, controlled trial evaluating counseling efficacy (Project RESPECT). Sex Transm Dis. 2004;31(8):469-74. [pmid: 15273579].
146 Semaan S, Neumann MS, Hutchins K, et al. Brief counseling for reducing sexual risk and bacterial STIs among drug users--results from Project RESPECT. Drug Alcohol Depend. 2010;106(1):7-15. [pmid: 19720471].
147 Rhodes F, Stein JA, Fishbein M, et al. Using theory to understand how interventions work: Project RESPECT, condom use, and the Integrative Model. AIDS Behav. 2007;11(3):393-407. [pmid: 17323123].
148 Benner TA. SiHLE: health workshops for young black women. Card JJ, Benner TA, editors. Model Programs for Adolescent Sexual Health: Evidence-Based HIV, STI and Pregnancy Prevention Interventions. New York. Springer. 2008:253-60.
149 Lang DL, DiClemente RJ, Hardin JW, et al. Threats of cross-contamination on effects of a sexual risk reduction intervention: fact or fiction. Prev Sci. 2009;10(3):270-5. [pmid: 19241171].
150 Kirby D. An HIV-prevention intervention for African American adolescent girls significantly increased condom use. Evid Based Obstet Gynecol. 2005;7:74-5.
151 Wingood GM, DiClemente RJ, Harrington KF, et al. Efficacy of an HIV prevention program among female adolescents experiencing gender-based violence. Am J Public Health. 2006;96(6):1085-90. [pmid: 16670238].
152 Sales JM, Lang DL, Hardin JW, et al. Efficacy of an HIV prevention program among African American female adolescents reporting high depressive symptomatology. J Womens Health (Larchmt). 2010;19(2):219-27. [pmid: 20109119].
153 Milhausen RR, DiClemente RJ, Lang DL, et al. Frequency of sex after an intervention to decrease sexual risk-taking among African-American adolescent girls: results of a randomized, controlled clinical trial. Sex Educ. 2008;8:47-57.
154 Korte JE, Shain RN, Holden AE, et al. Reduction in sexual risk behaviors and infection rates among African Americans and Mexican Americans. Sex Transm Dis. 2004;31(3):166-73. [pmid: 15076930].
155 Thurman AR, Holden AE, Shain RN, et al. Preventing recurrent sexually transmitted diseases in minority adolescents: a randomized controlled trial. Obstet Gynecol. 2008;111(6):1417-25. [pmid: 18515527].
156 Holden AE, Shain RN, Miller WB, et al. The influence of depression on sexual risk reduction and STD infection in a controlled, randomized intervention trial. Sex Transm Dis. 2008;35(10):898-904. [pmid: 18607311].
157 Carey MP, Vanable PA, Senn TE, et al. Evaluating a two-step approach to sexual risk reduction in a publicly-funded STI clinic: rationale, design, and baseline data from the Health Improvement Project-Rochester (HIP-R). Contemp Clin Trials. 2008;29(4):569-86. [pmid: 18325853].
158 Mittal M, Senn TE, Carey MP. Mediators of the relation between partner violence and sexual risk behavior among women attending a sexually transmitted disease clinic. Sex Transm Dis. 2011;38(6):510-5. [pmid: 21258269].
159 Peipert J, Redding CA, Blume J, et al. Design of a stage-matched intervention trial to increase dual method contraceptive use (Project PROTECT). Contemp Clin Trials. 2007;28(5):626-37. [pmid: 17374567].
160 O'Leary A, Jemmott LS, Jemmott JB. Mediation analysis of an effective sexual risk-reduction intervention for women: the importance of self-efficacy. Health Psychol. 2008;27(2 Suppl):S180-4. [pmid: 18377160].
161 Marrazzo JM, Thomas KK, Fiedler TL, et al. Relationship of specific vaginal bacteria and bacterial vaginosis treatment failure in women who have sex with women. Ann Intern Med. 2008;149(1):20-8. [pmid: 18591634].
162 Marrazzo JM, Thomas KK, Agnew K, et al. Prevalence and risks for bacterial vaginosis in women who have sex with women. Sex Transm Dis. 2010;37(5):335-9. [pmid: 20429087].
163 Hoffman S, Exner TM, Leu CS, et al. Female-condom use in a gender-specific family planning clinic trial. Am J Public Health. 2003;93(11):1897-903. [pmid: 14600063].
164 Enrhardt AA, Exner TM, Hoffman S, et al. HIV/STD risk and sexual strategies among women family planning clients in New York: Project FIO. AIDS Behav. 2002;6(1):1-13.
165 Miller S, Exner TM, Williams SP, et al. A gender-specific intervention for at-risk women in the USA. AIDS Care. 2000;12(5):603-12. [pmid: 11218546].
166 Dworkin SL, Beckford ST, Ehrhardt AA. Sexual scripts of women: a longitudinal analysis of participants in a gender-specific HIV/STD prevention intervention. Arch Sex Behav. 2007;36(2):269-79. [pmid: 17186128].
167 Champion JD. Behavioural interventions and abuse: secondary analysis of reinfection in minority women. Int J STD AIDS. 2007;18(11):748-53. [pmid: 18005508].
168 Arnold EA. A Randomized Controlled Trial of the Bruthas Project. San Francisco, CA. University of California, San Francisco. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01270230?term=Bruthas&rank=1. 15 September 2014.
169 Brady S. HIV Prevention With the Mentally Ill. Boston, MA. Boston Medical Center. 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT00643305?term=HIV+prevention+mentally+ill&rank=1. 14 September 2014.
170 Brady S. HIV/AIDS, Severe Mental Illness and Homelessness. Boston, MA. Boston University. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01172704?term=HIV%2FAIDS+mental+illness&rank=1. 15 September 2012.
171 Bull S. Effectiveness of an Online Prevention Program in Reducing the Risk of STD Infection in Young Adults (Youthnet). Denver, CO. University of Colorado, Denver. 2008. Accessed at http://clinicaltrials.gov/ct2/show/NCT00255944?term=youthnet&rank=2. 15 September 2014.
172 Colfax GN. Reducing HIV Risk Among Episodic Substance Using Men Who Have Sex With Men. San Francisco, CA. HIV Prevention Section, San Francisco Department of Public Health. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT01279044?term=reducing+HIV&rank=6. 15 September 2014.
173 Crosby RA, Mena LA. Safer Sex Program for Young African-American Men. Lexington, KY. University of Kentucky. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01439503?term=safer+sex+program&rank=1. 15 September 2014.
174 DiClemente RJ. HIV Prevention for African American Teens. Atlanta, GA. Emory University. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT00279799?term=Afiya&rank=1. 15 September 2012.
175 Du Bois SN, Johnson SE, Mustanski B. Examining racial and ethnic minority differences among YMSM during recruitment for an online HIV prevention intervention study. AIDS Behav. 2012;16(6):1430-5. [pmid: 21986869].
176 Fernandez I, Proyecto SOL. A Risk Reduction Intervention for Hispanic Men Who Have Sex With Men. Fort Lauderdale, FL. Nova Southeastern University. 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT00690976?term=proyecto+SOL&rank=1. 15 September 2014.
177 Garofalo R. HIV Prevention Intervention for Young Transgender Women (LifeSkills). Chicago, IL. Ann & Robert H. Lurie Children's Hospital of Chicago. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01575938?term=LifeSkills&rank=2. 15 September 2014.
178 Gold MA. The S.A.F.E. Study: Computer-Aided Counseling to Prevent Teen Pregnancy/Sexually Transmitted Diseases (STDs). Pittsburgh, Pennsylvania. University of Pittsburgh. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT00151151?term=S.A.F.E.&rank=2. 15 September 2014.
179 Houck CD. Affect Management for Early Adolescents. Providence, RI. Rhode Island Hospital. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01197404?term=affect+management&rank=1. 15 September 2014.
180 Ickovics J. Group Prenatal Care for Reducing the Risk of STDs in Pregnant Young Women. New Haven, CT. Yale University. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT00271960?term=prenatal+care+for+reducing&rank=1. 15 September 2014.
181 Kapungu CT, Kapungu CT. Recruiting and retaining high-risk adolescents into family-based HIV prevention intervention research. J Child Fam Studies. 2012;21(4).
182 Lauby JL. Evaluation of a New HIV Prevention Intervention for Black Bisexually-Active Men. Philadelphia, PA. Public Health Management Corporation. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT01347164?term=bisexually-active&rank=1. 15 September 2014.
183 Llewellyn C, Abraham C, Miners A, et al. Multicentre RCT and economic evaluation of a psychological intervention together with a leaflet to reduce risk behaviour amongst men who have sex with men (MSM) prescribed post-exposure prophylaxis for HIV following sexual exposure (PEPSE): a protocol. BMC Infect Dis. 2012;12:70. [pmid: 22440090].
184 Lescano C. Randomized Controlled Trial of Family-Based HIV Prevention for Latinos (Latino STYLE). Tampa, FL. University of South Florida. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01635335?term=Latino+STYLE&rank=1. 15 September 2014.
185 Miller LC. Effectiveness of Interactive Virtual Environment Games in Reducing Risky Sexual Behavior Among Men Who Have Sex With Men (the SOLVE-IT Study). Los Angeles, CA. University of Southern California. 2009. Accessed at http://clinicaltrials.gov/ct2/show/NCT00653991?term=SOLVE-IT&rank=1. 15 September 2009.
186 Morokoff P. Increasing Condom Use in People at Risk for HIV Infection. Providence, RI. University of Rhode Island. 2008. Accessed at http://clinicaltrials.gov/ct2/show/NCT00080093?term=morokoff&rank=1. 15 September 2014.
187 Murphy DA. Family-Based HIV Prevention for Adolescent Girls. Los Angeles, CA. University of California, Los Angeles. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT00243126?term=family-based+hiv+prevention+for+adolescent+girls&rank=1. 15 September 2014.
188 Noar SM. Computerized HIV/Sexually Transmitted Disease (STD) Prevention Program (TIPSS). Lexington, KY. University of Kentucky. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT00947947?term=tipss&rank=1. 15 September 2014.
189 Noar SM, Webb EM, Van Stee SK, et al. Using computer technology for HIV Prevention among African-Americans: development of a tailored information program for safer sex (TIPSS). Health Educ Res. 2011;26(3):393-406. [pmid: 21257676].
190 O'Donnell L. No Excuses/Sin Buscar Excusas Intervention to Reduce Latino Men's HIV Risks. New York, NY. Education Development Center. 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT00690690?term=no+excuses&rank=1. 15 September 2014.
191 Patterson TL. STD Risk Reduction for Heterosexual Methamphetamine Users. San Diego, CA. University of California, San Diego. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT00344214?term=std+risk+reduction+for+methamphetamine&rank=1. 15 September 2014.
192 Rizzo CJ. Dating Violence and HIV Prevention for Girls: Adapting Mental Health Interventions. Providence, RI. Rhode Island Hospital. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01326195?term=adapting+mental+health+interventions&rank=1 (http://clinicaltrials.gov/ct2/show/NCT01326195?term=adapting+mental+health+interventions&ran=). 15 September 2014.
193 Shegog R, Peskin M, Markham C, et al. Internet-Based Sexual Health Education for Middle School Native American Youth. Houston, TX. University of Texas Health Science Center. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT01303575?term=iyg-ai%2fan&rank=1. 15 September 2014.
194 Sperling C. An STD Prevention Intervention for Men Newly Released From Jail. Decatur, GA. STAND. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT00260780?term=misters&rank=2. 15 September 2014.
195 Sullivan LE. Reducing Sex-Related HIV Risk Behaviors in Patients Receiving Treatment for Opioid Dependence (Project RED). New Haven, CT. Yale University. 2010. Accessed at http://clinicaltrials.gov/ct2/show/NCT00548275?term=project+red&rank=1. 15 September 2014.
196 University Of Pittsburgh. Text-Message Program to Reduce Risk Sexual Behaviors in Young Adult Female Emergency Department Patients (STARSS). Pittsburgh, PA. University of Pittsburgh. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01548183?term=starss&rank=1. 15 September 2012.
197 Wechsberg WM. Young Women's COOP Study. Durham, NC. Research Triangle Institute International. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01224184?term=coop&rank=2. 15 September 2014.
198 Wu E. Connect ‘N Unite: Couples-Based HIV/STI Prevention for Drug-Involved, Black MSM. New York, NY. Columbia University. 2012. Accessed at http://clinicaltrials.gov/ct2/show/NCT01394900?term=connect+%27n&rank=1. 15 September 2014.
199 Zule W. Computer-Assisted Tailored Cue-Card Health (CATCH) Study. Durham, NC. Research Triangle Institute International. 2011. Accessed at http://clinicaltrials.gov/ct2/show/NCT01170741?term=catch&rank=3. 15 September 2014.