# DISCUSSION

## Summary of Evidence

This review included almost twice as many trials as the previous 2008 review because of the volume of data that has since been published, including considerably more data on the effectiveness of low- and moderate-intensity interventions, as well as additional trials including male participants. A summary of the evidence is shown in Table 6. Consistent with the previous review, we found that high-intensity (>2 hour) interventions were likely to reduce the rate of STIs in both adults and sexually active adolescents. Ten of the 16 high-intensity trials reported statistically significant reductions in the primary outcome (usually STIs). The odds of acquiring an STI were reduced by an estimated 30 percent in adults and by 62 percent in adolescents. Condom use also increased with high-intensity interventions, particularly in the short term (≤6 months). Several high-intensity trials that did not find reductions in STIs did find reductions in risky sexual behaviors. Effects on condom use were most consistently positive among adolescents receiving high-intensity interventions. Condom use and other behavioral outcomes, however, were all based on self-report, which may be biased because of social desirability effects.

Table 6 Summary of Evidence

Population | # of Studies, Observations (n) | Design | Major limitations | Consistency | Applicability | Overall quality | Summary of Findings
Key Question 1 (Health Outcomes)
Adolescents | 7 trials, 8 comparisons (n=3407) | RCTs (k=5), subgroup analyses from RCTs (k=3) | Little evidence on effects of counseling in boys, race/ethnicity groups other than African Americans and Latinos, and presexually active adolescents | Consistent | Primarily to African American and Latino girls, particularly in low-income urban settings | Fair | Sexual risk reduction counseling generally reduced the odds of STIs in sexually active adolescents in interventions of high (OR, 0.38 [95% CI, 0.24 to 0.60]; k=5; I^2^=65%) and moderate (OR, 0.57 [95% CI, 0.37 to 0.86]; k=2; I^2^=0%) intensity; data limited for low-intensity interventions; insufficient data on presexually active teens (k=1 in young adolescents, few events).
Adults | 19 trials, 23 comparisons (n=61,909) | RCTs (k=19), subgroup analyses from RCTs (k=4) | Almost no evidence on MSM, little data on general- or low-risk primary care settings, no information on adults age ≥50 y | Moderately inconsistent | Primarily to younger adults at increased risk for STIs | Fair | High-intensity interventions reduced odds of STIs by an average of 30% (OR, 0.70 [95% CI, 0.56 to 0.87]; k=9; I^2^=23%); most low- and moderate-intensity interventions were not effective and pooled estimates did not demonstrate a benefit of risk reduction counseling, although some promising approaches were identified.
Key Question 2 (Behavioral Outcomes)
Adolescents | 6 trials (n=3030) | RCTs (k=5), subgroup analyses from RCT (k=1) | Same as KQ1, plus inconsistency in outcomes reported, some outcomes sparsely reported | Inconsistent | Primarily to African American and Latino girls, particularly in low-income urban settings | Fair | 3 of 5 trials reporting outcomes related to condom use found group differences in at least one outcome, at one or more followup assessments; however, results were frequently inconsistent within studies. Other sexual outcomes were sparsely reported, but 4 trials found improvements in some other sexual outcome. One study showed a temporary increase in sexual activity in inner-city younger adolescents (but no differences in the longer term), but another found reductions in sexual activity in inner-city younger adolescents.
Adults | 21 trials, 25 comparisons (n=19,288) | RCTs (k=21) Subgroup analyses from RCTs (k=3) | Same as KQ1, plus inconsistency in outcomes reported, some outcomes sparsely reported | Inconsistent | Primarily to younger adults at increased risk for STIs | Fair | Most high-intensity trials reported improvements in some behavioral outcome at some time point; pooled analysis showed a 29% increase in percent reporting use of condoms in 4 trials (OR, 1.29 [95% CI, 1.13 to 1.48]; I^2^=0%). Results in moderate-intensity interventions were mixed and pooled analyses showed a 21% increase in percent reporting use of condoms in 4 trials (OR, 1.21 [95% CI, 1.00 to 1.46]; I^2^=28%); 6 low-intensity trials suggested little to no benefit on behavioral outcomes.
Key Question 3 (Other Positive Outcomes)
Adolescents | 3 trials (n=1936) | RCTs | Sparse data for any single outcome, risk for reporting bias | Inconsistent | Very limited | Fair | 3 trials reported pregnancy or birth control use; one found a short-term (6 mo) reduction in pregnancy, but group differences did not hold up at 12 mo.
Adults | 6 trials (n=4062) | RCTs | Sparse data for any single outcome, risk for reporting bias | Pregnancy outcome consistent, NA for other outcomes | Sexually active women | Fair | 4 trials reported no differences in pregnancy, but one increased use of dual contraceptive method use (condom + other) in the intervention group; single trials each reported greater reduction in depression in intervention participants and no differences in intimate partner violence.
Key Question 4 (Harms)
Adolescents | 0 trials | NA | No data | NA | NA | NA | No trials reported on harms; there was no paradoxical increases in STI rate or condom use; no consistent increase in sexual activity.
Adults | 3 trials (n=6792) | RCTs | Rarely reported, methods of ascertainment not reported | Consistent | Very limited | Fair | 2 trials found no harms of counseling; one trial found more nonserious harms (e.g., pain at finger-stick site) related to HIV test among intervention group than control group. 2 trials showed statistically nonsignificant increases in STIs, but with few events overall.

Abbreviations: CI = confidence interval; HIV = human immunodeficiency virus; KQ = key question; NA = not applicable; OR = odds ratio; RCT = randomized, controlled trial; STI = sexually transmitted infection.

While we included more than twice as many low- and moderate-intensity trials than in the previous review, most were still not efficacious. However, results from trials that did show a benefit were intriguing. Two trials that included high-intensity treatment counseling arms along with low- or moderate- intensity arms were successful in reducing STIs, and appeared to use the same interventionists for both treatment arms.58,79 These interventionists may have had more extensive training and perhaps a deeper knowledge base than typical, which hints that highly skilled interventionists may be able to provide effective, less-intensive counseling. In addition, the positive effect of a 45-minute intervention targeting African American men is encouraging, given the relative lack of data for this subgroup in the previous review.87 Also, the beneficial and highly disseminable low-intensity video intervention is promising for its potential reach.78 These results warrant replication.

Single-session interventions could be efficacious, particularly those of moderate or high intensity. Pooled effects for single-session interventions (OR, 0.73 [95% CI, 0.57 to 0.94]) were similar to those with multiple sessions (OR, 0.62 [95% CI, 0.47 to 0.81]) and were consistent with results of another review of 20 single-session sexual risk reduction counseling interventions. Most of these studies were conducted in health care settings (OR, 0.65 [95% CI, 0.55 to 0.77]).107

We found no evidence suggesting that sexual risk reduction counseling is harmful for adults or adolescents. The two trials conducted in young adolescents (mostly before sexual debut) that reported the proportion of participants engaging in any sexual activity had contradictory results, and sparse reporting precludes us from drawing conclusions related to the concern that sexual risk reduction counseling in health care settings could increase sexual activity. A review of community-based, comprehensive, sexual risk reduction group interventions, however, found that these interventions reduced sexual activity (any: OR, 0.84 [95% CI, 0.75 to 0.95]; frequency: OR, 0.81 [95% CI, 0.72 to 0.90]).108 We excluded most of these trials from our review because they were not conducted in health care settings, but the content of many of the interventions was quite similar to those in our review. Similarly, a meta-analysis of 174 trials that examined the effect of HIV risk reduction counseling on sexual activity concluded that sexual activity did not increase, and in fact decreased in some subgroups. However, these trials did not report adolescent results separately from adults.109

New data represented a wide range of population risk, and several studies included men, who were sparsely represented in the previous review. All but three of the included trials were conducted in the United States, most in primary care, STI clinics, or other reproductive health settings. While a few more trials included men, the majority still targeted young adult African American and Latina women. This is appropriate, considering the prevalence patterns of STIs in the United States. Interventions were frequently targeted to participants' gender and sociocultural background, although some mixed-gender trials (still primarily low-income and nonwhite) were also effective, such as the Project RESPECT trial and the brief video-based intervention in public STI clinic waiting rooms.58,78

## Important Components of Sexual Risk Reduction Counseling

There is broad consensus that sexual risk reduction interventions should provide information on HIV/STI risk and prevention strategies, use techniques to enhance motivation and commitment to change, and help persons develop the skills necessary to reduce risky behaviors and engage in protective behaviors. These components are prominent in two widely cited models, ARRM and IMB.110,111 Both of these theories are based on early examination of the AIDS risk reduction literature, and both have been tested in a number of trials. Almost all of the trials included in our review that used these models as the basis of their interventions were effective in reducing STIs or risky sexual behaviors.57,64,69,73,81,87,88 More recent reviewers have supported the importance of these components and elucidated other characteristics believed to be important by researchers in the field. These are entirely consistent with both the ARRM and IMB models, such as a clear focus on sexual risk reduction, a theoretical model as the basis for the intervention development, sufficient magnitude and duration (exact magnitude and duration not specified), use of a variety of evidence-based intervention methods, information personalized to the participant, clear messages that strengthen values and norms that favor safety, tailoring to cultural and community norms, inclusion of the target group in program development, and clear goals and objectives.112

Unfortunately, we found little evidence to expressly confirm the importance of any of these components due to limited reporting of specific components in some cases. Likewise, clinical and methodological heterogeneity make it difficult to isolate the effects of any one characteristic or component. While two trials explored the effect of skills training rather than simply providing information, results from these trials were conflicting.67,79 A review of the existing literature on sexual risk reduction counseling extracted information on moderator effects in 16 different reviews covering a wide range of target populations.113 This review found that interventions tailored for target subgroups by sex, race/ethnicity, or sexual orientation frequently showed larger effect sizes than those addressing broader populations. Although the results were not entirely consistent across reviews, multiple meta-analyses found that matching facilitator race, skills training (e.g., condom use, safe sex negotiation, problem solving, goal setting), and the underlying theoretical model to all be associated with improved outcomes. A greater number of sessions was also reported as definitely or possibly being associated with better outcomes in several reviews.

## Public Health Impact

The public health impact of sexual risk reduction counseling varies by community, based on such factors as the prevalence of STIs, the trend in prevalence over time, local norms regarding risky sexual behaviors, and the degree to which the target populations can be reached by an intervention. Nevertheless, estimated NNTs to prevent one STI infection are presented in Table 7, along with the estimated number of cases avoided per 1,000 persons receiving sexual risk reduction counseling. A high-intensity intervention in a setting with a baseline annual incidence rate of 15 percent could expect to need to treat 11 youths (95% CI, 9 to 18) over the course of 1 year to prevent one STI. In this scenario, an estimated 88 cases (95% CI, 55 to 110) per 1,000 adolescents would be prevented. Estimates are less precise for moderate-intensity interventions, however, since they are based on only two trials in adolescents. These estimates show a NNT of 17 (95% CI, 11 to 55) and 59 (95% CI, 19 to 89) cases prevented per 1,000 adolescents. These data for adolescents are based primarily on studies in African American and Latina girls. Between 2006 and 2010, there were 3.4 cases of chlamydia per 1,000 female adolescents. An estimated 75 to 85 percent of cases are asymptomatic in females, so reported cases may substantially underestimate the actual number of cases.114 Therefore, assuming a national annual incidence of chlamydial infection of 5 percent among females ages 15 to 19 years, high-intensity counseling could prevent 31 cases per 1,000 female adolescents, or about 10,981 cases, in the United States. Thus, widespread adoption of high-intensity counseling in high-risk settings could prevent thousands of cases of chlamydia in adolescent girls, not to mention reductions in other STIs as well. While STI screening will largely prevent the long-term health sequelae of untreated STIs, young, low-income women tend to have difficulty accessing regular health care and are at risk for missing recommended STI screening. Therefore, widespread risk reduction counseling may also help prevent sequelae, such as PID and its associated pain and infertility, among some women with untreated STIs.

Table 7 Estimated Number Needed to Treat to Prevent One STI and Number of Fewer STIs per 1,000 Persons With Sexual Risk Reduction Counseling

Intervention Intensity and Age Group | % STI in CG | NNT to Prevent One STI | Lower 95% CI | Upper 95% CI | # of Fewer STIs per 1,000 | Lower 95% CI | Upper 95% CI
High-intensity intervention in adolescents | 5 | 33 | 27 | 52 | 31 | 38 | 20
High-intensity intervention in adolescents | 15 | 11 | 9 | 18 | 88 | 110 | 55
High-intensity intervention in adolescents | 25 | 7 | 6 | 12 | 138 | 176 | 84
Moderate-intensity intervention in adolescents | 5 | 48 | 32 | 149 | 21 | 31 | 7
Moderate-intensity intervention in adolescents | 15 | 17 | 11 | 55 | 59 | 89 | 19
Moderate-intensity intervention in adolescents | 25 | 11 | 7 | 37 | 91 | 141 | 28
High-intensity intervention in adults | 5 | 69 | 47 | 161 | 15 | 22 | 7
High-intensity intervention in adults | 15 | 25 | 17 | 59 | 41 | 61 | 17
High-intensity intervention in adults | 25 | 16 | 11 | 40 | 61 | 93 | 26

Abbreviations: CG = control group; CI = confidence interval; NNT = number needed to treat; STI = sexually transmitted infection.

Twenty-five adults (95% CI, 17 to 59) would need high-intensity counseling to prevent one STI in a setting with an STI incidence of 15 percent. This would prevent 41 cases per 1,000 participants (95% CI, 61 to 17), again based largely on data from studies in nonwhite women. A study of 13 STI clinics in Los Angeles County seeing more than 32,000 unique patients in an 18-month period in 2006 to 2007 reported that 17 percent had an STI at their first visit.115 Applying our estimate of 41 cases per 1,000 persons, approximately 1,300 STIs could potentially be prevented in this health care system, or a similarly sized system, with widespread adoption of high-intensity counseling.

The effects of primary care–based, sexual risk reduction counseling may also potentiate the effects of other types of community-level interventions. For example, the likelihood of benefit for condom distribution programs is enhanced with additional individual, small group, or community STI prevention interventions.116 Given our finding that changes in condom use were primarily in the short-term only, STI prevention may be enhanced if persons hear risk-reduction messages from multiple sources, multiple times. Thus, even relatively modest effects may contribute to clinically important effects in communities where messages from other sources, such as community organizations and schools, are also frequently encountered.

The two low-intensity interventions that had a positive impact on STIs represent potentially important approaches that future studies should seek to replicate to confirm their effectiveness in populations at increased risk for STIs. One of these studies had a small absolute effect (14% reduction in STIs; 5.7% in the control group, 4.9% in the intervention group), but could fairly easily be widely implemented, potentially preventing thousands of the estimated 20 million new STIs cases annually.2 However, dissemination efforts have not been as effective as hoped. The CDC Diffusion of Effective Behavioral Intervention project made substantial efforts to make this video freely available to STI clinics from the CDC Web site and inform STI clinics about its availability when trial results were published. Three to 5 months after publication, 76 of 212 identified STI clinics were surveyed to determine uptake. Twelve of the 76 clinics ordered the video and only five were actively using it at the time of the survey. Most clinics that had not ordered the video had not heard of it or its availability. The two barriers to using the video that were commonly reported by clinic managers were lack of equipment to show the video and shared waiting areas with other clinics or services (and therefore frequent presence of children).

The other low-intensity intervention included a culturally tailored, 20 minute, one-on-one skills-based counseling visit for sexually active African American women in a women's health clinic. This trial used female African American nurses who had extensive training in the delivery of the intervention. As such, while it likely does not have the potential to reach such a large audience as a waiting room video, it could substantially reduce STIs in targeted populations. While group-based interventions can have advantages such as peer support and staffing efficiency, individual visits are advantageous in that they do not require the patient to return for a separate visit and are likely easier to integrate into the clinical flow of a primary care clinic.

## Acceptability of Sexual Risk Reduction Counseling

We identified limited data evaluating the acceptability of included interventions. While acceptability appeared to be good for participants, it was unclear for parents of adolescent participants. Eleven included trials reported on a measure related to acceptability,58,63,66-68,70,75, 76,83,84,86 and one longitudinal observational study assessed stigma in youth participating in a sexual risk reduction intervention.117

Two trials in sexually active adolescents compared satisfaction or favorability ratings between group-based general health information control conditions and sexual risk reduction counseling groups.58,68 Both trials reported high favorability ratings in both intervention and control groups, with almost no differences between the groups. The only group difference noted was that one of these trials reported higher favorability ratings in the skills-based sexual risk reduction intervention (average rating, 4.67 on a 5-point scale) than either the information-based sexual risk reduction intervention (average rating, 4.46) or the general health control (average rating, 4.55).58

Two trials reported the rate at which parents refused to allow their children to participate in the study.63,66 In one study of young adolescents (ages 12 to 15 years), 28 percent of parents reached by telephone to obtain study consent verbally refused or passively avoided consenting, although reasons for refusal were not reported.63 In the other trial, conducted in adolescent males ages 15 to 18 years (not all sexually active), 8.6 percent of parents reached by telephone to obtain consent refused a reproductive health visit with a nurse educator.66 Reasons for refusal were recorded for 47.8 percent of parents. Of those with a recorded reason for refusal, 64 percent said they were not interested, 28 percent said their child was too busy to participate, and a small number (not reported) explicitly objected to the sexual material covered in the study. Another study conducted in teens in the same health system during the same era reported a 16 percent refusal for a healthy lifestyle intervention of similar intensity, almost twice as high as the refusal rate for the reproductive health intervention. Recruitment in this latter study, however, took place face-to-face in the clinic as youth arrived for appointments rather than over the phone, which may have affected the refusal rate.118 In summary, most parents did not object to the child's participation and we found no information on refusals related to the content of the intervention. Likewise, we found no suggestion that refusal rates were higher than expected for adolescent populations in health care settings.

The remaining trials reported some measure related to satisfaction or helpfulness in the intervention group only. All trials reported adequate to excellent acceptability.58,70,75,76,83,84,86 For example, the Project RESPECT trial indicated that greater than 85 percent of participants surveyed about the interventions found that the sessions were “informative,” “good,” and “helpful.”58 Similarly, a study of a single counseling session and distribution of an educational leaflet for women with vulvoperineal warts reported that 95 percent of patients were satisfied or very satisfied with the leaflet compared with usual care.86 In a trial of unintended pregnancy prevention and STI risk reduction among women at risk for unintended pregnancy, 82 percent indicated it was helpful to talk about contraception, 90 percent felt that the health educator focused on their individual concerns, and 93 percent felt that the health educator addressed all of their questions.70

One study reported participants' ease of talking to a doctor about sex and preferred source of information about sex and related problems.76 This study of a brief individual session with a primary care provider indicated that the majority of participants found it to be “very easy” (22%) or “somewhat easy” (48%) to talk to their doctor about sex. Eleven percent of participants reported that it was “difficult” or “very difficult” to discuss sex with their doctor. Intervention group participants indicated they preferred information about sex from their usual primary care provider (49%), followed by sexual health clinic (12%) and family planning clinic (12%).

A longitudinal study not included in this review reported on the relationship between HIV-related stigma and gains in HIV knowledge in teens participating in a multilevel, multisite HIV risk reduction intervention.117 The intervention was not designed to reduce HIV-related stigma, but rather to compare the intervention's effect on HIV stigma with that of the health promotion control. Intervention participants showed more reduction in stigma compared with control participants (p<0.05). Additionally, researchers found that higher baseline HIV-related stigma was related to smaller gains in HIV knowledge, suggesting that stigma in teens regarding HIV may affect their ability to internalize information regarding HIV. This study suggests that participation in a HIV risk reduction intervention is more likely to reduce stigma than increase it, although data are extremely limited.

## Limitations of the Review

### Limitations of Our Report

One important limitation of the data on behavioral outcomes was that they were based on self-report. Indeed, a study of adolescent and young adult women who self-reported using condoms 100 percent of the time found a biomarker for unprotected vaginal intercourse within 14 days on swabs collected from 34 percent of participants.119 Sexual behavior outcomes may be especially vulnerable to biases related to social desirability, given the personal nature of sexual behavior and the risk for feeling shame or stigma as a result of particular behaviors. This is likely compounded for adolescents, many of whom may wish to keep their sexual activity hidden from their parents and other adults. While parental involvement in interventions targeting young adolescents remains an area of potential value for further exploration, strenuous efforts to ensure confidentiality may still fail to win confidence from participants and lead to biased findings.

Another limitation of our review is that we excluded comparative effectiveness trials, including some that barely exceeded our minimum threshold for a control group. We excluded 41 publications because of comparative effectiveness (Appendix B), one of the most common reasons for exclusion among studies that made it through the title and abstract screening process. Some of these studies may have been excluded for other reasons as well. Several trials that were excluded for comparative effectiveness tested different formats (e.g., group vs. individual, interactive computer vs. printed materials) for providing the same content and rarely found group differences. Trials that reported more and less intensive interventions, however, frequently reported greater reductions in risky sexual behaviors or STIs with more intensive interventions. Few trials attempted to isolate the effects of a single component of the intervention.

### Limitations of the Data on Populations

Some populations were not well represented in the included trials, even though they were at high risk for acquiring STIs. One notable population that was minimally represented in these studies, and missing entirely from high-intensity trials, was MSM. We excluded all trials that targeted MSM, most because they were not conducted in health care settings. However, there is a substantial body of literature on HIV/STI prevention in MSM in community settings. The Community Preventive Services Task Force found that community-based individual-, group-, and community-level interventions were effective in reducing risk for STIs in MSM.120 Of the few health care–based trials in MSM we identified, most were excluded because the control group exceeded our a priori threshold for intervention intensity (≤15 minutes). The trial that came closest to meeting our inclusion criteria was conducted in a health clinic that used a 20-minute control condition.121 In this trial, MSM with STIs were randomized to a single, one-on-one 20-minute session consistent with CDC guidelines or to both the 20-minute visit and a 1-day HIV prevention workshop. The intervention did not reduce the risk for subsequent infections over the course of the following year. In fact, there was a greater proportion of STIs in the intervention group (31%) than the control group (21%), although this difference was only marginally statistically significant (adjusted OR, 1.66 [95% CI, 1.00 to 2.74]). There are numerous studies in MSM currently underway (Appendix D), including one large (n=4,000) technology-based intervention that may meet inclusion criteria for future USPSTF reviews.

Illicit drug users and adults with psychiatric conditions are other high-risk populations that were not well represented in our review. We included only two trials in psychiatric patients, one of which was further limited to illicit drug users with mental illness.64,82 Most trials in adults with mental illness focused on populations recruited from residential or institutional settings and, as such, did not meet inclusion criteria. Similarly, trials targeting illicit drug users were generally conducted in community or inpatient settings or were excluded because their control condition was too intensive (e.g., two brief, individually tailored sessions using CDC guidelines for HIV counseling and testing, with an estimated contact time of >15 minutes). Meta-analyses of HIV prevention interventions in illicit drug users indicate modest benefit of risk reduction counseling in this population.122,123 While most trials included in the meta-analysis were not conducted in health care settings, it did identify 12 trials in drug treatment or other health care settings. However, it did not report results separately for these studies.122

We also found no primary care–relevant evidence for American Indians/Alaska Natives or adults age 50 years and older. Rates of chlamydia and gonorrhea in American Indians/Alaska Natives are second only to African Americans nationwide, and rates of both of these infections in Alaska are among the highest in the United States. Nevertheless, we identified no health care–based efforts that included substantial numbers of American Indians or Alaska Natives. While older adults do not represent a population with high absolute rates of STIs, the increase in STI rates in recent years suggests that interventions targeting this age group may be needed.34

### Limitations of the Data on Other STI Prevention Strategies

In addition to not covering all important subpopulations because of limitations of the literature, we also did not cover a number of important STI risk reduction strategies that cannot be implemented in health care settings or go beyond risk reduction counseling. For example, programs to encourage STI and HIV testing and partner notification programs aim to reduce STIs by increasing awareness and treatment of STIs that are frequently asymptomatic.

Similarly, the Community Preventive Services Task Force recommends partner notification by provider referral for persons with HIV (available at www.thecommunityguide.org). We did not include interventions to increase safe sex behaviors in persons with HIV because of limited applicability to most primary care settings. If effective, such programs may not only reduce the spread of HIV to HIV-negative persons, but may also reduce the rate of other STIs in the HIV-positive population. This may be especially important since HIV-positive persons are highly susceptible to STIs.8 Condom distribution programs can also be effective for reducing STI rates, but were not included in this review.116

We also did not cover school-based interventions. A review of school-based sexual risk reduction interventions in adolescents did not demonstrate a beneficial effect on self-reported sexual behaviors, although knowledge generally increased. Reviewers noted that interventions were frequently not implemented as intended due to variability in school culture, support from school administration, and enthusiasm and skill of teachers and other interventionists.124

The CDC maintains a regularly updated compendium of evidence-based individual-, group-, and community-level interventions and associated dissemination materials, targeting a wide range of risk populations and risk reduction strategies.125 This is an excellent source for interventions that have been empirically tested, and includes many interventions conducted in community-based settings that were not included in our review.

## Future Research Needs

While the body of literature on primary care–relevant sexual risk reduction counseling is relatively mature, there are still some important evidence gaps and promising single-study findings that need replication. Most evidence comes from adolescents and other high-risk populations, particularly high-risk women. While interventions tailored to fairly narrow populations tend to show larger effects than those designed for wider administration, broadly targeted interventions have the potential for greater reach and should not be abandoned. Thus, more data are needed in mixed-gender and other broad-based interventions that could be implemented in or linked to primary care.

We found minimal data on interventions conducted in health care settings targeted toward primary prevention in younger adolescents. This is another area that has the potential for broad reach, but trials would require large samples and long-term followup to observe initiation of sexual activity and exposure to STIs sufficient to demonstrate a public health impact. In particular, replicating the promising intervention that targeted mothers of younger adolescents with longer followup would be useful, so that risky sexual behavior outcomes and STI rates could be assessed.

While high-intensity interventions were most likely to be efficacious, there were two low-intensity interventions that reduced STIs. Replicating these two trials should be a priority.78,79 One trial was a 20-minute culturally tailored intervention that employed highly trained facilitators.79 This trial demonstrated a beneficial effect in African American women. The other intervention involved a video that is freely available from the CDC. While some clinics may prefer not to show such a video to everyone in their waiting area, this intervention may be amenable to adaptation for personal mobile devices, whether in a waiting room, examination room, or at home. Other uses of interactive mobile, Web-based, or other automated expert systems have been only minimally assessed in the health care context and represent potentially fruitful avenues for exploration. An example of one such intervention is a 12-episode soap opera streamed to smartphones of young urban African American women.126 This trial, which recruited from an STI clinic and four other nonhealth care–based community settings, found that participants recruited from the STI clinic showed greater reductions in risky sexual behaviors than those recruited from other community sources, suggesting that such interventions in a health care context may be promising.

## Conclusion

Moderate- and high-intensity interventions in primary care or similar health care settings can reduce STIs and risky sexual behaviors, particularly in sexually active adolescents and high-risk adults. While low-intensity interventions generally do not reduce STI risk, some approaches show promise and trial replication should be pursued. Data on primary prevention in presexually active adolescents are sparse. We found no evidence that sexual risk reduction counseling is harmful. These findings are consistent with the results of the previous USPSTF review on this topic. This review expands upon that review's findings with the addition of almost twice as many included trials, many with both low- and moderate-intensity interventions.