# RESULTS

## Literature Search

We included 31 trials in the review.57-59,63-90 The results of these trials were reported in 57 publications and were selected from our review of 3,241 abstracts and 218 full-text articles (Appendix A Figure 1). We identified 23 trials examining the primary effects of behavioral counseling interventions on health outcomes;57-59,63,64,67-74,78-80,83-85,87-90 25 trials examined the effects on sexual behaviors;57-59,63-68,71-73,75-77,79,81-88,90 nine trials examined the effects on other positive outcomes;59,63,66,68,70-72,75,81 and only three trials reported on adverse effects of the intervention.84,85,90

## Description of Included Studies

Of the 31 included trials (n=70,324), 16 were newly published trials that were not included in the previous review (n=56,110) and 15 were included in the 2008 review (n=14,214). Figure 2 lists all included studies stratified by intervention intensity and population risk. The majority of the trials targeted participants at increased risk for STIs or with a recent STI, and most trials provided high-intensity interventions. Figure 3 shows the distribution of trials across the levels of treatment intensity and population risk, weighted by sample size. Notably, three newly added trials provided low-intensity interventions to participants at increased risk, including one large trial conducted in STI clinics.78

Figure 2 Included Trials, by Intervention Intensity and Population Risk, Showing the Primary Outcome and Noting Trials With Narrowly Targeted Samples

* Statistically significant group differences in primary outcome (bolded).

† Adolescents only.

‡ Outlined studies indicate new studies added since the 2008 USPSTF review.

Abbreviations: adol = adolescents; Beh = primary outcome was a behavioral outcome; BV = only STI reported was bacterial vaginosis; Gen = general; ns = not significant; preg = trials limited to pregnant women; psych = trials limited to psychiatric patients; STI = reported sexually transmitted infection outcome; WSW = trial limited to women who have sex with women.

Figure 2 displays the distribution of included studies by intervention intensity and population risk.

Figure 3 Distribution of Included Studies Across the Levels of Treatment Intensity and Population Risk, Weighted by Sample Size

Abbreviations: adol = adolescents; min = minute(s); STI = sexually transmitted infection.

Figure 3 displays the weighted distribution (by sample size) of included studies by intervention intensity and population risk.

Tables 2 to 5 provide information about the study samples, intervention characteristics, and outcomes reported, organized by intervention intensity, with separate tables for adolescents and adults. Trials that conducted subgroup analyses by age are shown in both adolescent and adult tables. Detailed intervention descriptions are in Appendix C Table 1.

Table 2 Design and Baseline Population Characteristics of Included Studies Targeting Adolescents

Author, year Quality | Setting | Risk | N rand | Intervention Description | Control Description | Age Range (mean, y) | % Female | % Race/Ethnicity | Currently Sexually Active | STI History
Low-intensity (<30 min)
Boekeloo, 1999^63,143^ Fair | Washington DC, primary care | Low/mix | 219 | One 15-min audiotape and individual discussion with primary care provider during general health exam | Usual care | 12-15 (NR) | 50 | Black: 63.7 Hispanic: 3.2 White: 18.6 Other: 13.5 | Past 3 mo: 21.4% | Treated for STI: 5.9%
Moderate-intensity (30 to 120 min)
Guilamo-Ramos, 2011^65^ Fair | New York, NY, primary care | Low/mix | 264 | One 30-min individual session with social worker, primary care physician provided brief message, two booster calls with social worker for the mother | Usual care | 11-14 (12.9) | 52.3 | Parent's race/ethnicity: Black: 15.5 Hispanic: 84.5 | 6.4% | NR
Danielson, 1990^66^ Fair | Portland, OR and Vancouver, WA, HMO | Low/mix | 1195 | One 1-hr individual counseling session with study health care provider plus slide/ video presentation | No intervention | 15-18 (NR) | 0 | Black: <5 Asian/PI: <4 | Past 12 mo: 37% | NR
Kershaw, 2009^59^ Fair | Atlanta, GA and New Haven, CT, primary care | Increased | 513 (subgroup) | Ten 2-hr prenatal group sessions with midwife or obstetrician, HIV prevention discussion in three sessions (120 min total) | CG1: Attention control (10 2-hr prenatal group sessions with midwife or obstetrician) CG2: Usual prenatal care | 14-19 (NR) | 100 | Black: 80^*^ Hispanic: 13^*^ White: 6^*^ Other: 1^*^ | NR | Lifetime STI: “more than half”^*^
Kamb (mod IG) 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 508 (subgroup) | IG2: Two 20-min individual counseling sessions with counselor, based on CDC guidelines | CG1: Minimal intervention (two 5-min didactic sessions with physician) CG2: same as CG1, but fewer followup assessments | 14-19 (NR) | 43^*^ | Black: 59^*^ Hispanic: 19^*^ White: 16^*^ Other: 6^*^ | NR (mean number of sexl partners in past 3 mo, 2.3) | BL STI: 32%^*^
High-intensity (>120 min)
Jemmott, 2005^67^ Fair | Philadelphia, PA, primary care | Increased | 682 | IG1: One 4-hr information-based group session with a facilitator IG2: One 4-hr skills-based group session with a facilitator | Attention control (one 4-hr group health promotion session) | 12-19 (15.5) | 100 | Black: 67.9 Hispanic: 32.1 | Past 3 mo: 87.1% | BL STI: 21.6%
DiClemente, 2004^68,148-153^ Good | Birmingham, AL, primary care | Increased | 522 | Four 4-hr HIV prevention group sessions with health and peer educators | Attention control (four 4-hr health promotion group sessions) | 14-18 (16) | 100 | Black: 100 | Past 6 mo: 100% | BL STI: G: 5.2% C: 17.4% T: 12.6%
Kamb (high IG) 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 512 (subgroup) | IG1: Four 20- to 60-min individual counseling sessions with counselor | CG1: Minimal intervention (two 5-min didactic sessions with physician) CG2: same as CG1, but fewer followup assessments | 14-19 (NR) | 43^*^ | Black: 59^*^ Hispanic: 19^*^ White: 16^*^ Other: 6^*^ | NR (mean number of sex partners in past 3 mo, 2.3) | BL STI: 32%^*^
Champion, 2012^69^ Fair | Southwestern US, research clinic | Prior STI | 559 | Three clinical exams and interviews, two motivational workshop sessions, and weekly (3 to 5) support group sessions, plus individual counseling initiated by participants, all with nurse practitioner | Minimal intervention (one session of clinical counseling surrounding STI treatment [time NR] with nurse practitioner) | NR (16.5) | 100 | Black: 16.4 Hispanic: 83.6 | NR (mean age at first intercourse, 13.8 y) | Lifetime STI: 100% (of analyzed sample)
Shain, 1999^57,154-156^ Fair | San Antonio, TX, research clinic | Prior STI | 148 (subgroup) | Three 3- to 4-hr group cognitive behavioral counseling sessions with facilitator | Minimal intervention (one 15-min standardized individual counseling session per CDC guidelines with nurse clinician) | 14-18 (NR) | 100 | Black: 32 Hispanic: 68 | NR (age at first intercourse <15 y, 40.5%) | BL STI: 100%

* Data for entire study population, which included adults and adolescents.

Abbreviations: BL = baseline; C = chlamydia; CDC = Centers for Disease Control and Prevention; CG = control group; G = gonorrhea; HMO = health maintenance organization; HIV = human immunodeficiency virus; IG = intervention group; NR = not reported; rand = randomized; STI = sexually transmitted infection; T = trichomoniasis.

Table 3 Design and Baseline Population Characteristics of Included Studies Targeting Adults

Author, year Quality | Setting | Risk | N rand | Intervention Description | Control Description | Age Range (mean, y) | % Female | % Race/Ethnicity | Sexual History at BL | STI History
Low-intensity (<30 min)
Proude, 2004^76^ Fair | Australia, primary care | General | 312 | One brief individual session with primary care provider (family physician) | Attention control (tobacco screening and counseling) | 18-25 (NR) | 71 | NR | ≥1 sex partners: 78% | NR
Scholes, 2003^83^ Fair | WA and NC, primary care | General | 1210 | Two tailored mailings | Usual care | 18-25 (21) | 100 | Black: 19 White: 69 Other: 12 | ≥2 sex partners in past 12 mo: 56.5% | Lifetime STI: 27%
Carey (low IG), 2010^84,157,158^ Fair | Syracuse, NY, STI clinic | Increased | 496 | IG1: One 15-min motivational interview with clinic nurse | Minimal intervention (one 15-min educational intervention with clinic nurse) | ≥18 (29.2) | 46.4 | Black: 63.9 Hispanic: 8.7 White: 24.3 Other: 11.9 | Mean number of sex partners in past 3 mo: 2.8 | BL STI: 18.1%
Peipert, 2008^72,159^ Fair | Providence, RI, primary care and Planned Parenthood | Increased | 542 | Three sessions of tailored computer-based intervention | Minimal intervention (one computer session of standardized contraceptive and STI prevention information [time NR]) | 13-35 (22) | 100 | Black: 26 Hispanic: 17 White: 45 Other: 12 | ≥2 sex partners in past 30 days: 15% | Lifetime STI: 47%
Warner, 2008^78^ Good | Denver, CO, Long Beach, CA, and San Francisco, CA, STI clinic | Increased | 40,282 | One 23-min video on STI/HIV risk and prevention in clinic waiting room | Usual care | NR (NR) | 30 | Black: 18.5 Hispanic: 25.0 White: 46 Other: 11.0 | Men who have sex with men: 31% | BL STI: 15.5%
Jemmott (low IG), 2007^79,160^ Good | Newark, NJ, primary care | Increased | 322 | IG3: One 20-min individual skill intervention with nurses IG4: One 20-min individual information session with nurses | Attention control (general health promotion with nurses) | 18-45 (27.2) | 100 | Black: 100 | Mean number of sex partners in past 3 mo: 1.2 | BL STI: 20.3%
Marrazzo, 2011^74,161,162^ Fair | Seattle, WA, research clinic | Prior STI | 89 | One education session and motivational interviewing with study staff | Attention control (education session on Pap smears with study staff) | 16-30 (25.4) | 100 | Black: 7.9 | >1 female sex partner: 24.7% | Current BV: 100%
Cortes-Bordoy, 2010^86^ Fair | Spain, gynecology clinic | Prior STI | 211 | One counseling session with participant's gynecologist with educational leaflet | Usual care | 18-56 (30.2) | 100 | NR | Mean number of sex partners in past 12 mo: 2.7 | Lifetime STI: 100%
Moderate-intensity (30 to 120 min)
Petersen, 2007^70^ Fair | Chapel Hill, NC, primary care | General | 764 | Two individual STI risk reduction sessions with health educator | Attention control (one preventive health care individual session with health educator) | 16-44 (NR) | 100 | Black: 27 White: 62 Other: 10 | Sexual intercourse in last 30 days: 70% | NR
Wenger, 1992^77^ Fair | Los Angeles, CA, primary care | General | 435 | IG1: One 1-hr HIV/AIDS group education session with study physician IG2: One 1-hr HIV/AIDS group education session with study physician plus HIV testing | No intervention | ≥18 (23) | 72 | Black: 8 Hispanic: 13 White: 61 Asian: 15 | Mean number of sex partners in past 30 days: 0.8 | Lifetime STI: 23%
Metsch, 2013^90^ Good | 7 states and Washington, DC, STI clinics | Increased | 5012 | IG: One HIV testing and risk reduction counseling session with counselor (estimated median of 32 min total) | HIV testing, brief information about HIV according to CDC | ≥18 (NR) | 34 | Black: 41.9 Hispanic: 15.3 White: 31.8 Other: 11.1 | Predicted mean number of partners in past 6 mo: 4.65 | BL STI: 43.3%
Berenson (mod IG), 2012^71^ Fair | Southeast TX, reproductive health clinic | Increased | 771 | IG1: One 45-min individual contraception and STI counseling with research assistants | Usual care | 16-24 (19.9) | 100 | Black: 18.6 Hispanic: 54.2 White: 24.8 Other: 2.3 | Mean number of sex partners in past 12 mo: 1.6 | LifetimeSTI: 26.1%
Neumann, 2011^80^ Fair | Harlem, NY, and Puerto Rico, STI clinics | Increased | 3365 | One group session including video and group discussion with facilitator, plus free condoms | Usual care plus free condoms | 18-71 (29.3) | 51.5 | Black: 40.1 Hispanic: 50.9 White: 0.8 Other: 8.2 | Same-gender sex: 7.9% | BL STI: 22.2%
Kershaw, 2009^59^ Fair | Atlanta, GA, and New Haven, CT, primary care | Increased | 1047 | Ten 2-hr prenatal group sessions with midwife or obstetrician, HIV prevention discussion in three sessions (120 min total) | CG1: Attention control (10 2-hr prenatal group sessions with midwife or obstetrician) CG2: Usual prenatal care | 14-25 (20.4) | 100 | Black: 80 Hispanic: 13 White: 6 Other: 1 | NR | Lifetime STI: “more than half”
Kamb (mod IG), 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 2,890 | IG2: Two 20-min individual counseling sessions with counselor, based on CDC guidelines | CG1: Minimal intervention (two 5-min didactic sessions with physician) CG2: same as CG1, but fewer followup assessments | ≥14 (25) | 43 | Black: 59 Hispanic: 19 White: 16 Other: 6 | Mean number of sex partners in past 3 mo: 2.3 | BL STI: 32%
Crosby, 2009^87^ Fair | Southern US, STI clinic | Prior STI | 266 | One 45- to 50-min peer counseling session with lay health advisors | Minimal intervention (“few minutes” of messaging based on CDC guidelines with nurse, plus 12 free condoms) | 18-29 (23.2) | 0 | Black: 100 | Mean number of sex partners in past 3 mo: 3 | BL STI: 26%
High-intensity (>120 min)
Wingood, 2013^89^ Good | Atlanta, GA, HMO | Increased | 848 | Two 4-hr group HIV intervention with health educators | Attention control (nutrition health promotion) | 18-29 (22.0) | 100 | Black: 100 | Multiple sex partners in last 6 mo: 36.8% | BL STI: 17%
Berenson (high IG), 2012^71^ Fair | Southeast TX, reproductive health clinic | Increased | 772 | IG2: One 45-min individual contraception and STI counseling with research assistants, 6 to 10 phone calls on correct oral contraceptive and condom use | Usual care | 16-24 (19.9) | 100 | Black: 18.6 Hispanic: 54.2 White: 24.8 Other: 2.3 | Mean number of sex partners in past 12 mo: 1.6 | Lifetime: 26.1%
Cianelli, 2012^75^ Fair | Chile, primary care | Increased | 496 | Six 2-hr HIV/AIDS prevention group sessions with health educator | Waitlist control | 18-49 (32.5) | 100 | Chilean: 100 | NR | NR
Carey (high IG), 2010^84,157, 158^ Fair | Syracuse, NY, STI clinic | Increased | 1235 | IG2: 15-min motivational interview plus one 4-hr informational didactic workshop with facilitators IG3: 15-min motivational interview plus one 4-hr information, motivation, and skills workshop with facilitators IG4: CG plus one 4-hr informational workshop with facilitators IG5: CG plus one 4-hr information, motivation, and skills workshop with facilitators | Minimal intervention (one 15-min educational intervention with clinic nurse) | ≥18 (29.2) | 46.4 | Black: 63.9 Hispanic: 8.7 White: 24.3 Other: 11.9 | Mean number of sex partners in past 3 mo: 2.8 | BL STI: 18.1%
Berkman, 2007^82^ Good | New York, NY, psychiatric clinic | Increased | 149 | Thirteen 1-hr group sessions on HIV risk reduction (Enhanced-SexG) with a substance abuse and/or mental health counselor | Minimal intervention (one HIV presentation that emphasized condom use [time NR])/attention control [12 money management sessions]) | 18-59 (38.6) | 0 | Black: 54 Hispanic: 28 White: 11 Other: 7 | Mean vaginal intercourse with casual partner in past 6 mo: 0.4 | NR
Jemmott (high IG), 2007^79,160^ Good | Newark, NJ, primary care | Increased | 323 | IG1: One 3-hr group skills intervention with nurses IG2: One 3-hr group information session with nurses | Attention control (general health promotion with nurses) | 18-45 (27.2) | 100 | Black: 100 | Mean number of sex partners in past 3 mo: 1.2 | BL STI: 20.3%
Carey, 2004^64^ Fair | Syracuse, NY, psychiatric clinic | Increased | 408 | Ten HIV risk reduction group sessions with facilitators | CG1: Attention control (10 substance abuse group sessions with facilitators) CG2: Usual care | ≥18 (36.5) | 54 | Black: 21 White: 67 Other: 12 | Mean number of sex partners in past 3 mo: 1 | Lifetime STI: 38%
Ehrhardt, 2002^81,105,163-166^ Good | Brooklyn, NY, Planned Parenthood | Increased | 360 | Eight 2-hr HIV/STI prevention group sessions with facilitators | Minimal intervention (risk assessment only) | 18-30 (22.3) | 100 | Black: 72.5 Hispanic: 16.9 White/other: 10.6 | ≥2 current male partners: 23.4% | Past 3 mo STI: 16.9%
Kamb (high IG) 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 2,881 | IG1: Four 20- to 60-min individual counseling sessions with counselor | CG1: Minimal intervention (two 5-min didactic sessions with physician) CG2: same as CG1, but fewer followup assessments | ≥14 (25) | 43 | Black: 59 Hispanic: 19 White: 16 Other: 6 | Mean number of sex partners in past 3 mo: 2.3 | BL STI: 32%
Marion, 2009^85^ Fair | Chicago, IL, primary care | Prior STI | 342 | Four individual counseling sessions with nurse practitioner and 4 peer-led group classes with a peer educator | Minimal intervention (one 10- to 20-min standardized STI presentation plus STI test and referral to treatment) | ≥18 (38.1) | 100 | Black: 100 | Mean number of lifetime sex partners: 26.3 | BL STI: 75%
Shain, 2004^73,167^ Fair | San Antonio, TX, STI clinic | Prior STI | 775 | IG1: One 15- to 20-min individual and three 3-hr group cognitive behavioral counseling sessions with facilitator IG2: IG1, plus 5 optional support group sessions | Minimal intervention (one 15- to 20-min STI individual counseling session) | 14-43 (21.0) | 100 | Black: 23.2 Hispanic: 76.8 | >1 sex partner in past 3 mo: 25.7% | BL STI: 100%
Shain, 1999^57,154-156^ Fair | San Antonio, TX, research clinic | Prior STI | 617 | Three 3- to 4-hr group cognitive behavioral counseling sessions with facilitator | Minimal intervention (one 15-min standardized individual counseling session per CDC guidelines with nurse clinician) | 14-45 (21.6) | 100 | Black: 31 Hispanic: 69 | Mean number of sex partners in last 3 mo: 1.5 | BL STI: 100%
Boyer, 1997^88^ Fair | San Francisco, CA, STI clinic | Prior STI | 393 | Four 1-hr individual STI counseling sessions with counselor | Minimal intervention (one 15-min risk reduction individual counseling session with counselor) | 18-35 (NR) | 32.8 | Black: 45.8 Hispanic: 14.5 White: 29.3 Other: 10.2 | NR | Lifetime STI: 61.8%

Abbreviations: BL = baseline; CDC = Centers for Disease Control and Prevention; CG = control group; HMO = health maintenance organization; HIV = human immunodeficiency virus; IG = intervention group; NR = not reported; rand = randomized; STI = sexually transmitted infection.

Table 4 Summary of Included Studies—Adolescents

Author, year Quality | Setting | Risk | N rand | Population | STI history | Followup Time Points (m) | STI Outcomes | Unprotected Intercourse/Condom Use | Other Sexual Behavior Outcomes | Other Positive Outcomes
Low-intensity (<30 min)
Boekeloo, 1999^63,143^ Fair | Washington, DC, primary care | Low/mix | 219 | Adolescents ages 12 to 15 y | Treated for STI: 5.9% | 3, 9 | ↔^†^ | ↑↔ | ↑↔ | ↔
Moderate-intensity (30 to 120 min)
Guilamo-Ramos, 2011^65^ Fair | New York, NY, primary care | Low/mix | 264 | African American and Latino adolescents ages 11 to 14 y | NR | 9 | | | ↑
Danielson, 1990^66^ Fair | Portland, OR and Vancouver, WA, HMO | Low/mix | 1195 | Adolescent boys ages 15 to 18 y | NR | 12 | | ↔ | | ↑
Kershaw, 2009^59^ Fair | Atlanta, GA, and New Haven, CT, primary care | Increased | 513 (subgroup) | Pregnant adolescents age <20 y (NR) | Lifetime STI: “more than half” | 3rd trimester, 6, 12 | ↔
Kamb (mod IG), 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 508 (subgroup) | Sexually active adolescents ages 14 to 19 y | BL STI: 32%^*^ | 3, 6, 9, 12 | ↑
High-intensity (>120 min)
Jemmott, 2005^67^ Good | Philadelphia, PA, primary care | Increased | 682 | Sexually active African American or Latino adolescent girls ages 12 to 19 y | BL STI: 21.6% | 3, 6, 12 | ↑↔ | ↑↔ | ↑↔
DiClemente, 2004^68,148-153^ Good | Birmingham, AL, primary care | Increased | 522 | Sexually active African American adolescent girls ages 14 to 18 y | BL STI: G: 5.2% C: 17.4% T: 12.6% | 6, 12 | ↑↔ | ↑ | ↔ | ↑↔
Kamb (high IG), 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 512 (subgroup) | Sexually active adolescents ages 14 to 19 y | BL STI: 32%^*^ | 3, 6, 9, 12 | ↑
Champion, 2012^69^ Fair | Southwestern US, research clinic | Prior STI | 559 | Ethnic minority adolescent girls with STI or abuse | Lifetime STI: 100% (of analyzed sample) | 6, 12 | ↑
Shain, 1999^57^ Fair | San Antonio, TX, research clinic | Prior STI | 148 (subgroup) | Mexican American and African American adolescent girls ages 14 to 18 y with a nonviral STI | BL STI: 100% | 6, 12 | ↑ | ↔ | ↑↔

* Data for entire study population, which included adults and adolescents.

† Self-reported (only or in part) STI outcome.

↑ Results consistently show a benefit of treatment.

↔ Results consistently show no differences between groups.

↑↔ Results are mixed; benefit seen for some outcomes or followups, but not all.

Abbreviations: BL = baseline; C = chlamydia; CG = control group; CI = confidence interval; G = gonorrhea; HIV = human immunodeficiency virus; high= high intensity; IG = intervention group; mod = moderate intensity; NR = not reported; rand = randomized; STI = sexually transmitted infection; T = trichomoniasis.

Table 5 Summary of Included Studies—Adults

Author, year Quality | Country, Setting | Risk | N rand | Population (mean age, y) | STI History | Followup Time Points (m) | STI Outcomes | Unprotected Intercourse/Condom Use | Other Sexual Behavior Outcomes | Other Positive Outcomes | Other Harms
Low-intensity (<30 min)
Proude, 2004^76^ Fair | Australia, primary care | General | 312 | Adults ages 18 to 25 y | NR | 3 | | ↔
Scholes, 2003^83^ Fair | WA and NC, primary care | General | 1210 | Sexually active nonmonogamous women ages 18 to 24 y | Lifetime STI: 27% | 6 | ↔∥ | ↑↔
Carey (low IG), 2010^84,157,158^ Fair | Syracuse, NY, STI clinic | Increased | 496 | Adults age ≥18 y with high-risk behavior in past 3 mo | BL STI: 18.1% | 3, 6, 12 | ↔ | ↔ | ↔ | | ↔
Peipert, 2008^72, 159^ Fair | Providence, RI, primary care and Planned Parenthood | Increased | 542 | Women ages 13 to 35 y at high risk for STI or unplanned pregnancy due to age, behavior, history of STI, or pregnancy | Lifetime STI: 47% | 24 | ↔ | ↔ | | ↔
Warner, 2008^78^ Good | Denver, CO, Long Beach, CA, and San Francisco, CA, STI clinic | Increased | 40,282 | All patients | BL STI: 15.5% | 14.8 | ↑
Jemmott (low IG), 2007^79,160^ Good | Newark, NJ, primary care | Increased | 322 | African American women ages 18 to 45 y | BL STI: 20.3% | 6, 12 | ↑↔^*^ | ↑↔^*^
Marrazzo, 2011 74,161,162 Fair | Seattle, WA, research clinic | Prior STI | 89 | Women ages 16 to 30 y with bacterial vaginosis who have sex with women | Current BV: 100% | 3, 6, 9, 12 | ↔
Cortes-Bordoy, 2010^86^ Fair | Spain, gynecology clinic | Prior STI | 211 | Women age ≥18 y with vulvoperineal warts | Lifetime STI: 100% | 3, 6, 9, 12 | | ↔ | ↑ | ↔
Moderate-intensity (30 to 120 min)
Petersen, 2007^70^ Fair | Chapel Hill, NC, primary care | General | 764 | Women ages 16 to 44 y at risk for unintended pregnancy (no IUD or sterilization) | NR | 12 | ↔ | ↔ | | ↔
Wenger, 1992^77^ Fair | Los Angeles, CA, primary care | General | 435 | University students age ≥18 y | Lifetime STI: 23% | 6 | | ↔ | ↔
Metsch, 2013^90^ Good | 7 states and Washington, DC, STI clinics | Increased | 5012 | Adults age ≥18 y seeking services at an STI clinic | BL STI: 43.3% | 6 | ↔ | ↔ | ↑↔ | | ↔
Berenson (mod IG), 2012^71^ Fair | Southeast TX, reproductive health clinic | Increased | 771 | Sexually active women ages 16 to 24 y | Lifetime STI: 26.1% | 3, 6 | ↔∥ | ↔ | | ↔
Neumann, 2011^80^ Fair | Harlem, NY, and Puerto Rico, STI clinics | Increased | 3365 | Adults age ≥18 y, 99% racial/ethnic minority | BL STI: 22.2% | 22 | ↑
Kershaw, 2009^59^ Fair | Atlanta, GA, and New Haven, CT, primary care | Increased | 1047 | Pregnant women age <25 y | Lifetime STI: “more than half” | 3rd tri, 6, 12 | ↔ | ↑↔ | | ↑↔
Kamb (mod IG), 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 4320 | Adults and adolescents age ≥14 y | BL STI: 32% | 3, 6, 9, 12 | ↔^§^ | ↑↔ | ↑↔
Crosby, 2009^87^ Fair | Southern US, STI clinic | Prior STI | 266 | African American men ages 18 to 29 y with newly diagnosed STI and recent experience with condoms | BL STI: 100% | 3, 6 | ↑ | ↑ | ↑
High-intensity (>120 min)
Wingood, 2013^89^ Good | Atlanta, GA, HMO | Increased | 848 | Sexually active African American women ages 18 to 29 y | BL STI: 17% | 6, 12 | ↑
Berenson (high IG), 2012^71^ Fair | Southeast TX, reproductive health clinic | Increased | 772 | Sexually active women ages 16 to 24 y | Lifetime STI: 26.1% | 3, 6 | ↔∥ | ↑ | | ↔
Cianelli, 2012^75^ Fair | Chile, primary care | Increased | 496 | Chilean women ages 18 to 49 y | NR | 3 | | ↔ | | ↑
Carey (high IG), 2010^84,157,158^ Fair | Syracuse, NY, STI clinic | Increased | 1,235 | Adults age ≥18 y with high-risk behavior in past 3 mo | BL STI: 18.1% | 3, 6, 12 | ↔ | ↔ | ↔ | | ↔
Berkman, 2007^82^ Good | New York, psychiatric clinic | Increased | 149 | Adult males ages 18 to 59 y with severe mental illness | NR | 6, 12 | | ↔ | ↔
Jemmott (high IG), 2007^79,160^ Fair | Newark, NJ, primary care | Increased | 323 | African American women ages 18 to 45 y | BL STI: 20.3% | 6, 12 | ↑↔^*^ | ↑↔^*^
Carey, 2004^64^ Fair | Syracuse, NY, psychiatric clinic | Increased | 408 | Adults age ≥18 y with a mood or thought disorder and alcohol or drug use in past year | Lifetime STI: 38% | 3, 6 | ↑∥ | ↑ | ↑↔
Ehrhardt, 2002^81,105,163-166^ Good | Brooklyn, NY, Planned Parenthood | Increased | 360 | Women ages 18 to 30 y | Past 3-mo STI: 16.9% | 6, 12 | | ↑↔ | ↑↔ | ↔
Kamb (high IG), 1998^58,144-147^ Fair | 5 US cities, STI clinic | Increased | 4311 | Adults and adolescents age ≥14 y | BL STI: 32% | 3, 6, 9, 12 | ↔^§^ | ↑↔ | ↑↔
Marion, 2009^85^ Fair | Chicago, IL, primary care | Prior STI | 342 | Low-income African American women age ≥18 y with ≥2 STIs in the past year | BL STI: 75% | 3 | ↔ | | ↑ | | ↔
Shain, 2004^73,167^ Fair | San Antonio, TX, STI clinic | Prior STI | 775 | Mexican American and African American women ages 15 to 45 y with 1 of 4 STIs | BL STI: 100% | 12, 24 | ↑ | ↑ | ↑
Shain, 1999^57,154-156^ Fair | San Antonio, TX, research clinic | Prior STI | 617 | Mexican American and African American women ages 14 to 45 y with a nonviral STI | BL STI: 100% | 6, 12 | ↔ | ↑ | ↑↔
Boyer, 1997^88^ Fair | San Francisco, CA, STI clinic | Prior STI | 393 | Heterosexual adults ages 18 to 35 y with previous STI, STI symptoms, or known exposure to STI | Lifetime STI: 61.8% | 3, 5, 6 | ↔ | ↑↔

* Data not reported separately for high- and low-intensity interventions; instead reported skills-based approach (IG1, IG3) vs. control, skills-based approach (IG1, IG3) vs. information-based approach (IG2, IG4), and high- (IG1) vs. low-intensity (IG3), among skills-based interventions.

† Mail only.

‡ Interactive CD-ROM intervention, length NR.

§ STI results among adult subgroup only, not entire study population, which includes adults and adolescents.

∥ Self-reported (only or in part) STI outcome.

↑ Results consistently show a benefit of treatment.

↔ Results consistently show no differences between groups.

↑↔ Results are mixed; benefit seen for some outcomes or followups, but not all.

Abbreviations: BL = baseline; C = chlamydia; CG = control group; CI = confidence interval; G = gonorrhea; IG = intervention group; HIV = human immunodeficiency virus; high = high intensity; low = low intensity; mod = moderate intensity; NR = not reported; rand = randomized; STI = sexually transmitted infection; T = trichomoniasis.

Nine trials examined outcomes in adolescents. Six of these trials were limited to adolescents,63,65-69 and three additional trials included a wide age range, but reported subgroup analyses limited to adolescents.57-59 Twenty-five trials examined outcomes in adults, including trials covering both adolescents and adults.57-59,64,70-90 Most of the adult trials either targeted young adults (age <25 years) or had an average age of 25 years or younger, so adults older than age 30 years are only minimally represented, and adults older than age 50 years are represented even less.

According to our risk categorization, eight trials were in the highest risk category, which required a current or recent STI for inclusion.57,69,73,74,85-88 Sixteen trials included participants with elevated risk, primarily based on sociodemographic characteristics of the population or setting.58, 59,64,67,68,71,72,78-84,89,90 Four included trials recruited sexually active persons primarily from adult populations with no further risk factors required and not in high-risk settings.70,75-77 Finally, three trials limited their populations to adolescents and included both sexually and nonsexually active youth.63,65,66

Seventeen of the trials included only women and three included only men. The remaining trial populations ranged from 30 to 72 percent female. Excluding the large (n=40,282) trial by Warner and colleagues78 (which only included 30% females), an estimated 62 percent of included participants were female. In 19 of the trials, greater than 75 percent of the participants were African American and/or Latino, including 11 trials exclusively in persons of African American and/or Latino descent. After excluding the large Warner trial78 (in which 54% of participants were nonwhite), an estimated 77 percent of participants were nonwhite and primarily African American or Latino. None of the included trials targeted MSM, and only two trials included a sizeable proportion of MSM.78,90 Both of these trials reported results separately for MSM and heterosexual men. One other trial targeted women who have sex with women and have BV to reduce subsequent infection by increasing condom use for digital-vaginal intercourse and on shared insertive sex toys.74

All interventions sought to minimize high-risk sexual behaviors (e.g., unprotected sexual intercourse, multiple partners, sex while intoxicated) and maximize protective behaviors (e.g., consistent correct condom use). Interventions provided at least basic information about STIs, such as prevalence and how to prevent transmission. Interventions had a variety of theoretical underpinnings, including the AIDS Risk Reduction Model (ARRM);57,69,73,81,88 social cognitive theory;58,59,68,75,79,89 Information, Motivation, Behavior, Skills Model (IMB);64,87 transtheoretical model;72,84 health belief model;71 theory of reasoned action;58 theory of gender and power;89 and the model of client health behavior.85 In addition to basic education, interventions commonly included an individualized risk assessment (self-assessment or assessed by the interventionist), hands-on skills training in condom use, problem solving, decisionmaking, goal setting, and communication about condom use and safe sex, often including role playing. Three additional trials addressed broader relationship issues, such as discussions about what participants believe is important in a relationship.57,69,81 Techniques to increase motivation to practice safe sex were commonly used, including motivational interviewing. Three trials included HIV testing as part of their interventions.58,77,90 Many interventions were extensively culturally tailored to a target group, usually based on age, gender, and/or ethnicity. Examples include the trial by DiClemente and colleagues,68 Sister-to-Sister: The Black Women's Health Project,79 and Mano a Mano-Mujer,75 among others.57,67,69,73,87,89 Four trials targeted prevention of unintended pregnancy as well as STI transmission.66,70-72 One Spanish trial was limited to women with genital warts and included treatment of their lesions as part of the intervention.86

Interventions included between one and 13 sessions, with multiple-session interventions generally lasting 3 months or less. One third of the included trials involved only a single session, including some that were moderate- and high-intensity because of the length of the session. Two additional trials included treatment arms with only one brief session as well as more intensive treatment arms.79,84 Only two interventions involved continued contact for longer than 5 months and both employed lower-intensity booster contacts after the completion of the main intervention.82,85 Most of the high-intensity interventions involved group sessions, and some included these group sessions in addition to individual counseling sessions.69,73,84,85 Most of the low-intensity interventions involved individual meetings with a counselor, but three involved only mail-,83 computer-,72 or video-based78 interventions.

Almost all (28/31 or 90%) of the trials were conducted in the United States. The most common settings were primary care (15/31 or 48%), STI clinics (8/31 or 26%), and other reproductive health clinics, such as obstetrics/gynecology or Planned Parenthood clinics (3/31 or 10%). Only four of the interventions involved the participant's primary care provider or gynecologist in the delivery of the intervention, including two of the three trials conducted outside the United States. Other types of interventionists included health educators, nurses, nurse practitioners, trained lay educators, and other trained facilitators with educational backgrounds ranging from a bachelor's to a medical degree.

Most trials included usual care, a minimal intervention, or waitlist controls. Nine of the trials, however, used attention-control conditions that provided interventions on other healthy lifestyle topics or on topics targeted to the population (e.g., prenatal classes in the trial of pregnant women59).

We rated seven of the 31 trials as good quality.67,68,78,81,82,89,90 We rated the remaining trials as fair quality. We rated 13 additional trials as poor quality and excluded them from the review.91-103 The most common reasons these trials were rated as poor quality were high (>40%) attrition or substantial differences between groups at baseline. Sixty-one percent of the included trials reported valid randomization procedures and 61 percent reported allocation concealment. Forty-two percent of these trials reported blinding of outcomes assessment, although some trials that did not report outcomes assessment blinding relied on computer- or self-administered questionnaires, so they may not have been adversely affected by lack of blinding. Followup in the included trials ranged from 60 to 97 percent. One trial had high attrition at all followups beyond the initial 3-month followup, so those data were not included.85 Only six trials reported followup for greater than 90 percent of participants at one or more followups,63,65,73,74,78,81 and eight had overall followup of less than 80 percent at one or more followups (Appendix C Tables 11 and 12).58,69,72,84,85,87-89

## KQ 1 Is There Direct Evidence That Behavioral Counseling Interventions to Reduce Risky Sexual Behaviors and Increase Protective Sexual Behaviors Reduce STI Incidence and/or Related Morbidity and Mortality?

Twenty-three of the trials reported an STI outcome (n=66,902) (Appendix C Tables 3 and 4),57-59,63,64,67-74,78-80,83-85,87-90 and 20 of these were included in the meta-analysis.57-59,63,64,67-69,71-73,78-80, 83,85,87-90 Ten of these trials were conducted in or recruited from primary care.59,63,67,68,70,72,79,83,85, 89 STI results were generally based on laboratory tests, most commonly for gonorrhea and chlamydia. The next most common STIs assessed were trichomoniasis, syphilis, and HIV, and some trials also included additional infections (e.g., HSV, HPV, granuloma inguinale, lymphogranuloma venereum). One trial focused exclusively on BV prevention in women who have sex with women.74

Some trials collected their own laboratory specimens, while other trials supplemented their own specimen results with information from medical records or relied solely on medical records for laboratory test results. While some trials clearly detailed their approach to specimen collection, other trials did not clearly articulate whether specimens were collected for study purposes or clinical uses. Three trials were limited to self-reported STI information.63,64,83

### Results in Adolescents

Seven trials with eight treatment arms (n=3,407) reported STI outcomes in adolescent populations (Table 4). While five of these trials included high-intensity interventions (one of which also included a moderate-intensity arm),57,58,67-69 one trial had a moderate-intensity arm59 and another had a low-intensity63 arm. The trial with the low-intensity intervention targeted younger teens (ages 12 to 15 years) and was the only trial reporting an STI outcome that included both sexually active and nonsexually active teens (males and females).63 The moderate-intensity trial was limited to pregnant adolescents, most of whom were African American.59 The remaining trials primarily included sexually active African American and/or Latina females, generally limited to ages 14 to 19 years. Two trials targeted adolescents with a recent STI at baseline, the highest risk category.57,69 Because all sexually active adolescents are considered to be at increased risk, seven of the eight included comparisons targeted a group at increased risk.

STI incidence was reduced in all eight comparisons targeting adolescents (Figure 4), although results were not statistically significant in two trials.59,63 We present detailed results in Appendix C Table 3. Pooled results showed a 62 percent reduction in the odds of acquiring an STI with high-intensity counseling after 12 months (OR, 0.38 [95% CI, 0.24 to 0.60]; I^2^=65%; k=5) and a 43 percent reduction with the two moderate-intensity interventions (OR, 0.57 [95% CI, 0.37 to 0.86]; I^2^=0%). Several trials reported only the relative difference in STI rate between groups (i.e., ORs and not STI rates in each group), and STI rates in the trials that did report them were highly variable. In trials with high-intensity interventions, reported STI rates at followup ranged from 13 to 40 percent in the control groups compared with 5 to 24 percent in the intervention groups.63 Four of the trials were conducted in or recruited from primary care settings, and all reported reductions in the odds of acquiring an STI of 0.67 or less, although not all effects were statistically significant.59,63,67,68

Figure 4 Forest Plot of STI Incidence in Included Trials Targeting Adolescents

Abbreviations: adol/es = adolescent; CG = control group; CI = confidence interval; IG = intervention group; mod = moderate intensity; OR = odds ratio; preg = pregnant; SG = subgroup; STI = sexually transmitted infection.

Figure 4 displays a forest plot of the odds ratio (OR) of incidence sexually transmitted infections (STIs) in adolescent trials (k=7) stratified by intervention intensity. Among low intensity interventions (k=1), the overall OR was 0.17 (95% CI, 0.02 to 1.47). Among moderate intensity interventions (k=2), the overall OR was 0.57 (95% CI, 0.37 to 0.86). Among high intensity interventions (k=5), the overall OR was 0.38 (95% CI, 0.24 to 0.60).

The trial of pregnant adolescents and young adults found a statistically nonsignificant 33 percent reduction in the odds of acquiring an STI at the 12-month followup in adolescents.59 The one trial that targeted younger adolescents (both sexually and presexually active youth) and reported STI rates found no statistically significant group differences in self-report of treatment for an STI, but overall event rates were very low (1.1% reporting STI treatment in the past 6 months in the intervention group vs. 5.8% in the control group at 9 months followup), resulting in limited statistical power.63 This trial did find that a greater proportion of control group participants self-reported genital signs of possible STIs (6.8% in the control group vs. 0% in the intervention group).

Heterogeneity was high (I^2^=65%; p=0.02) in the analysis of high-intensity interventions, primarily due to a very large effect in a fairly large good-quality trial by DiClemente and colleagues (OR, 0.17 [95% CI, 0.10 to 0.30]) (Figure 4).68 Although the unadjusted rates of chlamydia in the study were similar between groups at the 12-month followup (2.1 per 100 person-months in the intervention group and 2.0 per 100 person-months in the control group), the baseline rates were higher in the intervention group. As such, the adjusted analysis shows a benefit of the intervention with a large effect. This study reported results separately for chlamydia (OR, 0.17 [95% CI, 0.03 to 0.92]), gonorrhea (OR, 0.14 [95% CI, 0.01 to 3.02]), and trichomoniasis (OR, 0.37 [95% CI, 0.09 to 1.46]), and did not report an overall STI incidence rate. We used results for the most prevalent STI (chlamydia) for our pooled analysis, which was the only effect that was statistically significant. Pooled results in sensitivity analyses using the results for gonorrhea and trichomoniasis instead of chlamydia were slightly attenuated, but they still showed a pooled 52 percent reduction in STIs for high-intensity interventions. Statistical heterogeneity was reduced to 0 percent when both the gonorrhea and trichomoniasis results were used.

The DiClemente trial involved four 4-hour group sessions developed specifically for African American adolescent girls. The intervention was delivered by a female African American health educator assisted by African American peer educators. The intervention covered knowledge and skills related to STI transmission and condom use, and included role playing of safe sex conversations, negotiating safer sex, and refusing unsafe sex. This intervention also covered the importance of healthy relationships. This intervention was compared with an intensity-matched general health intervention that received comparable favorability ratings (4.8 on a 5-point scale) as the sexual risk reduction counseling intervention, but was not as effective in reducing STIs.

Another trial, the Project RESPECT trial by Kamb and colleagues, tested both moderate- and high-intensity interventions in a high-risk setting (inner-city public STI clinic) and provided the only estimates for the effectiveness of behavioral counseling in mixed-gender sexually active adolescents.58 Both interventions demonstrated sizeable reductions in STIs among the adolescent subgroup of both treatment arms and no differences between the moderate- and high-intensity arms; after 1 year, STI incidence was 17.2 percent in the high-intensity intervention group, 17.5 percent in the moderate-intensity intervention group, and 26.6 percent in the control group. This trial included HIV-negative adolescents and adults attending STI clinics in five different U.S. cities and agreeing to HIV testing. Just fewer than half of the participants were female, 59 percent were African American, and 19 percent were Latino. The moderate-intensity intervention included two 20-minute sessions and was based on the CDC recommendation for counseling in association with HIV testing. The high-intensity intervention added three additional individual 60-minute sessions tailored to each person's individual risks, developing and following up on specific risk reduction goals. This trial reported generally good methods and procedures, but suffered from low retention (e.g., 66% retention at the 1-year followup), which could cause under- or over-estimation of the true effect if those lost to followup had higher or lower than average risk for STIs.

### Results in Adults

Nineteen trials (n=61,909) reported STI outcomes in adult populations (Table 5; Appendix C Table 4),57-59,64,70-74,78-80,83-85,87-90 four of which had multiple treatment arms with different intensities.58,71,79,84 Of the 23 comparisons, 10 examined high-intensity interventions,57,58,64,71,73,79, 84,85,88,89 seven examined moderate-intensity interventions,58,59,70,71,80,87, 90 and six examined low-intensity interventions.72,74,78,79,83,84 We included all but three trials in the meta-analysis. Of the three we did not include, one only reported BV74 (and was excluded because this outcome was substantially different from the other trials) and two trials did not provide sufficient data, reporting only that they found no statistically significant group differences.70,84 Seven of the trials were conducted in or recruited from primary care.59,70,72,79,83,85,89 The majority of the trials targeted patient populations at increased risk for STIs, but without requiring a recent STI diagnosis. Only two of the trials were in general primary care populations (one of which was included in the meta-analysis),70,83 and five were limited to adults at highest risk based on a recent STI.57,73,74,85,88 Several trials targeted narrow subpopulations, including one trial that targeted pregnant women,59 two that targeted psychiatric patients,64,82 one that targeted women with genital warts,86 and one that targeted women who have sex with women and have BV.74

While only nine of the 23 comparisons were statistically significant, most showed an effect in the direction of a reduction in STIs in the intervention groups. The pooled effects for high-intensity interventions were statistically significant with relatively low statistical heterogeneity. High-intensity interventions resulted in a 30 percent reduction in the odds of acquiring an STI (OR, 0.70 [95% CI, 0.56 to 0.87]; k=9; I^2^=23%) (Figure 5). The proportion of participants with an STI at followup in the high-intensity intervention groups ranged from 2 to 63 percent compared with 5 to 68 percent in the control groups. In a trial with an effect size close to the pooled effect,57 18 percent of control group participants contracted an STI over 12 months compared with 12 percent of intervention group participants. Three of these trials were conducted in primary care settings, with ORs ranging from 0.82 (95% CI, 0.46 to 1.45) to 0.48 (95% CI, 0.24 to 0.97).79,85,89

Figure 5 Forest Plot of STI Incidence in Included Trials Targeting Adults

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; mod = moderate intensity; OR = odds ratio; preg = pregnant; psych = psychiatric patients; SG = subgroup; STI = sexually transmitted infection.

Figure 5 displays a forest plot of the odds ratio (OR) of incidence sexually transmitted infections (STIs) in adult trials (k=16) stratified by intervention intensity. Among low intensity interventions (k=4), the overall OR was 0.83 (95% CI, 0.66 to 1.04). Among moderate intensity interventions (k=6), the overall OR was 0.85 (95% CI, 0.66 to 1.10). Among high intensity interventions (k=9), the overall OR was 0.70 (95% CI, 0.56 to 0.87).

The pooled effects for low- and moderate-intensity trials did not show a reduction in the odds of acquiring an STI (Figure 5). Most of the low- and moderate-intensity trials did not reduce the odds of an STI, including three trials not included in the meta-analysis because of missing data. Two low- and two moderate-intensity interventions, however, did prove effective in preventing STIs.78,79 For example, one large (n=40,282), good-quality randomized, controlled trial created a 23-minute video, “Safe in the City,” that participants watched in the waiting room of STI clinics.78 The video covered basic information on HIV/STI risk and prevention and attempted to build condom use skills, self-efficacy for condom use, and a positive attitude toward condom use. Vignettes with young couples of various race/ethnicity and sexual orientations demonstrated communication about partner notification and the acquisition, negotiation, and use of condoms. Control group participants attended the clinic when the video was not being shown. This trial found a small but statistically significant reduction in the proportion of participants with an STI. After an average of almost 15 months, 4.9 percent of intervention participants had an STI compared with 5.7 percent of control group participants (adjusted hazard ratio [HR], 0.91 [95% CI, 0.84 to 0.99]; unadjusted OR, 0.85 [95% CI, 0.73 to 0.99]), or a NNT of 123 (95% CI, 68 to 1,859). Planned subgroup analyses, however, revealed that the effect was statistically significant for men (adjusted HR, 0.88 [95% CI, 0.80 to 0.98]), but not for women (adjusted HR, 1.02 [95% CI, 0.86 to 1.21]).

Another trial by Jemmott and colleagues had five study arms, including an efficacious low-intensity intervention and a brief general health promotion arm as a control.79 Two of the active intervention arms targeted skill building while two provided information without the opportunity to practice skills. One of the skill-based treatment arms was a high-intensity (≥3 hours), small-group session and the other was a 20-minute individual session. Similarly, the information-only intervention also had high- and low- intensity versions. Both of the high-intensity interventions included group brainstorming, videos, and interactive exercises. Both of the low-intensity interventions were tailored to the participant's individual risk factors. Using a priori contrasts, Jemmott and colleagues reported that STIs were lower in both of the skill-based intervention groups at 12 months (14% [high-intensity] and 15% [low-intensity]) than in the control group (27%). Furthermore, the two skill-based interventions were not statistically different from the two information-based interventions (19% [high-intensity] and 22% [low-intensity]).

Across the body of evidence, there was no clear relationship between the effect size and the number of sessions, reporting of condom negotiation or other communication as an intervention component, type of control group, or study quality, based on qualitative synthesis. More intensive approaches generally used group formats and brief interventions usually involved individual sessions. As such, we could not disentangle the effects of format from treatment intensity. Almost all trials relied on trained providers to deliver the intervention. These trials relied little on mailed or computer-based interventions, and the initial results in these media were not promising; a mail-only intervention83 and a computer-based expert system72 intervention both showed no benefit over the control group, with ORs of greater than 0.95 in both cases.

## KQ 2 Do Behavioral Counseling Interventions to Prevent STIs Reduce Risky Sexual Behavior or Increase Protective Sexual Behavior?

Twenty-four trials reported an outcome related to condom use or unprotected sex (Appendix C Tables 5 and 6). Five trials were conducted in adolescents57,63,66-68 and 19 were conducted in adults.57-59,64,70-73,76,77,79,81- 84,86-88,90 Additional behavioral outcomes, such as number of partners or initiation of sexual activity, were also reported in some studies (Appendix C Tables 7 and 8).57,58,63-65,67,68,71,73,76,77, 81,82,84-88,90 All behavioral outcomes were based on self-report.

### Results in Adolescents

Six trials (n=3,030) reported sexual behavior outcomes. Three of these trials were high-intensity,57,67,68 two were moderate-intensity,65,66 and one was low-intensity.63 Three of the five trials that reported effects on condom use or unprotected sex found a benefit of the intervention at followup (Table 4; Appendix C Table 5). Four of the five trials that reported other sexual behavior outcomes found group differences (Table 4; Appendix C Table 7).

All three of the high-intensity interventions reporting behavioral outcomes found beneficial effects on at least one behavioral outcome at some point of followup. These results, however, were not entirely consistent with a clear benefit.57,67,68 For example, one trial found greater improvement with a skills-based group session than with the intensity-matched general health promotion control group on number of days of unprotected vaginal intercourse, number of sex partners, percentage with two or more partners in the past 3 months, and number of days of sex while under the influence of drugs or alcohol.67 These groups differed, however, at only one of three followup assessments in all cases. Additionally, the other information-only intervention arm (an intensity- and content-matched informational group session) did not improve behavioral outcomes beyond the control condition. Intervention group participants in the trial with the most consistently positive results showed improvement on four of five sexual behavior outcomes: condom use at most recent intercourse, consistent condom use in the past 6 months, number of unprotected vaginal intercourse episodes, and proportion with new sex partners at both 6- and 12-month followup assessments.68 This trial by DiClemente and colleagues (described under KQ 1) involved four 4-hour group sessions developed specifically for sexually active African American adolescent girls.

Only one65 of the two moderate-intensity trials reporting sexual behavioral outcomes demonstrated a positive effect.65,66 Young adolescents in the intervention group reported substantially reduced sexual activity at the 9-month followup (6.8% reporting any vaginal intercourse) compared with the control group (22%).65 These results are based on self-report, however, which may represent an even greater risk for bias than usual, since mothers were involved in this intervention. This was a primary care–based intervention conducted in New York City clinics that primarily serve Latino populations. The intervention targeted mothers rather than the adolescents themselves and included one 30-minute session with an interventionist, two booster calls, and self-study modules addressing topics such as adolescent development and self-esteem, parenting strategies, communication and relationship-building between parent and teen, techniques to help adolescents cope with peer pressure, and adolescent sexual behavior. This study did not report outcomes related to condom use, unprotected sex, or STIs.

In contrast, the one low-intensity intervention trial conducted in adolescents (younger adolescents who were mostly not sexually active) reported that a higher proportion of intervention participants were sexually active at the 3-month followup (27% in the intervention group vs. 20% in the control group), but found no differences at the 9-month followup.63 This trial also reported a higher proportion of participants using condoms at their most recent sexual intercourse in the intervention group (92%) than the control group (57%) at the 3-month followup, but not after 9 months.63 This trial was conducted in five managed care pediatric clinics in the Washington, D.C., area for youth with scheduled general health examinations. Pediatricians participated in a 45-minute, one-on-one training session that covered the ASSESS (Awareness, Skills, Self-Efficacy/Self-esteem, Social support) model. Participants listened to a 15-minute, audiotaped risk assessment and education module before their visit, which was followed by a discussion with the pediatrician about sexual risk assessment, preventive counseling (with study materials to assist the pediatrician), and informational materials for teens.

### Results in Adults

While the 21 trials (25 comparisons) in adults reporting behavioral outcomes were also mixed, the high-intensity interventions were fairly consistent in reporting beneficial results (Table 5). Our meta-analysis that included nine trials reporting condom use or related outcomes (11 comparisons) showed that the odds of condom use increased by 29 percent with high-intensity interventions (OR, 1.29 [95% CI, 1.13 to 1.48]; k=4; I^2^=0%) (Figure 6), and the majority of the high-intensity interventions that were not included in the meta-analysis also showed group differences at one or more time points. The pooled effect was similar for moderate-intensity interventions (OR, 1.21 [95% CI, 1.00 to 1.46]; k=4; I^2^=28%), but the two trials excluded from the meta-analysis had mixed findings. The pooled estimate for low-intensity trials was not statistically significant, and the trials that could not be included generally also showed no group differences. Effects in one study with multiple followup assessments were only statistically significant at 6 months (not 12 months), and several other trials reporting followup beyond 6 months showed no group differences.

Figure 6 Forest Plot of Condom Use and Unprotected Sexual Intercourse in Included Trials Targeting Adults

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; OR = odds ratio; STI = sexually transmitted infection.

Figure 6 displays a forest plot of the odds ratio (OR) of condom use and unprotected sexual intercourse in adult trials (k=9) stratified by intervention intensity. Among low intensity interventions (k=3), the overall OR was 1.10 (95% CI, 0.87 to 1.39). Among moderate intensity interventions (k=4), the overall OR was 1.21 (95% CI, 1.00 to 1.46). Among high intensity interventions (k=4), the overall OR was 1.29 (95% CI, 1.13 to 1.48).

When other sexual behavior outcomes were reported, results were almost always consistent with condom-related measures in the same study. The most commonly reported other sexual behavior outcome was number of sex partners. Other behavioral outcomes were usually improved with high-intensity interventions, and the results were mixed for moderate-intensity interventions. Other outcomes were sparsely reported in trials with low-intensity interventions.

## KQs 1a, 2a Are There Population or Intervention Characteristics That Influence the Effectiveness of Interventions?

### Important Population Characteristics

Most of the included trials were conducted in fairly narrow populations, and some trials conducted subgroup analyses to examine whether the intervention was effective in particular subpopulations, which are described below. Only one trial performed interaction tests before delving into subgroup analyses.59 As far as we could determine, only the Warner trial specifically described its subgroup analysis as being planned a priori and was adequately powered for the subgroup analysis.78 In general, we found that some populations were poorly represented, but there was no clear evidence that interventions were less likely to be effective for any important subpopulation. Subgroup results were frequently consistent with overall study results.

#### Age

Trials and subgroup analyses targeting adolescents were highly likely to be effective, with fairly large effects. Most adolescent results showed reductions in odds of acquiring an STI close to 50 percent or greater. Of the three trials that covered a wide age range and reported separate effect estimates for adolescents and adults, all three found that the intervention was effective for adolescents but not adults in at least one treatment arm.57-59 The pooled effects of counseling in adults for moderate- and high-intensity interventions demonstrated a reduction in STIs, but effect sizes tended to be smaller (generally <50%) and results were less consistently statistically significant than in adolescent trials or analyses.

The majority of the participants in the adult trials were young adults and the average age of participants was generally younger than 30 years. Several included trials were limited to young adults (ages 16 or 18 to 25 or 30 years). Pooled results for odds of acquiring an STI, however, were similar to those in adult trials with an average age of younger than 25 years (OR, 0.80 [95% CI, 0.60 to 1.08]; k=8; I^2^=59%) (data not shown) or 25 years or older (OR, 0.78 [95% CI, 0.68 to 0.90]; k=8; I^2^=22%) (data not shown). In contrast, the pooled OR for adolescents was 0.40 (95% CI, 0.26 to 0.60; k=7; I^2^=56%) (data not shown). These analyses differ slightly from the intensity-stratified analyses reported under KQ 1 because they combined all levels of intervention intensity in one analysis and used only the single most intensive treatment arm for each trial within the age strata to get a single result for each age group, with no duplication of trials within age group. We found no data specific to older adults.

#### Sex

Many of the included trials were limited to females, which covers a wide range of intervention intensity and population risk groups. Three trials only included males, and all targeted different populations (mostly Caucasian males ages 15 to 18 years,66 African American men ages 18 to 29 years with a newly diagnosed STI and a history of condom use,87 and men ages 18 to 59 years with severe mental illness82), which limits generalizability. Several trials limited to women or girls showed a greater reduction in STIs in intervention versus control participants.57,67-69,73,79,89 Female-only trials did not appear more or less likely to report statistically significant results than those in males or mixed-sex populations. In adolescents, however, only two trials included both boys and girls. The one trial that included only boys reported only behavioral outcomes. As such, there was insufficient data to assess differences in effects by gender in adolescents.58,63

Six adult trials reported results separately for males and females, and their findings were conflicting.58,64,78,80,88,90 As described above, the Warner trial, which had planned a subgroup analysis a priori, found that the intervention reduced STIs in men (adjusted HR, 0.88 [95% CI, 0.80 to 0.98]), but not women (adjusted HR, 1.02 [95% CI, 0.86 to 1.21]).78 Similarly, another trial found that the intervention benefited men on two behavioral outcomes at one of two followups, but not women for either outcome at either followup (3 or 5 months). This trial, however, found no group differences in the effect on STIs at either followup in either men or women.88 In contrast, the third trial, which was conducted in persons with major mood or thought disorders, found that the intervention reduced unprotected vaginal intercourse in women, but not men. It found no differences between men and women, however, in two other behavioral outcomes or STIs.64 Results did not differ between men and women in the final two trials that explored results by sex.58,80

#### Race/Ethnicity

Many of the included trials were limited to persons of African American and/or Latino descent because of the disease burden in these subpopulations. Most of the trials limited to only African Americans or Latinos were successful in reducing either STIs or risky sexual behaviors. We found no data specific to American Indians/Alaska Natives, despite the high prevalence of STIs in these populations.

Four adult trials reported exploratory subgroup analyses for different racial/ethnic groups, with inconsistent findings.57-59,90 One of these trials that included two treatment arms found the high-intensity intervention was beneficial for white participants, but not participants with other racial/ethnic backgrounds. In contrast, the moderate-intensity intervention was beneficial for African Americans, but not those with other racial/ethnic backgrounds.58 The other three trials were limited to or mostly African American or Latino women. A trial in pregnant women found no difference in treatment effectiveness between African American and Latino women,59 but the third trial found slight differences in the pattern of results. While results were similar between African American and Mexican American women for unprotected vaginal intercourse, Mexican American women showed greater improvements in STI rates and African American women showed greater changes in monogamy and rapid partner turnover.57 The final trial included both men and women and found no differences in effectiveness of the intervention by race. 90

#### Sexual Orientation

Only two trials included a substantial proportion of MSM; however, they did not compare the effectiveness of the intervention between MSM and heterosexual men, although they did perform subgroup analyses and reported treatment effects separately.78,90 Effect sizes were similar for MSM and heterosexual men in one trial;78 however, the other reported a statistically significant deleterious effect in MSM (adjusted RR, 1.41 [98.3% CI, 1.05 to 1.90]) but no group differences in heterosexual men (adjusted RR, 0.81 [ 98.3% CI, 0.50 to 1.31).90 This trial involved HIV testing as well as counseling, and was limited to participants with a negative HIV test. Thus, we cannot disentangle the effect of the HIV test from the counseling, but it may have been an important factor for MSM. Both trials involved brief, single-session interventions. One additional trial was limited to women who have sex with women and have BV, with the aim of reducing reinfection, but the intervention was no more effective in reducing subsequent BV infections than usual treatment plus information on adherence to Pap smear screening guidelines.74

#### Low-Income Urban Settings

Many trials were conducted in urban settings, and although indicators of socioeconomic status were not frequently reported, the trials that did report on these indicators generally reported low income and education levels. All of the trials in adolescents except one66 were conducted in urban, mostly publicly-funded clinics. Adult trials were more varied; however, most trials with high-intensity interventions (which were generally effective) were also in low-income, urban populations.

#### Mental Illness and Depression

Two trials were limited to patients with mental illnesses and both provided high-intensity interventions.64,82 Only one of these trials measured (self-reported) STIs in patients with a mood or thought disorder and substance use in the past year.64 This trial did not find that the intervention reduced STIs. It did, however, report greater reductions in the number of acts of unprotected intercourse and the number of casual sex partners, but not total number of partners, compared with an intensity-matched substance use reduction intervention. This study conducted exploratory analyses showing that the reduction in unprotected intercourse was only among patients with a diagnosis of major depressive disorder, and not those with other diagnoses (mostly thought disorders). However, there were no differences in the effects on STIs or the two other behavioral outcomes between participants with depression and those with other diagnoses. The other trial was conducted in psychiatric patients with severe mental illnesses and found no reductions in risky sexual behaviors as a result of the intervention.82

Two additional trials performed exploratory subgroup analyses on participants who screened positive and negative for symptoms of depression at baseline; one trial included only adolescent girls and the other included adolescent and adult women.57 Neither of the interventions in these trials directly addressed depression. Adolescent girls who screened positive for depressive symptoms showed improvements in multiple measures of condom use, which was consistent with the overall results of the trial.68 In the subgroup with depressive symptoms in the mixed-aged trial, the intervention group had better outcomes than the control group for STI reinfection, mutual monogamy, and rapid partner turnover. There were, however, smaller or no group differences in these outcomes in women without depressive symptoms. The presence of depressive symptoms did not have an effect on the percentage of the intervention group reporting unsafe sex.57

#### History of Abuse

One trial was limited to adolescent girls with a history of abuse and a current STI, including 60 percent who had a history of sexual abuse.69 The high-intensity intervention involved three one-on-one interviews with detailed assessment, two 3- to 4-hour group workshops based on ARRM, and three to five weekly support group meetings; a minimal treatment control group primarily covered treatment of STIs. Odds of acquiring an STI were reduced at 6- and 12-month followups; 4.8 percent of the intervention group had an STI between 6 and 12 months postbaseline compared with 13.2 percent of the control group. Exploratory subgroup analyses showed that the intervention effect was statistically significant for girls without a history of sexual abuse, but not for those with a history of sexual abuse.

Two additional high-intensity intervention trials conducted exploratory subgroup analyses of adolescent68 or adult81 women with history of gender-based or intimate partner violence. The trial in adolescents found that the intervention reduced the STI rate and improved condom use in multiple measures in girls with a history of gender-based violence, consistent with the overall study results.68 Similarly, the trial in adult women found that the intervention was effective in reducing unprotected vaginal intercourse and an overall risk score in the short term (1 month) only, but not at 6- or 12-month followups in women with a history of intimate partner violence. This finding is consistent with the overall results of this trial.81

### Important Intervention Characteristics

#### Intensity

Intensity influenced outcomes in included trials. High-intensity trials (contact time of >2 hours) were most likely to be effective. While moderate-intensity trials could also be effective, they were less consistently beneficial. Finally, low-intensity trials were least likely to be effective. A single session (which could be of low, moderate, or high intensity) in many cases was sufficient to reduce STIs.67,78-80,87 In fact, pooled effect estimates were similar for trials with a single session (OR, 0.73 [95% CI, 0.57 to 0.94]; k=7; I^2^=72%) (data not shown) and more than one session (OR, 0.62 [95% CI, 0.47 to 0.81]; k=13; I^2^=69%) (data not shown).

Although most of the low-intensity trials did not show a benefit of treatment, there were two low-intensity trials that effectively reduced the odds of acquiring an STI—the large Warner trial of the video-based intervention, powered to detect a small effect,78 and a low-intensity arm of a trial of African American women conducted by Jemmott and colleagues.79 The latter trial included a 20-minute individualized and culturally tailored counseling session with trained African American nurse educators (who had received ≥8 hours of training in providing the intervention) compared with a general health promotion control.

Two other low-intensity trials provided similarly brief individualized sexual risk reduction counseling sessions, likely covering the same basic material as the Jemmott intervention, but did not show a benefit of treatment.76,84 In one trial, Australian family physicians provided brief counseling to young adult patients of any risk level, guided by a study-provided checklist.76 The length of the counseling session and the extent of the training provided to the physicians are unknown. In the other trial that included a single, brief one-on-one session, a trained nurse in an STI clinic conducted a 15-minute motivational interview targeted at increasing participants' condom use.84 This was compared with a 15-minute informational session delivered primarily via DVD. Thus, there were some important differences between the Jemmott trial and the other two (ineffective) trials that may have contributed to the differences in effectiveness. The Jemmott trial, which was effective, provided the greatest degree of cultural tailoring, provided extensive training for the providers, and included a high-risk population. Thus, while only one of three low-intensity individualized brief interventions reduced STIs, there may be situations in which a single-session low-intensity intervention can be effective and for which replication is warranted.

#### Cultural Tailoring

Several trials reported cultural tailoring of their interventions.57,67-69,73,75,79,85,87,89 While the majority of these trials were effective in reducing STIs, it is difficult to disentangle the effects of the cultural tailoring from other trial characteristics because these trials were generally also high-intensity interventions in high-risk patients. One good-quality trial conducted in adolescents had some of the most extensive cultural tailoring and some of the largest effects on both risky sexual behaviors and STI incidence. This study devoted the first of four 4-hour sessions to ethnic and gender pride.68 The fact that the only low-intensity trial providing one-on-one counseling that was effective was a culturally tailored intervention is intriguing, but data were not available to isolate the effects of cultural tailoring. None of the included trials compared the culturally tailored intervention with a nontailored intervention.

#### Condom Negotiation or Communication

Most of the high-intensity and several of the moderate-intensity interventions included instruction in condom negotiation or communication. A subset of these provided practice role playing for condom negotiation or safe sex conversations,57-59,67,71,73,75,79-82,84,85 and many also included hands-on practice correctly applying condoms with anatomical models.57,58,67,71,73,79,82,84 Visual inspection of these trials compared with other trials showed no clear difference in effectiveness between those providing and not providing training in these areas. Meta-analysis limited to trials providing some type of condom negotiation or communication information (combining adolescent and adult studies, selecting only the highest-intensity intervention when there were multiple arms) resulted in a pooled OR of 0.60 (95% CI, 0.48 to 0.74; k=14; I^2^=72%) (data not shown), while those that did not provide such training had a pooled OR of 0.71 (95% CI, 0.46 to 1.08; k=5; I^2^=38%) (data not shown). CIs were highly overlapping between these two estimates, suggesting no clear differences in effectiveness between trials with and without condom negotiation and/or communication instruction. When we looked more narrowly at whether trials provided role playing of condom negotiation or safe sex conversations, CIs were again highly overlapping, suggesting no robust differences based on this single component (with role playing: OR, 0.68 [95% CI, 0.60 to 0.77]; k=9; I^2^=0%; without role playing: OR, 0.55 [95% CI, 0.36 to 0.85]; k=10; I^2^=80%) (data not shown). Two trials conducted by the same authors provided information but not opportunities to practice skills and had mixed results; one trial found larger effects in the interventions that provided skills practice, while the other did not.67,79

#### Relationship Issues

Three high-intensity intervention trials targeting nonwhite women addressed healthy relationships beyond safe sex communication.57,69,81 These included a trial of African American adolescent girls with a history of abuse and an STI,69 one targeting African American and Mexican American woman with an STI,57 and one conducted in a Planned Parenthood clinic in a low-income, primarily nonwhite neighborhood in Brooklyn, New York.81 These trials provided few details on how the topic was addressed, but described discussing what women want from a relationship and “avoiding partners who don't care.”57,81 All three trials were effective in reducing STI recurrence57,69 or (when STIs were not reported) the number of occasions of unprotected intercourse.81

#### Counselor Characteristics

One trial examined the effect of counselor characteristics on the STI rate.58 It found no association between STI rate and counselor characteristics (gender, ethnicity, education, counseling experience) or counselor-dyad characteristics (concordance of gender and ethnicity).104 Counselors in this trial ranged in educational attainment from high school graduates to having a post-bachelor degree.

#### Setting

There were no apparent differences in effectiveness of trials conducted in primary care compared with other settings. Ten trials were conducted in primary care; there was a 43 percent reduction in the odds of acquiring an STI among the nine trials that could be included in the analysis (OR, 0.57 [95% CI, 0.38 to 0.86]; k=9; I^2^=72%) (data not shown). In comparison, studies in other settings had a slightly smaller pooled effect, although the differences were not statistically significant (OR, 0.71 [95% CI, 0.58 to 0.87]; k=11; I^2^=70%) (data not shown).

## KQ 3 Are There Other Positive Outcomes Beside STI Incidence and Changes in Risky or Protective Sexual Behavior From Behavioral Counseling Interventions to Prevent STIs?

Nine fair- to good-quality trials (n=6,300) reported on other positive outcomes, including reducing unintended pregnancy,59,63,68,70-72 reducing interpersonal violence,81 increasing the use of oral contraceptives,66,70,71 improving depressive symptoms,75 and increasing testicular self-examinations (Tables 4 and 5; Appendix C Tables 9 and 10).66 The interventions and populations varied across studies. We could not pool data because of the few studies and/or events.

Pregnancy was reported in six trials after 3 to 24 months of followup. Most were in low- or moderate-intensity trials that did not show reductions in STIs. Two studies were conducted in adolescents63,68 and four were conducted in adults70-72 or mixed ages.59 Although fewer pregnancies were reported in the intervention group across all studies, only two studies showed a statistically significant difference between the intervention and control groups, at 6 months only.59,68 One was a fair-quality study that delivered a moderate-intensity HIV prevention group intervention to pregnant women (ages 14 to 25 years) receiving prenatal care.59 While this study reported fewer repeat pregnancies within 6 months postpartum in the intervention group than the two control groups (OR, 0.49 [95% CI, 0.27 to 0.91]), this difference was no longer statistically significant after 12 months postpartum. Furthermore, the intervention group differed from the usual care control group, but there was no difference between the intervention group and the attention-matched control group, which is the better test of the STI prevention component of the intervention. One good-quality study conducted in adolescents also showed a statistically significant difference in the number of pregnancies between groups at 6 months (OR, 0.38 [95% CI, 0.15 to 0.36]).68 As in the study among pregnant women, however, the effects were no longer significant at 12 months.

Three trials targeted contraceptive use as well as STI prevention. Two of the trials conducted in young women found no differences in contraceptive use outcomes between intervention and control participants.70,71 A fair-quality trial of a single moderate-intensity reproductive health consultation among adolescent males ages 15 to 18 years (n=1,195), however, found greater odds of using an effective form of birth control at the last intercourse in the intervention group than in the control group.66 This intervention also increased the number of adolescents who performed a testicular self-examination triennially in the past year compared with the waitlist control group. The trial did not report outcomes of the testicular self-examination (e.g., identification of a mass, physician examination).

Only one good-quality study (Project FIO [The Future Is Ours]) examined the effects of two high-intensity gender-specific HIV/STI risk reduction interventions (four or eight sessions) on intimate partner violence among adult women (n=360).81 At baseline, 42 percent of women had experienced intimate partner violence during the past 12 months.105 These women were more likely to be older, of a minority or low socioeconomic status, and at higher risk for an STI (e.g., previous STI, lifetime use of drugs) than women who had never experienced abuse. There were no statistically significant differences in the number of women reporting abuse between the intervention and control groups at 6 and 12 months of followup. Thus, the interventions caused no further harms, but also did not provide a further benefit in regards to violence. There was also no difference between groups in the number of women who did or did not have a safer sex discussion with their partners and experienced subsequent physical abuse.

One fair-quality study among adult Chilean women (n=496) assessed depressive symptoms over the past week, as measured by the 20-item Center for Epidemiological Studies Depression Scale.75 Participants in the high-intensity Mano a Mano-Mujer (Hand-to-Hand for Women) HIV-prevention intervention experienced significantly fewer depressive symptoms than the waitlist control group after 3 months of followup (p<0.05).

## KQ 4 What Adverse Effects Are Associated With Behavioral Counseling Interventions to Prevent STIs in Primary Care?

Two fair-quality trials84,85 and one good-quality trial90 explicitly reported on adverse events (n=6,837). Two did not find any adverse events associated with the interventions; however, no further details were provided about the types of adverse effects examined or how they were ascertained.84,85 The third trial reported more nonserious adverse events during the HIV test (e.g., syncope, pain) in the intervention group than in the control group (13 vs. 5 events).90 The populations and interventions examined in these three trials were heterogeneous. One trial examined five combinations of brief and intensive motivational, informational, and behavioral workshops among adults (mean age, 29.2 years) who had engaged in risky sexual behavior during the past 3 months compared with a single information-only session.84 Another trial examined the Well Women Program among low-income African American women (mean age, 38.1 years) with at least two previously diagnosed STIs in the past year.85 The third trial examined a moderate-intensity HIV testing and risk reduction counseling intervention among 5,012 adults seeking services at an STI clinic.90

No study has shown an overall statistically significant paradoxical effect in the incidence of STIs or change in sexual or other behaviors. Only three trials found statistically nonsignificant increases in the odds of acquiring an STI.59,88,90 Two of these three studies were relatively small and had fewer than 15 events in either arm.59,88 However, as described above, a subgroup analysis in the largest of these trials showed a statistically significant deleterious effect on STI incidence in MSM, with 12.5 percent of control and 18.7 percent of intervention participants reporting an STI at followup (adjusted RR, 1.41 [98.3% CI, 1.05 to 1.90]).90 Another trial that reported results separately for MSM and heterosexual men did not see a deleterious effect in MSM. There was no consistent evidence that the interventions increased sexual activity in adolescents; while one trial reported a short-term increase in the proportion of youth who were sexually active in the previous 3 months,63 another reported a decrease (p<0.05),65 and other trials found no differences in frequency or number of partners.57,67,106 No trials reported on the time to sexual debut in younger adolescents.