# Summary Tables

Appendix C Table 1 Intervention Characteristics of Included Studies Targeting Adolescents

Appendix C Table 2 Intervention Characteristics of Included Studies Targeting Adults or Mixed Ages

Appendix C Table 3 Results From Included Studies Targeting Adolescents—STIs

Appendix C Table 4 Results From Included Studies Targeting Adults—STIs

Appendix C Table 5 Results From Included Studies Targeting Adolescents—Condom Use and Unprotected Sexual Intercourse

Appendix C Table 6 Results From Included Studies Targeting Adults—Condom Use and Unprotected Sexual Intercourse

Appendix C Table 7 Results From Included Studies Targeting Adolescents—Other Sexual Behavioral Outcomes

Appendix C Table 8 Results From Included Studies Targeting Adults—Other Sexual Behavioral Outcomes

Appendix C Table 9 Results From Included Studies Targeting Adolescents—Other Positive Outcomes

Appendix C Table 10 Results From Included Studies Targeting Adults—Other Positive Outcomes

Appendix C Table 11 Selected Methodological Quality Indicators From Included Studies Targeting Adolescents (Excluding Subgroup Analyses)

Appendix C Table 12 Selected Methodological Quality Indicators From Included Studies Targeting Adults (Excluding Subgroup Analyses)