# Excluded Studies

Exclusion code key

E1. Study relevance/aim
E2a. Setting: Not one of the specified settings
E2b. Setting: Setting is substance abuse treatment center
E2c. Setting: Not linked to primary care
E3. Comparative effectiveness (control group received active intervention)
E4. No relevant outcomes
E5a. Population: Limited to HIV+ individuals
E5b. Population: Limited to other populations (inmates, juvenile offenders, court-involved, psychiatric inpatients)
E6. Intervention
E7. Study design: Not a randomized or controlled clinical trial
E8a. Study quality: High or differential attrition
E8b. Study quality: Other quality issue
E8c. Study quality: Timing of outcome assessment <3 mo
E9. Non-English language
E10. Non-high HDI country
E11. Published in 1987 or earlier
E12. Not able to locate full text

1 The NIMH Multisite HIV Prevention Trial: reducing HIV sexual risk behavior. The National Institute of Mental Health (NIMH) Multisite HIV Prevention Trial Group. Science. 1998;280(5371):1889-94. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 9632382].
2 Social-cognitive theory mediators of behavior change in the National Institute of Mental Health Multisite HIV Prevention Trial. Health Psychol. 2001;20(5):369-76. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 11570651].
3 Akers DD. ASSESS: For adolescent risk reduction. Card JJ, Benner TA, editors. Model Programs for Adolescent Sexual Health: Evidence-based HIV, STI, and Pregnancy Prevention Interventions. New York, NY. Springer Publishing Company, LLC. 2008:375-82. PMID: None. KQ4E4.
4 Alemagno SA, Stephens RC, Stephens P, et al. Brief motivational intervention to reduce HIV risk and to increase HIV testing among offenders under community supervision. J Correct Health Care. Jul. 2009;15(3):210-21. KQ1E8c, KQ2E8c, KQ3E8c, KQ4E8c. [pmid: 19477803].
5 Bangi A, Dolcini MM, Harper GW, et al. Psychosocial outcomes of sexual risk reduction in a brief intervention for urban African American female adolescents. J HIV AIDS Soc Serv. Apr. 2013;12(2):146-59. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 24039550].
6 Barresi P, Husnik M, Camacho M, et al. Recruitment of men who have sex with men for large HIV intervention trials: analysis of the EXPLORE study recruitment effort. AIDS Educ Prev. Feb. 2010;22(1):28-36. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20166785].
7 Bedoya CA, Mimiaga MJ, Beauchamp G, et al. Predictors of HIV transmission risk behavior and seroconversion among Latino men who have sex with men in Project EXPLORE. AIDS Behav. Apr. 2012;16(3):608-17. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21390540].
8 Belcher L, Kalichman S, Topping M, et al. A randomized trial of a brief HIV risk reduction counseling intervention for women. J Consult Clin Psychol. 1998;66(5):856-61. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 9803706].
9 Benner TA. What Could You Do? Interactive video intervention to reduce adolescent females' STI risk. Card JJ, Benner TA, editors. Model Program for Adolescent Sexual Health: Evidence-based HIV, STI and Pregnancy Prevention Interventions. New York, NY. Springer Publishing Company, LLC. 2008:227-34. PMID: None. KQ1E3, KQ2E3, KQ3E3, KQ4E3.
10 Benner TA. SiHLE: Health workshops for young black women. Card JJ, Benner TA, editors. Model Programs for Adolescent Sexual Health: Evidence-based HIV, STI and Pregnancy Prevention Interventions. New York, NY. 2008:253-60. PMID: None. KQ4E4.
11 Benner TA. FOCUS: Preventing sexually transmitted infections and unwanted pregnancies among young women. Card JJ, Benner TA, editors. Model Programs for Adolescent Sexual Health: Evidence-based HIV, STI and Pregnancy Prevention Interventions. New York, NY. Springer Publishing Company, LLC. 2008:217-26. PMID: None. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.
12 Berenson AB, Rahman M. A randomized controlled study of two educational interventions on adherence with oral contraceptives and condoms. Contraception. Dec. 2012;86(6):716-24. KQ4E4. [pmid: 22840278].
13 Berenson AB. A study of two interventions to increase adherence with oral contraceptives and condom use among adolescents and young adults. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2013;73(11-B). PMID: None. KQ1E12, KQ2E12, KQ3E12, KQ4E12.
14 Berkman A. Reducing sexual risk behaviors of men with severe mental illness. J Consult Clin Psychol. 2006;57(3):417. KQ1E7, KQ2E7, KQ3E7, KQ4E7. [pmid: 16525006].
15 Berkman A, Cerwonka E, Sohler N, et al. A randomized trial of a brief HIV risk reduction intervention for men with severe mental illness. J Consult Clin Psychol. Mar. 2006;57(3):407-9. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 16525002].
16 Berkman A, Pilowsky DJ, Zybert PA, et al. HIV prevention with severely mentally ill men: a randomised controlled trial. AIDS Care. May. 2007;19(5):579-88. KQ1E4, KQ3E4, KQ4E4. [pmid: 17505917].
17 Boekeloo BO, Schamus LA, Simmens SJ, et al. A STD/HIV prevention trial among adolescents in managed care. Pediatrics. Jan. 1999;103(1):107-15. KQ4E4. [pmid: 9917447].
18 Bolu OO, Lindsey C, Kamb ML, et al. Is HIV/sexually transmitted disease prevention counseling effective among vulnerable populations?: a subset analysis of data collected for a randomized, controlled trial evaluating counseling efficacy (Project RESPECT). Sex Transm Dis. Aug. 2004;31(8):469-74. KQ2E4, KQ3E4, KQ4E4. [pmid: 15273579].
19 Bowen AM, Horvath K, Williams ML. A randomized control trial of Internet-delivered HIV prevention targeting rural MSM. Health Educ Res. Feb. 2007;22(1):120-7. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 16849391].
20 Boyer CB, Barrett DC, Peterman TA, et al. Sexually transmitted disease (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial. AIDS. Mar. 1997;11(3):359-67. KQ3E4, KQ4E4. [pmid: 9147428].
21 Branson BM, Peterman TA, Cannon RO, et al. Group counseling to prevent sexually transmitted disease and HIV: a randomized controlled trial. Sex Transm Dis. Nov. 1998;25(10):553-60. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 9858353].
22 Bull S, Pratte K, Whitesell N, et al. Effects of an Internet-based intervention for HIV prevention: the Youthnet trials. AIDS & Behav. Jun. 2009;13(3):474-87. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 19037719].
23 Bull SS, Levine DK, Black SR, et al. Social media-delivered sexual health intervention: a cluster randomized controlled trial. Am J Prev Med. Nov. 2012;43(5):467-74. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 23079168].
24 Callahan EJ, Flynn NM, Kuenneth CA, et al. Strategies to reduce HIV risk behavior in HIV primary care clinics: brief provider messages and specialist intervention. AIDS & Behav. Sep. 2007;11(5:Suppl):S48-S57. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 17205389].
25 Calsyn DA, Hatch-Maillette M, Tross S, et al. Motivational and skills training HIV/sexually transmitted infection sexual risk reduction groups for men. J Subst Abuse Treat. Sep. 2009;37(2):138-50. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 19150206].
26 Calsyn DA, Burlew AK, Hatch-Maillette MA, et al. An HIV prevention intervention for ethnically diverse men in substance abuse treatment: pilot study findings. Am J Public Health. May. 2013;103(5):896-902. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 23488494].
27 Campbell AN, Tross S, Hu MC, et al. Female condom skill and attitude: results from a NIDA Clinical Trials Network gender-specific HIV risk reduction study. AIDS Educ Prev. Aug. 2011;23(4):329-40. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 21861607].
28 Card JJ, Kuhn T, Solomon J, et al. Translating an effective group-based HIV prevention program to a program delivered primarily by a computer: methods and outcomes. AIDS Educ Prev. Apr. 2011;23(2):159-74. PMID:. [doi: 10.1521/aeap.2011.23.2.159]. [pii: 10.1521/aeap.2011.23.2.159]. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 21517664].
29 Carey MP, Carey KB, Maisto SA, et al. Reducing HIV-risk behavior among adults receiving outpatient psychiatric treatment: results from a randomized controlled trial. J Consult Clin Psychol. Apr. 2004;72(2):252-68. KQ3E4, KQ4E4. [pmid: 15065959].
30 Carey MP, Vanable PA, Senn TE, et al. Evaluating a two-step approach to sexual risk reduction in a publicly-funded STI clinic: rationale, design, and baseline data from the Health Improvement Project-Rochester (HIP-R). Contemp Clin Trials. Jul. 2008;29(4):569-86. KQ3E4, KQ4E4. [pmid: 18325853].
31 Carey MP, Senn TE, Vanable PA, et al. Brief and intensive behavioral interventions to promote sexual risk reduction among STD clinic patients: results from a randomized controlled trial. AIDS & Behav. Jun. 2010;14(3):504-17. KQ3E4. [pmid: 19590947].
32 Carpenter KM, Stoner SA, Mikko AN, et al. Efficacy of a web-based intervention to reduce sexual risk in men who have sex with men. AIDS & Behav. Jun. 2010;14(3):549-57. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 19499321].
33 Castor D, Pilowsky DJ, Hadden B, et al. Sexual risk reduction among non-injection drug users: report of a randomized controlled trial. AIDS Care. Jan. 2010;22(1):62-70. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 20390482].
34 Champion JD. Behavioural interventions and abuse: secondary analysis of reinfection in minority women. Int J STD AIDS. Nov. 2007;18(11):748-53. KQ2E4, KQ3E4, KQ4E4. [pmid: 18005508].
35 Champion JD, Collins J. African-and Mexican-American Adolescent women with sti and a history of abuse: Biological outcome of a randomised trial of behavioural intervention. Sex Transm Infect. 2011;87(Suppl 1):A266. PMID: None. KQ1E4, KQ2E4, KQ3E4, KQ4E4.
36 Champion JD, Collins JL. Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: results of a randomized controlled trial. Int J Nurs Stud. Feb. 2012;49(2):138-50. PMID: 21937041KQ2E4, KQ3E4, KQ4E4. [pmid: 21937041].
37 Chawarski MC, Mazlan M, Schottenfeld RS. Behavioral drug and HIV risk reduction counseling with abstinence-contingent take-home buprenorphine: A pilot randomized clinical trial. Drug Alcohol Depend. 2007;94(1-3):281-4. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 18164145].
38 Choi KH, Hoff C, Gregorich SE, et al. The efficacy of female condom skills training in HIV risk reduction among women: a randomized controlled trial. Am J Public Health. Oct. 2008;98(10):1841-8. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 18703460].
39 Cianelli R, Ferrer L, Norr KF, et al. Mano a Mano-Mujer: an effective HIV prevention intervention for Chilean women. Health Care Women Int. 2012;33(4):321-41. KQ1E4, KQ4E4. [pmid: 22420675].
40 Cohen DA, Dent C, MacKinnon D, et al. Condom skills education and sexually transmitted disease reinfection. J Sex Res. 1991;28(1):139-45. PMID: None. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b.
41 Collins PY, von UH, Putnins S, et al. Adding the female condom to HIV prevention interventions for women with severe mental illness: a pilot test. Community Ment Health J. Apr. 2011;47(2):143-55. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b. [pmid: 20336486].
42 Cortes-Bordoy J, Vidart JA, Coll-Capdevila C, et al. Usefulness of an educational leaflet to modify sexual risk behaviour in women with external genital warts. Eur J Dermatol. May. 2010;20(3):339-44. KQ1E4, KQ3E4, KQ4E4. [pmid: 20146965].
43 Cottler LB, Compton WM, Ben AA, et al. Peer-delivered interventions reduce HIV risk behaviors among out-of-treatment drug abusers. Public Health Rep. Jun. Suppl 1. 1998;113:31-41. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 9722808].
44 Crosby R, DiClemente RJ, Charnigo R, et al. A brief, clinic-based, safer sex intervention for heterosexual African American men newly diagnosed with an STD: a randomized controlled trial. Am J Public Health. Apr. 2009;99(Suppl 1):S96-S103. KQ3E4, KQ4E4. [pmid: 19218185].
45 Dancy BL, Dancy BL. African American adolescent females: Mother-involved HIV risk-reduction intervention. Journal of HIV/AIDS & Social Services. Jul. 2009;8(3):292-307. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b. [pmid: 20090855].
46 Danielson CK, McCauley JL, Jones AM, et al. Feasibility of Delivering Evidence-Based HIV/STI Prevention Programming to a Community Sample of African American Teen Girls Via the Internet. AIDS Education & Prevention. Oct. 2013;25(5):394-404. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 24059877].
47 Danielson R, Marcy S, Plunkett A, et al. Reproductive health counseling for young men: what does it do?. Fam Plann Perspect. May. 1990;22(3):115-21. KQ1E4, KQ4E4. [pmid: 2379568].
48 Davey-Rothwell MA, Tobin K, Yang C, et al. Results of a randomized controlled trial of a peer mentor HIV/STI prevention intervention for women over an 18 month follow-up. AIDS & Behav. Nov. 2011;15(8):1654-63. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 21468659].
49 Dermen KH, Thomas SN. Randomized controlled trial of brief interventions to reduce college students' drinking and risky sex. Psychol Addict Behav. Dec. 2011;25(4):583-94. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21928866].
50 Di NJ, Schinke SP. Gender-specific HIV prevention with urban early-adolescent girls: outcomes of the Keepin' It Safe Program. AIDS Educ Prev. Dec. 2007;19(6):479-88. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 18190273].
51 Diallo DD, Moore TW, Ngalame PM, et al. Efficacy of a single-session HIV prevention intervention for black women: a group randomized controlled trial. AIDS & Behav. Jun. 2010;14(3):518-29. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 20135214].
52 DiClemente RJ, Wingood GM, Harrington KF, et al. Efficacy of an HIV prevention intervention for African American adolescent girls: a randomized controlled trial. JAMA. Jul. 14. 2004;292(2):171-9. KQ4E4. [pmid: 15249566].
53 DiClemente RJ, Wingood GM, Rose ES, et al. Efficacy of sexually transmitted disease/human immunodeficiency virus sexual risk-reduction intervention for african american adolescent females seeking sexual health services: a randomized controlled trial. Arch Pediatr Adolesc Med. Dec. 2009;163(12):1112-21. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 19996048].
54 DiClemente RJ, Wingood GM, Rose E, et al. Evaluation of an HIV/STD sexual risk-reduction intervention for pregnant African American adolescents attending a prenatal clinic in an urban public hospital: preliminary evidence of efficacy. J Pediatr Adolesc Gynecol. Feb. 2010;23(1):32-8. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a. [pmid: 19643646].
55 DiClemente RJ, Brown JL, Sales JM, et al. Rate of decay in proportion of condom-protected sex acts among adolescents after participation in an HIV risk-reduction intervention. JAIDS. Jun. 1. 2013;63(Suppl 1):S85-S89. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 23673893].
56 DiIorio C, McCarty F, Resnicow K, et al. REAL men: a group-randomized trial of an HIV prevention intervention for adolescent boys. Am J Public Health. Jun. 2007;97(6):1084-9. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 17463382].
57 Dilley JW, Woods WJ, Sabatino J, et al. Changing sexual behavior among gay male repeat testers for HIV: a randomized, controlled trial of a single-session intervention. J Acquir Immune Defic Syndr. Jun. 1. 2002;30(2):177-86. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a. [pmid: 12045680].
58 Dilley JW, Woods WJ, Loeb L, et al. Brief cognitive counseling with HIV testing to reduce sexual risk among men who have sex with men: results from a randomized controlled trial using paraprofessional counselors. J Acquir Immune Defic Syndr. Apr. 15. 2007;44(5):569-77. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 17310937].
59 Dilley JW, Loeb L, Marson K, et al. Sexual compulsiveness and change in unprotected anal intercourse: unexpected results from a randomized controlled HIV counseling intervention study. J Acquir Immune Defic Syndr. May. 1. 2008;48(1):113-4. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 18438179].
60 Dilley JW, Schwarcz S, Murphy J, et al. Efficacy of personalized cognitive counseling in men of color who have sex with men: secondary data analysis from a controlled intervention trial. AIDS & Behav. Jul. 2011;15(5):970-5. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 20680432].
61 Dunn KE, Saulsgiver KA, Patrick ME, et al. Characterizing and improving HIV and hepatitis knowledge among primary prescription opioid abusers. Drug Alcohol Depend. 2013. Aug. 30. KQ1E7, KQ2E7, KQ3E7, KQ4E7.
62 Dworkin SL, Beckford ST, Ehrhardt AA. Sexual scripts of women: a longitudinal analysis of participants in a gender-specific HIV/STD prevention intervention. Arch Sex Behav. Apr. 2007;36(2):269-79. KQ1E4, KQ3E4, KQ4E4. [pmid: 17186128].
63 Eaton LA, Cherry C, Cain D, et al. A novel approach to prevention for at-risk HIV-negative men who have sex with men: creating a teachable moment to promote informed sexual decision-making. Am J Public Health. Mar. 2011;101(3):539-45. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21233441].
64 Eaton LA. The development and outcomes of an intervention to address serosorting among HIV negative men who have sex with men. Storrs-Mansfield, CT. University of Connecticut. 2010. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.
65 Ehrhardt AA, Exner TM, Hoffman S, et al. A gender-specific HIV/STD risk reduction intervention for women in a health care setting: short- and long-term results of a randomized clinical trial. AIDS Care. Apr. 2002;14(2):147-61. KQ1E4, KQ4E4. [pmid: 11940275].
66 El-Bassel N, Witte SS, Gilbert L, et al. The efficacy of a relationship-based HIV/STD prevention program for heterosexual couples. Am J Public Health. 2003;93(6):963-9. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 12773363].
67 El-Bassel N, Witte SS, Gilbert L, et al. Long-term effects of an HIV/STI sexual risk reduction intervention for heterosexual couples. AIDS Behav. 2005;9(1):1-13. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 15812609].
68 El-Bassel N, Gilbert L, Wu E, et al. Couple-based HIV prevention for low-income drug users from New York City: a randomized controlled trial to reduce dual risks. J Acquir Immune Defic Syndr. Oct. 1. 2011;58(2):198-206. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21725249].
69 Enrhardt AA, Exner TM, Hoffman S, et al. HIV/STD risk and sexual strategies among women family planning clients in New York: Project FIO. AIDS Behav. 2002;6(1):1-13. PMID: None. KQ3E4, KQ4E4.
70 Exner TM, Tesoriero JM, Battles HB, et al. A randomized controlled trial to evaluate a structural intervention to promote the female condom in New York state. AIDS & Behav. Jul. 2012;16(5):1121-32. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 22484992].
71 Ferrer RA, Fisher JD, Buck R, et al. Pilot test of an emotional education intervention component for sexual risk reduction. Health Psychol. Sep. 2011;30(5):656-60. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21534680].
72 Flaskerud JH, Nyamathi AM, Uman GC. Longitudinal effects of an HIV testing and counseling programme for low-income Latina women. Ethn Health. Mar. 1997;2(1-2):89-103. [doi]. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 9395592].
73 Forehand R, Armistead L, Long N, et al. Efficacy of a parent-based sexual-risk prevention program for African American preadolescents: a randomized controlled trial. Arch Pediatr Adolesc Med. Dec. 2007;161(12):1123-9. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 18056556].
74 Fortune T, Wright E, Juzang I, et al. Recruitment, enrollment and retention of young black men for HIV prevention research: experiences from The 411 for Safe Text project. Contemp Clin Trials. Mar. 2010;31(2):151-6. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 20035899].
75 Gold J, Aitken CK, Dixon HG, et al. A randomised controlled trial using mobile advertising to promote safer sex and sun safety to young people. Health Educ Res. Oct. 2011;26(5):782-94. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 21447750].
76 Gollub EL, French P, Loundou A, et al. A randomized trial of hierarchical counseling in a short, clinic-based intervention to reduce the risk of sexually transmitted diseases in women. AIDS. Jun. 16. 2000;14(9):1249-55. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 10894290].
77 Gollub EL, Armstrong K, Boney T, et al. Correlates of trichomonas prevalence among street-recruited, drug-using women enrolled in a randomized trial. Subst Use Misuse. Nov. 2010;45(13):2203-20. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20482337].
78 Gollub EL, Cyrus-Cameron E, Armstrong K, et al. Basic body knowledge in street-recruited, active drug-using women enrolled in a “body empowerment” intervention trial. AIDS Care. Dec. 7. 2012;25(6):732-7. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 23216297].
79 Gottlieb SL, Douglas JM Jr, Foster M, et al. Incidence of herpes simplex virus type 2 infection in 5 sexually transmitted disease (STD) clinics and the effect of HIV/STD risk-reduction counseling. J Infect Dis. Sep. 15. 2004;190(6):1059-67. KQ2E4, KQ3E4, KQ4E4. [pmid: 15319854].
80 Grimley DM, Hook EW III. A 15-minute interactive, computerized condom use intervention with biological endpoints. Sex Transm Dis. Feb. 2009;36(2):73-8. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a. [pmid: 19125141].
81 Guilamo-Ramos V, Bouris A, Jaccard J, et al. A parent-based intervention to reduce sexual risk behavior in early adolescence: building alliances between physicians, social workers, and parents. J Adolesc Health. Feb. 2011;48(2):159-63. KQ1E4, KQ3E4, KQ4E4. [pmid: 21257114].
82 Harvey SM, Henderson JT, Thorburn S, et al. A randomized study of a pregnancy and disease prevention intervention for Hispanic couples. Perspect Sex Reprod Health. 2004;36(4):162-9. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 15321783].
83 Harvey SM, Kraft JM, West SG, et al. Effects of a health behavior change model--based HIV/STI prevention intervention on condom use among heterosexual couples: a randomized trial. Health Educ Behav. Oct. 2009;36(5):878-94. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 18784350].
84 Hien DA, Campbell AN, Killeen T, et al. The impact of trauma-focused group therapy upon HIV sexual risk behaviors in the NIDA Clinical Trials Network “Women and trauma” multi-site study. AIDS & Behav. Apr. 2010;14(2):421-30. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 19452271].
85 Hoffman JA, Klein H, Crosby H, et al. Project neighborhoods in action: an HIV-related intervention project targeting drug abusers in Washington, DC. J Urban Health. 1999;76(4):419-34. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 10609592].
86 Hoffman S, Exner TM, Leu CS, et al. Female-condom use in a gender-specific family planning clinic trial. Am J Public Health. Nov. 2003;93(11):1897-903. KQ1E4, KQ3E4, KQ4E4. [pmid: 14600063].
87 Holden AE, Shain RN, Miller WB, et al. The influence of depression on sexual risk reduction and STD infection in a controlled, randomized intervention trial. Sex Transm Dis. Oct. 2008;35(10):898-904. KQ3E4, KQ4E4. [pmid: 18607311].
88 Hops H, Ozechowski TJ, Waldron HB, et al. Adolescent health-risk sexual behaviors: effects of a drug abuse intervention. AIDS & Behav. Nov. 2011;15(8):1664-76. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 21833690].
89 Howard MN, Howard MN. Improving low-income teen health behaviors with Internet-linked clinic interventions. Sex Res Social Policy. Mar. 8. 2011;(1). PMID: None. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a.
90 Imrie J, Stephenson JM, Cowan FM, et al. A cognitive behavioural intervention to reduce sexually transmitted infections among gay men: randomised trial. BMJ. Jun. 16. 2001;322(7300):1451-6. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 11408300].
91 Ito KE, Kalyanaraman S, Ford CA, et al. “Let's Talk About Sex”: pilot study of an interactive CD-ROM to prevent HIV/STIS in female adolescents”. AIDS Educ Prev. Feb. 2008;20(1):78-89. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 18312069].
92 Jemmott JB III, Jemmott LS, Fong GT. Reductions in HIV risk-associated sexual behaviors among black male adolescents: effects of an AIDS prevention intervention. Am J Public Health. Mar. 1992;82(3):372-7. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 1536352].
93 Jemmott JB III, Jemmott LS, Braverman PK, et al. HIV/STD risk reduction interventions for African American and Latino adolescent girls at an adolescent medicine clinic: a randomized controlled trial. Arch Pediatr Adolesc Med. May. 2005;159(5):440-9. KQ3E4, KQ4E4. [pmid: 15867118].
94 Jemmott JB III, Jemmott LS, Fong GT, et al. Effectiveness of an HIV/STD risk-reduction intervention for adolescents when implemented by community-based organizations: a cluster-randomized controlled trial. Am J Public Health. Apr. 2010;100(4):720-6. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20167903].
95 Jemmott LS, Jemmott JB III, O'Leary A. Effects on sexual risk behavior and STD rate of brief HIV/STD prevention interventions for African American women in primary care settings. Am J Public Health. Jun. 2007;97(6):1034-40. KQ3E4, KQ4E4. [pmid: 17463391].
96 Jones DL, Kashy D, Villar-Loubet OM, et al. The impact of substance use, sexual trauma, and intimate partner violence on sexual risk intervention outcomes in couples: a randomized trial. Ann Behav Med. Dec. 4. 2012;45(3):318-28. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 23208648].
97 Jones R, Lacroix LJ. Streaming weekly soap opera video episodes to smartphones in a randomized controlled trial to reduce HIV risk in young urban African American/black women. AIDS & Behav. Jul. 2012;16(5):1341-58. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 22430640].
98 Juzang I, Fortune T, Black S, et al. A pilot programme using mobile phones for HIV prevention. J Telemed Telecare. 2011;17(3):150-3. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 21270049].
99 Kalichman SC, Cain D, Weinhardt L, et al. Experimental components analysis of brief theory-based HIV/AIDS risk-reduction counseling for sexually transmitted infection patients. Health Psychol. Mar. 2005;24(2):198-208. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 15755234].
100 Kamb ML, Fishbein M, Douglas JM Jr, et al. Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. Project RESPECT Study Group. JAMA. Oct. 7. 1998;280(13):1161-7. KQ3E4, KQ4E4. [pmid: 9777816].
101 Kelly JA, McAuliffe TL, Sikkema KJ, et al. Reduction in risk behavior among adults with severe mental illness who learned to advocate for HIV prevention. J Consult Clin Psychol. 1997;48(10):1283-8. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 9323747].
102 Kennedy SB, Nolen S, Applewhite J, et al. Condom use behaviours among 18-24 year-old urban African American males: a qualitative study. AIDS Care. Sep. 2007;19(8):1032-8. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 17852001].
103 Kennedy SB, Nolen S, Applewhite J, et al. A quantitative study on the condom-use behaviors of eighteen- to twenty-four-year-old urban African American males. AIDS Patient Care STDS. May. 2007;21(5):306-20. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 17518523].
104 Kennedy SB, Nolen S, Pan Z, et al. Effectiveness of a brief condom promotion program in reducing risky sexual behaviours among African American men. J Eval Clin Pract. Mar. 21. 2012;19(2):408-13. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 22435646].
105 Kershaw TS, Magriples U, Westdahl C, et al. Pregnancy as a window of opportunity for HIV prevention: effects of an HIV intervention delivered within prenatal care. Am J Public Health. Nov. 2009;99(11):2079-86. KQ4E4. [pmid: 19762662].
106 Klein CH, Card JJ. Preliminary efficacy of a computer-delivered HIV prevention intervention for African American teenage females. AIDS Educ Prev. Dec. 2011;23(6):564-76. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 22201239].
107 Koblin BA, Bonner S, Hoover DR, et al. A randomized trial of enhanced HIV risk-reduction and vaccine trial education interventions among HIV-negative, high-risk women who use noninjection drugs: the UNITY study. J Acquir Immune Defic Syndr. Mar. 2010;53(3):378-87. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20190585].
108 Koblin BA, Bonner S, Powell B, et al. A randomized trial of a behavioral intervention for black MSM: the DiSH study. AIDS. Feb. 20. 2012;26(4):483-8. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a. [pmid: 22156967].
109 Kogan SM, Yu T, Brody GH, et al. Integrating condom skills into family-centered prevention: efficacy of the Strong African American Families-Teen program. J Adolesc Health. Aug. 2012;51(2):164-70. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 22824447].
110 Koniak-Griffin D, Lesser J, Takayanagi S, et al. Couple-focused human immunodeficiency virus prevention for young Latino parents: randomized clinical trial of efficacy and sustainability. Arch Pediatr Adolesc Med. Apr. 2011;165(4):306-12. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 21464378].
111 Konkle-Parker DJ, Amico KR, McKinney VE. Effects of an intervention addressing information, motivation, and behavioral skills on HIV care adherence in a southern clinic cohort. AIDS Care. 2013. Oct. 14. KQ1E1, KQ2E1, KQ3E1, KQ4E1.
112 Korte JE, Shain RN, Holden AE, et al. Reduction in sexual risk behaviors and infection rates among African Americans and Mexican Americans. Sex Transm Dis. Mar. 2004;31(3):166-73. KQ3E4, KQ4E4. [pmid: 15076930].
113 Kott A. Family intervention may reduce HIV risk-taking in Hispanic adolescents. [References]. Perspect Sex Reprod Health. Dec. 2011;43(4):267-8. PMID: None. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c.
114 Kraft JM, Harvey SM, Thorburn S, et al. Intervening with couples: assessing contraceptive outcomes in a randomized pregnancy and HIV/STD risk reduction intervention trial. Womens Health Issues. Jan. 2007;17(1):52-60. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 17321948].
115 Kurtz SP, Stall RD, Buttram ME, et al. A randomized trial of a behavioral intervention for high risk substance-using MSM. AIDS Behav. 2013. Jun. 4. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a. [pmid: 23732957].
116 Lang DL, DiClemente RJ, Hardin JW, et al. Threats of cross-contamination on effects of a sexual risk reduction intervention: fact or fiction. Prev Sci. Sep. 2009;10(3):270-5. KQ1E4, KQ4E4. [pmid: 19241171].
117 Lau JT, Lau M, Cheung A, et al. A randomized controlled study to evaluate the efficacy of an Internet-based intervention in reducing HIV risk behaviors among men who have sex with men in Hong Kong. AIDS Care. Aug. 2008;20(7):820-8. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 18608057].
118 Lau JT, Tsui HY, Cheng S, et al. A randomized controlled trial to evaluate the relative efficacy of adding voluntary counseling and testing (VCT) to information dissemination in reducing HIV-related risk behaviors among Hong Kong male cross-border truck drivers. AIDS Care. Jan. 2010;22(1):17-28. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20390477].
119 Lau JT, Tsui HY. Voluntary counselling and testing plus information distribution to reduce HIV-related risk behaviours among Hong Kong male cross-border truck drivers: a randomised controlled study. Hong Kong Med J. Aug. 2012;18(Suppl 3):39-41. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 22865223].
120 Lau JT, Tsui HY, Lau MM. A pilot clustered randomized control trial evaluating the efficacy of a network-based HIV peer-education intervention targeting men who have sex with men in Hong Kong, China. AIDS Care. Dec. 17. 2012;25(7):812-9. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 23244706].
121 Lesser J, Koniak-Griffin D, Huang R, et al. Parental protectiveness and unprotected sexual activity among Latino adolescent mothers and fathers. AIDS Educ Prev. Oct. 2009;21(5:Suppl):88-102. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 19824837].
122 Li X, Stanton B, Feigelman S, et al. Unprotected sex among African-American adolescents a three-year study. J Natl Med Assoc. 2002;94(9):789-96. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 12392042].
123 Lindenberg CS, Solorzano RM, Bear D, et al. Reducing substance use and risky sexual behavior among young, low-income, Mexican-American women: comparison of two interventions. Appl Nurs Res. 2002;15(3):137-48. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b. [pmid: 12173165].
124 Mallory C, Hesson-McInnis M. Pilot test results of an HIV prevention intervention for high-risk women. West J Nurs Res. Mar. 2013;35(3):313-29. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a. [pmid: 21821725].
125 Malow RM, McMahon RC, Devieux J, et al. Cognitive behavioral HIV risk reduction in those receiving psychiatric treatment: a clinical trial. AIDS & Behav. Jul. 2012;16(5):1192-202. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b. [pmid: 22210481].
126 Mansergh G, Koblin BA, McKirnan DJ, et al. An intervention to reduce HIV risk behavior of substance-using men who have sex with men: a two-group randomized trial with a nonrandomized third group. PLoS Med. 2010;7(8):e1000329. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b. [pmid: 20811491].
127 Marion LN, Finnegan L, Campbell RT, et al. The Well Woman Program: a community-based randomized trial to prevent sexually transmitted infections in low-income African American women. Res Nurs Health. Jun. 2009;32(3):274-85. KQ3E4. [pmid: 19373824].
128 Marrazzo JM, Thomas KK, Fiedler TL, et al. Relationship of specific vaginal bacteria and bacterial vaginosis treatment failure in women who have sex with women. Ann Intern Med. Jul. 1. 2008;149(1):20-8. KQ2E4, KQ3E4, KQ4E4. [pmid: 18591634].
129 Marrazzo JM, Thomas KK, Agnew K, et al. Prevalence and risks for bacterial vaginosis in women who have sex with women. Sex Transm Dis. May. 2010;37(5):335-9. KQ2E4, KQ3E4, KQ4E4. [pmid: 20429087].
130 Marrazzo JM, Thomas KK, Ringwood K. A behavioural intervention to reduce persistence of bacterial vaginosis among women who report sex with women: results of a randomised trial. Sex Transm Infect. Aug. 2011;87(5):399-405. KQ2E4, KQ3E4, KQ4E4. [pmid: 21653935].
131 Marsch LA, Grabinski MJ, Bickel WK, et al. Computer-assisted HIV prevention for youth with substance use disorders. Subst Use Misuse. 2011;46(1):46-56. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 21190405].
132 Mausbach BT, Semple SJ, Strathdee SA, et al. Efficacy of a behavioral intervention for increasing safer sex behaviors in HIV-negative, heterosexual methamphetamine users: results from the Fast-Lane Study. Ann Behav Med. Nov. 2007;34(3):263-74. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 18020936].
133 McCollister KE, Freitas DM, Prado G, et al. Opportunity Costs and Financial Incentives for Hispanic Youth Participating in a Family-Based HIV and Substance Use Preventive Intervention. J Prim Prev. 2013. Oct. 26. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.
134 McCoy CB, Chitwood DD, Khoury EL. The implementation of an experimental research design in the evaluation of an intervention to prevent AIDS among IV drug users. J Drug Issues. 1990;20(2):215-22. PMID: None. KQ1E4, KQ2E4, KQ3E4, KQ4E4.
135 McCoy HV, Dodds SE, Nolan C. AIDS intervention design for program evaluation: the Miami Community Outreach Program. J Drug Issues. 1990;20(2):223-43. PMID: None. KQ1E4, KQ2E4, KQ3E4, KQ4E4.
136 McMahon JM, Tortu S, Pouget ER, et al. Effectiveness of couple-based HIV counseling and testing for women substance users and their primary male partners: a randomized trial. Adv Prev Med. 2013;2013:286207. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 23555059].
137 Melendez RM, Hoffman S, Exner T, et al. Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Arch Sex Behav. Dec. 2003;32(6):499-511. KQ1E4, KQ4E4. [pmid: 14574094].
138 Metsch LR, Feaster DJ, Gooden L, et al. Implementing rapid HIV testing with or without risk-reduction counseling in drug treatment centers: results of a randomized trial. Am J Public Health. Jun. 2012;102(6):1160-7. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 22515871].
139 Metsch LR, Feaster DJ, Gooden L, et al. Effect of risk-reduction counseling with rapid HIV testing on risk of acquiring sexually transmitted infections: the AWARE randomized controlled trial. JAMA. 2013;310(16):1701-10. KQ3E4. [pmid: 24150466].
140 Mevissen FE, Ruiter RA, Meertens RM, et al. Justify your love: testing an online STI-risk communication intervention designed to promote condom use and STI-testing. Psychol Health. Feb. 2011;26(2):205-21. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 21318930].
141 Milhausen RR, DiClemente RJ, Lang DL, et al. Frequency of sex after an intervention to decrease sexual risk-taking among African-American adolescent girls: Results of a randomized, controlled clinical trial. Sex Education. 2008;8:47-57. KQ1E4, KQ3E4, KQ4E4.
142 Milhausen RR, Milhausen RR. Justify your love: testing an online STI-risk communication intervention designed to promote condom use and STI-testing. Sex Educ. Feb. 2008;8(1):47-57. PMID: None. KQ1E4, KQ3E4, KQ4E4.
143 Miller KS, Forehand R, Wiegand R, et al. Making HIV prevention programming count: identifying predictors of success in a parent-based HIV prevention program for youth. AIDS Educ Prev. Feb. 2011;23(1):38-53. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 21341959].
144 Miller KS, Lin CY, Poulsen MN, et al. Enhancing HIV communication between parents and children: efficacy of the Parents Matter! Program. AIDS Educ Prev. Dec. 2011;23(6):550-63. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 22201238].
145 Miller S, Exner TM, Williams SP, et al. A gender-specific intervention for at-risk women in the USA. AIDS Care. Oct. 2000;12(5):603-12. KQ1E4, KQ3E4, KQ4E4. [pmid: 11218546].
146 Mimiaga MJ, Noonan E, Donnell D, et al. Childhood sexual abuse is highly associated with HIV risk-taking behavior and infection among MSM in the EXPLORE Study. J Acquir Immune Defic Syndr. Jul. 1. 2009;51(3):340-8. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 19367173].
147 Mittal M, Senn TE, Carey MP. Mediators of the relation between partner violence and sexual risk behavior among women attending a sexually transmitted disease clinic. Sex Transm Dis. Jun. 2011;38(6):510-5. KQ3E4. [pmid: 21258269].
148 Morgenstern J, Bux DA Jr, Parsons J, et al. Randomized trial to reduce club drug use and HIV risk behaviors among men who have sex with men. J Consult Clin Psychol. Aug. 2009;77(4):645-56. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a. [pmid: 19634958].
149 Morrison-Beedy D, Carey MP, Kowalski J, et al. Group-based HIV risk reduction intervention for adolescent girls: evidence of feasibility and efficacy. Res Nurs Health. Feb. 2005;28(1):3-15. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a. [pmid: 15625713].
150 Morrison-Beedy D, Carey MP, Crean HF, et al. Determinants of adolescent female attendance at an HIV risk reduction program. J Assoc Nurses AIDS Care. Mar. 2010;21(2):153-61. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20116296].
151 Morrison-Beedy D, Jones SH, Xia Y, et al. Reducing sexual risk behavior in adolescent girls: results from a randomized controlled trial. J Adolesc Health. Mar. 2013;52(3):314-21. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 23299011].
152 Murry VM, Berkel C, Chen YF, et al. Intervention induced changes on parenting practices, youth self-pride and sexual norms to reduce HIV-related behaviors among rural African American youths. J Youth Adolesc. Sep. 2011;40(9):1147-63. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21373904].
153 Mustanski B, Garofalo R, Monahan C, et al. Feasibility, acceptability, and preliminary efficacy of an online HIV prevention program for diverse young men who have sex with men: the Keep It Up! intervention. AIDS Behav. 2013. May. 15. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 23673793].
154 Negash S. Sexual health education in college: The impact of sexual negotiation training on sexual risk reduction. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2013;74. No. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c.
155 Neumann MS, O'Donnell L, Doval AS, et al. Effectiveness of the VOICES/VOCES sexually transmitted disease/human immunodeficiency virus prevention intervention when administered by health department staff: does it work in the “real world”?. Sex Transm Dis. Feb. 2011;38(2):133-9. KQ2E4, KQ3E4, KQ4E4. [pmid: 20729794].
156 NIMH Collaborative HIV/STD Prevention Trial Group. Results of the NIMH collaborative HIV/sexually transmitted disease prevention trial of a community popular opinion leader intervention. J Acquir Immune Defic Syndr. Jun. 2010;54(2):204-14. KQ1E10, KQ2E10, KQ3E10, KQ4E10. [pmid: 20354444].
157 Norr KF, Ferrer L, Cianelli R, et al. Peer group intervention for HIV prevention among health workers in Chile. J Assoc Nurses AIDS Care. Jan. 2012;23(1):73-86. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21497113].
158 Norton W, Fisher J, Amico K, et al. Relative efficacy of a pregnancy, sexually transmitted infection, or human immunodeficiency virus prevention-focused intervention on changing sexual risk behavior among young adults. J Am Coll Health. Nov. 2012;60(8):574-82. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 23157199].
159 Nydegger LA, Keeler AR, Hood C, et al. Effects of a one-hour intervention on condom implementation intentions among drug users in Southern California. AIDS Care. 2013. May. 8. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 23656365].
160 O'Leary A, Jemmott LS, Jemmott JB. Mediation analysis of an effective sexual risk-reduction intervention for women: the importance of self-efficacy. Health Psychol. Mar. 2008;27(2 Suppl):S180-S184. KQ3E4, KQ4E4. [pmid: 18377160].
161 Pachankis JE, Lelutiu-Weinberger C, Golub SA, et al. Developing an online health intervention for young gay and bisexual Men. AIDS Behav. 2013. May. 15. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 23673791].
162 Pantin H, Prado G, Lopez B, et al. A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosom Med. Nov. 2009;71(9):987-95. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 19834053].
163 Peipert J, Redding CA, Blume J, et al. Design of a stage-matched intervention trial to increase dual method contraceptive use (Project PROTECT). Contemp Clin Trials. Sep. 2007;28(5):626-37. KQ4E4. [pmid: 17374567].
164 Peipert JF, Redding CA, Blume JD, et al. Tailored intervention to increase dual-contraceptive method use: a randomized trial to reduce unintended pregnancies and sexually transmitted infections. Am J Obstet Gynecol. Jun. 2008;198(6):630-8. KQ4E4. [pmid: 18395692].
165 Peragallo N, Gonzalez-Guarda RM, McCabe BE, et al. The efficacy of an HIV risk reduction intervention for Hispanic women. AIDS & Behav. Jul. 2012;16(5):1316-26. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21969175].
166 Pereira LM. Risk and relationship: examining the outcomes of couples-based HIV prevention among low-income men of color in heterosexual relationships. New York. Columbia University. 2001. PMID: None. KQ1E3, KQ2E3, KQ3E3, KQ4E3.
167 Peterman A. Physician initiated STI prevention counselling: targeting women to reach couples. Ontario. University of Western Ontario. 2008. PMID: None. KQ1E12, KQ2E12, KQ3E12, KQ4E12.
168 Petersen R, Albright J, Garrett JM, et al. Pregnancy and STD prevention counseling using an adaptation of motivational interviewing: a randomized controlled trial. Perspect Sex Reprod Health. Mar. 2007;39(1):21-8. KQ2E4, KQ4E4. [pmid: 17355378].
169 Picciano JF, Roffman RA, Kalichman SC, et al. Lowering obstacles to HIV prevention services: effects of a brief, telephone-based intervention using motivational enhancement therapy. Ann Behav Med. Oct. 2007;34(2):177-87. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 17927556].
170 Prado G, Pantin H, Briones E, et al. A randomized controlled trial of a parent-centered intervention in preventing substance use and HIV risk behaviors in Hispanic adolescents. J Consult Clin Psychol. Dec. 2007;75(6):914-26. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 18085908].
171 Prado G, Pantin H, Huang S, et al. Effects of a family intervention in reducing HIV risk behaviors among high-risk Hispanic adolescents: a randomized controlled trial. Arch Pediatr Adolesc Med. Feb. 2012;166(2):127-33. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 21969363].
172 Proude EM, D'Este C, Ward JE. Randomized trial in family practice of a brief intervention to reduce STI risk in young adults. Fam Pract. Oct. 2004;21(5):537-44. KQ1E4, KQ3E4, KQ4E4. [pmid: 15367476].
173 Reback CJ, Peck JA, Dierst-Davies R, et al. Contingency management among homeless, out-of-treatment men who have sex with men. J Subst Abuse Treat. Oct. 2010;39(3):255-63. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a. [pmid: 20667681].
174 Rhodes F, Stein JA, Fishbein M, et al. Using theory to understand how interventions work: Project RESPECT, condom use, and the Integrative Model. AIDS & Behav. May. 2007;11(3):393-407. KQ3E4, KQ4E4. [pmid: 17323123].
175 Rhodes SD, McCoy TP, Vissman AT, et al. A randomized controlled trial of a culturally congruent intervention to increase condom use and HIV testing among heterosexually active immigrant Latino men. AIDS & Behav. Nov. 2011;15(8):1764-75. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21301948].
176 Rosser BR, Oakes JM, Konstan J, et al. Reducing HIV risk behavior of men who have sex with men through persuasive computing: results of the Men's INTernet Study-II. AIDS. Aug. 24. 2010;24(13):2099-107. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 20601853].
177 Rosser BRS. Evaluation of the efficacy of AIDS education interventions for homosexually active men. Health Educ Res. 1990;5(3):299-308. PMID: None. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c.
178 Rotheram-Borus MJ. HIV prevention in persons with mental health problems. Psychol Health Med. 2006;11(2):142-54. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 17129904].
179 Roye C, Perlmutter SP, Krauss B. A brief, low-cost, theory-based intervention to promote dual method use by black and Latina female adolescents: a randomized clinical trial. Health Educ Behav. Aug. 2007;34(4):608-21. KQ1E8a, KQ2E8a, KQ3E8a, KQ4E8a. [pmid: 16740522].
180 Sales JM, Lang DL, Hardin JW, et al. Efficacy of an HIV prevention program among African American female adolescents reporting high depressive symptomatology. J Womens Health (Larchmt). Feb. 2010;19(2):219-27. KQ1E4, KQ3E4, KQ4E4. [pmid: 20109119].
181 Sales JM, Lang DL, DiClemente RJ, et al. The mediating role of partner communication frequency on condom use among African American adolescent females participating in an HIV prevention intervention. Health Psychol. Jan. 2012;31(1):63-9. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 21843001].
182 Sanchez J, De La Rosa M, Serna CA. Project Salud: Efficacy of a Community-Based HIV Prevention Intervention for Hispanic Migrant Workers in South Florida. AIDS Education & Prevention. Oct. 2013;25(5):363-75. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 24059875].
183 Sanderson CA, Yopyk DJ. Improving condom use intentions and behavior by changing perceived partner norms: an evaluation of condom promotion videos for college students. Health Psychol. Jul. 2007;26(4):481-7. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 17605568].
184 Scholes D, McBride CM, Grothaus L, et al. A tailored minimal self-help intervention to promote condom use in young women: results from a randomized trial. AIDS. Jul. 4. 2003;17(10):1547-56. KQ3E4, KQ4E4. [pmid: 12824793].
185 Schumann A, Nyamathi A, Stein JA. HIV risk reduction in a nurse case-managed TB and HIV intervention among homeless adults. J Health Psychol. Sep. 2007;12(5):833-43. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 17855466].
186 Schwartz RP, Stitzer ML, Feaster DJ, et al. HIV rapid testing in drug treatment: comparison across treatment modalities. J Subst Abuse Treat. Apr. 2013;44(4):369-74. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 23021496].
187 Seibold-Simpson S, Morrison-Beedy D. Avoiding early study attrition in adolescent girls: impact of recruitment contextual factors. West J Nurs Res. Oct. 2010;32(6):761-78. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 20634400].
188 Semaan S, Neumann MS, Hutchins K, et al. Brief counseling for reducing sexual risk and bacterial STIs among drug users--results from project RESPECT. Drug Alcohol Depend. Jan. 1. 2010;106(1):7-15. KQ3E4, KQ4E4. [pmid: 19720471].
189 Senn N, de VS, Berdoz D, et al. Motivational brief intervention for the prevention of sexually transmitted infections in travelers: a randomized controlled trial. BMC Infect Dis. 2011;11:300. KQ1E8c, KQ2E8c, KQ3E8c, KQ4E8c. [pmid: 22044609].
190 Shain RN, Piper JM, Newton ER, et al. Even if you build it, we may not come: correlates of non-attendance at a sexual risk reduction workshop for STD clinic patients. N Engl J Med. Jan. 14. 1999;340(2):93-100. KQ3E4, KQ4E4. [pmid: 9887160].
191 Shain RN, Piper JM, Holden AE, et al. Prevention of gonorrhea and Chlamydia through behavioral intervention: results of a two-year controlled randomized trial in minority women. Sex Transm Dis. Jul. 2004;31(7):401-8. KQ3E4, KQ4E4. [pmid: 15215694].
192 Shoptaw S, Reback CJ, Larkins S, et al. Outcomes using two tailored behavioral treatments for substance abuse in urban gay and bisexual men. J Subst Abuse Treat. Oct. 2008;35(3):285-93. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 18329226].
193 Sieving RE, Bernat DH, Resnick MD, et al. A clinic-based youth development program to reduce sexual risk behaviors among adolescent girls: prime time pilot study. Health Promot Pract. Jul. 2012;13(4):462-71. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 21606323].
194 Sinclair AH, Tolsma D, Weathersby A, et al. Feasibility of conducting a large, randomized controlled trial for STD counseling in a managed care setting. Sex Transm Dis. Nov. 2008;35(11):920-3. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 18665018].
195 Slesnick N, Kang MJ. The impact of an integrated treatment on HIV risk behavior among homeless youth: a randomized controlled trial. J Behav Med. Feb. 2008;31(1):45-59. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 17940861].
196 Smith PB, Weinman ML, Parrilli J. The role of condom motivation education in the reduction of new and reinfection rates of sexually transmitted diseases among inner-city female adolescents. Patient Educ Couns. May. 1997;31(1):77-81. PMID:. [pii: S0738-3991(97)01009-4]. KQ1E8b, KQ2E8b, KQ3E8b, KQ4E8b. [pmid: 9197805].
197 St Lawrence JS, Brasfield TL, Jefferson KW, et al. Cognitive-behavioral intervention to reduce African American adolescents' risk for HIV infection. J Consult Clin Psychol. 1995;63(2):221-37. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 7751483].
198 Sullivan PS, White D, Rosenberg ES, et al. Safety and acceptability of couples HIV testing and counseling for US men who have sex with men: a randomized prevention study. J Int Assoc Provid AIDS Care. 2013. Aug. 30. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 23995295].
199 Swartz LH, Sherman CA, Harvey SM, et al. Midlife women online: evaluation of an internet-based program to prevent unintended pregnancy & STIs. J Women Aging. 2011;23(4):342-59. KQ1E2c, KQ2E2c, KQ3E2c, KQ4E2c. [pmid: 22014222].
200 Thurman AR, Holden AE, Shain RN, et al. Preventing recurrent sexually transmitted diseases in minority adolescents: a randomized controlled trial. Obstet Gynecol. Jun. 2008;111(6):1417-25. KQ3E4, KQ4E4. [pmid: 18515527].
201 Thurman AR, Holden AE, Shain RN, et al. The male sexual partners of adult versus teen women with sexually transmitted infections. Sex Transm Dis. Dec. 2009;36(12):768-74. KQ1E7, KQ2E7, KQ3E7, KQ4E7. [pmid: 19704393].
202 Tobin K, Kuramoto SJ, German D, et al. Unity in Diversity: results of a randomized clinical culturally tailored pilot HIV prevention intervention trial in Baltimore, Maryland, for African American men who have sex with men. Health Educ Behav. 2012. Sep. 14. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a. [pmid: 22984216].
203 Tobin KE, Kuramoto SJ, Davey-Rothwell MA, et al. The STEP into Action study: a peer-based, personal risk network-focused HIV prevention intervention with injection drug users in Baltimore, Maryland. Addiction. Feb. 2011;106(2):366-75. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 21054614].
204 Tolou-Shams M, Houck C, Conrad SM, et al. HIV prevention for juvenile drug court offenders: a randomized controlled trial focusing on affect management. J Correct Health Care. Jul. 2011;17(3):226-32. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 21474529].
205 Trenholm C, Devaney B, Fortson K, et al. Impacts of abstinence education on teen sexual activity, risk of pregnancy, and risk of sexually transmitted diseases. J Policy Anal Manage. 2008;27(2):255-76. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 18401923].
206 Tross S, Campbell AN, Cohen LR, et al. Effectiveness of HIV/STD sexual risk reduction groups for women in substance abuse treatment programs: results of NIDA Clinical Trials Network Trial. J Acquir Immune Defic Syndr. Aug. 15. 2008;48(5):581-9. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 18645513].
207 Warner L, Klausner JD, Rietmeijer CA, et al. Effect of a brief video intervention on incident infection among patients attending sexually transmitted disease clinics. PLoS Med. Jun. 24. 2008;5(6):e135. KQ2E4, KQ3E4, KQ4E4. [pmid: 18578564].
208 Weir BW, O'Brien K, Bard RS, et al. Reducing HIV and partner violence risk among women with criminal justice system involvement: a randomized controlled trial of two motivational interviewing-based interventions. AIDS Behav. Jun. 2009;13(3):509-22. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b. [pmid: 18636325].
209 Wenger NS, Greenberg JM, Hilborne LH, et al. Effect of HIV antibody testing and AIDS education on communication about HIV risk and sexual behavior. A randomized, controlled trial in college students. Ann Intern Med. Dec. 1. 1992;117(11):905-11. KQ1E4, KQ3E4, KQ4E4. [pmid: 1443951].
210 Wilson TE, Hogben M, Malka ES, et al. A randomized controlled trial for reducing risks for sexually transmitted infections through enhanced patient-based partner notification. Am J Public Health. Apr. 2009;99. Suppl-10. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 18556619].
211 Wilton L, Herbst JH, Coury-Doniger P, et al. Efficacy of an HIV/STI prevention intervention for black men who have sex with men: findings from the Many Men, Many Voices (3MV) project. AIDS & Behav. Jun. 2009;13(3):532-44. KQ1E6, KQ2E6, KQ3E6, KQ4E6. [pmid: 19267264].
212 Wingood GM, DiClemente RJ, Harrington KF, et al. Efficacy of an HIV prevention program among female adolescents experiencing gender-based violence. Am J Public Health. Jun. 2006;96(6):1085-90. KQ4E4. [pmid: 16670238].
213 Wingood GM, Card JJ, Er D, et al. Preliminary efficacy of a computer-based HIV intervention for African-American women. Psychol Health. Feb. 2011;26(2):223-34. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 21318931].
214 Wingood GM, DiClemente RJ, Villamizar K, et al. Efficacy of a health educator-delivered HIV prevention intervention for Latina women: a randomized controlled trial. Am J Public Health. Dec. 2011;101(12):2245-52. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 22021297].
215 Wingood GM, DiClemente RJ, Robinson-Simpson L, et al. Efficacy of an HIV intervention in reducing high-risk human papillomavirus, nonviral sexually transmitted infections, and concurrency among African American women: a randomized-controlled trial. JAIDS. Jun. 1. 2013;63(Suppl 1):S36-S43. KQ2E8b, KQ3E4, KQ4E4. [pmid: 23673884].
216 Witte SS, El-Bassel N, Gilbert L, et al. Promoting female condom use to heterosexual couples: findings from a randomized clinical trial. Perspect Sex Reprod Health. 2006;38(3):148-54. KQ1E3, KQ2E3, KQ3E3, KQ4E3. [pmid: 16963388].
217 Yancey EM, Mayberry R, Armstrong-Mensah E, et al. The community-based participatory intervention effect of “HIV-RAAP”. Am J Health Behav. Jul. 2012;36(4):555-68. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a. [pmid: 22488405].
218 Zule WA, Bobashev GV, Reif SM, et al. Results of a pilot test of a brief computer-assisted tailored HIV prevention intervention for use with a range of demographic and risk groups. AIDS Behav. 2013. Jul. 20. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 23872994].