# References

1 Caspersen CJ, Powell KE, Christenson GM. Physical activity, exercise, and physical fitness: definitions and distinctions for health-related research. Public Health Rep. 1985;100(2):126-31. [pmid: 3920711].
2 Haskell WL, Lee IM, Pate RR, et al. Physical activity and public health: updated recommendation for adults from the American College of Sports Medicine and the American Heart Association. Med Sci Sports Exerc. 2007;39(8):1423-34. [pmid: 17762377].
3 Nelson ME, Rejeski WJ, Blair SN, et al. Physical activity and public health in older adults: recommendation from the American College of Sports Medicine and the American Heart Association. Med Sci Sports Exerc. 2007;39(8):1435-45. [pmid: 17762378].
4 U.S. Department of Health and Human Services. 2008 Physical Activity Guidelines for Americans. Washington, DC. U.S. Department of Health and Human Services. 2008.
5 D'Agostino RB Sr, Vasan RS, Pencina MJ, et al. General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743-53. [pmid: 18212285].
6 Yusuf S, Hawken S, Ounpuu S, et al. Effect of potentially modifiable risk factors associated with myocardial infarction in 52 countries (the INTERHEART study): case-control study. Lancet. 2004;364(9438):937-52. [pmid: 15364185].
7 Wilson PW, D'Agostino RB, Levy D, et al. Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97(18):1837-47. [pmid: 9603539].
8 Goldstein LB, Bushnell CD, Adams RJ, et al. Guidelines for the primary prevention of stroke: a guideline for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2011;42(2):517-84. [pmid: 21127304].
9 Norris SL, Kansagara D, Bougatsos C, et al. Screening for Type 2 Diabetes Mellitus: Update of 2003 Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis. AHRQ Publication 08-05116-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2008;61.
10 Mokdad AH, Marks JS, Stroup DF, et al. Actual causes of death in the United States, 2000. JAMA. 2004;291(10):1238-45. [pmid: 15010446].
11 Murphy SL, Xu J, Kochanek KD. Deaths: final data for 2010. Natl Vital Stat Rep. 2013;61(4):1-117. [pmid: 24979972].
12 Centers for Disease Control and Prevention. Vital signs: avoidable deaths from heart disease, stroke, and hypertensive disease - United States, 2001-2010. MMWR Morb Mortal Wkly Rep. 2013;62(35):721-7. [pmid: 24005227].
13 Centers for Disease Control and Prevention. Million hearts: strategies to reduce the prevalence of leading cardiovascular disease risk factors--United States, 2011. MMWR Morb Mortal Wkly Rep. 2011;60(36):1248-51. [pmid: 21918495].
14 Yoon SS, Burt V, Louis T, et al. Hypertension among adults in the United States, 2009-2010. NCHS Data Brief. 2012;(107):1-8. [pmid: 23102115].
15 Carroll MD, Kit B, Lacher D. Total and high-density lipoprotein cholesterol in adults: National Health and Nutrition Examination Survey, 2009-2010. NCHS Data Brief. 2012;(92):1-8. [pmid: 22617230].
16 Kuklina EV, Carroll MD, Shaw KM, et al. Trends in high LDL cholesterol, cholesterol-lowering medication use, and dietary saturated-fat intake: United States, 1976-2010. NCHS Data Brief. 2013;(117):1-8. [pmid: 23759124].
17 Cowie CC, Rust KF, Ford ES, et al. Full accounting of diabetes and pre-diabetes in the U.S. population in 1988-1994 and 2005-2006. Diabetes Care. 2009;32(2):287-94. [pmid: 19017771].
18 Ervin RB. Prevalence of Metabolic Syndrome Among Adults 20 Years of Age and Over, by Sex, Age, Race and Ethnicity, and Body Mass Index: United States, 2003-2006. Hyattsville, MD. National Center for Health Statistics. 2009. [pmid: 19634296].
19 Schiller JS, Lucas JW, Peregoy JA. Summary health statistics for U.S. adults: National Health Interview Survey, 2010. Vital Health Stat. 2012;(252):1-207. [pmid: 22834228].
20 Chobanian AV, Bakris GL, Black HR, et al. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension. 2003;42(6):1206-52. [pmid: 14656957].
21 Centers for Disease Control and Prevention. Vital signs: prevalence, treatment, and control of high levels of low-density lipoprotein cholesterol---United States, 1999-2002 and 2005-2008. MMWR Morb Mortal Wkly Rep. 2011;60(4):109-14. [pmid: 21293326].
22 Centers for Disease Control and Prevention. QuickStats: age-adjusted percentage of adults aged >20 years with hypertension, by poverty level---National Health and Nutrition Examination Survey, United States, 2003-2006. MMWR Morb Mortal Wkly Rep. 2008;57(20):557.
23 Ford ES, Bergmann MM, Boeing H, et al. Healthy lifestyle behaviors and all-cause mortality among adults in the United States. Prev Med. 2012;55(1):23-7. [pmid: 22564893].
24 Nettleton JA, Polak JF, Tracy R, et al. Dietary patterns and incident cardiovascular disease in the Multi-Ethnic Study of Atherosclerosis. Am J Clin Nutr. 2009;90(3):647-54. [pmid: 19625679].
25 Kant AK, Leitzmann MF, Park Y, et al. Patterns of recommended dietary behaviors predict subsequent risk of mortality in a large cohort of men and women in the United States. J Nutr. 2009;139(7):1374-80. [pmid: 19474153].
26 Anderson AL, Harris TB, Tylavsky FA, et al. Dietary patterns and survival of older adults. J Am Diet Assoc. 2011;111(1):84-91. [pmid: 21185969].
27 Lantz PM, Golberstein E, House JS, et al. Socioeconomic and behavioral risk factors for mortality in a national 19-year prospective study of U.S. adults. Soc Sci Med. 2010;70(10):1558-66. [pmid: 20226579].
28 Mente A, de Koning L, Shannon HS, et al. A systematic review of the evidence supporting a causal link between dietary factors and coronary heart disease. Arch Intern Med. 2009;169(7):659-69. [pmid: 19364995].
29 Crowe FL, Key TJ, Appleby PN, et al. Dietary fibre intake and ischaemic heart disease mortality: the European Prospective Investigation into Cancer and Nutrition-Heart study. Eur J Clin Nutr. 2012;66(8):950-6. [pmid: 22617277].
30 Chowdhury R, Stevens S, Gorman D, et al. Association between fish consumption, long chain omega 3 fatty acids, and risk of cerebrovascular disease: systematic review and meta-analysis. BMJ. 2012;345:e6698. [pmid: 23112118].
31 Eckel RH, Jakicic JM, Ard JD, et al. 2013 AHA/ACC guideline on lifestyle management to reduce cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2960-84. [pmid: 24239922].
32 U.S. Department of Health and Human Services. Healthy People 2020. Washington, DC. U.S. Department of Health and Human Services. 2014. Accessed at http://www.healthypeople.gov/2020/topicsobjectives2020/. 22 July 2014.
33 U.S. Department of Health and Human Services. Nutrition and Your Health: Dietary Guidelines for Americans. 5th ed. Washington, DC. U.S. Department of Health and Human Services. 2000. Accessed at http://www.cnpp.usda.gov/Publications/DietaryGuidelines/2000/2000DGProfessionalBooklet.pdf. 22 July 2014.
34 Huffman MD, Capewell S, Ning H, et al. Cardiovascular health behavior and health factor changes (1988-2008) and projections to 2020: results from the National Health and Nutrition Examination Surveys. Circulation. 2012;125(21):2595-602. [pmid: 22547667].
35 King DE, Mainous AG III, Carnemolla M, et al. Adherence to healthy lifestyle habits in US adults, 1988-2006. Am J Med. 2009;122(6):528-34. [pmid: 19486715].
36 Mellen PB, Gao SK, Vitolins MZ, et al. Deteriorating dietary habits among adults with hypertension: DASH dietary accordance, NHANES 1988-1994 and 1999-2004. Arch Intern Med. 2008;168(3):308-14. [pmid: 18268173].
37 Kirkpatrick SI, Dodd KW, Reedy J, et al. Income and race/ethnicity are associated with adherence to food-based dietary guidance among US adults and children. J Acad Nutr Diet. 2012;112(5):624-35. [pmid: 22709767].
38 Oldroyd J, Burns C, Lucas P, et al. The effectiveness of nutrition interventions on dietary outcomes by relative social disadvantage: a systematic review. J Epidemiol Community Health. 2008;62(7):573-9. [pmid: 18559438].
39 Trost SG, Owen N, Bauman AE, et al. Correlates of adults' participation in physical activity: review and update. Med Sci Sports Exerc. 2002;34(12):1996-2001. [pmid: 12471307].
40 Zhou Q, Remsburg R, Caufield K, et al. Lifestyle behaviors, chronic diseases, and ratings of health between black and white adults with pre-diabetes. Diabetes Educ. 2012;(2):219-28. [pmid: 22454406].
41 Beydoun MA, Gary TL, Caballero BH, et al. Ethnic differences in dairy and related nutrient consumption among US adults and their association with obesity, central obesity, and the metabolic syndrome. Am J Clin Nutr. 2008;87(6):1914-25. [pmid: 18541585].
42 Dubowitz T, Heron M, Bird CE, et al. Neighborhood socioeconomic status and fruit and vegetable intake among whites, blacks, and Mexican Americans in the United States. Am J Clin Nutr. 2008;87(6):1883-91. [pmid: 18541581].
43 Talbot LA, Morrell CH, Fleg JL, et al. Changes in leisure time physical activity and risk of all-cause mortality in men and women: the Baltimore Longitudinal Study of Aging. Prev Med. 2007;45(2-3):169-76. [pmid: 17631385].
44 Allender S, Cowburn G, Foster C. Understanding participation in sport and physical activity among children and adults: a review of qualitative studies. Health Educ Res. 2006;21(6):826-35. [pmid: 16857780].
45 American Academy of Family Physicians. Summary of Recommendations for Clinical Preventive Services. Leawood, KS. American Academy of Family Physicians. 2014. Accessed at http://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf. 22 July 2014.
46 American College of Physicians. ACP Clinical Practice Guidelines. Washington, DC. American College of Physicians. 2014. Accessed at http://www.acponline.org/clinical_information/guidelines/guidelines/. 22 July 2014.
47 Artinian NT, Fletcher GF, Mozaffarian D, et al. Interventions to promote physical activity and dietary lifestyle changes for cardiovascular risk factor reduction in adults: a scientific statement from the American Heart Association. Circulation. 2010;122(4):406-41. [pmid: 20625115].
48 Academy of Nutrition and Dietetics. Hypertension Evidence-Based Nutrition Practice Guideline. Chicago. Academy of Nutrition and Dietetics. 2008. Accessed at http://www.andeal.org/topic.cfm?cat=3259&auth=1. 22 July 2014.
49 Academy of Nutrition and Dietetics. Disorders of Lipid Metabolism Update Evidence-Based Nutrition Practice Guideline. Chicago. Academy of Nutrition and Dietetics. 2011. Accessed at http://www.andeal.org/topic.cfm?cat=4528. 22 July 2014.
50 Hiddink GJ, Hautvast JG, van Woerkum CM, et al. Consumers' expectations about nutrition guidance: the importance of primary care physicians. Am J Clin Nutr. 1997;65(6 Suppl):1974S-9. [pmid: 9174506].
51 Ayala C, Neff LJ, Croft JB, et al. Prevalence of self-reported high blood pressure awareness, advice received from health professionals, and actions taken to reduce high blood pressure among US adults--Healthstyles 2002. J Clin Hypertens (Greenwich). 2005;7(9):513-9. [pmid: 16227770].
52 Flocke SA, Clark A, Schlessman K, et al. Exercise, diet, and weight loss advice in the family medicine outpatient setting. Fam Med. 2005;37(6):415-21. [pmid: 15933914].
53 Barnes PM, Schoenborn CA. Trends in adults receiving a recommendation for exercise or other physical activity from a physician or other health professional. NCHS Data Brief. 2012;(86):1-8. [pmid: 22617014].
54 Hebert ET, Caughy MO, Shuval K. Primary care providers' perceptions of physical activity counselling in a clinical setting: a systematic review. Br J Sports Med. 2012;46(9):625-31. [pmid: 22711796].
55 Lin JS, O'Connor E, Whitlock EP, et al. Behavioral counseling to promote physical activity and a healthful diet to prevent cardiovascular disease in adults: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2010;153(11):736-50. [pmid: 21135297].
56 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;43(3 Suppl):21-35. [pmid: 11306229].
57 LeBlanc E, O'Connor E, Whitlock EP, et al. Screening for and Management of Obesity and Overweight in Adults. Evidence Synthesis. AHRQ Publication No. 11-05159-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2011;89. [pmid: 22049569].
58 U.S. Preventive Services Task Force. Screening for and management of obesity in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(5):373-8. [pmid: 22733087].
59 U.S. Preventive Services Task Force. Behavioral counseling interventions to promote a healthful diet and physical activity for cardiovascular disease prevention in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(5):367-71. [pmid: 22733153].
60 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. U.S. Preventive Services Task Force. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm. 22 July 2014.
61 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2012. Accessed at http://publications.nice.org.uk/the-guidelines-manual-pmg6. 22 July 2014.
62 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
63 Taylor BN, Thompson A, editors. The International System of Units. NIST Special Publication 330. Gaithersburg, MD. National Institute of Standards and Technology. 2008. Accessed at http://physics.nist.gov/Pubs/SP330/sp330.pdf. 22 July 2014.
64 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
65 Egger M, Davey SG, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563].
66 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58(9):894-901. [pmid: 16085192].
67 Voils CI, Coffman CJ, Yancy WS Jr, et al. A randomized controlled trial to evaluate the effectiveness of CouPLES: a spouse-assisted lifestyle change intervention to improve low-density lipoprotein cholesterol. Prev Med. 2013;56(1):46-52. [pmid: 23146744].
68 Broekhuizen K, van Poppel MN, Koppes LL, et al. Can multiple lifestyle behaviours be improved in people with familial hypercholesterolemia? Results of a parallel randomised controlled trial. PLoS One. 2012;7(12):e50032. [pmid: 23251355].
69 Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9(5):274-81. [pmid: 8257616].
70 Anderson JW, Garrity TF, Wood CL, et al. Prospective, randomized, controlled comparison of the effects of low-fat and low-fat plus high-fiber diets on serum lipid concentrations. Am J Clin Nutr. 1992;56(5):887-94. [pmid: 1329482].
71 Stefanick ML, Mackey S, Sheehan M, et al. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12-20. [pmid: 9647874].
72 Delahanty LM, Sonnenberg LM, Hayden D, et al. Clinical and cost outcomes of medical nutrition therapy for hypercholesterolemia: a controlled trial. J Am Diet Assoc. 2001;101(9):1012-23. [pmid: 11573752].
73 Moy TF, Yanek LR, Raqueño JV, et al. Dietary counseling for high blood cholesterol in families at risk of coronary disease. Prev Cardiol. 2001;4(4):158-64. [pmid: 11832672].
74 Ammerman AS, Keyserling TC, Atwood JR, et al. A randomized controlled trial of a public health nurse directed treatment program for rural patients with high blood cholesterol. Prev Med. 2003;36(3):340-51. [pmid: 12634025].
75 Bloemberg BP, Kromhout D, Goddijn HE, et al. The impact of the guidelines for a healthy diet of the Netherlands Nutrition Council on total and high density lipoprotein cholesterol in hypercholesterolemic free-living men. Am J Epidemiol. 1991;134(1):39-48. [pmid: 1853859].
76 Hyman DJ, Ho KS, Dunn JK, et al. Dietary intervention for cholesterol reduction in public clinic patients. Am J Prev Med. 1998;15(2):139-45. [pmid: 9713670].
77 Johnston HJ, Jones M, Ridler-Dutton G, et al. Diet modification in lowering plasma cholesterol levels. A randomised trial of three types of intervention. Med J Aust. 1995;162(10):524-6. [pmid: 7776913].
78 Neil HA, Roe L, Godlee RJ, et al. Randomised trial of lipid lowering dietary advice in general practice: the effects on serum lipids, lipoproteins, and antioxidants. BMJ. 1995;310(6979):569-73. [pmid: 7888933].
79 van der Veen J, Bakx C, van den Hoogen H, et al. Stage-matched nutrition guidance for patients at elevated risk for cardiovascular disease: a randomized intervention study in family practice. J Fam Pract. 2002;51(9):751-8. [pmid: 12366892].
80 Anderssen SA. Oslo Diet and Exercise Study: a one year randomized intervention trial. Effect on haemostatic variables and other coronary risk factors. Nutr Metab Cardiovasc Dis. 1995;5:189-200.
81 Keyserling TC, Ammerman AS, Davis CE, et al. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135-45. [pmid: 9075448].
82 Stevens VJ, Glasgow RE, Toobert DJ, et al. One-year results from a brief, computer-assisted intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Prev Med. 2003;36(5):594-600. [pmid: 12689805].
83 Tomson Y, Johannesson M, Aberg H. The costs and effects of two different lipid intervention programmes in primary health care. J Intern Med. 1995;237(1):13-7. [pmid: 7830025].
84 Bosworth HB, Olsen MK, Grubber JM, et al. Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009;151(10):687-95. [pmid: 19920269].
85 Janus ED, Best JD, Davis-Lameloise N, et al. Scaling-up from an implementation trial to state-wide coverage: results from the preliminary Melbourne Diabetes Prevention Study. Trials. 2012;13:152. [pmid: 22929458].
86 Kanaya AM, Santoyo OJ, Gregorich S, et al. The Live Well, Be Well Study: a community-based, translational lifestyle program to lower diabetes risk factors in ethnic minority and lower-socioeconomic status adults. Am J Pub Health. 2012;102:1551-8. [pmid: 22698027].
87 Ma J, Yank V, Xiao L, et al. Translating the Diabetes Prevention Program lifestyle intervention for weight loss into primary care: a randomized trial. JAMA Intern Med. 2013;173:113-21. [pmid: 23229846].
88 Vermunt PW, Milder IE, Wielaard F, et al. Lifestyle counseling for type 2 diabetes risk reduction in Dutch primary care: results of the APHRODITE study after 0.5 and 1.5 years. Diabetes Care. 2011;34(9):1919-25. [pmid: 21775759].
89 Knowler WC, Barrett CE, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. New Engl J Med. 2002;346:393-403. [pmid: 11832527].
90 Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001;52(1):29-43. [pmid: 11182214].
91 Penn L, White M, Oldroyd J, et al. Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009;9:342. [pmid: 19758428].
92 Moore SM, Hardie EA, Hackworth NJ, et al. Can the onset of type 2 diabetes be delayed by a group-based lifestyle intervention? A randomised control trial. Psychol Health. 2011;26(4):485-99. [pmid: 20945253].
93 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67(2):152-62. [pmid: 15649575].
94 Ockene IS, Tellez TL, Rosal MC, et al. Outcomes of a Latino community-based intervention for the prevention of diabetes: the Lawrence Latino Diabetes Prevention Project. Am J Pub Health. 2012;102(2):336-42. [pmid: 22390448].
95 Kulzer B, Hermanns N, Gorges D, et al. Prevention of Diabetes Self-Management Program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32(7):1143-6. [pmid: 19509014].
96 Mensink M, Corpeleijn E, Feskens EJ, et al. Study on Lifestyle-Intervention and impaired Glucose Tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61:49-58. [pmid: 12849923].
97 Watanabe M, Yamaoka K, Yokotsuka M, et al. Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. 2003;26(12):3209-14. [pmid: 14633803].
98 Morey MC, Pieper CF, Edelman DE, et al. Enhanced fitness: a randomized controlled trial of the effects of home-based physical activity counseling on glycemic control in older adults with prediabetes mellitus. J Am Geriatr Soc. 2012;60(9):1655-62. [pmid: 22985140].
99 Yates T, Davies M, Gorely T, et al. Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32(8):1404-10. [pmid: 19602539].
100 Tiessen AH, Smit AJ, Broer J, et al. Randomized controlled trial on cardiovascular risk management by practice nurses supported by self-monitoring in primary care. BMC Fam Pract. 2012;13:90. [pmid: 22947269].
101 Lakerveld J, Bot SD, Chinapaw MJ, et al. Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: design of a randomized controlled trial. BMC Endocr Disord. 2008;8:6. [pmid: 18573221].
102 Cochrane T, Davey R, Iqbal Z, et al. NHS health checks through general practice: randomised trial of population cardiovascular risk reduction. BMC Public Health. 2012;12:944. [pmid: 23116213].
103 Harris MF, Fanaian M, Jayasinghe UW, et al. A cluster randomised controlled trial of vascular risk factor management in general practice. Med J Aust. 2012;197:387-93. [pmid: 23025735].
104 Moreau KL, Degarmo R, Langley J, et al. Increasing daily walking lowers blood pressure in postmenopausal women. Med Sci Sports Exerc. 2001;33:1825-31. [pmid: 11689731].
105 van Keulen HM, Mesters I, Ausems M, et al. Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Ann Behav Med. 2011;41(1):104-18. [pmid: 20878293].
106 Wood DA, Kotseva K, Connolly S, et al. Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet. 2008;371:1999-2012. [pmid: 18555911].
107 Toft U, Kristoffersen L, Ladelund S, et al. The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake. The Inter99 study--a randomized controlled trial. Int J Behav Nutr Phys Act. 2008;5:59. [pmid: 19025583].
108 Hayashi T, Farrell MA, Chaput LA, et al. Lifestyle intervention, behavioral changes, and improvement in cardiovascular risk profiles in the California WISEWOMAN project. J Womens Health (Larchmt). 2010;19(6):1129-38. [pmid: 20509780].
109 Murphy SM, Edwards RT, Williams N, et al. An evaluation of the effectiveness and cost effectiveness of the National Exercise Referral Scheme in Wales, UK: a randomised controlled trial of a public health policy initiative. J Epidemiol Community Health. 2012;66(8):745-53. [pmid: 22577180].
110 Keyserling TC, Samuel Hodge CD, Jilcott SB, et al. Randomized trial of a clinic-based, community-supported, lifestyle intervention to improve physical activity and diet: the North Carolina enhanced WISEWOMAN project. Prev Med. 2008;46(6):499-510. [pmid: 18394692].
111 Beckmann SL, Os I, Kjeldsen SE, et al. Effect of dietary counselling on blood pressure and arterial plasma catecholamines in primary hypertension. Am J Hypertens. 1995;8(7):704-11. [pmid: 7546496].
112 Fagerberg B, Wikstrand J, Berglund G, et al. Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens. 1998;11(1 Pt 1):14-22. [pmid: 9504445].
113 Rodriguez MA. Is behavior change sustainable for diet, exercise, and medication adherence?. Diss Abstr Int B Sci Eng. 2012;73(3B):1860.
114 Eakin E, Reeves M, Lawler S, et al. Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med. 2009;36(2):142-9. [pmid: 19062240].
115 Agewall S, Wikstrand J, Samuelsson O, et al. The efficacy of multiple risk factor intervention in treated hypertensive men during long-term follow up. J Intern Med. 1994;236(6):651-9. [pmid: 7989900].
116 Appel LJ, Champagne CM, Harsha DW, et al. Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289:2083-93. [pmid: 12709466].
117 Whelton PK, Appel LJ, Espeland MA, et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). JAMA. 1998;279(11):839-46. [pmid: 9515998].
118 Tuomilehto J, Lindström J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. New Engl J Med. 2001;344:1343-50. [pmid: 11333990].
119 Nilsson PM, Lindholm LH, Schersten BF. Life style changes improve insulin resistance in hyperinsulinaemic subjects: a one-year intervention study of hypertensives and normotensives in Dalby. J Hypertens. 1992;10(9):1071-8. [pmid: 1328367].
120 Bruckert E, Giral P, Paillard F, et al. Effect of an educational program (PEGASE) on cardiovascular risk in hypercholesterolaemic patients. Cardiovasc Drugs Ther. 2008;22(6):495-505. [pmid: 18830810].
121 Babazono A, Kame C, Ishihara R, et al. Patient-motivated prevention of lifestyle-related disease in Japan: a randomized, controlled clinical trial. Dis Manage Health Outcomes. 2007;15(2):119-26.
122 Fortier MS, Hogg W, O'Sullivan TL, et al. Impact of integrating a physical activity counsellor into the primary health care team: physical activity and health outcomes of the Physical Activity Counselling randomized controlled trial. Appl Physiol Nutr Metab. 2011;36(4):503-14. [pmid: 21848444].
123 Elley CR, Kerse N, Arroll B, et al. Effectiveness of counselling patients on physical activity in general practice: cluster randomised controlled trial. BMJ. 2003;326:793. [pmid: 12689976].
124 Uusitupa M, Peltonen M, Lindström J, et al. Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study--secondary analysis of the randomized trial. PLoS One. 2009;4:e5656. [pmid: 19479072].
125 Young DR, Coughlin J, Jerome GJ, et al. Effects of the PREMIER interventions on health-related quality of life. Ann Behav Med. 2010;40:302-12. [pmid: 20799005].
126 Migneault JP, Dedier JJ, Wright JA, et al. A culturally adapted telecommunication system to improve physical activity, diet quality, and medication adherence among hypertensive African-Americans: a randomized controlled trial. Ann Behav Med. 2012;43(1):62-73. [pmid: 22246660].
127 Applegate WB, Miller ST, Elam JT, et al. Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152(6):1162-6. [pmid: 1599343].
128 Arroll B, Beaglehole R. Salt restriction and physical activity in treated hypertensives. N Z Med J. 1995;108(1003):266-8. [pmid: 7637923].
129 Edelman D, Oddone EZ, Liebowitz RS, et al. A multidimensional integrative medicine intervention to improve cardiovascular risk. J Gen Intern Med. 2006;21(7):728-34. [pmid: 16808774].
130 Van Roie E, Delecluse C, Opdenacker J, et al. Effectiveness of a lifestyle physical activity versus a structured exercise intervention in older adults. J Aging Phys Act. 2010;18(3):335-52. [pmid: 20651418].
131 Sluijs EM, Poppel MN, Twisk JW, et al. Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95:1825-31. [pmid: 16186461].
132 Lakerveld J, Bot SD, Chinapaw MJ, et al. Motivational interviewing and problem solving treatment to reduce type 2 diabetes and cardiovascular disease risk in real life: a randomized controlled trial. Int J Behav Nutr Phys Act. 2013;10:47. [pmid: 23597082].
133 Koelewijn-van Loon MS, van der Weijden T, van Steenkiste B, et al. Involving patients in cardiovascular risk management with nurse-led clinics: a cluster randomized controlled trial. CMAJ. 2009;181(12):E267-74. [pmid: 19948811].
134 Muhlhauser I, Sawicki PT, Didjurgeit U, et al. Evaluation of a structured treatment and teaching programme on hypertension in general practice. Clin Exp Hypertens. 1993;15(1):125-42. [pmid: 8467308].
135 Hyman DJ, Pavlik VN, Taylor WC, et al. Simultaneous vs sequential counseling for multiple behavior change. Arch Intern Med. 2007;167(11):1152-8. [pmid: 17563023].
136 Svetkey LP, Pollak KI, Yancy WS Jr, et al. Hypertension Improvement Project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54(6):1226-33. [pmid: 19920081].
137 Kastarinen MJ, Puska PM, Korhonen MH, et al. Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20(12):2505-12. [pmid: 12473876].
138 Burke V, Beilin L, Cutt H, et al. A lifestyle program for treated hypertensives improves cardiovascular risk factors: a randomized controlled trial. J Clin Epidemiol. 2007;60(2):133-41. [pmid: 17208119].
139 Ter Bogt NC, Bemelmans WJ, Beltman FW, et al. Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37(4):270-7. [pmid: 19765497].
140 Wister A, Loewen N, Kennedy-Symonds H, et al. One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk. CMAJ. 2007;177(8):859-65. [pmid: 17923653].
141 Kallings LV, Sierra JJ, Fisher RM, et al. Beneficial effects of individualized physical activity on prescription on body composition and cardiometabolic risk factors: results from a randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2009;16(1):80-4. [pmid: 19237997].
142 Burke V, Beilin LJ, Cutt HE, et al. Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23:1241-9. [pmid: 15894901].
143 Svetkey LP, Erlinger TP, Vollmer WM, et al. Effect of lifestyle modifications on blood pressure by race, sex, hypertension status, and age. J Human Hypertens. 2005;19:21-31. [pmid: 15385946].
144 Broekhuizen K, van Poppel MN, Koppes LL, et al. A tailored lifestyle intervention to reduce the cardiovascular disease risk of individuals with familial hypercholesterolemia (FH): design of the PRO-FIT randomised controlled trial. BMC Public Health. 2010;10:69. [pmid: 20156339].
145 Burke V, Beilin LJ, Cutt HE, et al. Moderators and mediators of behaviour change in a lifestyle program for treated hypertensives: a randomized controlled trial (ADAPT). Health Educ Res. 2008;23:583-91. [pmid: 17890759].
146 Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22(12):1695-703. [pmid: 17922167].
147 Lin PH, Yancy WS Jr, Pollak KI, et al. The influence of a physician and patient intervention program on dietary intake. J Acad Nutr Diet. 2013;113(11):1465-75. [pmid: 23999279].
148 Anderssen S, Holme I, Urdal P, et al. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4(6):343-9. [pmid: 8746601].
149 Roumen C, Feskens EJ, Corpeleijn E, et al. Predictors of lifestyle intervention outcome and dropout: the SLIM study. Eur J Clin Nutr. 2011;65(10):1141-7. [pmid: 21587283].
150 Ammerman A, Pignone M, Fernandez L, et al. Counseling to Promote a Healthy Diet. Systematic Evidence Review No. 18. Rockville, MD. Agency for Healthcare Research and Quality. 2002. [pmid: 20722113].
151 Eden KB, Orleans CT, Mulrow CD, et al. Clinician Counseling to Promote Physical Activity. Systematic Evidence Review No. 9. Rockville, MD. Agency for Healthcare Research and Quality. 2002. [pmid: 20722178].
152 Baker MK, Simpson K, Lloyd B, et al. Behavioral strategies in diabetes prevention programs: a systematic review of randomized controlled trials. Diabetes Res Clin Pract. 2011;91(1):1-12. [pmid: 20655610].
153 Gillett M, Royle P, Snaith A, et al. Non-pharmacological interventions to reduce the risk of diabetes in people with impaired glucose regulation: a systematic review and economic evaluation. Health Technol Assess. 2012;16(33):1-236. [pmid: 22935084].
154 Hopper I, Billah B, Skiba M, et al. Prevention of diabetes and reduction in major cardiovascular events in studies of subjects with prediabetes: meta-analysis of randomised controlled clinical trials. Eur J Cardiovasc Prev Rehabil. 2011;18(6):813-23. [pmid: 21878448].
155 Schellenberg ES, Dryden DM, Vandermeer B, et al. Lifestyle interventions for patients with and at risk for type 2 diabetes: a systematic review and meta-analysis. Ann Intern Med. 2013;159(8):543-51. [pmid: 24126648].
156 Ebrahim S, Taylor F, Ward K, et al. Multiple risk factor interventions for primary prevention of coronary heart disease. Cochrane Database Syst Rev. 2011;(1):CD001561. [pmid: 21249647].
157 Law MR, Wald NJ, Thompson SG. By how much and how quickly does reduction in serum cholesterol concentration lower risk of ischaemic heart disease?. BMJ. 1994;308(6925):367-72. [pmid: 8043072].
158 Cook NR, Cutler JA, Obarzanek E, et al. Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the Trials of Hypertension Prevention (TOHP). BMJ. 2007;334(7599):885-8. [pmid: 17449506].
159 MacMahon S, Peto R, Cutler J, et al. Blood pressure, stroke, and coronary heart disease, 1: prolonged differences in blood pressure: prospective observational studies corrected for the regression dilution bias. Lancet. 1990;335(8692):765-74. [pmid: 1969518].
160 Jensen MD, Ryan DH, Apovian CM, et al. 2013 AHA/ACC/TOS guideline for the management of overweight and obesity in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Obesity Society. J Am Coll Cardiol. 2014;63(25 Pt B):2985-3023. [pmid: 24239920].
161 Danaei G, Ding EL, Mozaffarian D, et al. The preventable causes of death in the United States: comparative risk assessment of dietary, lifestyle, and metabolic risk factors. PLoS Med. 2009;6(4):e1000058. [pmid: 19399161].
162 U.S. Department of Health and Human Services. 2008 Physical Activity Guidelines for Americans. Washington, DC. U.S. Department of Health and Human Services. 2008. Accessed at http://www.health.gov/paguidelines/pdf/paguide.pdf. 22 July 2014.
163 Sattelmair J, Pertman J, Ding EL, et al. Dose response between physical activity and risk of coronary heart disease: a meta-analysis. Circulation. 2011;124(7):789-95. [pmid: 21810663].
164 Garber CE, Blissmer B, Deschenes MR, et al. American College of Sports Medicine position stand. Quantity and quality of exercise for developing and maintaining cardiorespiratory, musculoskeletal, and neuromotor fitness in apparently healthy adults: guidance for prescribing exercise. Med Sci Sports Exerc. 2011;43(7):1334-59. [pmid: 21694556].
165 Zheng H, Orsini N, Amin J, et al. Quantifying the dose-response of walking in reducing coronary heart disease risk: meta-analysis. Eur J Epidemiol. 2009;24(4):181-92. [pmid: 19306107].
166 U.S. Department of Health and Human Services. 2008 Physical Activity Guidelines for Americans Summary. Washington, DC. U.S. Department of Health and Human Services. 2014. Accessed at http://www.health.gov/paguidelines/guidelines/summary.aspx. 22 July 2014.
167 Murphy S, Raisanen L, Moore G, et al. A pragmatic randomised controlled trial of the Welsh National Exercise Referral Scheme: protocol for trial and integrated economic and process evaluation. BMC Public Health. 2010;10:352. [pmid: 20565846].
168 Hardcastle S, Taylor A, Bailey M, et al. A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Educ Counsel. 2008;70(1):31-9. [pmid: 17997263].
169 Michie S, Abraham C, Whittington C, et al. Effective techniques in healthy eating and physical activity interventions: a meta-regression. Health Psychol. 2009;28(6):690-701. [pmid: 19916637].
170 Greaves CJ, Sheppard KE, Abraham C, et al. Systematic review of reviews of intervention components associated with increased effectiveness in dietary and physical activity interventions. BMC Public Health. 2011;11:119. [pmid: 21333011].
171 Zaza S, Lawrence RS, Mahan CS, et al. Scope and organization of the Guide to Community Preventive Services. Am J Prev Med. 2000;18(1 Suppl):27-34. [pmid: 10806977].
172 Look AHEAD Research Group. Wing RR, Bolin P, et al. Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. New Engl J Med. 2013;369(2):145-54. [pmid: 23796131].
173 Rodriguez Cristobal JJ, Alonso-Villaverde GC, Trave MP, et al. Randomised clinical trial of an intensive intervention in the primary care setting of patients with high plasma fibrinogen in the primary prevention of cardiovascular disease. BMC Res Notes. 2012;5:126. [pmid: 22381072].
174 Keyserling TC, Ammerman AS, Atwood JR, et al. A cholesterol intervention program for public health nurses in the rural southeast: description of the intervention, study design, and baseline results. Public Health Nurs. 1999;16(3):156-67. [pmid: 10388332].
175 Tomson Y, Aberg H. Risk factors for cardiovascular disease--a comparison between Swedes and immigrants. Scand J Prim Health Care. 1994;12(3):147-54. [pmid: 7997691].
176 Kallings LV. Physical Activity on Prescription: Studies on Physical Activity Level, Adherence, and Cardiovascular Risk Factors [Dissertation]. Stockholm. Karolinska Institutet. 2008. Accessed at http://diss.kib.ki.se/2008/978-91-7409-111-3/thesis.pdf. 22 July 2014.