# Discussion

## Summary of Evidence

We conducted this systematic review to assist the USPSTF in updating its previous recommendations on physical activity and healthy diet counseling.55,150,151 This review focused on the effectiveness and harms of primary care–relevant diet and physical activity counseling interventions in persons with CVD risk factors. We included 74 unique trials that met our inclusion criteria, the vast majority of which (k=51) were published since the previous USPSTF recommendations in 2002.

Based on a large body of evidence (k=71), we found that intensive combined lifestyle counseling in persons with CVD risk factors reduced cholesterol, blood pressure, measures of weight, glucose, and diabetes incidence at 12 to 24 months (Table 25). Effects of counseling interventions (k=61) on objectively measured or self-reported behavioral outcomes were generally consistent with findings on intermediate health outcomes. We found more limited information about longer-term benefits. Benefits on blood pressure, measures of weight, and glucose reduction appear to persist after 24 months, but are based on only a small subset of trials with longer-term followup. Reduction in diabetes incidence appears to persist for 3 to 4 years. Several trials evaluated a diet-only counseling message. Intensive diet-only counseling in persons with dyslipidemia also reduced cholesterol. Both medium- and high-intensity interventions reduced lipids, blood pressure, and measures of weight. High-intensity interventions reduced glucose and diabetes incidence. In general, effective counseling interventions were intensive and involved several hours (median, 13 hours [IQR, 9 to 19 hours]), over several contacts (median, 8 contacts [IQR, 5 to 16 contacts]), over several months duration (median, 12 months [IQR, 6 to 12 months]). We found more limited information about physical activity–only counseling interventions. Mostly medium-intensity physical activity–only counseling in persons with CVD risk factors did not appear to have consistent benefits on intermediate health outcomes, but trials were quite heterogeneous in populations studied, interventions evaluated, and outcomes measured. While findings were mixed for physical activity–only counseling interventions, the limited number of studies and heterogeneity across trials limits our ability to make any definitive conclusions about the benefits, or lack thereof, of these types of counseling interventions. Four of the five physical activity–only counseling trials that reported outcomes at 12 to 24 months, however, found statistically significant improvements in self-reported measures of physical activity.98,99,109,123

Table 25 Overall Summary of Evidence by Key Question

Trials (k), Participants (n) | Overall quality | Consistency | Applicability | Summary of findings
Key Question 1. Health outcomes
k=16 n=7,053 | Fair: sparse reporting of health outcomes or use of clinically important self-reported health outcomes (i.e., QOL); generally low CVD event rates; variation in QOL instruments used | Generally consistent findings of no benefit on reduction of CVD events, mixed findings for benefit on QOL | Persons with any number of CVD risk factors, no major limitations in populations studied; mainly high-intensity combined lifestyle counseling interventions | Generally no reduction in CVD events (including mortality) at 6 to 79 months and at 10 years (k=4); no reduction in depression symptoms at 6 to 12 months (k=4); mixed findings on self-reported measures of QOL at 6 to 12 months (k=7). One earlier trial found a reduction in CVD events at 6.6 years (RR, 0.71 [95% CI, 0.51 to 0.99]) using a high-intensity intervention including a protocol to initiate medication in Swedish men at high risk for CVD (including 29% smokers, 22% with diabetes).
Key Question 2. Intermediate outcomes
k=71 n=32,734 | Fair to good: high statistical heterogeneity for fasting glucose and weight outcomes; sparse reporting of outcomes beyond 24 months; limited number of trials with significant clinical heterogeneity among physical activity–only counseling trials | Consistent findings of benefit across intermediate health outcomes; trials not included in meta-analyses generally consistent with trials that could be included | Persons with any number of CVD risk factors, no major limitations in populations studied. Medium- to high-intensity combined lifestyle counseling; diet-only counseling mostly in persons with dyslipidemia not yet taking medications | Across all trials reporting each specific outcome, at 12 to 24 months, overall reduction in:; - Total cholesterol (k=34) by 4.48 mg/dL (95% CI, 6.36 to 2.59); - LDL cholesterol (k=25) by 3.43 mg/dL (95% CI, 5.37 to 1.49); - SBP (k=31) by 2.03 mm Hg (95% CI, 2.91 to 1.15); - DBP (k=24) by 1.38 mm Hg (95% CI, 1.92 to 0.84); - Fasting glucose (k=22) by 2.08 mg/dL (95% CI, 3.29 to 0.88); - Diabetes incidence (k=8) by RR of 0.58 (95% CI, 0.37 to 0.89); - Weight outcomes (k=34) by SMD of 0.26 (95% CI, 0.35 to 0.16); Overall evidence for longer-term (>24 months) findings are limited, except for reduction in diabetes incidence in persons with impaired fasting glucose or glucose tolerance (k=5) (RR, 0.55 [95% CI, 0.45 to 0.67]). No consistent finding of benefit on intermediate health outcomes for physical activity–only counseling interventions.
Key Question 3. Behavioral outcomes
k=61 n=31,751 | Fair: heterogeneity in dietary and physical activity outcome measures, mainly use of self-reported outcomes | Generally consistent with intermediate outcome findings | Persons with any number of CVD risk factors, no major limitations in populations studied. Medium- to high-intensity combined lifestyle counseling and diet-only counseling | Generally findings of improvement, or lack of improvement, in behavioral outcomes consistent with findings on intermediate health outcomes. Overall improved dietary intake and physical activity outcomes in trials of persons taking lipid- or blood pressure-lowering medications, which did not demonstrate a benefit on intermediate health outcomes (k=6). Trials only reporting behavioral outcomes (no intermediate outcomes) found small but statistically significant improvements in diet (fat, saturated fat, fiber, fruits/vegetables) and total physical activity (∼35–50 minutes more per week) at 12 to 18 months (k=3).
Key Question 4. Adverse effects
k=10 n=6,381 | Fair: sparse reporting of harms | Generally consistent findings of no significant harms | Finding of serious harm applicable to high-intensity physical activity counseling in older adult VA population | Generally no findings of serious harms (i.e., requiring unexpected or unwanted medical attention), except in one trial (n=302) targeting older adults (2 persons with serious adverse events attributed to physical activity). Generally no findings of paradoxical changes in intermediate or behavioral outcomes. Increased self-reported carbohydrate intake accompanied by dietary improvements in fat/saturated fat, fiber, fruits/vegetables without an overall increase in energy intake (k=9).

Only a small subset of trials (k=16) reported patient health outcomes, which prevented us from drawing any definitive conclusions as to whether these types of interventions can decrease CVD events or improve QOL.85,86,89,92,94,95,98,110,115-122 Overall, there does not appear to be a significant reduction in CVD events in the long term, but event rates in these trials, even after 10 years of followup, are generally quite low. Findings of benefit on self-reported QOL measures were mixed. Likewise, only a small subset of trials (k=10) reported on harms of counseling interventions, but overall we found no serious harms, with the exception of two adverse events in one physical activity counseling intervention aimed at older adults.89,94,98,113,114,116,117,123,130,138,146 There are surprisingly few current existing systematic reviews addressing the effectiveness or harms of lifestyle behavioral counseling in persons with traditional CVD risk factors. Most recent reviews of lifestyle counseling interventions focus on obesity management or CVD prevention in populations with known diabetes and/or coronary heart disease. Our review found a similar reduction in progression to diabetes as in existing systematic reviews examining the effectiveness of these types of interventions to prevent diabetes in persons with impaired fasting glucose or glucose intolerance.152-155 Our review found a similar reduction in blood pressure and cholesterol as a Cochrane review of multiple risk factor interventions for the primary prevention of CVD by Ebrahim and colleagues.156 The Cochrane review, however, also found a decrease in mortality, primarily due to the inclusion of trials of early CVD prevention. Given the applicability of many earlier trials to current understanding and management of CVD risk, as well as trends in the distribution of CVD and its risk factors over time, our review was restricted to trials published after 1990.

## Clinical Interpretation of Benefit and Harms Given Paucity of Direct Health Outcome Data

### Effects on Lipids and Blood Pressure

Medium- to high-intensity combined lifestyle or diet-only counseling interventions decreased total cholesterol by approximately 3 to 8 mg/dL and decreased LDL cholesterol by approximately 1.5 to 6 mg/dL at 12 to 24 months. Based on observational data, a 10 percent reduction (approximately 20 mg/dL) in total cholesterol is associated with a decreased incidence of CAD by approximately 54 percent at age 40 years, 39 percent at age 50 years, and 27 percent at age 60 years.157 Although plausible, it is still unclear if smaller reductions in cholesterol can also translate into reductions in CAD or CVD events.

Medium- to high-intensity combined lifestyle interventions can decrease SBP and DBP by approximately 1 to 3 and 1 to 2 mm Hg, respectively, at 12 to 24 months. Long-term observational followup of Trials of Hypertension Prevention I and II (n=3,126) showed that persons with prehypertension who were initially randomized to receive intensive lifestyle counseling had decreased composite CVD events over 10 to 15 years (HR, 0.70 [95% CI, 0.53 to 0.94]), suggesting that small reductions in blood pressure (i.e., approximately 2 mm Hg reduction in SBP and 1 mm Hg reduction in DBP) seen in the original Trials of Hypertension Prevention may result in longer-term reduction in CVD morbidity and mortality.158 Epidemiologic data also suggest that small changes in blood pressure (i.e., 2 mm Hg reduction in SBP) are associated with a decreased risk for CAD by 6 percent or cerebrovascular accident by 16 percent.159

### Effects on Glucose and Diabetes Incidence

Medium- to high-intensity combined lifestyle counseling interventions decreased fasting glucose and diabetes incidence. The reduction in fasting glucose across all 18 trials reporting this outcome was approximately 0.5 to 3.5 mg/dL at 12 to 24 months. Fewer trials (k=8) reported diabetes incidence at 12 to 24 months; these trials were generally high-intensity combined lifestyle counseling interventions aimed at persons with impaired fasting glucose or glucose tolerance. In the long term (>24 months), the overall pooled estimate of RR for high-intensity combined lifestyle counseling was 0.61 (95% CI, 0.46 to 0.79). In DPP, for example, fasting blood glucose was approximately 4 mg/dL lower in the intensive lifestyle counseling group than the control group at 3 years, which corresponded to 14.4 percent of persons developing diabetes in the intervention group compared with 28.9 percent in the control group (number needed to treat [NNT], about 7 [95% CI, 5 to 10]). The lifestyle intervention was more effective than metformin alone in reducing diabetes incidence (results were 39% lower [95% CI, 24 to 51]). Even in populations with lower rates of progression to diabetes than DPP, one would not have to intensively counsel many individuals to prevent a single case of diabetes mellitus. If only 10 percent of persons in the control group progress to diabetes over 3 to 6 years, for example, then the NNT would be 26 (95% CI, 19 to 48); if 20 percent of persons progress to diabetes, then the NNT would be 13 (95% CI, 9 to 24); if 25 percent of persons progress to diabetes, then the NNT would be 10 (95% CI, 7 to 19); and if 33 percent of persons progress to diabetes, then the NNT would be 8 (95% CI, 6 to 14).

### Effects on Weight Outcomes

Medium- to high-intensity combined lifestyle counseling interventions also decreased weight outcomes by a standardized effect size of 0.24 (95% CI, 0.35 to 0.14) at 12 to 24 months. The statistical heterogeneity for this pooled effect was very high, however, and therefore should be interpreted with caution. Overall, this represents a small effect in weight reduction. When this effect size is back translated into individual trials, the effect is approximately equivalent to a 2- to 3-kg weight loss or 0.5- to 1.5-kg/m^2^ decrease in BMI. These results are generally consistent with the small effects found in a recent systematic review of behavioral treatment of adult obesity. This review found that behavioral treatment resulted in an average of 3 kg of weight loss in the intervention versus control groups.57 Our findings are also consistent with the 2013 AHA/ACC/Obesity Society Guideline for the Management of Overweight and Obesity in Adults, which found strong evidence to support the association of sustained weight loss of 3 to 5 percent and clinically meaningful reductions in triglycerides and glucose outcomes.160 Epidemiological data also suggest that the risk for both CVD and diabetes increases with each kg/m^2^ unit change in BMI.161 However, it is still unclear if small sustained reductions in weight or BMI after the intervention's conclusion translate into better cardiovascular patient health outcomes (i.e., decreased CVD events and/or mortality from CVD or diabetes). The clinical significance of changes in weight measures should therefore primarily be based on accompanying changes in lipid, blood pressure, and glucose outcomes.

### Effects on Increases in Self-Reported Physical Activity

Medium-intensity physical activity–only counseling trials generally found no effect on intermediate health outcomes at 12 to 24 months. Four of the five counseling trials that reported behavioral outcomes at 12 to 24 months found statistically significant improvements in physical activity in the intervention versus control groups.98,99,109,123 These trials used different measures of physical activity and found a 10 to 25 percent increase in the percentage of persons who met the recommended 150 minutes per week of moderate-intensity exercise (k=2)98,123 and an approximate 35-minute/week increase in moderate or total physical activity (k=2).99,109 This increase in the amount of physical activity per week is similar to findings in our previous review in adults without cardiovascular risk factors.55 It is clear that increased physical activity is associated with a decrease in CVD events and mortality.162 Based on a meta-analysis by Stattelmair and colleagues of 33 observational studies to determine the dose-response between levels of physical activity and risk for CAD, it appears that persons who had 150 minutes per week of physical activity had a 14 percent lower CAD risk. Persons who were physically active at levels lower than recommended also had statistically significant lower risk.163 This finding supports the 2008 Physical Activity Guidelines for Americans and the American College of Sports Medicine recommendations for 150 minutes per week of moderate-intensity exercise, with the caveat that adults who are unable or unwilling to meet this goal still benefit from engaging in amounts of exercise less than recommended.162,164 Another review by Zheng and colleagues of 12 studies to quantify the dose-response between walking and CVD risk found that an increase of approximately 30 minutes per week was associated with a 19 percent lower CAD risk.165 Based on extrapolation from observational studies, it is likely that even a modest increase in the percentage of persons meeting a recommended 150 minutes per week of moderate-intensity activity or a modest increase in total or moderate-intensity activity per week can lower incidence of CAD and CAD events.

### Adverse Effects

We did not a priori hypothesize any serious harms for counseling intervention. Overall, a limited number of trials reported on adverse effects of interventions and only one trial in older adults found two events of serious harms resulting from physical activity.98 Observational studies from our previous systematic review of lifestyle counseling interventions suggest an increased risk for serious cardiac events during vigorous physical activity, primarily in persons with low levels of habitual activity.55 The absolute risk for serious cardiac events related to physical activity, however, appears to be extremely small. In these observational studies, minor musculoskeletal injuries were fairly common when participants increased their physical activity from their habitual levels. The type and total amount of activity and relative change in activity were all important factors in determining the risk for injury. Noncontact, low-impact activities had lower injury rates, including walking, bicycling, and swimming. Increasing physical activity in a series of small increments, each followed by an adaptation period, resulted in lower rates of injury.166 Additional information regarding harms of physical activity are detailed in the DHHS 2008 report on physical activity.166 Therefore, focusing on low-impact activities and increasing activity in small increments can mitigate serious harm or injury from counseling interventions in older adults or persons at high risk for injury.

## Considerations for Applicability of Findings

### Population Considerations

Our review's findings are widely applicable to a broad range of individuals with CVD risk factors, including dyslipidemia, hypertension, impaired fasting glucose, glucose intolerance, metabolic syndrome, obesity, and smoking. Our review did not include trials conducted exclusively in persons with diabetes or in populations selected exclusively for obesity. Nearly all trials included persons who were overweight or obese. Several trials also included some persons who were already diagnosed with diabetes. Included trials also involved persons who had not yet started antihypertension or lipid-lowering medications, as well as those already taking them. Although included trials provided little direct evidence of comparisons of findings between the two sexes and across different age or racial/ethnic groups, we have no reason to believe that the benefit of intensive counseling would not apply to both men and women, middle-aged and older adults, and nonwhite subpopulations (namely African and Latino Americans), given the fair representation of these groups across included trials. Serious harms from increased physical activity were reported in one trial in older adults. As such, older adults may be at increased risk for adverse events, but very sparse reporting of harms limits any definitive conclusions about harms, much less differential harms between subpopulations.

Trials varied in their recruitment strategies, the restrictiveness of the eligibility criteria, and recruitment and retention rates. Of the trials with adequate reporting about recruitment methods, 16 trials relied on volunteers as part (k=8) or all (k=8) of their recruitment strategy. Most trials had eligibility criteria excluding persons with acute medical conditions or any known serious medical conditions. The proportion of trial participants out of the entire eligible sample ranged from 15 to 100 percent (k=53). The majority of trials had very high recruitment rates, with only 10 trials having less than 50 percent of eligible participants randomized into the trial. Overall, retention rates in the trials were greater than 80 percent. Sixteen trials had retention rates less than 80 percent. Trials with volunteer participants, restrictive eligibility criteria, low recruitment rates, and/or high retention rates likely overestimate the true magnitude of benefit of these counseling interventions in real-world settings.

### Intervention Considerations

Effective interventions were medium- to high-intensity combined lifestyle or diet-only counseling interventions. Medium-intensity interventions are defined as greater than 30 minutes up to 360 minutes of contact. Approximately two thirds of the medium-intensity interventions had 120 minutes of contact time or greater; the median number of contacts was five and median duration of the intervention was 9 months. Diet-only and physical activity–only counseling interventions were mostly medium-intensity. High-intensity interventions had greater than 360 minutes of contact; the median number of contacts was 16 and median duration of the intervention was 12 months. Specially trained individuals delivered these interventions, including dietitians or nutritionists, physiotherapists or exercise professionals, as well as health educators, nurses, or psychologists.

Counseling interventions generally focused on behavioral change and could include cointerventions. Ten trials explicitly reported medication adjustment or counseling on medication adherence as part of the intervention protocol. In one of these 10 trials, the intervention protocol for medication adjustment focused on withdrawal or tapering off of antihypertension medications.117 Several trials explicitly stated provision of free or low-cost access to exercise classes (although supervised exercise was not mandatory). Only two trials reported provision of financial incentives for participation, and two other trials offered some provision of free food to intervention participants (but were not considered to be feeding trials). Adherence, and therefore effectiveness, in trials may be higher than in real-world practice, especially for higher-intensity interventions. Unfortunately, measures of adherence and fidelity were not consistently reported in included trials. Thirty-three of the 74 trials reported adherence.72-74,76,77,80-82,84,86,87,89,90,92,94,98,99,105,107,114,116,118,122,127,129,130,132-134,137,146,167,168 Adherence in the 13 trials that reported the proportion of participants who attended all of the sessions ranged from 50 to 95 percent.74,77,81,84,87,91,116,122,127,129,130,137,167 Adherence in the seven trials that reported the proportion of participants who received any intervention ranged from 46 to 99 percent.72,82,86,99,105,133,134

Based on included trials, we are not able to define the minimum necessary counseling components for an effective intervention. All included counseling interventions involved more than didactic education alone. Most of these trials included audit and feedback (including self-monitoring), problem solving skills, and individualized care plans. Using qualitative analyses and meta-regressions, we did not find that the intervention format (e.g., face-to-face, group, individual, phone), the person delivering the counseling, the number of sessions, or the duration of intervention significantly affected the direction or magnitude of benefit. Based on a meta-analysis by Michie and colleagues of combined lifestyle counseling interventions specifically using meta-regressions to examine a number of a priori–specified intervention components, it appears that interventions with “self-monitoring” and use of at least one “self-regulatory technique” derived from control theory (i.e., prompt intention formation, prompt specific goal setting, provide feedback on performance, prompt self-monitoring behavior, prompt review of behavioral goals) were significantly more effective than interventions not including these components.169 This review found that the duration of the intervention, the person delivering the counseling, the intervention format (i.e., individual vs. group), the study setting, the number of included sessions, or the number of behavior change techniques employed did not distinguish between effective and ineffective interventions. Greaves and colleagues conducted a systematic review of existing reviews of diabetes prevention lifestyle counseling and found that interventions that targeted both diet and physical activity, mobilized social support, used well-established behavior change techniques, used self-regulatory techniques (i.e., goal setting, self-monitoring, feedback on performance, and goal review), and had greater contact time or frequency of contact had greater effectiveness.170 The review by Greaves and colleagues did not identify a minimum threshold of time/intensity that was effective and did not find any clear associations between intervention effectiveness and the person delivering counseling, the study setting, or the intervention format.

## Review Limitations

Eating a healthy diet and increasing physical activity clearly have health benefits beyond CVD prevention and CVD risk factor modification. To support the USPSTF recommendation process, however, our review focused narrowly on the primary prevention of CVD in persons with risk factors for CVD. Therefore, we excluded persons with known diabetes, coronary heart disease, cerebrovascular disease, peripheral artery disease, and chronic kidney disease. We previously conducted a similar review of behavioral counseling interventions for the primary prevention of CVD focused on unselected populations and persons without known risk factors, as well as a review on the management of adult obesity, which included behavioral interventions.55,57 Therefore, this systematic review represents only a subset of a much larger body of literature on diet and physical activity counseling interventions in other populations and similar interventions with different specific aims (i.e., to prevent other diseases [e.g., cancer] or conditions [e.g., falls/disability]). Our review also focused on interventions that were relevant to primary care (i.e., those that could be conducted in or referred from primary care). Therefore, our review excluded behavioral interventions delivered through worksites, schools, and community organizations (e.g., churches); for these, we refer the reader to the CDC's Community Preventive Services Task Force.171 Additionally, we limited included studies of effectiveness to fair- to good-quality randomized, controlled trials or controlled clinical trials conducted in developed countries so as to identify the evidence with the least risk for bias and the highest applicability to current U.S. practice. We only included studies published after 1990. We also excluded trials without a true control arm (e.g., usual care, minimal intervention, attention control, wait list control). As a result, we did not address literature addressing the comparative effectiveness of different types of behavioral counseling and intervention elements.

We categorized and pooled clinically heterogeneous interventions and lengths of followup in order to synthesize the evidence. We categorized length of followup into short (<12 months), intermediate (12 to 24 months), and long (>24 months). We pooled outcomes according to these categorizations. Likewise, we categorized interventions by intensity (minutes of persons-contact) rather than total number of, or duration of contacts. While this categorization scheme is consistent with the definitions of intensity used in our previous work supporting the USPSTF healthy lifestyle counseling recommendation, it is somewhat arbitrary, and some “medium-intensity” interventions were still quite intensive (in terms of minutes, frequency, and duration of contacts). Furthermore, because of limitations in reporting of intervention characteristics in the published literature, we had to estimate the duration of contacts in several instances. Our assumptions in these instances, however, would not change the overall categorization of intensity (low, medium, high). Therefore, we use gross categorizations of “intensity” rather than report actual minutes of contact.

There were also limitations posed by the quantitative pooling of results. Of the 71 trials, only 14 trials could not be included in meta-analyses because of limitations in reporting at the primary study level (e.g., no measure of dispersion). Of the data included in the meta-analyses, some degree of calculation was necessary to include the trials in the meta-analyses, although only a small percentage required statistical judgment. These calculations included determining that an abnormally small value reported as a standard deviation was actually a standard error and estimating the correlation between baseline and followup values in order to calculate the standard deviation of the change score. In these instances, we erred on the side of avoiding a type I error or overestimation of effect size.

We purposefully pooled across a clinically heterogeneous body of counseling literature. For most outcomes, the statistical heterogeneity was moderate and, therefore, was still reasonable to allow for the interpretation of pooled estimates. Given the clinical heterogeneity and our use of random-effects analyses, confidence interval estimates should be primarily used to understand the magnitude of effects on the individual outcomes. There was considerable statistical heterogeneity for fasting blood glucose and weight outcomes. As a result, one should interpret pooled estimates with caution. Likewise, we believe the clinical significance of the overall reduction in weight across trials should be interpreted in the context of the accompanying reductions in lipids, blood pressure, and measures of glucose. Despite examining for a number of factors that may explain for the heterogeneity of findings across trials, we were unable to identify additional population, intervention, or study characteristics that explained the statistical heterogeneity in pooled analyses (other than at a gross level of population targeted and intervention type).

Other potential sources of risk for bias in our review includes limiting the search to English-only publications, only including published trials, potential selective reporting of outcomes, and including trials that used volunteer participants. Egger's statistical test for small-study effects was significant only for triglyceride outcomes, which we do not discuss at length.

## Study Limitations and Future Research Needs

Behavioral counseling to prevent CVD is a very active field of research and numerous trials in persons at risk for CVD are currently underway (Appendix B). Despite a very large body of trial evidence, well-conducted trials (and funding for these trials) are still needed to understand the full impact of these behavioral interventions on important health outcomes. Additional studies should also determine if less-intensive interventions are as effective as higher-intensity counseling.

While medium- to high-intensity combined lifestyle and diet-only interventions are effective, many of the high-intensity interventions would require resources that are not currently available or paid for in the current health system (and real-world patient adherence to intensive counseling may be considerably lower than in included trials). Additional research on how best to disseminate and implement these types of intensive behavioral counseling interventions into current practice is needed. Details on the fidelity of and adherence to counseling interventions should be routinely reported to better understand the applicability of behavioral counseling trial findings. We found a wide range of intensity for effective interventions, from a couple hours to greater than 30 hours of contact time. Future research should also evaluate if lower-intensity counseling interventions (e.g., a couple hours) are as effective as higher-intensity counseling (e.g., DPP) or if there is a minimum intensity, frequency, or duration of contact that could still improve lipids, blood pressure, and diabetes incidence. Evaluating true low-intensity interventions may not be feasible given that the standard of care for persons with CVD risk factors is at least minimal counseling. Future research on different modalities that require minimal health care resources (i.e., technology-based counseling), and therefore “lower the intensity” of interventions, is advisable.

It is clear that healthy diet and physical activity behaviors both contribute to good cardiovascular and overall health. Additional research on the additive or differential benefit of different counseling messages (i.e., diet, physical activity, or both) in different populations would be helpful in determining whether clinical scenarios focusing on diet or physical activity alone is advisable (or preferable) to combined lifestyle counseling.

Only a limited number of trials (k=11) reported followup beyond 24 months.69,89,91,93,107,115,117,118, 138,139,149 While it is clear that high-intensity counseling interventions can reduce diabetes incidence in the long term, additional trials are needed to determine if beneficial effects of reductions in other important intermediate health outcomes are reproducible in the longer term. Many of the trials that had longer-term followup were high-intensity interventions with ongoing maintenance sessions throughout the trial period. Therefore, relatively little is known about the maintenance of beneficial physiologic (or behavior) change after an active intervention ends. Trials evaluating lower-intensity interventions rarely report longer-term outcomes. If additional evidence supports the effectiveness of low- to medium-intensity interventions, longer-term followup for these interventions would also help us understand the benefits of these interventions.

Given the progress of medical care and other factors, CVD events are relatively low. Therefore, the sample sizes and length of followup for counseling trials are likely to be prohibitively large or long if powered to detect differences in CVD outcomes. For example, the Look AHEAD (Action for Health in Diabetes) trial (n=5,145) that evaluated a high-intensity lifestyle intervention in overweight or obese persons with diabetes found no reduction in the rate of CVD events at about 10 years despite reductions in intermediate health outcomes (i.e., weight, glucose) and improvements in physical activity levels.172 Self-reported patient outcomes, namely health-related QOL measures, are in fact health outcomes (i.e., can be experienced by the patient) and are underutilized in this body of literature. Future research would benefit from measuring and consistently reporting QOL and related self-reported patient outcomes.

Given the mixed findings for physical activity–only counseling trials, future research replicating successful physical activity–only counseling interventions would help us determine if such types of counseling interventions work and the populations these interventions should target. Physical activity–only counseling trials were generally of lower intensity than other included trials. Future research on the effectiveness of higher-intensity counseling interventions, especially in persons with CVD risk factors, is advisable. We primarily found evidence of increases in self-reported measures of physical activity. Greater use of objective measures to assess physical activity (i.e., step counts using pedometers, V0_2_max to measure cardiorespiratory fitness) would corroborate self-reported changes in physical activity level, which is especially important when the changes in magnitude are small.

## Conclusions

In general, medium- to high-intensity diet and physical activity behavioral counseling in persons with CVD risk factors resulted in consistent improvements across a variety of important cardiovascular intermediate health outcomes, including total and LDL cholesterol, blood pressure, glucose, and weight outcomes up to 2 years. Overall, high-intensity combined lifestyle counseling can reduce diabetes incidence at 3 to 4 years. The applicability of intensive counseling interventions depends largely on their availability and real-world adherence to these interventions. Very limited evidence exists on health outcomes or harmful effects of these counseling interventions. Extrapolating from other bodies of literature, the improvements we observed in intermediate health outcomes could translate into long-term reduction in CVD events. It is unlikely that intensive counseling interventions have serious patient harms. Future research on behavioral counseling in this population should focus on the effectiveness of lower-intensity interventions and should consistently include self-reported measures of health-related QOL.