# Results

## Description of Included Studies

We included 74 fair- to good-quality healthy lifestyle counseling trials in persons with cardiovascular risk factors that met our inclusion criteria (Tables 1 and 2). Of these 74 included trials, only 16 trials reported health outcomes (KQ 1) (e.g., CVD events, self-reported QOL), 71 trials reported intermediate health outcomes (KQ 2) (e.g., lipid measures, blood pressure, glucose, diabetes incidence, weight measures), 61 trials reported behavioral outcomes (KQ 3) (e.g., objective or self-reported measures of change in diet or physical activity), and 10 trials explicitly reported on harms (or lack thereof) of counseling interventions (KQ 4). We did not identify any additional studies that addressed harms of counseling interventions other than the trials included for KQs 1–3.

Table 1 Included Studies by Population and Key Question

Population | Study Reference | N | Intervention Focus | Intervention Intensity^*^ | KQ1 | KQ2 | KQ3 | KQ4
Dyslipidemia | CouPLES, 2013^67^ | 255 | HD + PA | Medium | | × | ×
Dyslipidemia | PRO-FIT, 2012^68^ | 340 | HD + PA | Medium | | × | ×
Dyslipidemia | RHPP Trial, 1993^69^ | 1,197 | HD + PA | Medium (IG1+IG2)^‡^ | | ×^†^
Dyslipidemia | Anderson, 1992^70^ | 177 | HD | High (IG1+IG2)^‡^ | | × | ×
Dyslipidemia | DEER, 2010^71^ | 189 | HD | High | | × | ×
Dyslipidemia | Delahanty, 2001^72^ | 90 | HD | High | | × | ×
Dyslipidemia | Moy, 2001^73^ | 235 | HD | High | | × | ×
Dyslipidemia | Ammerman, 2003^74^ | 468 | HD | Medium | | ×
Dyslipidemia | Bloemberg, 1991^75^ | 80 | HD | Medium | | ×
Dyslipidemia | Hyman, 1998^76^ | 123 | HD | Medium | | ×^†^ | ×
Dyslipidemia | Johnston, 1995^77^ | 179 | HD | Medium (IG1+IG2)^‡^ | | ×^†^
Dyslipidemia | Neil, 1995^78^ | 309 | HD | Medium (IG1+IG2)^‡^ | | ×
Dyslipidemia | NFPMP, 2004^79^ | 143 | HD | Medium | | × | ×
Dyslipidemia | ODES, 1997^80^ | 98 | HD | Medium | | × | ×
Dyslipidemia | Southeast Cholesterol Project, 1997^81^ | 372 | HD | Medium | | × | ×
Dyslipidemia | Stevens, 2003^82^ | 616 | HD | Medium | | ×
Dyslipidemia | Tomson, 1995^83^ | 92 | HD | Medium | | ×
HTN | Applegate, 1992^127^ | 56 | HD + PA | High | | ×^†^ | ×
HTN | LIHEF, 2003^137^ | 715 | HD + PA | High | | × | ×
HTN | Migneault, 2012^126^ | 337 | HD + PA | High | | ×^†^ | ×
HTN | PREMIER, 2009^116^ | 304 | HD + PA | High (IG1+IG2)^§^ | × | × | × | ×
HTN | TONE, 1998^117^ | 975 | HD + PA | High (IG2+IG3)^§^ | × | ×^†^ | × | ×
HTN | HIP136 | 574 | HD + PA | High (Pt, MD+pt) Medium (MD only) | | × | ×
HTN | Arroll, 1995^128^ | 208 | HD + PA | Medium | | ×^†^ | ×
HTN | ADAPT, 2008^138^ | 241 | HD + PA | Medium | | × | × | ×
HTN | Bosworth, 2009^84,§^ | 477 | HD + PA | Medium (IG1+IG2) | | ×
HTN | Hyman, 2007^135^ | 281 | HD + PA | Medium (IG1+IG2)^‡^ | | × | ×
HTN | HTTP, 1993^134^ | 200 | HD + PA | Medium | | ×
HTN | Rodriguez, 2012^113^ | 533 | HD + PA | Medium | | × | × | ×
HTN | Vitalum, 2008–2011^105^ | 1,629 | HD + PA | Medium (IG2+IG3)^§^ Low (IG1) | | | ×
HTN | TONE, 1998^117^ | 975 | HD | High (IG1) | × | ×^†^ | × | ×
HTN | Arroll, 1995^128^ | 208 | HD | Medium | | ×^†^ | ×
HTN | Beckman, 1995^111^ | 64 | HD | Medium | | × | ×
HTN | Arroll, 1995^128^ | 208 | PA | Medium | | ×^†^ | ×
HTN | Moreau, 2001^104^ | 24 | PA | Medium | | × | ×
Glucose | APHRODITE, 2011^88^ | 925 | HD + PA | High | | × | ×
Glucose | DPP, 2002^89^ | 2,161 | HD + PA | High | × | × | × | ×
Glucose | EDIPS-Newcastle, 2009^91^ | 102 | HD + PA | High | | × | ×
Glucose | E-LITE, 2013^87^ | 162 | HD + PA | High | | ×
Glucose | FDPS, 2001^118^ | 522 | HD + PA | High | × | × | ×
Glucose | HLC, 2012^92^ | 307 | HD + PA | High | × | × | ×
Glucose | Kosaka, 2004^93^ | 482 | HD + PA | High | | ×
Glucose | Live Well, Be Well, 2012^86^ | 238 | HD + PA | High | × | × | ×
Glucose | Melbourne DPS, 2012^85^ | 92 | HD + PA | High | × | × | ×
Glucose | LLDP, 2012^94^ | 312 | HD + PA | High | × | × | × | ×
Glucose | PREDIAS, 2009^95^ | 182 | HD + PA | High | × | × | ×
Glucose | SLIM, 2011^149^ | 147 | HD + PA | High | | × | ×
Glucose | EDIPS, 2006^90^ | 78 | HD + PA | Medium | | × | ×
Glucose | Watanabe, 2003^97^ | 173 | HD | Low | | ×^†^ | ×
Glucose | Enhanced Fitness Trial, 2012^98^ | 302 | PA | High (IG1+IG2) | × | × | × | ×
Glucose | Prepare Trial, 2009^99^ | 98 | PA | Medium (IG1+IG2)^§^ | | × | ×
Mixed | Cochrane, 2012^102^ | 601 | HD + PA | High | | × | ×
Mixed | Edelman, 2006^129^ | 154 | HD + PA | High | | ×^†^ | ×
Mixed | EURO-ACTION, 2008^106^ | 2,385 | HD + PA | High | | × | ×
Mixed | HIPS, 2012^103^ | 814 | HD + PA | High | | × | ×
Mixed | Inter99, 2011^107^ | 4,503 | HD + PA | High | | × | ×
Mixed | Nilsson, 1992^119^ | 63 | HD + PA | High | × | × | ×
Mixed | RIS, 1994^115^ | 508 | HD + PA | High | × | ×
Mixed | WISEWOMAN North Carolina, 2008^110^ | 236 | HD + PA | High | × | × | ×
Mixed | Bo, 2007^146^ | 375 | HD + PA | Medium | | × | × | ×
Mixed | GOAL, 2011^139^ | 457 | HD + PA | Medium | | × | ×
Mixed | Hardcastle, 2008^168^ | 334 | HD + PA | Medium | | × | ×
Mixed | Hoorn, 2013^132^ | 622 | HD + PA | Medium | | × | ×
Mixed | Logan Healthy Living, 2010^114^ | 434 | HD + PA | Medium | | | × | ×
Mixed | PEGASE, 2008^120^ | 640 | HD + PA | Medium | × | ×^†^ | ×
Mixed | PHPP, 2007^121^ | 99 | HD + PA | Medium | × | × | ×
Mixed | SPRING, 2012^100^ | 201 | HD + PA | Medium | | × | ×
Mixed | WISEWOMAN California, 2012^108^ | 1,093 | HD + PA | Medium | | ×^†^ | ×
Mixed | Wister, 2007^140^ | 315 | HD + PA | Medium | | × | ×
Mixed | IMPALA, 2009^133^ | 615 | HD + PA | Medium | | × | ×
Mixed | Rodriguez-Cristobal, 2012^173^ | 436 | HD + PA | Medium | | ×
Mixed | LIFE, 2010^130^ | 186 | PA | High | | ×^†^ | × | ×
Mixed | Green Prescription Programme, 2003^123^ | 878 | PA | Medium | | × | × | ×
Mixed | NERS, 2012^109^ | 2,160 | PA | Medium | | | ×
Mixed | PAC, 2001^122^ | 120 | PA | Medium | × | × | ×
Mixed | PACE, 2005^131^ | 771 | PA | Medium | | ×^†^ | ×
Mixed | Kallings, 2009^141^ | 101 | PA | Medium | | × | ×

* Low: ≤30 min; medium: 30–360 min; high: ≥360 min.

† Not included in meta-analyses because of limitations in reporting of outcomes.

‡ Meta-analysis combines the two intervention groups.

§ Meta-analysis included higher-intensity intervention.

Abbreviations: ADAPT = Activity Diet and Blood Pressure Trial; APHRODITE = Active Prevention in High-Risk Individuals of Diabetes Type 2 in and Around Eindhoven; CouPLES = Couples Partnering for Lipid Enhancing Strategies; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; E-Lite = Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care; FDPS = Finnish Diabetes Prevention Study; GOAL = Groningen Overweigh and Lifestyle Study; HD = healthy diet; HIP = Hypertension Improvement Project; HIPS = Health Improvement and Prevention Study; HLC = Healthy Living Course; HTN = hypertension; HTTP = Hypertension Teaching and Treatment Program; IG = intervention group; IMPALA = Improving Patient Adherence to Lifestyle Advice ; KQ = key question; LIFE = Lifestyle Interventions and Independence for Elder; LIHEF = Lifestyle Intervention against Hypertension in Eastern Finland; LLDP = Lawrence Latino Diabetes Prevention Project; MD = physician; N = study population; NERS = National Exercise Referral Scheme; PA = physical activity; PAC = Physical Activity Counseling; PACE = Physician-based Assessment and Counseling for Exercise; PEGASE = Pan European Grid Advanced Simulation and State Estimation; PHPP = Patient-motivated Health Promotion Program; PREDIAS = Prevention of Diabetes Self-Management Program; pt = patient; RIS = Risk Factor Intervention Study; SLIM = Study on Lifestyle Interventions and IGT Maastricht; SPRING = Self-monitoring and Prevention of Risk Factors; TONE = Trial of Non-Pharmacological Interventions in the Elderly.

Table 2 Included Studies by Intervention Focus and Key Question

Intervention Focus | Study Reference | N | Intervention Intensity^*^ | Population | KQ1 | KQ2 | KQ3 | KQ4
HD + PA | Applegate, 1992^127^ | 56 | High | HTN | | ×^†^ | ×
HD + PA | HIP136 | 574 | High | HTN | | × | ×
HD + PA | LIHEF, 2003^137^ | 715 | High | HTN | | × | ×
HD + PA | Migneault, 2012^126^ | 337 | High | HTN | | ×^†^ | ×
HD + PA | PREMIER, 2009^116^ | 304 | High | HTN | × | × | × | ×
HD + PA | TONE, 1998^117^ | 975 | High | HTN | × | ×^†^ | × | ×
HD + PA | APHRODITE, 2011^88^ | 925 | High | IFG | | × | ×
HD + PA | EDIPS-Newcastle, 2009^91^ | 102 | High | IFG | | × | ×
HD + PA | E-LITE, 2013^87^ | 162 | High | IFG | | ×
HD + PA | DPP, 2002^89^ | 2,161 | High | IFG | × | × | × | ×
HD + PA | FDPS, 2001^118^ | 522 | High | IFG | × | × | ×
HD + PA | HLC, 2012^92^ | 307 | High | IFG | × | × | ×
HD + PA | Kosaka, 2005^93^ | 482 | High | IFG | | ×
HD + PA | Live Well, Be Well, 2012^86^ | 230 | High | IFG | × | × | ×
HD + PA | LLDP, 2012^94^ | 312 | High | IFG | × | × | × | ×
HD + PA | Melbourne DPS, 2012^85^ | 92 | High | IFG | × | × | ×
HD + PA | PREDIAS, 2009^95^ | 182 | High | IFG | × | × | ×
HD + PA | SLIM, 2011^149^ | 147 | High | IFG | | × | ×
HD + PA | Cochrane, 2012^102^ | 601 | High | Mixed | | × | ×
HD + PA | Edelman, 2006^129^ | 154 | High | Mixed | | ×^†^ | ×
HD + PA | EURO-ACTION, 2008^106^ | 2,385 | High | Mixed | | × | ×
HD + PA | HIPS, 2012^103^ | 814 | High | Mixed | | × | ×
HD + PA | Inter99, 2008^107^ | 4,503 | High | Mixed | | × | ×
HD + PA | Nilsson, 1992^119^ | 63 | High | Mixed | × | × | ×
HD + PA | PEGASE, 2008^120^ | 640 | High | Mixed | × | ×^†^ | ×
HD + PA | RIS, 1994^115^ | 508 | High | Mixed | × | ×
HD + PA | WISEWOMAN North Carolina, 2008^110^ | 236 | High | Mixed | × | × | ×
HD + PA | PRO-FIT, 2012^68^ | 340 | Medium | Dyslipidemia | | × | ×
HD + PA | RHPP Trial, 1993^69^ | 1,197 | Medium | Dyslipidemia | | ×^†^
HD + PA | CouPLES, 2013^67^ | 255 | Medium | Dyslipidemia | | × | ×
HD + PA | ADAPT, 2008^138^ | 241 | Medium | HTN | | × | × | ×
HD + PA | Arroll, 1995^128^ | 208 | Medium | HTN | | ×^†^ | ×
HD + PA | Bosworth, 2009^84,‡^ | 477 | Medium | HTN | | ×
HD + PA | HTTP, 1993^134^ | 200 | Medium | HTN | | ×
HD + PA | Hyman, 2007^135^ | 281 | Medium | HTN | | × | ×
HD + PA | Rodriguez, 2012^113^ | 533 | Medium | HTN | | × | × | ×
HD + PA | Vitalum, 2011^105^ | 1,629 | Medium | HTN | | | ×
HD + PA | EDIPS, 2006^90^ | 78 | Medium | IFG | | × | ×
HD + PA | Hoorn, 2013^132^ | 622 | Medium | Mixed | | × | ×
HD + PA | Logan Healthy Living, 2010^114^ | 434 | Medium | Mixed | | | × | ×
HD + PA | Rodriguez-Cristobal, 2012^173^ | 436 | Medium | Mixed | | ×
HD + PA | SPRING, 2012^100^ | 201 | Medium | Mixed | | × | ×
HD + PA | Bo, 2007^146^ | 375 | Medium | Mixed | | × | × | ×
HD + PA | PHPP, 2007^121^ | 99 | Medium | Mixed | × | × | ×
HD + PA | Hardcastle, 2008^168^ | 334 | Medium | Mixed | | × | ×
HD + PA | GOAL, 2011^139^ | 457 | Medium | Mixed | | × | ×
HD + PA | WISEWOMAN California, 2012^108^ | 1,093 | Medium | Mixed | | ×^†^ | ×
HD + PA | Wister, 2007^140^ | 315 | Medium | Mixed | | × | ×
HD + PA | IMPALA, 2009^133^ | 615 | Medium | Mixed | | × | ×
HD | Anderson, 1992^70^ | 177 | High | Dyslipidemia | | × | ×
HD | DEER, 2010^71^ | 189 | High | Dyslipidemia | | × | ×
HD | Delahanty, 2001^72^ | 90 | High | Dyslipidemia | | × | ×
HD | Moy, 2001^73^ | 235 | High | Dyslipidemia | | × | ×
HD | TONE, 1998^117^ | 975 | High | HTN | × | ×^†^ | × | ×
HD | Ammerman, 2003^74^ | 468 | Medium | Dyslipidemia | | ×
HD | Bloemberg, 1991^75^ | 80 | Medium | Dyslipidemia | | ×
HD | Hyman, 1998^76^ | 123 | Medium | Dyslipidemia | | ×^†^ | ×
HD | Johnston, 1995^77^ | 179 | Medium | Dyslipidemia | | ×^†^
HD | Neil, 1995^78^ | 309 | Medium | Dyslipidemia | | ×
HD | NFPMP, 2002^79^ | 143 | Medium | Dyslipidemia | | × | ×
HD | ODES, 1997^80^ | 98 | Medium | Dyslipidemia | | × | ×
HD | Southeast Cholesterol Project, 1997^81^ | 372 | Medium | Dyslipidemia | | × | ×
HD | Stevens, 2003^82^ | 616 | Medium | Dyslipidemia | | ×
HD | Tomson, 1994^83^ | 92 | Medium | Dyslipidemia | | ×
HD | Arroll, 1995^128^ | 208 | Medium | HTN | | ×^†^ | ×
HD | Beckman, 1995^111^ | 64 | Medium | HTN | | × | ×
HD | Watanabe, 2003^97^ | 173 | Low | IFG | | ×^†^ | ×
PA | Enhanced Fitness Trial, 2012^98^ | 302 | High | IFG | × | × | × | ×
PA | PAC, 2001^122^ | 120 | Medium | Mixed | × | × | ×
PA | Arroll, 1995^128^ | 208 | Medium | HTN | | ×^†^ | ×
PA | Moreau, 2001^104^ | 24 | Medium | HTN | | × | ×
PA | Prepare Trial, 2009^99^ | 98 | Medium | IFG | | × | ×
PA | LIFE, 2010^130^ | 186 | High | Mixed | | ×^†^ | × | ×
PA | Green Prescription Programme, 2003^123^ | 878 | Medium | Mixed | | × | × | ×
PA | Kallings, 2009^141^ | 101 | Medium | Mixed | | × | ×
PA | NERS, 2012^109^ | 2,160 | Medium | Mixed | | | ×
PA | PACE, 2005^131^ | 771 | Medium | Mixed | | ×^†^ | ×

* Low: ≤30 min; medium: 30–360 min; high ≥360 min.

† Not included in meta-analyses because of limitations in reporting of outcomes.

‡ Meta-analysis included higher-intensity intervention.

Abbreviations: ADAPT = Activity Diet and Blood Pressure Trial; APHRODITE = Active Prevention in High-Risk Individuals of Diabetes Type 2 in and Around Eindhoven; CouPLES = Couples Partnering for Lipid Enhancing Strategies; DEER = Diet and Exercise for Elevated Risk; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; E-Lite = Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care; FDPS = Finnish Diabetes Prevention Study; GOAL = Groningen Overweigh and Lifestyle Study; HD = healthy diet; HIP = Hypertension Improvement Project; HIPS = Health Improvement and Prevention Study; HLC = Healthy Living Course; HTN = hypertension; HTTP = Hypertension Teaching and Treatment Program; IFG = impaired fasting glucose; IMPALA = Improving Patient Adherence to Lifestyle Advice; KQ = key question; LIFE = Lifestyle Interventions and Independence for Elder; LIHEF = Lifestyle Intervention against Hypertension in Eastern Finland; LLDP: Lawrence Latino Diabetes Prevention Project; N = study population; NERS = National Exercise Referral Scheme; NFPMP = Nijmegen Family Practices Monitoring Project; ODES = Oslo Diet and Exercise Study; PA = physical activity; PAC = Physical Activity Counseling; PACE = Physician-based Assessment and Counseling for Exercise; PEGASE = Pan European Grid Advanced Simulation and State Estimation; PHPP = Patient-motivated Health Promotion Program; PREDIAS = Prevention of Diabetes Self-Management Program; RIS = Risk Factor Intervention Study; SLIM = Study on Lifestyle Interventions and IGT Maastricht; SPRING = Self-monitoring and Prevention of Risk Factors; TONE = Trial of Non-Pharmacological Interventions in the Elderly.

### Included Populations

We included 17 trials conducted exclusively in persons with dyslipidemia or that included an intervention aim that was primarily focused on reducing cholesterol (Table 3).67-83 We included 15 trials conducted exclusively in persons with hypertension (Table 4).67,69-87 We included 16 trials aimed at preventing diabetes in persons with impaired fasting glucose or glucose tolerance (Table 5).88-103 We included 26 trials in persons selected for any one or a combination of CVD risk factors, most commonly including dyslipidemia, hypertension, elevated glucose (including diabetes), metabolic syndrome, obesity, and smoking (Table 6). Most trials ranged from 50 to 1,000 participants. Only one trial had fewer than 50 participants.104 Seven trials had more than 1,000 participants, including Vitalum,105 Diabetes Prevention Program (DPP),89 Euroaction,106 Inter99,^107^ WISEWOMAN California,108 Rural Health Promotion Project (RHPP), and the National Exercise Referral Scheme (NERS) trial.109 The mean age in populations studied ranged from 40.5 to 71 years (interquartile range [IQR], 52.0 to 59.4 years). Nine trials specifically targeted older adults. The mean age in these trials ranged from 64.5 to 71 years. Both men and women were well represented in included trials, most of which included both sexes. Four trials included only women82,104,108,110 and five trials included only men.75,93,97, 111,112 About one third (k=28) of included trials were conducted in the United States. The remaining trials were conducted in western Europe (k=33), Australia (k=6), Japan (k=3), Canada (k=2), and New Zealand (k=2). Of the trials conducted in the United States, 23 trials reported including nonwhite populations that ranged from 4 to 100 percent. More than one third of participants were nonwhite in 12 of the U.S.-based trials.

Table 3 Behavioral Counseling Trials in Persons With Dyslipidemia or Elevated Cholesterol: Study and Population Characteristics

Study, Year | Quality | Country | N | Mean Age, y | % Men | Mean TC and LDL, mg/dL | % On Lipid-Lowering Medications | Mean BMI, kg/m^2^ | % DM
Healthy diet and physical activity interventions
CouPLES, 2009, 2013^67^ | Fair | US | 255 | 61 | 94.9 | TC: NR LDL: 126.3 | 46.3 | NR | NR
PRO-FIT, 2012^68^ | Fair | The Netherlands | 340 | 45 | 44.0^†^ | TC: 204.6^†^ LDL: 142.8^†^ | 69.0^†^ | 26.5^†^ | NR
RHPP Trial, 1993^69^ | Fair | US | 1,197 | 71 | 43.2^†^ | TC: 266.9^†^ LDL: NR | NR | % with BMI >30: 30.8^†^ | 16.3^†^
Healthy diet–only interventions
Anderson, 1992^70^ | Fair | US | 177 | 41^†^ | 56.6^†^ | TC: 233.2 LDL: 158.3^†^ | 0 | NR | 0
Ammerman, 2003^74^ Keyserling, 1999^174^ | Fair | US | 468 | 55 | 29.0 | TC: 257^†^ LDL: 180^†^ | 0 | 28.8^†^ | 3.6^†^
Bloemberg, 1991^75^ | Fair | The Netherlands | 80 | 47^†^ | 100.0 | TC: 268.3^†^ LDL: NR | NR | 26.2^†^ | 0
DEER, 1998^71^ | Fair | US | 189 | 52^†^ | 51.8^†^ | TC: 232.5^†^ LDL: 158.2^†^ | 0 | 26.7^†^ | 0
Delahanty, 2001^72^ | Good | US | 90 | 49 | 66.7^†^ | TC: 238.6^†^ LDL: 164.9^†^ | 0 | NR | 0
Hyman, 1998^76^ | Fair | US | 123 | 57^†^ | 25.2^†^ | TC: 272.8^†^ LDL: NR | 0 | 31.2^†^ | NR
Johnston, 1995^77^ | Fair | Australia | 179 | 57^†^ | 31.0^†^ | TC: 245.2^†^ LDL: 156.4^†^ | NR | 25.1^†^ | 0
Moy, 2001^73^ | Fair | US | 235 | 46^*^ | 51.9^*^ | TC: NR LDL: 173.7^*^ | NR | 29.0^*^ | NR
Neil, 1995^78^ | Fair | UK | 309 | 55^*^ | 52.8^†^ | TC: 273.4^*^ LDL: 199.6 | 0 | 26.4 | NR
NFPMP, 2002^79^ | Fair | The Netherlands | 143 | 58 | 37.0 | TC: NR LDL: NR | NR | 28.7 | 8.0
ODES, 1995^80^ | Fair | Norway | 98 | 45^†^ | 85.3^†^ | TC: 249.8^†^ LDL: 170.3^†^ | 0^‡^ | 29.0^†^ | 0
Southeast Cholesterol Project, 1997^81^ | Fair | US | 372 | 56 | 38.0^†^ | TC: 253.3^†^ LDL: 180.3^†^ | 0 | % with BMI >30: 23 | 0
Stevens, 2003^82^ | Fair | US | 616 | 54^†^ | 0 | NR | 0 | 30.3^†^ | NR
Tomson, 1995^83^ Tomson, 1994^175^ | Fair | Sweden | 92 | 43^†^ | 56.6^†^ | TC: 281.5^†^ LDL: NR | NR | 25.0^†^ | 0

* Median.

† Calculated.

‡ Assumed.

Abbreviations: BMI = body mass index; CouPLES = Couples Partnering for Lipid Enhancing Strategies ; DEER = Diet and Exercise for Elevated Risk; DM = diabetes mellitus; LDL = low-density lipoprotein; N = study population; NFPMP = Nijmegen Family Practice Monitoring Project; NR = not reported; ODES = Oslo Diet and Exercise Study; RHPP = Rural Health Promotion Project; UK = United Kingdom; US = United States; TC = total cholesterol.

Table 4 Behavioral Counseling Trials in Persons With Hypertension: Study and Population Characteristics

Study, Year | Quality | Country | N | Mean Age, y | % Men | Mean SBP and DBP, mm HG | % on HTN Medications | Mean BMI, kg/m^2^ | % DM
Healthy diet and physical activity interventions
ADAPT, 2006^138^ | Fair | Australia | 241 | 56^*^ | 44.4^*^ | SBP: 126.5^*^ DBP: 76.5^*^ | 100 | 30.1^*^ | 0
Applegate, 1992^127^ | Fair | US | 56 | 65^*^ | 44.7^*^ | SBP: 144.0^*^ DBP: 87.0^*^ | 0 | NR | 0
Arroll, 1995^128^ (Also arms in HD- & PA-only sections) | Fair | New Zealand | 208 | 55 | 52.0^*^ | SBP: 144.6 DBP: 89.4 | 100 | NR | NR
Bosworth, 2009^84^ | Fair | US | 478 | 61^*^ | 36.0^*^ | SBP: 125^*^ DBP: 71^*^ | 100 | 32.3^*^ | 36.0^*^
HIP, 2009^136^ | Fair | US | 574 | 61 | 39.0 | SBP: 133.1 DBP: 74.1 | 97 | 32.5 | 30.0
HTTP, 1993^134^ | Fair | Germany | 200 | 51^*^ | 43.1^*^ | SBP: 161.5^*^ DBP: 96.5^*^ | 81.5^*^ | NR | NR
Hyman, 2007^135^ | Fair | US | 281 | 53^*^ | 32.7^*^ | SBP: 138.9 DBP: 85.3 | NR | 32.4 | 18.5
LIHEF, 2002^137^ | Fair | Finland | 715 | 54^*^ | 47.0^*^ | SBP: 148.5^*^ DBP: 91.0^*^ | 52.5^*^ | 28.7^*^ | NR
Migneault, 2012^126^ | Fair | US | 337 | 57^*^ | 29.7 | SBP: 131.2^*^ DBP: 80.6^*^ | 100 | 34.4^*^ | 38.3^*^
PREMIER, 2003^116^ | Good | US | 304 | 52 | 36.5 | SBP: 143.9 DBP: 87.5 | 0 | % with BMI >30: women, 63%^*^; men, 66%^*^ | 0
Rodriguez, 2012^113^ | Fair (poor for diet) | US | 533 | 67 | 98.7 | SBP: NR DBP: NR | NR | 30.4^*^ | NR
TONE, 1998^117^ (Also arm in HD-only section) | Good | US | 975 | 67 | 52.0 | SBP: 127.5 DBP: 71.3 | 100 | 28.9^*^ | 0
Vitalum, 2011^105^ | Fair | The Netherlands | 1,629 | 57 | 55.0 | SBP: NR DBP: NR | NR | 27.5^*^ | 10.0^*^
Healthy diet–only interventions
Arroll, 1995^128^ (Also arms in HD+PA & PA-only sections) | Fair | New Zealand | 208 | 55 | 52.0^*^ | SBP: 144.6 DBP: 89.4 | 100 | NR | NR
Beckman, 1995^111^ | Fair | Norway | 64 | NR | 100.0 | SBP: NR DBP: NR | NR | 27.3^*^ | NR
TONE, 1998^117^ (Also arm in HD+PA section) | Good | US | 975 | 67 | 52.0 | SBP: 127.5 DBP: 71.3 | 100 | 28.9^*^ | 0
Physical activity–only interventions
Arroll, 1995^128^ (Also arms in HD+PA & HD-only sections) | Fair | New Zealand | 208 | 55 | 52.0^*^ | SBP: 144.6 DBP: 89.4 | 100 | NR | NR
Moreau, 2001^104^ | Fair | US | 24 | 54^*^ | 0 | SBP: NR DBP: NR | 42.0 | NR | NR

* Calculated.

Abbreviations: ADAPT = Activity Diet and Blood Pressure Trial; BMI = body mass index; DBP = diastolic blood pressure; DM = diabetes mellitus; HIP = Hypertension Improvement Project; HTN = hypertension; HTTP = Hypertension Teaching and Treatment Programme; LIHEF = Lifestyle Intervention against Hypertension in Eastern Finland; N = study population; NR = not reported; SBP = systolic blood pressure; TONE = Trial of Non-Pharmacological Interventions in the Elderly; US = United States.

Table 5 Behavioral Counseling Trials in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance: Study and Population Characteristics

Study, Year | Quality | Country | N | Mean Age, y | % Men | Mean Glucose (FBG/GTT/HbA1c) | Mean BMI, kg/m^2^ | % HTN | % Dyslipidemia
Healthy diet and physical activity interventions
APHRODITE, 2011^88^ | Fair | The Netherlands | 925 | 58 | 38.3 | FBG: 100.9^*^ | 28.8 | NR | NR
DPP, 2002^89^ | Good | US | 2,161 | 51 | 32.3 | FBG: 106.5 | 34.0 | 26.9 | 34.6
EDIPS, 2001^90^ | Fair | UK | 78 | 58 | 56.7 | FBG: 109.9^*^ | 30.2 | NR | NR
EDIPS-Newcastle, 2009^91^ | Fair | UK | 102 | 57 | 40.2 | FBG: 104.5^*^ | 33.8 | NR | NR
E-LITE, 2013^87^ | Good | US | 162 | 52.0^*^ | 54^*^ | FBG: 99.7 | 32.0 | NR | NR
FDPS, 2001^118^ | Good | Finland | 522 | 55 | 33.0 | FBG: 109.5^*^ | 31.2 | 30.5^†^ | 5.5^†^
HLC, 2011^92^ | Fair | Australia | 307 | 63 | 41.0^*^ | FBG: 105.9^*^ | 29.7^*^ | NR | NR
Kosaka, 2005^93^ | Fair | Japan | NR (reports participants still present at 1-year observation [482]) | 50s | 100 | NR | 23.9 | NR | NR
Live Well, Be Well, 2012^86^ | Good | US | 238 | 56^*^ | 26.0^*^ | FBG: 93.7^*^ | 30.0^*^ | 47.0^*^ | NR
LLDP, 2012^94^ | Good | US | 312 | 52 | 25.6 | FBG: 105 | 33.9 | NR | NR
Melbourne DPS, 2012^85^ | Fair | Australia | 92 | 65^*^ | 27.0^*^ | FBG: 93.2 | 30.8^*^ | NR | NR
PREDIAS, 2009^95^ | Fair | Germany | 182 | 56 | 57.0 | FBG: 105.7^*^ | 31.5 | NR | NR
SLIM, 2011^149^ | Fair | The Netherlands | 147 | 57 | 51.0 | FBG: 108.1^*^ | 29.8 | 26.5^†^ | 7.5^†^
Healthy diet–only interventions
Watanabe, 2003^97^ | Fair | Japan | 173 | 55 | 100 | FBG: 104.5^*^ | 24.4 | NR | NR
Physical activity–only interventions
Enhanced Fitness Trial, 2012^98^ | Fair | US | 302 | 67 | 97.0 | FBG: 110.6 | 31.2 | 72 | NR
Prepare Trial, 2009^99^ | Fair | UK | 98 | 65 | 66.0 | FBG: 100.9^*^ | 29.2 | 54^†^ | 55^†^

* Calculated.

† Percent on medication.

Abbreviations: APHRODITE = Active Prevention in High-Risk Individuals of Diabetes Type 2 in and Around Eindhoven; BMI = body mass index; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; E-Lite = Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care; FBG = fasting blood glucose; FDPS = Finnish Diabetes Prevention Study; GTT = glucose tolerance test; HbA1c = glycated hemoglobin; HLC = Healthy Living Course; HTN = hypertension; LLDP = Lawrence Latino Diabetes Prevention Project; N = study population; NR = not reported; PREDIAS = Prevention of Diabetes Self-Management Program; SLIM = Study on Lifestyle Intervention and IGT Maastricht; UK = United Kingdom; US = United States.

Table 6 Behavioral Counseling Trials in Persons With Mixed Cardiovascular Risk Factors: Study and Population Characteristics

Study, Year Quality | Country | N | Mean Age, y | % Men | % HTN | Mean BP, mm HG | % Dyslipidemia | Mean TC & LDL, mg/dL | % IFG or IGT | % DM | Mean FBG, mg/dL | Mean BMI, kg/m^2^
Healthy diet and physical activity interventions
Bo, 2007^146^ Fair | Italy | 375 | 56^*^ | 41.7^*^ | 93.8^*^ | SBP: 142.0^*^ DBP: 88^*^ | 16.7^†^ | TC: 227.8^*^ LDL: NR | 38^*^ | 0 | 104.5^*^ | 29.7^*^
Cochrane, 2012^102^ Fair | UK | 601 | 64^*^ | 88.2^*^ | NR | SBP: 145.4^*^ DBP: 85.1^*^ | NR | TC: 185.3^*^ LDL: NR | NR | NR | 99.1^*^ | 28.1^*^
Edelman, 2006^129^ Fair | US | 154 | 53^*^ | 19.5^*^ | 37.7^*^ | NR | NR | LDL: 134.7^*^ | NR | 15.6^*^ | NR | 33.7^*^
EURO-ACTION, 2008^106^ Fair | France, Italy, Poland, Spain, Sweden, Denmark, The Netherlands, UK | 2,385 | 62^*^ | 53.6^*^ | 63.0^*^ | NR | 75.2 | NR | NR | 28.7^*^ | NR | NR
GOAL, 2009^139^ Good | The Netherlands | 457 | 56^*^ | 48.1^*^ | 61.7^*^ | SBP: 145.5^*^ DBP: 86.5^*^ | 39.2^*^ | TC: 216.6^*^ LDL: 133.9^*^ | NR | 0 | 93.7^*^ | 29.6^*^
Hardcastle, 2008^168^ Fair | UK | 334 | 50^*^ | 33 | 35 | SBP: 133.7^*^ DBP: 83.0^*^ | 57 | TC: 210.4^*^ LDL: 115.0^*^ | NR | NR | NR | 34.0^*^
HIPS, 2012^103^ Fair | Australia | 814 | 40–64 (range) | 42.6^*^ | 8.7^*^ | NR | 88.0 | NR | NR | 0 | NR | NR
Hoorn, 2013^132^ Fair | The Netherlands | 622 | 44.0^*^ | 41.6^*^ | NR | SBP: 129.0^*^ DBP: 73.4^*^ | NR | NR | NR | 0 | NR | NR
IMPALA, 2009^133^ Fair | The Netherlands | 615 | 57 | 45 | 65.2^*^ | SBP: 146.9^*^ DBP: NR | 43.3^*^ | TC: NR LDL: 144.8^*^ | NR | 14.1^*^ | 106.3^*^ | 29
Inter99, 2008^107^ Fair | Denmark | 4,053 | 47 | 50.1^*^ | NR | SBP: 140.5^*^ DBP: NR | NR | TC: 223.9^*^ LDL: NR | NR | 9.9 | NR | 29.8^*^
Logan Healthy Living, 2009^114^ Fair | Australia | 434 | 58 | 38.9 | 85.5 | NR | NR | NR | NR | 45.4 | NR | 31.1
Nilsson, 1992^119^ Fair | Sweden | 63 | 56^*^ | 78.0^*^ | 78.0 | SBP: 149.6^*^ DBP: 85.9^*^ | NR | TC: 220.1^*^ LDL: 154.4^*^ | NR | NR | FBG: 92.8^*^ | 28.4^*^
PEGASE, 2008^120^ Fair | France | 640 | 57^*^ | 60.0^*^ | 34.0^*^ | NR | 81.0^*^ | TC: NR LDL: 148.5^*^ | NR | 8.7^*^ | NR | % with BMI >30: 19.9^*^
PHPP, 2007^121^ Fair | Japan | 99 | 64^*^ | 42.4^*^ | 30.3^*^ | SBP: 129.8^*^ DBP: 78.8^*^ | NR | TC: 205.7^*^ LDL: 122.4^*^ | NR | 17.2^*^ | NR | NR
RIS, 1994^115^ Good (KQ1),Fair (KQ2) | Sweden | 508 | 66 | 100.0 | 100.0 | SBP: 155 DBP: 91 | 74 | TC: 258.7^*^ LDL: 177.6 | 3.0 | 22 | 104.5 | 27.1
Rodriguez-Cristobal, 2012^173^ Fair | Spain | 436 | 58^*^ | 37^*^ | 42^*^ | SBP: 134.3^*^ DBP: 81.2^*^ | NR | TC: 210.6^*^ LDL: 134.5^*^ | NR | 13.5^*^ | NR | 30.4^*^
SPRING, 2012^100^ Fair | The Netherlands | 201 | 65^*^ | 62.0^*^ | 76.0^*^ | SBP: 158.0^*^ DBP: 92.0^*^ | 78.0^*^ | TC: 216.2^*^ LDL: 139.0^*^ | NR | 0 | 97.3^*^ | 28.0^*^
WISEWOMAN California, 2010^108^ Fair | US | 1093 | 52^*^ | 0 | 17.3 | SBP: 125.1^*^ DBP: 76.7^*^ | 13.0 | TC: 198.1^*^ LDL: NR | NR | 22.0 | NR | 31.9^*^
WISEWOMAN NC, 2006, 2008^110^ Fair | US | 236 | 53^*^ | 0 | 47.9^*^ | SBP: 127^*^ DBP: 78^*^ | 33.7^*^ | TC: 210.5^*^ LDL: 126.5^*^ | NR | 11.5^*^ | FBG: 111.8^*^ | 31
Wister, 2007^140^ Good | Canada | 315 | 55^*^ | 41.6^*^ | NR | SBP: 137.5^*^ DBP: NR | NR | TC: 220.1^*^ LDL: NR | NR | NR | Glucose: 147.8^*^ | 32.5
Physical activity–only interventions
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ Fair | New Zealand | 878 | 58 | 34 | 52^*^ | SBP: 135.2^*^ DBP: 82.1^*^ | NR | TC: 220.1^*^ LDL: NR | NR | 11 | NR | 30
NERS, 2012^109^ Fair | UK | 2,160 | 52 | 34 | NR | NR | NR | NR | NR | NR | NR | NR
PAC, 2001, 2007^122^ Fair | Canada | 120 | 47^*^ | 32^*^ | 34.2^*^ | NR | NR | TC: 191.1^*^ LDL: 112.0^*^ | NR | 10.8^*^ | FBG: 104.5^*^ | 30.7^*^
PACE, 2005^131^ Fair | The Netherlands | 771 | 56 | 51 | NR | NR | NR | NR | NR | NR | NR | 28.9
Kallings, 2009^141^ Good | Sweden | 101 | 68^*^ | 43 | NR | SBP: 140.1 DBP: 80.8 | NR | TC: 212.3 LDL: 127.4 | NR | NR | 97.3^*^ | 30.1
LIFE, 2010^130^ Fair | Belgium | 126 | 67^*^ | 52.4^*^ | NR | SBP: 145.6^*^ DBP: 86.2^*^ | NR | TC: 239.2^*^ LDL: 148.5^*^ | NR | 0 | 94.5^*^ | 26.7^*^

* Calculated.

† Patients with low HDL cholesterol.

Abbreviations: BP = blood pressure; DBP = diastolic blood pressure; DM = diabetes mellitus; FBG = fasting blood glucose; GOAL = Groningen Overweight and Lifestyle Study; HIPS = Health Improvement and Prevention Study; HTN = hypertension; IFG = impaired fasting glucose; IGT = impaired glucose tolerance; IMPALA = Improving Patient Adherence to Lifestyle Advice; LDL = low-density lipoprotein; LIFE = Lifestyle Intervention and Independence for elder; N = study population; NERS = National Exercise Referral Scheme; NR = not reported; PAC = Physical Activity Counseling; PACE = Physician-based Assessment and Counseling for Exercise; PEGASE = Pan European Grid Advanced Stimulation and State Examination; PHPP = Patient-motivated Health Promotion Program; RIS = Risk Factor Intervention Study; SBP = systolic blood pressure; SPRING = Self-monitoring and Prevention of Risk Factors; TC = total cholesterol; US = United States; UK = United Kingdom.

The proportion of participants with dyslipidemia at baseline ranged from 5.5 to 100 percent for included trials, where reported, with a range of baseline LDL cholesterol from 105.7 to 202.7 mg/dL. The proportion with hypertension ranged from 0 to 100 percent, with a range of SBP from 123 to 162 mm Hg. In trials including persons with impaired fasting glucose or glucose intolerance, fasting blood glucose at baseline ranged from 93.2 to 110.6 mg/dL. When reported, the proportion of smokers in included trials ranged from 0 to 100 percent. The average BMI in all but two trials93,97 ranged from overweight to obese. The median BMI was 29.8 kg/m^2^ (IQR, 28.4 to 31.2 kg/m^2^). While we excluded trials conducted exclusively in persons with diabetes, many trials included some persons with diabetes, ranging from 3.6 to 45.4 percent.

Trials did not generally restrict or require the use of lipid-, blood pressure-, or glucose-lowering medications. In nine of the 17 trials conducted exclusively in persons with dyslipidemia, however, participants were not allowed to be taking lipid-lowering medications. Three of the 15 trials were conducted exclusively in persons with hypertension who were not allowed to be taking antihypertension medication, while five trials explicitly selected for persons taking them. None of the trials in persons with impaired fasting glucose or glucose tolerance included participants taking medications for glycemic control.

### Included Interventions

The 74 trials included 49 diet and exercise counseling intervention arms, 18 diet-only intervention arms, and 10 physical activity intervention arms (Table 2). Of the interventions evaluated, only two were low-intensity, 48 were medium-intensity, and 37 were high-intensity interventions (Tables 7–10). Medium-intensity interventions had a median number of five contacts (IQR, 3 to 8 contacts), with a median duration of 9 months (IQR, 4 to 11 months). High-intensity interventions had a median number of 16 contacts (IQR, 9 to 31 contacts), with a median duration of 12 months (IQR, 8 to 18 months). The vast majority of interventions relied on face-to-face sessions, either in individual or group sessions (Appendix E). Although many interventions used adjunctive telephone contacts, five medium-intensity trials relied solely on telephone and mail contacts to deliver the behavioral counseling.67,84,105,113,114 Given the intensity and expertise needed for these interventions, the counseling interventions evaluated are primarily referable from primary care, as opposed to delivered in primary care. Counseling interventions were delivered by dieticians or nutritionists, physiotherapists or exercise professionals/consultants, and/or trained interventionists (e.g., health educators, psychologists, nurses, case managers, life coaches).

Table 7 Behavioral Counseling Trials in Persons With Dyslipidemia or Elevated Cholesterol: Intervention Characteristics

Study, Year | Quality | N | Intervention Intensity | # of Contacts Interactive (I), Other (O) | Duration of Intervention | Type of Control
Healthy diet and physical activity interventions
CouPLES, 2013^67^ | Fair | 255 | Medium: phone only; included medication adherence, included spouse | I: 16 O: 0 | 10 months | MI
PRO-FIT, 2012^68^ | Fair | 340 | Medium | I: 6 O: 0 | 12 months | UC
RHPP Trial, 1993^69^ | Fair | 1,197 | IG1: Medium^†^ (hospital-based) | I: range, 1 to 5 (mean, 4.2) O: 0 | 12 months | UC
RHPP Trial, 1993^69^ | Fair | 1,197 | IG2: Medium^†^ (clinic-based) | I: range, 1 to 5 (mean, 3.4) O: 0 | 12 months | UC
Healthy diet–only interventions
Anderson, 1992^70^ | Fair | 177 | IG1: High (AHA diet) | I: 29 O: 0 | 12 months | UC
Anderson, 1992^70^ | Fair | 177 | IG2: High (AHA high fiber) | I: 29 O: 0 | 12 months | UC
Ammerman, 2003^74^ Keyserling, 1999^174^ | Fair | 468 | Medium | I: 7 O: 2 | 12 months | UC
Bloemberg, 1991^75^ | Fair | 80 | Medium | I: 3 O: 5 | 6 months^*^ | No advice
DEER, 1998^71^ | Fair | 189 | High | I: 17 O: 0 | 11 months | No advice
Delahanty, 2001^72^ | Good | 90 | High | I: 6 O: 0 | 6 months | UC
Hyman, 1998^76^ | Fair | 123 | Medium | I: 16 O: 12 | 6 months | UC
Johnston, 1995^77^ | Fair | 179 | IG1: Medium (group) | I: 3 O: 0 | 6 months^*^ | UC
Johnston, 1995^77^ | Fair | 179 | IG2: Medium (individual) | I: 3 O: 0 | 6 months^*^ | UC
Moy, 2001^73^ | Fair | 235 | High | I: 13 O: 0 | 2 years^*^ | UC
Neil, 1995^78^ | Fair | 309 | IG1: Medium (40 min) (nurse) | I: 2 O: 0 | 8 weeks | UC
Neil, 1995^78^ | Fair | 309 | IG2: Medium (40 min) (dietician) | I: 2 O: 0 | 8 weeks | UC
NFPMP, 2002^79^ | Fair | 143 | Medium | I: 6 O: 0 | 14 weeks | UC
ODES, 1995^80^ | Fair | 98 | Medium | I: 3 O: 0 | 9 months | Waitlist control
Southeast Cholesterol Project, 1997^81^ | Fair | 372 | Medium | I: 6 O: 4 | 12 months | UC
Stevens, 2003^82^ | Fair | 616 | Medium | I: 4 O: 0 | 9 weeks | AC
Tomson, 1995^83^ Tomson, 1994^175^ | Fair | 92 | Medium | I: 6 O: 0 | 12 months | UC

* Assumed.

† Based on means.

Abbreviations: AC = attention control; AHA = American Health Association; CouPLES = Couples Partnering for Lipid Enhancing Strategies; DEER = Diet and Exercise for Elevated Risk; IG = intervention group; MI = minimal intervention; N = study population; NFPMP = Nijmegen Family Practices Monitoring Project; ODES = Oslo Diet and Exercise Study; UC = usual care.

Table 8 Behavioral Counseling Trials in Persons With Hypertension: Intervention Characteristics

Study, Year Intervention Focus | Quality | N | Intervention Intensity | # of Contacts Interactive (I), Other (O) | Duration of Intervention | Type of Control
Healthy diet and physical activity interventions
ADAPT, 2006^138^ | Fair | 241 | Medium | I: 6 O: 4 | 12 months | UC with partial AC
Applegate, 1992^127^ | Fair | 56 | High | I: 14 O: 0 | 6 months | No advice
Arroll, 1995^128^ (Also has arms in HD- and PA-only sections) | Fair | 208 | IG1: Medium (PA + Salt) | I: 1 O: 0 | Unknown | UC
Bosworth, 2009^84^ | Fair | 478 | IG1: Medium (self-management + incentives) | I: 12 O: 0 | 24 months | UC
Bosworth, 2009^84^ | Fair | 478 | IG2: Medium (combined + incentives) | I: 12 O: 0 | 24 months | UC
HIP, 2009^136^ | Fair | 574 | IG1: High (pt only) | I: 32 O: 0 | 18 months | UC
HIP, 2009^136^ | Fair | 574 | IG2: High (MD + pt) | I: 32 O: 4 | 18 months | UC
HIP, 2009^136^ | Fair | 574 | CG2: Medium (MD only) | I: 2 O: 4 | 18 months | UC
HTTP, 1993^134^ | Fair | 200 | Medium (6 hr) | I: 4 O: 0 | 1 month | MI
Hyman, 2007^135^ | Fair | 281 | IG1: Medium (6 hr) (addressed 3 target areas at each clinic session) | I: 24 O:3 | 18 months | MI
Hyman, 2007^135^ | Fair | 281 | IG2: Medium (6 hr) (addressed 1 at each session [in random order]) | I: 24 O:3 | 18 months | MI
LIHEF, 2002^137^ | Fair | 715 | High | I: 9 O: 0 | 18 months | UC
Migneault, 2012^126^ | Fair | 337 | High | I: 33 O: 0 | 8 months | MI (manual + pedometer + scale)
PREMIER, 2003^116^ | Good | 304 | IG1: High | I: 33 O: 0 | 18 months | UC
PREMIER, 2003^116^ | Good | 304 | IG2: High (DASH diet) | I: 33 O: 0 | 18 months | UC
Rodriguez, 2012^113^ | Fair (poor for diet) | 533 | Medium (phone only) | I: 6 O:0 | 6 months | CG1: MI CG2: UC
TONE, 1998^117^ (Also has arm in HD-only section) | Good | 975 | IG2: High (weight loss) | I: 32 O: 0 | 15–36 months; median, 29 months | UC with partial AC
TONE, 1998^117^ (Also has arm in HD-only section) | Good | 975 | IG3: High (decreased sodium + weight loss) | I: 32 O: 0 | 15–36 months; median, 29 months | UC with partial AC
Vitalum, 2011^105^ | Fair | 1,629 | IG1: Low (mail only) | I: 0 O: 4 | 3.6 months | UC
Vitalum, 2011^105^ | Fair | 1,629 | IG2: Medium (phone) | I: 4 O:0 | 3.6 months | UC
Vitalum, 2011^105^ | Fair | 1,629 | IG3: Medium (mail + phone) | I: 2 O: 2 | 3.6 months | UC
Healthy diet–only interventions
Arroll, 1995^128^ (Also has arms in HD+PA and PA-only sections) | Fair | 208 | IG3: Medium (salt only) | I: 1 O: 0 | Unknown | UC
Beckman, 1995^111^ | Fair | 64 | Medium | I: 5 O: 0 | 12 months | Waitlist control
TONE, 1998^117^ (Also has arms in HD+PA section) | Good | 975 | IG1: High (decreased sodium only) | I: 32 O: 0 | 15–36 months; median, 29 months | UC with partial AC
Physical activity–only interventions
Arroll, 1995^128^ (Also has arms in HD+PA and PA-only sections) | Fair | 208 | IG2: Medium (PA only) | I: 1 O: 0 | Unknown | UC
Moreau, 2001^104^ | Fair | 24 | Medium (assumed) | I: assumed ≥1 O: 0 | Unknown | No advice

Abbreviations: AC = attention control; ADAPT = Activity Diet and Blood Pressure Trial; CG = control group; HIP = Hypertension Improvement Project; HTTP = Hypertension Teaching and Treatment Programme; IG = intervention group; LIHEF = Lifestyle Intervention against Hypertension in Eastern Finland; MD = physician; MI = minimal intervention; N = study population; pt = patient; TONE = Trial of Non-Pharmacological Interventions in the Elderly; UC = usual care.

Table 9 Behavioral Counseling Trials in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance: Intervention Characteristics

Study, Year | Quality | N | Intervention Intensity | # of Contacts Interactive (I), Other (O) | Duration of Intervention | Type of Control
Healthy diet and physical activity interventions
APHRODITE, 2011^88^ | Fair | 925 | High | I: 18 O: 0 | 18 months | UC
DPP, 2002^89^ | Good | 2,161 | High | I: ≥32^*^ O: 0 | 6 months core curriculum + 1.8–4.6 years maintenance (mean, 2.8 years) | MI^†^
EDIPS, 2001^90^ | Fair | 78 | Medium | I: 12 O: 0 | 24 months | No advice
EDIPS-Newcastle, 2009^91^ | Fair | 102 | High | I: 24 O: 20 | 5 years | UC
E-LITE, 2013^87^ | Good | 162 | High | I: 2 O: 42 | 15 months | UC
FDPS, 2001^118^ | Good | 522 | High | I: 16^‡^ O: 0 | Mean, 38.4 months | UC
HLC, 2011^92^ | Fair | 307 | High | I: 7 O: 0 | 6 months | Waitlist control
Kosaka, 2005^93^ | Fair | NR^§^ | High | I: 16 O: 0 | 48 months | MI
Live Well, Be Well, 2012^86^ | Good | 238 | High | I: 20 O: 12 | 12 months | Waitlist control
LLDP, 2012^94^ | Good | 312 | High | I: 16 O: 0 | 12 months | UC
Melbourne DPS, 2012^85^ | Fair | 92 | High | I: 7 O: 0 | 8 months | Waitlist control
PREDIAS, 2009^95^ | Fair | 182 | High | I: 12 O: 0 | 12 months | MI
SLIM, 2011^149^ | Fair | 147 | High | I: 15 (+ option to join exercise program for 1 hr/wk) O: 0 | 3 years║ | UC (single session)
Healthy diet–only interventions
Watanabe, 2003^97^ | Fair | 173 | Low (30 min) | I: 1 O: 1 | 6 months | UC
Physical activity–only interventions
Enhanced Fitness Trial, 2012^98^ | Fair | 302 | IG1: High (same content) | I: 23 O: 5 | 12 months | MI (referral to program)
Enhanced Fitness Trial, 2012^98^ | Fair | 302 | IG2: High (same content) | I: 26 O: 5 | 12 months | MI (referral to program)
Prepare Trial, 2009^99^ | Fair | 98 | IG1: Medium (counseling) | I: 3 O: 0 | 6 months | UC (mailed info)
Prepare Trial, 2009^99^ | Fair | 98 | IG2: Medium (counseling + pedometer) | I: 3 O: 0 | 6 months | UC (mailed info)

* Based on the 1.8-years maintenance phase.

† Recommendations reviewed annually.

‡ Based on a mean followup of 38.4 months +optional supervised exercise twice per week.

§ Only participants still present at 1-year observation (n=482) are reported.

║ Mean followup of 4.1 years (49.2 months).

Abbreviations: APHRODITE = Active Prevention in High-Risk Individuals of Diabetes Type 2 in and Around Eindhoven; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; E-LITE = Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care; FDPS = Finnish Diabetes Prevention Study; HLC = Healthy Living Course; IG = intervention group; LLDP = Lawrence Latino Diabetes Prevention Project; MI = minimal intervention; N = study population; NR = not reported; PREDIAS = Prevention of Diabetes Self-Management Program; SLIM = Study on Lifestyle Intervention and IGT Maastricht; UC = usual care.

Table 10 Behavioral Counseling Trials in Persons With Mixed Cardiovascular Risk Factors: Intervention Characteristics

Study, Year | Quality | N | Intervention Intensity | # of Contacts Interactive (I), Other (O) | Duration of Intervention | Type of Control
Healthy diet and physical activity interventions
Bo, 2007^146^ | Fair | 375 | Medium | I: 5 O: 0 | 12 months | UC
Cochrane, 2012^102^ | Fair | 601 | High | I: 7 O: 0 | 12 months | MI
Edelman, 2006^129^ | Fair | 154 | High | I: 52 O: 0 | 10 months | UC
EURO-ACTION, 2008^106^ | Fair | 2,384 | High | I: 8 O: 0 | 16 weeks^*^ | UC
GOAL, 2009^139^ | Good | 457 | Medium | I: 5 O: 0 | 8 months | UC
Hardcastle, 2008^168^ | Fair | 334 | Medium | I: 5 O: 0 | 6 months | UC
HIPS, 2012^103^ | Fair | 814 | High | I: 6 O: 0 | 12 months | Waitlist control
Hoorn, 2013^132^ | Fair | 622 | Medium | I: 9 O: 0 | 16 months | UC
IMPALA, 2009^133^ | Fair | 615 | Medium (50 min) | I: 3 O: 0 | 12 weeks | UC
Inter99, 2008^107^ | Fair | 4,053 | High | I: 10 O: 0 | 5 years | MI (annual session)
Logan Healthy Living, 2009^114^ | Fair | 434 | Medium (6 hr; phone only) | I: 18 O: 1 | 12 months | MI (3 sessions with brief, tailored feedback)
Nilsson, 1992^119^ | Fair | 63 | High | I: 15 O: 0 | 12 months | UC
PEGASE, 2008^120^ | Fair | 640 | High | I: 6 O: 0 | 6 months | UC
PHPP, 2007^121^ | Fair | 99 | Medium | I: 6 O: 0 | 12 months | UC
RIS, 1994^115^ | Good (KQ1) Fair (KQ2) | 508 | High | I: 7 (+5 for smokers [29%]) O: 0 | 4 months | UC
Rodriguez-Cristobal, 2012^173^ | Fair | 436 | Medium^†^ | I: 12 O: 0 | 2 years | UC
SPRING, 2012^100^ | Fair | 201 | Medium | I: 5^§^ O: 0 | 12 months | MI
WISEWOMAN California, 2010^108^ | Fair | 1,093 | Medium | I: 3 (+ telephone sessions^‡^ + incentives) O: 0 | 6 months | UC
WISEWOMAN NC, 2008^110^ | Fair | 236 | High | I: 16 O: 4 | 12 months | UC
Wister, 2007^140^ | Good | 315 | Medium | I: 2 (+4 more for quitting smokers [<15%]) O: 1 | 1 year | UC
Physical activity–only interventions
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ | Fair | 878 | Medium | I: ≥4 O: 4 | 12 months | Waitlist control
NERS, 2012^109^ | Fair | 2,160 | Medium | I: 5 (+ option for exercise sessions) O: 0 | 8 months | Waitlist control
PAC, 2011^122^ | Fair | 120 | Medium | I: 7 O: 0 | 13 weeks | MI (tailored PA prescription)
PACE, 2005^131^ | Fair | 771 | Medium | I: 4 O: 0 | 8 weeks | UC
Kallings, 2009^141^ Kallings, 2008^176^ | Good | 101 | Medium | I: 4 O: 1 | 6 months | UC
LIFE, 2010^130^ | Fair | 126 | High | I: 23 O: 0 | 11 months | UC

* Assumed.

† Possibly high, but intervention NR.

‡ Number NR.

§ Median of 4.9 sessions.

Abbreviations: GOAL = Groningen Overweight and Lifestyle Study; IMPALA = Improving Patient Adherence to Lifestyle Advice; KQ = key question; LIFE = Lifestyle Interventions and Independence for elder; MI = minimal intervention; N = study population; NERS = National Exercise Referral Scheme; PA = physical activity; PAC = Physical Activity Counseling; PACE = Physician-based Assessment and Counseling for Exercise; PEGASE = Pan European Grid Advanced Simulation and State Examination; PHPP = Patient-motivated Health Promotion Program; RIS = Risk Factor Intervention Study; SPRING = Self-monitoring and Prevention of Risk Factors; UC = usual care.

Counseling interventions were aimed at promoting knowledge, motivation, and skills for healthy diet and/or increased physical activity (Appendix E). Individually-tailored healthy diet counseling included at least one, but most often a combination of messages, including: decreased portion sizes/calories; decreased fat, saturated fat, and cholesterol; decreased salt; increased fruits and vegetables; increased complex carbohydrates and/or fiber; decreased refined sugar; and alcohol in moderation. Individually-tailored physical activity counseling focused on increasing physical activity, some of which included optional supervised exercise sessions, pedometers, and diaries. Counseling interventions, regardless of focus on diet, physical activity, or combined lifestyle messages, included didactic education (i.e., with limited patient interaction) as well as individualized care plans, problem solving skills, and audit and feedback. A few interventions also included financial incentives (including low-cost exercise options) and family/spouse support. Although our review excluded interventions solely aimed at weight loss or weight management, many included trials involved weight loss or weight goals for participants who were overweight. Similarly, although our review excluded interventions solely aimed at smoking cessation, some counseling interventions included smoking cessation counseling when applicable. Some counseling interventions were paired with management algorithms to adjust medications (start, stop, change dosage). The vast majority of trials (k=47) used usual care as a comparator. Therefore, while we assume that persons in the control group received some sort of counseling, it was not well described in the majority of articles. Twelve trials used a wait-list control, in which participants in the control group likely did not receive active counseling during the trial period. Fourteen trials used minimal intervention as a control, and these trials included counseling that may not be provided as standard of care in most primary care settings (e.g., reminder email prompts to primary care clinicians, substantive nontailored written patient education materials, pedometers, brief annual counseling).

### Quality

All trials were rated as fair to good quality. Thirteen trials were excluded for poor quality (Appendix C). We included 11 good-quality and 63 fair-quality trials. We rated one trial as good quality for health outcomes (KQ 1), but only fair quality for intermediate health outcomes (KQ 2) because of higher attrition for measurement of intermediate outcomes. In general, the limitations for these fair-quality studies included: lack of reporting of details about randomization; small differences in baseline characteristics between intervention arms; lack of blinding of outcomes assessment (for nonobjective measures); attrition greater than 20 percent, but less than 40 percent; differential attrition between study arms; evidence of attrition bias or lack of details to assess for attrition bias; and lack of reporting on how missing data were handled or having completers-only analyses. Fidelity of, and adherence to, the intervention was not commonly reported.

## KQ 1 Do Primary Care–Relevant Behavioral Counseling Interventions for Healthy Diet and/or Physical Activity Improve CVD-Related Health Outcomes in Adults With Known CVD Risk Factors?

### Overall Results

Only 16 included trials reported measures of patient health outcomes (Table 11). Five of these trials reported CVD events, including mortality.89,115-118 Nine of these trials combined lifestyle interventions85,86,92,94,95,110,119-121 and two of the physical activity–only trials98,122 reported self-reported QOL or depression symptom outcomes. One additional physical activity counseling trial used QOL outcomes (the 36-Item Short-Form Health Survey [SF-36]), but only reported results for selected domains (subscores).123 Overall, there was no reduction in CVD events or mortality at 6 to 79 months across four of five trials reporting these outcomes. Event rates, however, were generally low. One good-quality trial, the Finnish Diabetes Prevention Study, found no difference in CVD events or mortality at the 10-year observational followup from the original trial.124 One early good-quality trial, the Risk Factor Intervention Study, was a high-intensity behavioral counseling intervention in conjunction with a protocol to start medication for dyslipidemia or elevated glucose or nicotine replacement therapy for tobacco smoking among Swedish men. This intervention reduced a composite measure of all CVD events compared with usual care at 6.6. years (relative risk [RR], 0.71 [95% CI, 0.51 to 0.99]).112 Overall, combined lifestyle interventions do not appear to improve self-reported depression symptoms (k=4) in persons with impaired fasting glucose or glucose tolerance at 6 to 12 months.85,92,94,95 Findings of benefit on self-reported QOL measures were mixed. While three combined lifestyle counseling interventions appeared to improve selected measures of QOL,86,110,119 two combined lifestyle counseling interventions120,121 and two physical activity–only counseling interventions98,122 showed no benefit on self-reported QOL at 6 to 12 months.

Table 11 Behavioral Counseling Trials: Key Question 1 Outcomes

Study, year Quality | N | Risk Population | Mean Age, y % Men | Intervention Type Intensity | Followup Time, mo | CVD Outcomes | Self-Reported QOL
PREMIER, 2003^116^ Good | 304 | HTN | 52 36.5 | HD+PA High | Short: 6 | Stroke↔^†^ TIA↔^†^ MI↔^†^ | NR^##^
PREMIER, 2003^116^ Good | 304 | HTN | 52 36.5 | HD+PA High | Intermediate: 18 | NR | NR
PREMIER, 2003^116^ Good | 304 | HTN | 52 36.5 | HD+PA High | Long: NR | -- | --
TONE, 1998^117^ Good | 975 | HTN | 67 52.0 | HD+PA High | Short: 9 | NR | NR
TONE, 1998^117^ Good | 975 | HTN | 67 52.0 | HD+PA High | Intermediate: 18^¶¶^ | NR | NR
TONE, 1998^117^ Good | 975 | HTN | 67 52.0 | HD+PA High | Long: 30 or 36^¶¶^ | Stroke↔ TIA↔ MI↔ Angina↔ CHF↔ Other CV↔ Total CV↔ | NR
DPP, 2002^89^ Good | 2,161 | IFG | 51 32.3 | HD+PA High | Short: NR | -- | --
DPP, 2002^89^ Good | 2,161 | IFG | 51 32.3 | HD+PA High | Intermediate: 12 + 24 | NR | NR
DPP, 2002^89^ Good | 2,161 | IFG | 51 32.3 | HD+PA High | Long: 36 | CVD-related deaths↔ Nonfatal CVD events↔ | NR
FDPS, 2001^118^ Good | 522 | IFG | 55 33.0 | HD+PA High | Short: 12 | NR | NR
FDPS, 2001^118^ Good | 522 | IFG | 55 33.0 | HD+PA High | Intermediate: 24 | NR | NR
FDPS, 2001^118^ Good | 522 | IFG | 55 33.0 | HD+PA High | Long: 120 | Mortality↔ CVD events↔ | NR
HLC, 2011^92^ Fair | 307 | IFG | 62 41.0^*^ | HD+PA High | Short: 6 | NR | Depression score^‡^↔
HLC, 2011^92^ Fair | 307 | IFG | 62 41.0^*^ | HD+PA High | Intermediate: NR | -- | --
HLC, 2011^92^ Fair | 307 | IFG | 62 41.0^*^ | HD+PA High | Long: NR | -- | --
Live Well, Be Well, 2012^86^ Good | 238 | IFG | 56 26.0^*^ | HD+PA High | Short: 6 | -- | Health Status^***^↑ QOL^†††^↑
Live Well, Be Well, 2012^86^ Good | 238 | IFG | 56 26.0^*^ | HD+PA High | Intermediate: 12 | NR | Health Status^***^↔ QOL^†††^↑
Live Well, Be Well, 2012^86^ Good | 238 | IFG | 56 26.0^*^ | HD+PA High | Long: NR | -- | --
LLDP, 2012^94^ Good | 312 | IFG | 52 25.6 | HD+PA High | Short: NR | -- | --
LLDP, 2012^94^ Good | 312 | IFG | 52 25.6 | HD+PA High | Intermediate: 12 | NR | Depression score^§^↔
LLDP, 2012^94^ Good | 312 | IFG | 52 25.6 | HD+PA High | Long: NR | -- | --
Melbourne DPS, 2012^85^ Fair | 92 | IFG | 65 27.0 | HD+PA High | Short: NR | -- | --
Melbourne DPS, 2012^85^ Fair | 92 | IFG | 65 27.0 | HD+PA High | Intermediate: 12 | NR | Depression score^‡‡‡^↔
Melbourne DPS, 2012^85^ Fair | 92 | IFG | 65 27.0 | HD+PA High | Long: NR | -- | --
PREDIAS, 2009^95^ Fair | 182 | IFG | 56 57.0 | HD+PA High | Short: NR | -- | --
PREDIAS, 2009^95^ Fair | 182 | IFG | 56 57.0 | HD+PA High | Intermediate: 12 | NR | % Depression^§^↔ QOL║↔
PREDIAS, 2009^95^ Fair | 182 | IFG | 56 57.0 | HD+PA High | Long: NR | -- | --
Enhanced Fitness Trial, 2012^98^ Fair+ | 302 | IFG | 67 97.0 | PA only High | Short: NR | -- | --
Enhanced Fitness Trial, 2012^98^ Fair+ | 302 | IFG | 67 97.0 | PA only High | Intermediate: 12 | NR | QOL^¶^↔
Enhanced Fitness Trial, 2012^98^ Fair+ | 302 | IFG | 67 97.0 | PA only High | Long: NR | -- | --
Nilsson, 1992^119^ Fair | 63 | Mixed | 56^*^ 78.0^*^ | HD+PA High | Short: NR | -- | --
Nilsson, 1992^119^ Fair | 63 | Mixed | 56^*^ 78.0^*^ | HD+PA High | Intermediate: 12 | NR | Health status^§§^↑
Nilsson, 1992^119^ Fair | 63 | Mixed | 56^*^ 78.0^*^ | HD+PA High | Long: NR | -- | --
PEGASE, 2008^120^ Fair | 640 | Mixed | 57^*^ 60.0^*^ | HD+PA High | Short: 6 | NR | QOL (PCS)^††^↑ QOL (MCS)^††^↔
PEGASE, 2008^120^ Fair | 640 | Mixed | 57^*^ 60.0^*^ | HD+PA High | Intermediate: NR | -- | --
PEGASE, 2008^120^ Fair | 640 | Mixed | 57^*^ 60.0^*^ | HD+PA High | Long: NR | -- | --
RIS, 1998^112^ Good | 508 | Mixed | 66 100.0 | HD+PA High | Short: NR | -- | --
RIS, 1998^112^ Good | 508 | Mixed | 66 100.0 | HD+PA High | Intermediate:12 | Total mortality↔ | NR
RIS, 1998^112^ Good | 508 | Mixed | 66 100.0 | HD+PA High | Long: 36^‡‡^ | Total mortality↔ CVD mortality↔ MI↔ Stroke↔ First CV event↔ CVD events↔ | NR
WISEWOMAN NC, 2008^110^ Fair | 236 | Mixed | 53 0 | HD+PA High | Short: 6 | NR | QOL^**^↔
WISEWOMAN NC, 2008^110^ Fair | 236 | Mixed | 53 0 | HD+PA High | Intermediate: 12 | NR | QOL^**^↔
WISEWOMAN NC, 2008^110^ Fair | 236 | Mixed | 53 0 | HD+PA High | Long: NR | -- | --
PHPP, 2007^121^ Fair | 99 | Mixed | 64^*^ 42.4^*^ | HD+PA Medium | Short: NR | -- | --
PHPP, 2007^121^ Fair | 99 | Mixed | 64^*^ 42.4^*^ | HD+PA Medium | Intermediate: 12 | NR | QOL^#^↔
PHPP, 2007^121^ Fair | 99 | Mixed | 64^*^ 42.4^*^ | HD+PA Medium | Long: NR | -- | --
PAC, 2011^122^ Fair | 120 | Mixed | 47^*^ 32^*^ | PA only Medium | Short: 6 | NR | QOL║║↔
PAC, 2011^122^ Fair | 120 | Mixed | 47^*^ 32^*^ | PA only Medium | Intermediate: NR | -- | --
PAC, 2011^122^ Fair | 120 | Mixed | 47^*^ 32^*^ | PA only Medium | Long: NR | -- | --

* Calculated.

† Health outcomes for entire study population, not stratified by HTN status.

‡ Based on DASS-21.

§ Based on CES-D.

║ Psychological well-being using WHO-5.

¶ SF-36, general health and physical function.

# Using GHQ-30.

** Based on SF-8, PCS and MCS both↔.

†† SF-36.

‡‡ Health outcomes not reported at 72-month followup.

§§ Visual analogue scale.

║║ Based on SF-12, PCS and MCS.

¶¶ Results for combined salt reduction and weight loss arm; results similar for sodium reduction arm alone.

## QOL outcomes were not reported separately for persons with HTN.

*** Self-rated health using Likert Scale.

††† Psychological Well-being II Scale.

‡‡‡ Hospital Anxiety and Depression Scale.

Abbreviations: CES-D = Center for Epidemiologic Studies Depression Scale; CHF = congestive heart failure; CV = cardiovascular; CVD = cardiovascular disease; DASS = Depression Anxiety & Stress Scale; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; FDPS = Finnish Diabetes Prevention Study; HD = healthy diet; HLC = Healthy Living Course; HTN = hypertension; IFG = impaired fasting glucose; LLDP = Lawrence Latino Diabetes Prevention Project; MCS = Mental Component Summary; MI = myocardial infarction; N = study population; NR = not reported; PA = physical activity; PAC = Physical Activity Counseling; PCS = Physical Component Summary; PEGASE = Pan European Grid Advanced Simulation and State Estimation; PHPP = Patient-motivated Health Promotion Program; PREDIAS = Prevention of Diabetes Self-Management Program; QOL = quality of life; SF = Short-form Health Survey; TIA = transient ischemic attack; TONE = Trial of Non-Pharmacological Interventions in the Elderly.

Sparse reporting of both CVD events and self-reported measures of depression symptoms or QOL do not allow for definitive conclusions as to whether or not behavioral counseling interventions can improve patient health outcomes. We did not consider diabetes incidence or changes in CVD risk score as health outcomes. We discuss these outcomes with intermediate health outcomes in KQ 2.

### Detailed Results for CVD Events and/or Mortality

Four good-quality trials (n=3,962) of high-intensity combined lifestyle behavioral counseling interventions did not reduce CVD outcomes or mortality (Table 11; Appendix G Table 1).89,116-118 These event rates were very low, however. DPP (n=2,161) was aimed at preventing diabetes in overweight persons with impaired fasting glucose.89 The mean age of participants was 51 years and about one quarter to one third of participants had hypertension or dyslipidemia, respectively. PREMIER (n=304, hypertension subgroup only) was aimed at lowering blood pressure in persons who were not yet taking medications.116 The mean age of participants was 52 years and the mean SBP at baseline was 144 mm Hg. The Trial of Non-pharmacologic Intervention in the Elderly (TONE) (n=975) was aimed at lowering blood pressure in persons who were already taking antihypertension medications; participants were older, with a mean age of 67 years, and the mean SBP at baseline was 128 mm Hg.117 None of these studies included persons with diabetes. PREMIER only had 6 months of followup. While DPP and TONE reported longer-term followup (up to 36 months), they had low CVD event rates at approximately 6 to 15 CVD events per 1,000 person-years. One good-quality trial, the Finnish Diabetes Prevention Study (n=522), was conducted in Finland and evaluated a high-intensity combined lifestyle counseling intervention to prevent diabetes. This trial reported long-term observational followup on mortality and CVD events from the original trial.124 At approximately 10 years, the study reported no statistically significant difference in mortality (hazard ratio [HR], 0.57 [95% CI, 0.21 to 1.58]) (2.2 vs. 3.8 deaths per 1,000 person-years in the intervention and control groups, respectively) or CVD events (HR, 1.04 [95% CI, 0.72 to 1.51]) (22.9 vs. 22.0 events per 1,000 person-years in the intervention and control groups, respectively) between the group originally assigned to a high-intensity combined lifestyle intervention to prevent diabetes and the usual care control group.

The Risk Factor Intervention Study (n=508) was also a good-quality trial that evaluated a high-intensity behavioral counseling intervention that reported CVD outcomes, including mortality.112 This trial, however, was conducted in Sweden in the late 1980s and only included men. The mean age of participants was 66 years, all participants had hypertension, the mean SBP was 155 mm Hg, and three quarters of participants also had dyslipidemia (mean LDL cholesterol, 178 mg/dL). Notably, 29 percent of participants were current smokers and 22 percent had diabetes. Eight percent of participants had a previous myocardial infarction (MI). In addition to this population being at much higher risk for CVD events than those in the other four trials, the intervention included a protocol to start medication for dyslipidemia or elevated glucose or nicotine replacement therapy if counseling was not sufficient. At 6.6 years, 41 persons had died in the intervention group compared with 64 persons in the usual care group (RR, 0.62 [95% CI, 0.42 to 0.92]). The trial reported 63 CVD events (fatal or nonfatal MI or cerebrovascular accident) in the intervention group compared with 84 CVD events in the usual care group (RR, 0.71 [95% CI, 0.51 to 0.99]).112 It is unclear if the higher event rate (presumably due to a sicker population and inclusion of persons with diabetes and prior MI), the addition of medication adjustment to behavioral counseling, or the difference in standard of care for CVD risk reduction in the 1980s led to the difference in beneficial effect on health outcomes seen in this trial.

### Detailed Results for Self-Reported Patient Health Outcomes

Four trials (n=893), three fair-quality trials conducted in Australia and Germany and one good-quality trial conducted in the United States, evaluated high-intensity combined lifestyle behavioral interventions (Table 11).85,92,94,95 These trials reported that the interventions did not reduce self-reported depression symptoms as measured by the Depression Anxiety Stress Scale, Hospital Anxiety and Depression Scale, or Center for Epidemiologic Studies Depression Scale at 6 to 12 months. Although conducted in different countries, all trials included similar populations: middle-aged adults (mean age range, 52 to 65 years) at risk for developing diabetes (mean fasting blood glucose range, 93 to 106 mg/dL). The U.S. trial was conducted in mostly Latina women with a mean BMI of 34 kg/m^2^, which was somewhat higher than in the other three trials.94

Five fair-quality trials (n=1,268) evaluated combined lifestyle counseling interventions and showed mixed findings of benefit on self-reported QOL measures, two of which were conducted in the United States.86,110,119-121 While PREMIER also reported self-reported QOL measures, these results were not reported for the hypertension subgroup and are not discussed further.125 The three fair-quality trials (n=529) evaluating medium- to high-intensity counseling interventions showed greater improvement in self-reported QOL compared with usual care at 6 to 12 months.119,120 A small trial (n=63) conducted in Sweden showed a statistically significant difference in health status as measured on a 100-mm Visual Analogue Scale (72.8 vs. 54.5 in the intervention and usual care groups, respectively; p<0.001 at 12 months). This study was conducted by Nilsson and colleagues in 1992 among mostly men with hypertension and a mean age of 56 years.119 A more recent, and much larger, trial (n=640) conducted in France, the Pan European Grid Advanced Stimulation and State Examination, included both men and women with a mean age of 57 years and a mixture of CVD risk factors. This trial showed a small, but statistically significant, change in the physical component score (PCS) of the SF-36: an increase of 2.57 in the intervention group versus a decline of 0.5 in the usual care group at 6 months.120 This trial found no difference in results for the mental component score (MCS) of the SF-36. Finally, a recent trial, Live Well Be Well (n=230), evaluated a high-intensity diabetes prevention intervention in a racially diverse U.S. population with impaired fasting glucose.86 This trial showed a small, but statistically significant, improvement in QOL as measured by the Psychological Well-Being II scale at 6 and 12 months. However, there were no statistically significant differences between groups at 12 months in other measures, including self-rated health and the Psychological Distress II scale.

Two fair-quality trials (n=739) that evaluated medium- to high-intensity counseling interventions did not show any difference in self-reported QOL measures compared with usual care at 6 to 12 months. A small trial (n=99), the Patient-motivated Health Promotion Program, was conducted in Japanese men and women with a mean age of 64 years. Participants had hypertension or impaired fasting glucose and showed no change in General Health Questionnaire-30 scores at 12 months.121 A larger trial (n=236), WISEWOMAN North Carolina, was conducted in poor underinsured and uninsured American women. Participants had a mean age of 53 years and a mixture of hypertension, dyslipidemia, diabetes, and obesity. This trial reported no changes in the MCS or PCS of the SF-8 at 6 or 12 months.110

Two fair-quality trials (n=422) evaluated physical activity–only counseling interventions and showed no benefit on self-reported QOL measures.98,122 One U.S.-based trial (n=302), the Enhanced Fitness Trial, included men attending a VA hospital center with a mean age of 67 years and impaired fasting glucose. This trial found no improvements in SF-36 scores at 12 months between participants receiving a high-intensity counseling intervention to increase physical activity and those receiving a minimal intervention that included a referral to a physical activity and nutrition program.98 A Canadian trial (n=120), the Physical Activity Counseling trial, targeted inactive adults who had CVD risk factors, including hypertension, diabetes, and obesity. The mean age of participants was 47 years. This trial found no improvement in the MCS or PCS of the SF-12 at 6 months between participants receiving a medium-intensity counseling intervention to increase physical activity and those receiving a minimal intervention of a tailored physical activity prescription.122

## KQ 2 Do Primary Care–Relevant Behavioral Counseling Interventions for Healthy Diet and/or Physical Activity Improve CVD-Related Intermediate Outcomes in Adults With Known CVD Risk Factors?

### Overall Results

Seventy-one of the 74 included trials evaluating diet and/or physical activity counseling interventions reported intermediate health outcomes (Tables 1 and 2). Commonly reported intermediate outcomes included: objective lipid measures, blood pressure, glucose, weight, composite cardiovascular risk scores, medication use, and diabetes incidence (Appendix D Tables 1–9). Of the 71 trials, only 14 trials could not be included in meta-analyses of intermediate health outcomes, primarily because of limitations in data reporting at the primary study level (e.g., no measure of dispersion).69,76,77,97,108,117,120,126-132 Therefore, we focus primarily on results of meta-analyses and discuss discrepancies between meta-analysis findings and trial results that we did not include in quantitative analyses. In a handful of instances, there were minor discrepancies in results presented in the meta-analyses and summary tables because unadjusted values were used in the meta-analyses (if adjusted values could not be used in quantitative pooling) and adjusted results were presented in the summary tables. These differences are noted in the summary tables (Tables 12–15).

Table 12 Behavioral Counseling Trials in Persons With Dyslipidemia or Elevated Cholesterol: Key Question 2 Outcomes

Study, Year Quality | N | Followup Time, mo | TC | LDL | TG | Weight/BMI | Other Intermediate Outcomes
Healthy diet and physical activity interventions
CouPLES, 2013^67^ Fair | 255 | Short: 11 | NR | ↔ | NR | NR | Changes in meds (%): no difference
CouPLES, 2013^67^ Fair | 255 | Intermediate: NA | -- | -- | -- | -- | --
CouPLES, 2013^67^ Fair | 255 | Long: NA | -- | -- | -- | -- | --
PRO-FIT, 2012^68^ Fair | 340 | Short: NA | -- | -- | -- | -- | --
PRO-FIT, 2012^68^ Fair | 340 | Intermediate: 12 | ↔ | NR | NR | BMI↔ | HDL↔ SBP↔ FBG↔
PRO-FIT, 2012^68^ Fair | 340 | Long: NA | -- | -- | -- | -- | --
RHPP Trial, 1993^69^ Fair | 1,197 | Short: NA | -- | -- | -- | -- | --
RHPP Trial, 1993^69^ Fair | 1,197 | Intermediate: NA | -- | -- | -- | -- | --
RHPP Trial, 1993^69^ Fair | 1,197 | Long: 30^§^ | ↔ | NR | NR | NR | NR
Healthy diet–only interventions
Anderson, 1992^70^ Fair | 177 | Short: NA | -- | -- | -- | -- | --
Anderson, 1992^70^ Fair | 177 | Intermediate: 12 | ↑ | ↑^*^ | ↔ | Weight↔^**^ | HDL↔ Started meds (%): no difference
Anderson, 1992^70^ Fair | 177 | Long: NA | -- | -- | -- | -- | --
Ammerman, 2003^74^ Keyserling, 1999^174^ Fair | 468 | Short: 6 | ↔ | ↔ | ↔ | Weight↑ | HDL↔ Started meds (%): increase^#^
Ammerman, 2003^74^ Keyserling, 1999^174^ Fair | 468 | Intermediate: 12 | ↔ | ↔ | ↔ | Weight↔ | HDL↔ Started meds (%): no difference
Ammerman, 2003^74^ Keyserling, 1999^174^ Fair | 468 | Long: NA | -- | -- | -- | -- | --
Bloemberg, 1991^75^ Fair | 80 | Short: 6 | ↑ | NR | NR | Weight↑ | HDL↔
Bloemberg, 1991^75^ Fair | 80 | Intermediate: NA | -- | -- | -- | -- | --
Bloemberg, 1991^75^ Fair | 80 | Long: NA | -- | -- | -- | -- | --
DEER, 1998^71^ | 189 | Short: NA | -- | -- | -- | -- | --
DEER, 1998^71^ | 189 | Intermediate: 12^†^ | ↑ | ↑ | ↔ | Weight↑ | HDL↔ SBP↔ DBP↔ FBG↑ 2-GTT↑^#^ METS incidence, n (%)↑
DEER, 1998^71^ | 189 | Long: NA | -- | -- | -- | -- | --
Delahanty, 2001^72^ Good | 90 | Short: 6 | ↑ | ↔ | ↔ | Weight↑^**^ | HDL↔
Delahanty, 2001^72^ Good | 90 | Intermediate: 12 | ↔ | ↔ | ↔ | Weight↔ | HDL↔
Delahanty, 2001^72^ Good | 90 | Long: NA | -- | -- | -- | -- | --
Hyman, 1998^76^ Fair | 123 | Short: 6 | ↔ | NR | NR | Weight↔ | Started meds (%): no difference
Hyman, 1998^76^ Fair | 123 | Intermediate: NA | -- | -- | -- | -- | --
Hyman, 1998^76^ Fair | 123 | Long: NA | -- | -- | -- | -- | --
Johnston, 1995^77^ Fair | 179 | Short: 6^§^ | ↔ | ↔ | NR | BMI↔ Weight↔ | HDL↔
Johnston, 1995^77^ Fair | 179 | Intermediate: NA | -- | -- | -- | -- | --
Johnston, 1995^77^ Fair | 179 | Long: NA | -- | -- | -- | -- | --
Moy, 2001^73^ Fair | 235 | Short: NA | -- | -- | -- | -- | --
Moy, 2001^73^ Fair | 235 | Intermediate: 24 | NR | ↑ | ↔ | BMI↔ | HDL↔
Moy, 2001^73^ Fair | 235 | Long: NA | -- | -- | -- | -- | --
Neil, 1995^78^ Fair | 309 | Short: 6^§^ | ↔ | ↔ | ↔ | BMI↔ | HDL↔
Neil, 1995^78^ Fair | 309 | Intermediate: NA | -- | -- | -- | -- | --
Neil, 1995^78^ Fair | 309 | Long: NA | -- | -- | -- | -- | --
NFPMP, 2002^79^ | 143 | Short: 6 | NR | NR | NR | BMI↑ Weight↑ | NR
NFPMP, 2002^79^ | 143 | Intermediate: 12 | ↔ | ↔ | ↔ | BMI↑ Weight↑ | HDL↔ Started meds (%): no difference
NFPMP, 2002^79^ | 143 | Long: NA | -- | -- | -- | -- | --
ODES,1995^80^ Fair | 98 | Short: NA | -- | -- | -- | -- | --
ODES,1995^80^ Fair | 98 | Intermediate: 12 | ↔ | ↔ | ↔ | BMI↑ Weight↑ | HDL↔ SBP↑ DBP↔ FBG↑ 1-GTT↔ METS (%)↑
ODES,1995^80^ Fair | 98 | Long: NA | -- | -- | -- | -- | --
Southeast Cholesterol Project, 1997^81^ Fair | 372 | Short: 7 | ↔ | ↔║ | NR | NR | On meds (%): decrease
Southeast Cholesterol Project, 1997^81^ Fair | 372 | Intermediate: 12 | ↔║ | ↔║ | NR | NR | On meds (%): no difference
Southeast Cholesterol Project, 1997^81^ Fair | 372 | Long: NA | -- | -- | -- | -- | --
Stevens, 2003^82^ Fair | 616 | Short: NA | -- | -- | -- | -- | --
Stevens, 2003^82^ Fair | 616 | Intermediate: 12 | ↔ | NR | NR | NR | NR
Stevens, 2003^82^ Fair | 616 | Long: NA | -- | -- | -- | -- | --
Tomson, 1995^83^ Tomson, 1994^175^ Fair | 92 | Short: NA | -- | -- | -- | -- | --
Tomson, 1995^83^ Tomson, 1994^175^ Fair | 92 | Intermediate: 12 | ↔ | NR | ↔ | NR | HDL↓^¶^
Tomson, 1995^83^ Tomson, 1994^175^ Fair | 92 | Long: NA | -- | -- | -- | -- | --

* IG2 only.

† Outcome by men and women separately; no difference between sexes.

§ Results for IG1 and IG2 combined; no difference between groups.

║ ↑ in persons not taking lipid-lowering medications.

¶ HDL cholesterol was statistically significantly higher in control group. Authors state that more women were in the control group and that HDL is generally higher in women. Outcome not adjusted for sex.

# p-value NR.

** Because of the adjustment of some reported data, values may be different than the unadjusted values reported in meta-analysis.

Abbreviations: BMI = body mass index; CouPLES = Couples Partnering for Lipid Enhancing Strategies; DBP = diastolic blood pressure; DEER = Diet and Exercise for Elevated Risk; FBG = fasting blood glucose; GTT = glucose tolerance test; HDL = high-density lipoprotein; LDL = low-density lipoprotein; meds = medications; METS = metabolic syndrome; N = study population; n = sample population; NA = not available; NFPMP = Nijmegen Family Practices Monitoring Project; NR = not reported; ODES = Oslo Diet and Exercise Study; RHPP = Rural Health Promotion Project; TC = total cholesterol; TG = triglycerides.

Table 13 Behavioral Counseling Trials in Persons With Hypertension: Key Question 2 Outcomes

Study, Year Quality | N | Followup Time, mo | SBP | DBP | Weight/BMI | Other Intermediate Outcomes
Healthy diet and physical activity interventions
ADAPT, 2006^138^ Fair | 241 | Short: NA | -- | -- | -- | --
ADAPT, 2006^138^ Fair | 241 | Intermediate: 12 | NR | NR | Weight↑ | TC (mg/dL)↔ HDL (mg/dL)↔ LDL (mg/dL)↑ TG (mg/dL)↔ FBG (mg/dL)↔
ADAPT, 2006^138^ Fair | 241 | Long: 36 | ↔ | ↔ | Weight↔ | Composite CVD risk^*^↔ Change in need for antiHTN meds (%): no difference Started statins (%)↔ Statin dose decreased (%)↔ TC (mg/dL)↑^##^ HDL (mg/dL)↔ LDL (mg/dL) NR TG (mg/dL)↔ FBG (mg/dL)↔
Applegate, 1992^127^ Fair | 56 | Short: 6 | ↑ | ↑ | Weight↑ | NR
Applegate, 1992^127^ Fair | 56 | Intermediate: NA | -- | -- | -- | --
Applegate, 1992^127^ Fair | 56 | Long: NA | -- | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD- & PA-only sections) | 208 | Short: 6 | ↔ | ↔ | NR | HDL↑
Arroll, 1995^128^ Fair (Also arms in HD- & PA-only sections) | 208 | Intermediate: NA | -- | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD- & PA-only sections) | 208 | Long: NA | -- | -- | -- | --
Bosworth, 2009^84^ Fair | 477 | Short: NA | -- | -- | -- | --
Bosworth, 2009^84^ Fair | 477 | Intermediate: 12 | ↑ | ↑ | NR | NR
Bosworth, 2009^84^ Fair | 477 | Long: 24 | ↑^***^ | ↑^***^ | NR | NR
HIP, 2009^136^ Fair | 574 | Short: 6 | MD↔ Pt↑ | MD↔ Pt↑ | Weight: MD↔ Pt↑ | NR
HIP, 2009^136^ Fair | 574 | Intermediate: 18 | MD↔ Pt↔ | MD↔ Pt↔ | Weight: MD↔ Pt↔ | NR
HIP, 2009^136^ Fair | 574 | Long: NA | -- | -- | -- | --
HTTP, 1993^134^ Fair | 200 | Short: NA | -- | -- | -- | --
HTTP, 1993^134^ Fair | 200 | Intermediate: 18 | ↔ | ↑ | NR | Number of meds per person: decrease
HTTP, 1993^134^ Fair | 200 | Long: NA | -- | -- | -- | --
Hyman, 2007^135^ Fair | 281 | Short: 6 | ↔ | ↔ | BMI↔ | TC (mg/dL)↔
Hyman, 2007^135^ Fair | 281 | Intermediate: 18^†^ | ↔ | ↔ | BMI↔ | TC (mg/dL)↔
Hyman, 2007^135^ Fair | 281 | Long: NA | -- | -- | -- | --
LIHEF, 2002^137^ Fair | 715 | Short: NA | -- | -- | -- | --
LIHEF, 2002^137^ Fair | 715 | Intermediate: 12 and 24^‡^ | ↔ | ↔^§^ | Weight↑ | TC (mg/dL)↑^§^ HDL (mg/dL)↔ LDL (mg/dL)↑^¶¶^ TG (mg/dL)↔
LIHEF, 2002^137^ Fair | 715 | Long: NA | -- | -- | -- | --
Migneault, 2012^126^ Fair | 337 | Short: 8 | ↔ | ↔ | NR | % with BP control (<140/90 mm Hg)↔
Migneault, 2012^126^ Fair | 337 | Intermediate: 12║ | ↔ | ↔ | NR | NR
Migneault, 2012^126^ Fair | 337 | Long: NA | -- | -- | -- | --
PREMIER, 2003^116^ Good | 304 | Short: 6 | ↑ | ↑ | Weight↔ | % optimal BP control (<120/80 mm Hg)↑ Use of meds (%): decrease % HTN↑^¶^ TC (mg/dL)^#^↑ LDL (mg/dL)^#^↔ HDL (mg/dL)^#^↔ TG (mg/dL)^#^↑ Glucose (mg/dL)^#^↑ Composite CVD risk^*^↔
PREMIER, 2003^116^ Good | 304 | Intermediate: 18^††^ | ↔ | ↔ | NR | Use of meds (%): decrease % HTN↑ Change in HTN status↔^‡‡^
PREMIER, 2003^116^ Good | 304 | Long: NA | -- | -- | -- | --
Rodriguez, 2012^113^ Fair (poor for diet) | 533 | Short: 6 | ↔ | NR | NR | NR
Rodriguez, 2012^113^ Fair (poor for diet) | 533 | Intermediate: 12 | ↔ | NR | NR | NR
Rodriguez, 2012^113^ Fair (poor for diet) | 533 | Long: NA | -- | -- | -- | --
TONE, 1998^117^ Good (Also arm in HD-only section) | 975 | Short: 9 | NR | NR | Weight↑ | NR
TONE, 1998^117^ Good (Also arm in HD-only section) | 975 | Intermediate: 18 | NR | NR | Weight↑ | % Free of CVD events, HTN↑ % Free of meds: increase
TONE, 1998^117^ Good (Also arm in HD-only section) | 975 | Long: 30 or 36^§§^ | NR | NR | Weight↑ | % at BP goal (<140/90 mm Hg)↔ % Free of CVD events, HTN↑ % Free of meds: increase
Vitalum105 Fair | 1,629 | Short: 6 | NR | NR | NR | NR
Vitalum105 Fair | 1,629 | Intermediate: 18 | NR | NR | NR | NR
Vitalum105 Fair | 1,629 | Long: NA | -- | -- | -- | --
Healthy diet–only interventions
Arroll, 1995^128^ Fair (Also arms in HD+PA & PA-only sections) | 208 | Short: 6 | ↔ | ↔ | NR | NR
Arroll, 1995^128^ Fair (Also arms in HD+PA & PA-only sections) | 208 | Intermediate: NA | -- | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD+PA & PA-only sections) | 208 | Long: NA | -- | -- | -- | --
Beckman, 1995^111^ Fair | 64 | Short: 6 | NR | NR | NR | NR
Beckman, 1995^111^ Fair | 64 | Intermediate: 12 | ↑║║ | ↑║║ | Weight↔ BMI↔ | TC (mg/dL)↔ HDL (mg/dL)↔ TG (mg/dL)↔
Beckman, 1995^111^ Fair | 64 | Long: NA | -- | -- | -- | --
TONE, 1998^117^ Good (Also listed in HD+PA section) | 975 | Short: 9 | NR | NR | NR | NR
TONE, 1998^117^ Good (Also listed in HD+PA section) | 975 | Intermediate: 18 | NR | NR | NR | % Free of CVD events, HTN↑ % Free of meds: increase
TONE, 1998^117^ Good (Also listed in HD+PA section) | 975 | Long: 30 or 36^§§^ | NR | NR | Weight↑ | % Free of CVD events, HTN↑ % Free of meds: increase
Physical activity–only interventions
Arroll, 1995^128^ Fair (Also arms in HD+PA & HD-only sections) | 208 | Short: 6 | ↔ | ↔ | NR | HDL↑
Arroll, 1995^128^ Fair (Also arms in HD+PA & HD-only sections) | 208 | Intermediate: NA | -- | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD+PA & HD-only sections) | 208 | Long: NA | -- | -- | -- | --
Moreau, 2001^104^ Fair | 24 | Short: 6 | ↑ | ↔ | Weight↔ % body fat↔ | FBG (mg/dL)↔
Moreau, 2001^104^ Fair | 24 | Intermediate: NA | -- | -- | -- | --
Moreau, 2001^104^ Fair | 24 | Long: NA | -- | -- | -- | --

* Using 10-year FRS.

† Results are for IG1 and IG2 combined.

‡ Outcomes for 12 and 24 months unless otherwise noted.

§ Significant at 12 months, not at 24 months.

║ Outcomes derived from figure only.

¶ Among participants with HTN, those with HTN at followup.

# Patients with metabolic syndrome only.

** Health outcomes for entire study population, not stratified by HTN status.

†† IG1 and IG2 combined; outcomes for subgroup with HTN unless otherwise noted.

‡‡ Among participants with HTN, percent with normal BP and no medications at 18 months.

§§ Outcomes for IG2 (weight loss) and IG3 (sodium + weight loss) unless otherwise noted.

║║ Reports mean arterial pressure only.

¶¶ Significant at 24 months, not significant at 12 months.

## Because of the adjustment of some reported data, values may be different than the unadjusted values reported in the meta-analysis.

*** Significant for IG2 only (BP reduction not significant for IG1 at 24 months).

Abbreviations: ADAPT = Activity Diet and Blood Pressure Trial; BMI = body mass index; CVD = cardiovascular disease; DBP = diastolic blood pressure; FBG = fasting blood glucose; HD = healthy diet; HDL = high-density lipoprotein; HIP = Health Improvement Project; HTN = hypertension; HTTP = Hypertension Teaching and Treatment Programme; LDL = low-density lipoprotein; LIHEF = Lifestyle Intervention against Hypertension in Eastern Finland; MD = physician; meds = medications; N = study population; NA = not available; NR = not reported; PA = physical activity; pt = patient; SBP = systolic blood pressure; TC = total cholesterol; TG = triglycerides; TONE = Trial of Non-Pharmacological Interventions in the Elderly.

Table 14 Behavioral Counseling Trials in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance: Key Question 2 Outcomes

Study, Year Quality | N | Followup Time, mo | DM Incidence | Glucose (FBG/GTT/HbA1c) | BP, mm Hg | Lipids, mg/dL | Weight (lb, BMI) | Other Intermediate Outcomes
Healthy diet and physical activity interventions
APHRODITE, 2011^88^ Fair | 925 | Short: 6 | NR | FBG↔ 2h-GTT↔ | NR | NR | BMI↔ | NR
APHRODITE, 2011^88^ Fair | 925 | Intermediate: 18 | ↔ | FBG↔ 2h-GTT↔ | NR | NR | BMI↔ | NR
APHRODITE, 2011^88^ Fair | 925 | Long: NA | -- | -- | -- | -- | -- | __
DPP, 2002^89^ Good | 2,161 | Short: N/A | -- | -- | -- | -- | -- | __
DPP, 2002^89^ Good | 2,161 | Intermediate: 12 + 24 | NR | FBG↑ | SBP↑ DBP↑ | TG↑ HDL↑^†††^ | Weight↑ | NR
DPP, 2002^89^ Good | 2,161 | Long: 36 | ↑ | FBG↑ | SBP↑ DBP↑ | TC↔ LDL↔ TG↑ HDL↑^†††^ | Weight↑ | METs incidence↑
EDIPS, 2001^90^ Fair | 78 | Short: 6 | NR | FBG↔ 2h-GTT↔ A1c↔ | SBP: NR DBP↔ | TC↔ LDL↔ HDL↔ TG↔ | Weight↑ BMI↑ | NR
EDIPS, 2001^90^ Fair | 78 | Intermediate: 24 | ↔ | FBG↔ 2h-GTT↔ | NR | TC↔ LDL↔ | Weight↑ | NR
EDIPS, 2001^90^ Fair | 78 | Long: NR | -- | -- | -- | -- | -- | --
EDIPS-Newcastle, 2009^91^ Fair | 102 | Short: NA | -- | -- | -- | -- | -- | NR
EDIPS-Newcastle, 2009^91^ Fair | 102 | Intermediate: 12 | NR | -- | -- | -- | Weight↑ | NR
EDIPS-Newcastle, 2009^91^ Fair | 102 | Long: 36 (mean followup) | ↔ | NR | NR | NR | Weight↔ | NR
E-LITE, 2013^87^ Good | 162 | Short: 6 | NR | NR | NR | NR | Weight↑ BMI↑ | NR
E-LITE, 2013^87^ Good | 162 | Intermediate: 15 | ↔ | FBG↑ | SBP↔ DBP↔ | TC↑ LDL↔ HDL↔ TG↔ | Weight↑ BMI↑ | NR
E-LITE, 2013^87^ Good | 162 | Long: NA | -- | -- | -- | -- | -- | --
FDPS, 2001^118^ Good | 522 | Short: 12 | ↑ | FBG↑ GTT↑ A1c↑ | SBP↑ DBP↑ | TC↔ HDL↔ TG↑ | Weight↑ BMI↑ | Cholesterol-lowering drugs (%): no difference AntiHTN drugs (%): no difference
FDPS, 2001^118^ Good | 522 | Intermediate: 24 | ↑ | FBG↑ GTT↑ | SBP↑ DBP↑ | TC↔ TG↑ HDL↔ | Weight↑ | NR
FDPS, 2001^118^ Good | 522 | Long: 36 | ↑^#^ | FBG↔ GTT↔ A1c↑ | NR | TC↔ HDL↔ TG↑^†††^ | BMI↑ | NR
HLC, 2011^92^ Fair | 307 | Short: 6 | (%)↔ | FBG↑ 2h-GTT↔ | NR† | LDL↔ HDL↔ TG↔ | Weight↑ BMI↑^†††^ | NR
HLC, 2011^92^ Fair | 307 | Intermediate: NA | -- | -- | -- | -- | -- | --
HLC, 2011^92^ Fair | 307 | Long: NA | -- | -- | -- | -- | -- | --
Kosaka, 2005^93^ Fair | NR^**^ | Short: 12 | NR | NR | NR | NR | NR | NR
Kosaka, 2005^93^ Fair | NR^**^ | Intermediate: 24 | NR | NR | NR | NR | NR | NR
Kosaka, 2005^93^ Fair | NR^**^ | Long: 48 | ↑ | GTT↑^‡^ | NR | NR | Weight↑ | NR
Live Well, Be Well, 2012^86^ Good | 238 | Short: 6 | NR | FBG↔ | SBP↔ | LDL↔ HDL↔ TG↑ | Weight↑ | NR
Live Well, Be Well, 2012^86^ Good | 238 | Intermediate: 12 | NR | FBG↔ | SBP↔ | LDL↔ HDL↔ TG↔ | Weight↔ | NR
Live Well, Be Well, 2012^86^ Good | 238 | Long: NA | -- | -- | -- | -- | -- | --
LLDP94 Good | 312 | Short: NA | -- | -- | -- | -- | -- | --
LLDP94 Good | 312 | Intermediate: 12 | ↔ | FBG↔ HbA1c↑ | NR | NR | Weight↑ BMI↑ | NR
LLDP94 Good | 312 | Long: NA | -- | -- | -- | -- | -- | --
Melbourne DPS, 2012^85^ Fair | 92 | Short: NA | -- | -- | -- | -- | -- | --
Melbourne DPS, 2012^85^ Fair | 92 | Intermediate: 12 | NR | FBG↔ 2h-GTT↔ A1c↔ | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ TG↔ | Weight↑ BMI↑ | 5% weight loss goal (%)↑
Melbourne DPS, 2012^85^ Fair | 92 | Long: NA | -- | -- | -- | -- | -- | --
PREDIAS, 2009^95^ Fair | 182 | Short: NA | -- | -- | -- | -- | -- | --
PREDIAS, 2009^95^ Fair | 182 | Intermediate: 12 | NR | FBG↑ 2h-GTT↔ A1c↔ | SBP↔ DBP↔ | TC↔ | Weight↑ BMI↑ | NR
PREDIAS, 2009^95^ Fair | 182 | Long: NA | -- | -- | -- | -- | -- | --
SLIM149 Fair | 147 | Short: NA | -- | -- | -- | -- | -- | --
SLIM149 Fair | 147 | Intermediate: 12 + 24 | NR | FBG↔^†††^ 2h-GTT↑ A1c↔ | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ TG↑^††^ | Weight↑ BMI↑ | NR
SLIM149 Fair | 147 | Long: 36–72^‡‡^ | ↑ | FBG↔ 2h-GTT↑ A1c↔ | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ TG↔ | Weight↑ BMI↑ | % meds^§§^: no difference
Healthy diet–only interventions
Watanabe, 2003^97^ Fair | 173 | Short: NA | -- | -- | -- | -- | -- | --
Watanabe, 2003^97^ Fair | 173 | Intermediate: 12 | NR | FBG↔ 1h-GTT↔ 2h-GTT↑ | NR | NR | NR | NR
Watanabe, 2003^97^ Fair | 173 | Long: NA | -- | -- | -- | -- | -- | --
Physical activity–only interventions
Enhanced Fitness Trial, 2012^98^ Fair | 302 | Short: NA | -- | -- | -- | -- | -- | --
Enhanced Fitness Trial, 2012^98^ Fair | 302 | Intermediate: 12 | ↔ | FBG↔ A1c↔ | NR | TC↔ LDL↔ HDL↔ TG↔ | Weight↔ BMI↔ | NR
Enhanced Fitness Trial, 2012^98^ Fair | 302 | Long: NA | -- | -- | -- | -- | -- | --
Prepare Trial, 2009^99^ Fair | 98 | Short: 6║║ | NR | FBG↑ A1c↔ | SBP↔ DBP: NR | TC↔ HDL↔ TG↔ | Weight↔ | NR
Prepare Trial, 2009^99^ Fair | 98 | Intermediate: 12 + 24^¶¶^ | ↔ | FBG↔^##^ A1c↔ | SBP↔^***^ DBP: NR | TC↔ HDL↔^***^ TG↔^***^ | Weight↔ | NR
Prepare Trial, 2009^99^ Fair | 98 | Long: NA | -- | -- | -- | -- | -- | --

‡ Percent conversion from IGT to nonIGT.

§ Based on CES-D.

║ Psychological well-being using WHO-5.

¶ SF-36, general health and physical function.

# Up to 48 months.

** Trial only reports participants still present at 1-year observation (n=482).

†† ↔ at 12 months.

‡‡ Mean followup of 4.1 years.

§§ On BP-, lipid-, or glucose-lowering medications.

║║ Results for IG1 and IG2 unless otherwise noted.

¶¶ Results for 12 and 24 months unless otherwise noted.

## ↑at 12 months.

*** 12-month outcome only.

††† Because of the adjustment of some reported data, values may be different than the unadjusted values reported in the meta-analysis.

Abbreviations: APHRODITE = Active Prevention in High-Risk Individuals of Diabetes Type 2 in and Around Eindhoven; BMI = body mass index; BP = blood pressure; CES-D = Center for Epidemiologic Studies Depression Scale; DASS = Depression Anxiety & Stress Scale; DBP = diastolic blood pressure; DM = diabetes mellitus; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; E-LITE = Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care; FBG = fasting blood glucose; FDPS = Finnish Diabetes Prevention Study; GTT = glucose tolerance test; HbA1c = glycated hemoglobin; HDL = high-density lipoprotein; HLC = Healthy Living Course; HTN = hypertension; LDL = low-density lipoprotein; LLDP = Lawrence Latino Diabetes Prevention Project; METS = metabolic syndrome; meds = medications; N = study population; NA = not available; NR = not reported; PREDIAS = Prevention of Diabetes Self-Management Program; SBP = systolic blood pressure; SF = Short-form Health Survey; SLIM = Study on Lifestyle Intervention and IGT Maastricht; TC = total cholesterol; TG = triglycerides.

Table 15 Behavioral Counseling Trials in Persons With Mixed Cardiovascular Risk Factors: Key Question 2 Outcomes

Study, Year Quality | N | Followup Time, Mo | BP, mm Hg | Lipids, mg/dL | Glucose (FBG/GTT/HbA1c) | Weight (lb/BMI) | Other Intermediate Outcomes
Healthy diet and physical activity interventions
Bo, 2007^146^ Fair | 375 | Short: NA | -- | -- | -- | -- | --
Bo, 2007^146^ Fair | 375 | Intermediate: 12 | SBP↑ DBP↑ | TC↔ HDL↑ TG↑ | FBG↑ | Weight↑ BMI↑ | DM incidence (%)↑ HTN incidence (%)↔
Bo, 2007^146^ Fair | 375 | Long: NA | -- | -- | -- | -- | --
Cochrane, 2012^102^ Fair | 601 | Short: NA | -- | -- | -- | -- | --
Cochrane, 2012^102^ Fair | 601 | Intermediate: 12 | SBP↔ DBP↔ | TC↔ | NR | Weight↔ BMI↔ | Composite CVD risk^#^↔
Cochrane, 2012^102^ Fair | 601 | Long: NA | -- | -- | -- | -- | --
Edelman, 2006^129^ Fair | 154 | Short: 10 | NR | LDL↔ | NR | BMI↔ | Good BP control (%)↑
Edelman, 2006^129^ Fair | 154 | Intermediate: NA | -- | -- | -- | -- | --
Edelman, 2006^129^ Fair | 154 | Long: NA | -- | -- | -- | -- | --
EURO-ACTION, 2008^106^ Fair | 2,384 | Short: NA | -- | -- | -- | -- | --
EURO-ACTION, 2008^106^ Fair | 2,384 | Intermediate: 12 | SBP↔ DBP↔ | TC↑ LDL↑ | FBG↔ HbA1c↔ | BMI↑ | BP <140/90 (%)↑ DM incidence (%)↔ Started meds (%)^‡‡‡^
EURO-ACTION, 2008^106^ Fair | 2,384 | Long: NA | -- | -- | -- | -- | --
GOAL, 2009^139^ Good | 457 | Short: NA | -- | -- | -- | -- | --
GOAL, 2009^139^ Good | 457 | Intermediate: 12 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ | FBG↔ | Weight↑^§§§^ | Composite CVD risk^*^↔
GOAL, 2009^139^ Good | 457 | Long: 36 | NR | NR | NR | Weight↔^§§§^ | --
Hardcastle, 2008^168^ Fair | 334 | Short: 6 | SBP↔ DBP↑ | TC↔ LDL↔ HDL↔ TG↔ | NR | Weight↑ BMI↑ | NR
Hardcastle, 2008^168^ Fair | 334 | Intermediate: 18 | SBP↔ DBP↑ | TC↑ LDL↔ HDL↔ TG↔ | NR | BMI↑ | NR
Hardcastle, 2008^168^ Fair | 334 | Long: NA | -- | -- | -- | -- | --
HIPS, 2012^103^ Fair | 814 | Short: NA | -- | -- | -- | -- | --
HIPS, 2012^103^ Fair | 814 | Intermediate: 12 | SBP↔ | LDL↔ HDL↔ TG↔ | NR | Weight↔ BMI↔ | Composite CVD risk↔ Started meds (%)↔
HIPS, 2012^103^ Fair | 814 | Long: NA | -- | -- | -- | -- | --
Hoorn, 2013^132^ Fair | 622 | Short: 6 | NR | NR | NR | NR | Composite CVD risk *↔
Hoorn, 2013^132^ Fair | 622 | Intermediate: 12 | NR | NR | NR | NR | Composite CVD risk *↔
Hoorn, 2013^132^ Fair | 622 | Long: NA | -- | -- | -- | -- | --
IMPALA, 2009^133^ Fair | 615 | Short term: NA | -- | -- | -- | -- | --
IMPALA, 2009^133^ Fair | 615 | Intermediate: 12 | SBP↑ DBP: NR | Cholesterol ratio ↔ | NR | NR | Composite CVD risk *↑
IMPALA, 2009^133^ Fair | 615 | Long: NA | -- | -- | -- | -- | --
Inter99, 2008^107^ Fair | 4,053 | Short: NA | -- | -- | -- | -- | --
Inter99, 2008^107^ Fair | 4,053 | Intermediate: NA | -- | -- | -- | -- | --
Inter99, 2008^107^ Fair | 4,053 | Long: 60 | NR | NR | FBG↑ GTT↔ | BMI↔ | DM incidence (%)↔
Logan Healthy Living, 2009^114^ Fair | 434 | Short: 12 | NR | NR | NR | NR | NR
Logan Healthy Living, 2009^114^ Fair | 434 | Intermediate: 18 | NR | NR | NR | NR | NR
Logan Healthy Living, 2009^114^ Fair | 434 | Long: NA | -- | -- | -- | -- | --
Nilsson, 1992^119^ Fair | 63 | Short: NA | -- | -- | -- | -- | --
Nilsson, 1992^119^ Fair | 63 | Intermediate: 12 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ TG↔ | FBG↔ 1h-GTT↔ 2h-GTT↑ | Weight↔ | NR
Nilsson, 1992^119^ Fair | 63 | Long: NA | -- | -- | -- | -- | --
PEGASE, 2008^120^ Fair | 640 | Short: 6 | SBP↔ DBP: NR | TC↔ LDL↑ HDL↔ | NR | NR | Composite CVD risk^#^↔
PEGASE, 2008^120^ Fair | 640 | Intermediate: NA | -- | -- | -- | -- | --
PEGASE, 2008^120^ Fair | 640 | Long: NA | -- | -- | -- | -- | --
PHPP, 2007^121^ Fair | 99 | Short: NA | -- | -- | -- | -- | --
PHPP, 2007^121^ Fair | 99 | Intermediate: 12 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ TG↔ | HbA1c↔ | Weight↔ BMI↔ | DM incidence (%)↔
PHPP, 2007^121^ Fair | 99 | Long: NA | -- | -- | -- | --
RIS112 Good (KQ1), Fair (KQ2) | 508 | Short: NA | -- | -- | -- | -- | --
RIS112 Good (KQ1), Fair (KQ2) | 508 | Intermediate: 12 | SBP↔ DBP↑ | TC↑ LDL↑ HDL↔ TG↔ | FBG↔ | Weight↑ BMI↑ | NR
RIS112 Good (KQ1), Fair (KQ2) | 508 | Long: 79 | SBP↔^****^ DBP↔^****^ | TC↑ LDL↑ HDL↔^****^ TG↑ | FBG↔║║║ | Weight↑║║║ BMI↔║║║ | Started lipid meds (%): increase
Rodriguez-Cristobal, 2012^173^ Fair | 436 | Short: NA | -- | -- | -- | -- | --
Rodriguez-Cristobal, 2012^173^ Fair | 436 | Intermediate: 24 | SBP↑ DBP↑ | TC↑ LDL↔ HDL↔ TG↔ | NR^‡‡^ | BMI↑ | NR
Rodriguez-Cristobal, 2012^173^ Fair | 436 | Long: NA | -- | -- | -- | -- | --
SPRING, 2012^100^ Fair | 201 | Short: NA | -- | -- | -- | -- | --
SPRING, 2012^100^ Fair | 201 | Intermediate: 12 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ TG↔ | FBG↔ | BMI↔ | Composite CVD risk *↔ Started HTN meds (%): increase Started lipid meds (%): no change
SPRING, 2012^100^ Fair | 201 | Long: NA | -- | -- | -- | -- | --
WISEWOMAN California, 2010^108^ Fair | 1,093 | Short: NA | -- | -- | -- | -- | --
WISEWOMAN California, 2010^108^ Fair | 1,093 | Intermediate: 12 | SBP↑ DBP↔ | TC↔ HDL↔ | NR | BMI↔ | Composite CVD risk^#,¶¶¶^↔ Dyslipidemia (%)↔ Started lipid meds (%)^###^
WISEWOMAN California, 2010^108^ Fair | 1,093 | Long: NA | -- | -- | -- | -- | --
WISEWOMAN North Carolina, 2008^110^ Fair | 236 | Short: 6 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ | NR | Weight↔ | NR
WISEWOMAN North Carolina, 2008^110^ Fair | 236 | Intermediate: 12 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ | NR | Weight↔ | NR
WISEWOMAN North Carolina, 2008^110^ Fair | 236 | Long: NA | -- | -- | -- | -- | --
Wister, 2007^140^ Good | 315 | Short: NA | -- | -- | -- | -- | --
Wister, 2007^140^ Good | 315 | Intermediate: 12 | SBP↑ DBP: NR | TC↑ HDL↔ | FBG↔ | BM ↔ | Composite CVD risk^#^ ↑
Wister, 2007^140^ Good | 315 | Long: NA | -- | -- | -- | -- | --
Physical activity–only interventions
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ Fair | 878 | Short: NA | -- | -- | -- | -- | --
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ Fair | 878 | Intermediate: 12 | SBP^¶¶^↔ DBP^¶¶^↔ | TC↔ | NR | BMI↔ | Composite CVD risk^##^↔
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ Fair | 878 | Long: NA | -- | -- | -- | -- | --
NERS, 2012^109^ Fair | 2,160 | Short: NA | -- | -- | -- | -- | --
NERS, 2012^109^ Fair | 2,160 | Intermediate: 12 | NR | NR | NR | NR | NR
NERS, 2012^109^ Fair | 2,160 | Long: NA | -- | -- | -- | -- | --
PAC, 2011^122^ Fair | 120 | Short: 6 | NR | TC↔ LDL↔ HDL↔ TG↔ | NR^†††^ | NR^†††^ | NR
PAC, 2011^122^ Fair | 120 | Intermediate: NA | -- | -- | -- | -- | --
PAC, 2011^122^ Fair | 120 | Long: NA | -- | -- | -- | -- | --
PACE, 2005^131^ Fair | 771 | Short: 6 | NR | NR | NR | NR | NR
PACE, 2005^131^ Fair | 771 | Intermediate: 12 | NR | NR | NR | Weight↔ BMI↔ | NR
PACE, 2005^131^ Fair | 771 | Long: NA | -- | -- | -- | -- | --
Kallings, 2009^141^ Good | 101 | Short: 6 | SBP↔ DBP↔ | TC↑ LDL↔ HDL↔ TG↔ | FBG↔ A1c↑ | Weight↑ BMI↑ | NR
Kallings, 2009^141^ Good | 101 | Intermediate: NA | -- | -- | -- | -- | --
Kallings, 2009^141^ Good | 101 | Long: NA | -- | -- | -- | -- | --
LIFE, 2010^130^ Fair | 186 | Short: 6 | SBP↔ DBP↔ | TC↔ LDL↔ HDL↔ | FBG↔ | Weight↔ BMI↔ | NR
LIFE, 2010^130^ Fair | 186 | Intermediate: NA | -- | -- | -- | -- | --
LIFE, 2010^130^ Fair | 186 | Long: NA | -- | -- | -- | -- | --

* 10-year CVD risk based on SCORE.

† Poor-quality trials not abstracted.

‡ Based on DASS-21 scale.

║ Based on CES-D.

¶ Visual analogue scale.

# 10-year CVD risk using FRS.

** SF-36.

†† Using GHQ-30.

‡‡ A1c only reported for persons with DM.

§§ Based on SF-8, PCS and MCS both ↔.

║║ SF-36 used but PCS and MCS NR.

¶¶ Only reported for subgroup ages 65 to 79 years.

## 4-year CVD risk using FRS.

*** Based on SF-12, PCS and MCS.

††† Only 13-week outcomes reported, assume 24-week outcomes were not significant.

‡‡‡ More patients started angiotensin-converting enzyme inhibitors and statins in IG vs. CG, perhaps accounting for increase in persons meeting BP and lipid goals.

§§§ Subgroup analysis: ↑ for men, ↔ for women.

║║║ ↑ at 36 months.

¶¶¶ P=0.051.

### More persons in IG started lipid medications (p=NR).

**** 36-month outcomes.

†††† Based on 5-year CVD risk; risk score that was used NR.

Abbreviations: BMI = body mass index; BP = blood pressure; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; FBG = fasting blood glucose; GOAL = Groningen Overweight and Lifestyle Study; GTT = glucose tolerance test; HbA1c = glycated hemoglobin; HDL = high-density lipoprotein; HIPS = Health Improvement and Prevention Study; HTN = hypertension; IMPALA = Improving Patient Adherence to Lifestyle Advice; LDL = low-density lipoprotein; LIFE = Lifestyle Interventions and Independence for Elder; meds = medications; N = study population; NA = not available; NERS = National Exercise Referral Scheme; NR = not reported; PAC = Physical Activity Counseling; PACE = Physician-based Assessment and Counseling for Exercise; PEGASE = Pan European Grid Advanced Simulation and State Examination; PHPP = Physician-motivated Health Promotion Program; RIS = Risk Factor Intervention Study; SBP = systolic blood pressure; SPRING = Self-monitoring and Prevention of Risk Factors; TC = total cholesterol; TG = triglycerides.

Medium- to high-intensity diet and physical activity counseling interventions in persons selected for CVD risk factors (dyslipidemia, hypertension, and/or impaired fasting glucose or glucose intolerance) can decrease total cholesterol, LDL cholesterol, blood pressure, fasting glucose, diabetes incidence, and measures of weight (Appendix D Tables 1–9). Overall, benefits in these intermediate health outcomes appear to be most robust at 12 to 24 months. The limited number of trials that included longer-term followup limits interpretation of the benefit of findings to after 24 months. Across all trials that reported each specific outcome at 12 to 24 months, behavioral counseling appears to reduce total cholesterol (k=34) by an average of 4.48 mg/dL (95% CI, 6.36 to 2.59), LDL cholesterol (k=25) by 3.43 mg/dL (95% CI, 5.37 to 1.49), SBP (k=31) by 2.03 mm Hg (95% CI, 2.91 to 1.15), diastolic blood pressure (DBP) (k=24) by 1.38 mm Hg (95% CI, 1.92 to 0.84), fasting glucose (k=22) by 2.08 mg/dL (95% CI, 3.29 to 0.88), diabetes incidence (k=8) by an RR of 0.58 (95% CI, 0.37 to 0.89), and measures of weight (k=34) by a pooled mean difference of 0.26, using standardized units (standardized mean difference [SMD], 0.26 [95% CI, 0.35 to 0.16]). However, statistical heterogeneity across all trials for fasting glucose and weight outcomes was very high. Pooled effect sizes were generally similar for medium- versus high-intensity counseling interventions (Appendix F Figures 1–12). High-intensity combined lifestyle counseling in persons with impaired fasting glucose or glucose tolerance (k=5) reduces diabetes incidence in the longer term (RR, 0.55 [95% CI, 0.45 to 0.67]; I^2^=27%). Medium- to high-intensity counseling interventions focusing on dietary changes alone, primarily in persons with dyslipidemia who are not yet taking medications to lower cholesterol, can modestly lower total cholesterol (k=9) by 3.75 mg/dL (95% CI, 6.50 to 1.01; I^2^=24%) and LDL cholesterol (k=7) by 4.27 mg/dL (95% CI, 7.84 to 0.70; I^2^=40%) at 12 to 24 months. Both medium- and high-intensity interventions were effective. While high-intensity counseling resulted in slightly larger pooled estimates of total and LDL cholesterol and fasting glucose, the confidence interval estimates for medium- and high-intensity interventions overlapped (Appendix F Figure 3). Most physical activity–only counseling interventions were of medium intensity (k=8), although two were of high intensity. While our ability to draw definitive conclusions is limited by the small number of physical activity only–counseling trials (k=10) and heterogeneity (e.g., in populations studied, outcomes measured) among the trials, these types of interventions do not appear to improve intermediate CVD-related outcomes at 12 to 24 months.

The populations targeted and the types of counseling interventions evaluated were the two main a priori–specified explanatory factors for clinical (and statistical) heterogeneity in this body of literature. Populations were defined as selected primarily for having: 1) dyslipidemia, 2) hypertension, 3) impaired fasting glucose or glucose tolerance, or 4) a mixture of CVD risk factors, including dyslipidemia, hypertension, elevated glucose (including diabetes), metabolic syndrome, smoking, and obesity. We categorized interventions as focusing on: 1) both diet and physical activity counseling, 2) diet-only counseling, or 3) physical activity–only counseling. Therefore, we present our results stratified by population (Tables 16–19) and intervention type (Table 20).

Table 16 Pooled Effect Sizes for Intermediate Health Outcomes in Persons With Dyslipidemia

Followup, months | Cholesterol | | | Cholesterol and Mixed
Followup, months | Effect Size (95% CI) | K | I^2^ | Effect Size (95% CI) | K | I^2^
Total cholesterol, mg/dL
<12 | -4.18 (-8.53 to 0.18) | 5 | 38 | -4.52 (-7.92 to -1.13) | 9 | 34
12–24 | -3.31 (-5.98 to -0.64) | 9 | 24 | -5.11 (-7.77 to -2.45) | 22 | 68
>24 | NR | -- | -- | -19.31 (-25.36 to -13.25) | 1 | NA
Low-density lipoprotein cholesterol, mg/dL
<12 | -1.33 (-5.06 to 2.40) | 5 | 43 | -2.14 (-4.94 to 0.66) | 9 | 24
12–24 | -3.93 (-7.23 to -0.62) | 8 | 34 | -3.74 (-6.39 to -1.09) | 17 | 53
>24 | NR | -- | -- | -15.44 (-21.50 to -9.39) | 1 | NA
High-density lipoprotein cholesterol, mg/dL
<12 | -0.20 (-1.52 to 1.12) | 2 | 0 | 0.13 (-0.98 to 1.24) | 4 | 0
12–24 | -0.29 (-1.62 to 1.04) | 3 | 0 | 0.74 (-0.24 to 1.72) | 11 | 51
>24 | NR | -- | -- | 0.77 (-0.74 to 2.29) | 1 | NA
Triglycerides, mg/dL
<12 | NR | -- | -- | -10.82 (-26.23 to 4.64) | 2 | 34
12–24 | -17.86 (-33.10 to -2.62) | 3 | 0 | -13.35 (-20.34 to -6.35) | 6 | 0.0
>24 | NR | -- | -- | -19.47 (-31.61 to -7.33) | 1 | NA
Systolic blood pressure, mm Hg
<12 | NR | -- | -- | 0.12 (-3.44 to 3.68) | 3 | 60
12–24 | -0.19 (-0.53 to -0.14) | 3 | 73 | -1.83 (-3.19 to -0.47) | 17 | 57
>24 | NR | -- | -- | -2.00 (-4.80 to 0.80) | 1 | NA
Diastolic blood pressure, mm Hg
<12 | NR | -- | -- | -0.54 (-3.07 to 1.99) | 3 | 69
12–24 | -0.32 (-0.55 to -0.08) | 2 | 0 | -1.35 (-2.08 to -0.62) | 14 | 34
>24 | NR | -- | -- | -1.00 (-2.29 to 0.29) | 1 | NA
Fasting glucose, mg/dL
<12 | NR | -- | -- | -1.72 (-4.26 to 0.83) | 2 | 0
12–24 | -0.82 (-1.67 to 0.4) | 3 | 96 | -2.50 (-4.40 to -0.59) | 10 | 76
>24 | NR | -- | -- | -3.60 (-7.84 to 0.63) | 1 | NA
Diabetes incidence, RR
<12 | NR | -- | -- | NR | -- | --
12–24 | NR | -- | -- | 0.26 (0.09 to 0.76) | 2 | 0
>24 | NR | -- | -- | 1.03 (0.67 to 1.59) | 1 | NA
Adiposity, Hedges g
<12 | -0.20 (-0.38 to -0.02) | 5 | 41 | -0.20 (-0.32 to -0.08) | 9 | 26
12–24 | -0.38 (-0.78 to 0.03) | 6 | 90 | -0.22 (-0.35 to -0.10) | 18 | 80
>24 | NR | -- | -- | -0.23 (-0.52 to 0.06) | 2 | 76

Abbreviations: CI = confidence interval; NR = not reported; NA = not available; RR = relative risk.

Table 17 Pooled Effect Sizes for Intermediate Health Outcomes in Persons With Hypertension

Followup, months | Hypertension | | | Hypertension and Mixed
Followup, months | Effect Size (95% CI) | K | I^2^ | Effect Size (95% CI) | K | I^2^
Total cholesterol, mg/dL
<12 | -6.15 (-15.03 to 2.73) | 1 | NA | -5.37 (-10.22 to -0.53) | 5 | 25
12–24 | -3.43 (-5.78 to -1.08) | 4 | 0 | -5.77 (-8.73 to -2.80) | 17 | 71
>24 | -3.86 (-11.50 to 3.78) | 1 | NA | -11.77 (-26.90 to 3.36) | 2 | 90
Low-density lipoprotein cholesterol, mg/dL
<12 | NR | -- | -- | -4.22 (-8.82 to 0.38) | 4 | 0
12–24 | -5.29 (-7.53 to -3.05) | 2 | 0 | -4.20 (-7.07 to -1.33) | 11 | 58
>24 | NR | -- | -- | -15.44 (-21.50 to -9.39) | 1 | NA
High-density lipoprotein cholesterol, mg/dL
<12 | NR | -- | -- | 0.92 (-1.12 to 2.97) | 2 | 0
12–24 | -0.24 (-4.41 to 3.93) | 2 | 55 | 1.00 (-0.02 to 2.01) | 10 | 50
>24 | -0.77 (-2.50 to 0.96) | 1 | NA | 0.06 (-1.45 to 1.57) | 2 | 42
Triglycerides, mg/dL
<12 | NR | -- | -- | -10.82 (-26.29 to 4.64) | 2 | 34
12–24 | -0.54 (-5.92 to 4.83) | 2 | 0 | -5.62 (-12.08 to 0.84) | 5 | 45
>24 | NR | -- | -- | -19.47 (-31.61 to -7.33) | 1 | NA
Systolic blood pressure, mm Hg
<12 | -4.47 (-7.91 to -1.04) | 5 | 80 | -2.73 (-5.44 to -0.01) | 8 | 79
12–24 | -2.29 (-3.81 to -0.76) | 6 | 20 | -1.99 (-3.15 to -0.83) | 20 | 50
>24 | -2.00 (-4.97 to 0.97) | 1 | NA | -2.00 (-4.04 to 0.04) | 2 | 0.0
Diastolic blood pressure, mm Hg
<12 | -2.33 (-5.02 to -0.36) | 3 | 62 | -1.39 (-3.09 to 0.30) | 6 | 64
12–24 | -1.22 (-2.53 to 0.08) | 4 | 38 | -1.24 (-1.91 to -0.56) | 16 | 36
>24 | -1.00 (-3.22 to 1.22) | 1 | NA | -1.00 (-2.12 to 0.12) | 2 | 0
Fasting glucose, mg/dL
<12 | -1.80 (-15.29 to 11.68) | 1 | NA | -1.72 (-4.22 to 0.78) | 3 | 0
12–24 | -0.18 (-1.20 to 0.84) | 1 | NA | -1.59 (-3.92 to 0.74) | 8 | 76
>24 | 0.0 (-2.72 to 2.72) | 1 | NA | -1.42 (-4.87 to 2.03) | 2 | 49
Diabetes incidence, RR
<12 | NR | -- | -- | NR | -- | --
12–24 | NR | -- | -- | 0.26 (0.09 to 0.76) | 2 | 0
>24 | NR | -- | -- | 1.03 (0.67 to 1.59) | 1 | NA
Adiposity, Hedges g
<12 | -0.45 (-0.88 to -0.02) | 5 | 87 | -0.35 (-0.61 to -0.09) | 9 | 81
12–24 | -0.37 (-0.93 to 0.19) | 4 | 93 | -0.21 (-0.34 to -0.08) | 16 | 81
>24 | -0.08 (-0.33 to 0.17) | 1 | NA | -0.19 (-0.40 to 0.02) | 3 | 64

Abbreviations: CI = confidence interval; NA = not available; NR = not reported; RR = relative risk.

Table 18 Pooled Effect Sizes for Intermediate Health Outcomes in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance

Followup, months | Impaired Fasting Glucose/Tolerance | | | Impaired Fasting Glucose/Tolerance and Mixed
Followup, months | Effect Size (95% CI) | K | I^2^, % | Effect Size (95% CI) | K | I^2^, %
Total cholesterol, mg/dL
<12 | -5.01 (-17.45 to 7.42) | 2 | 50 | -5.04 (-10.22 to 0.14) | 6 | 31
12–24 | -2.62 (-5.43 to 0.91) | 8 | 0 | -5.21 (-8.264 to -2.15) | 21 | 68
>24 | -2.05 (-14.46 to 10.36) | 2 | 77 | -7.93 (-20.31 to 4.46) | 3 | 89
Low-density lipoprotein cholesterol, mg/dL
<12 | -4.15 (-8.39 to 0.09) | 3 | 0 | -4.18 (-7.30 to -1.07) | 7 | 0
12–24 | 0.04 (-3.45 to 3.54) | 6 | 0 | -2.57 (-5.70 to 0.55) | 15 | 55
>24 | 4.63 (-4.68 to 13.94) | 1 | NA | -5.73 (-25.40 to 13.94) | 2 | 92
High-density lipoprotein cholesterol, mg/dL
<12 | 0.46 (-2.38 to 3.30) | 3 | 56 | 0.88 (-0.78 to 2.53) | 5 | 26
12–24 | 0.38 (-0.28 to 1.04) | 6 | 16 | 0.90 (-0.14 to 1.65) | 14 | 55
>24 | 0.22 (-0.93 to 1.38) | 2 | 32 | 0.17 (-0.46 to 0.80) | 3 | 20
Triglycerides, mg/dL
<12 | -20.27 (-34.27 to -6.26) | 3 | 0 | -15.28 (-24.56 to -6.01) | 5 | 0
12–24 | -12.46 (-19.96 to 4.97) | 6 | 0 | -12.31 (-17.74 to -6.88) | 9 | 0
>24 | -8.85 (-20.76 to 3.06) | 1 | NA | -14.09 (-24.50 to -3.68) | 2 | 33
Systolic blood pressure, mm Hg
<12 | -1.10 (-6.42 to 4.22) | 3 | 59 | -0.23 (-2.85 to 2.39) | 6 | 51
12–24 | -2.42 (-4.02 to -0.82) | 8 | 35 | -1.96 (-3.10 to -0.82) | 22 | 54
>24 | -2.10 (-4.68 to 0.48) | 2 | 26 | -2.41 (-3.63 to -1.20) | 3 | 0
Diastolic blood pressure, mm Hg
<12 | -4.90 (-9.76 to -0.04) | 1 | NA | -1.19 (-3.58 to 1.19) | 4 | 65
12–24 | -1.50 (-2.64 to -0.35) | 6 | 43 | -1.33 (-2.01 to -0.65) | 18 | 48
>24 | -1.88 (-2.68 to -1.08) | 2 | 0 | -1.63 (-2.32 to -0.95) | 3 | 0
Fasting glucose, mg/dL
<12 | -1.69 (-3.82 to 0.45) | 5 | 59 | -1.51 (-3.15 to 0.13) | 7 | 45
12–24 | -2.05 (-3.86 to -0.24) | 11 | 74 | -2.04 (-3.58 to -0.50) | 18 | 74
>24 | -2.53 (-5.09 to 0.03) | 2 | 16 | -2.63 (-4.54 to -0.71) | 3 | 0
Diabetes incidence, RR
<12 | 1.70 (0.76 to 3.81) | 1 | NA | 1.70 (0.76 to 3.81) | 1 | NA
12–24 | 0.65 (0.42 to 1.02) | 6 | 34 | 0.58 (0.37 to 0.89) | 8 | 32
>24 | 0.55 (0.46 to 0.67) | 5 | 27 | 0.61 (0.46 to 0.79) | 6 | 61
Adiposity, Hedges g
<12 | -0.26 (-0.44 to 0.08) | 6 | 54 | -0.23 (-0.36 to -0.11) | 10 | 40
12–24 | -0.26 (-0.39 to -0.13) | 12 | 64 | -0.21 (-0.29 to -0.13) | 24 | 63
>24 | -0.63 (-1.21 to -0.04 | 3 | 94 | -0.46 (-0.84 to -0.09) | 5 | 93

Abbreviations: CI = confidence interval; NA = not available; RR = relative risk.

Table 19 Pooled Effect Sizes for Intermediate Health Outcomes in Persons in All Risk Groups

Followup, months | All Risk Groups
Followup, months | Effect Size (95% CI) | K | I^2^
Total cholesterol, mg/dL
<12 | -4.58 (-7.44 to -1.73) | 12 | 23
12–24 | -4.48 (-6.36 to -2.59) | 34 | 56
>24 | -7.03 (-16.46 to 2.40) | 4 | 85
Low-density lipoprotein cholesterol, mg/dL
<12 | -2.53 (-4.74 to -0.32) | 12 | 10
12–24 | -3.43 (-5.37 to -1.49) | 25 | 47
>24 | -5.73 (-25.40 to 13.94) | 2 | 92
High-density lipoprotein cholesterol, mg/dL
<12 | 0.38 (-0.72 to 1.49) | 7 | 17
12–24 | 0.69 (0.09 to 1.30) | 19 | 46
>24 | 0.02 (-0.40 to 0.44) | 4 | 8
Triglycerides, mg/dL
<12 | -15.28 (-24.56 to -6.01) | 5 | 0
12–24 | -8.85 (-13.91 to -3.78) | 14 | 32
>24 | -14.09 (-24.50 to -3.68) | 2 | 33
Systolic blood pressure, mm Hg
<12 | -2.36 (-4.78 to 0.06) | 11 | 77
12–24 | -2.03 (-2.91 to -1.15) | 31 | 48
>24 | -2.35 (-3.48 to -1.23) | 4 | 0
Diastolic blood pressure, mm Hg
<12 | -1.67 (-3.30 to -0.04) | 7 | 61
12–24 | -1.38 (-1.92 to -0.84) | 24 | 41
>24 | -1.58 (-2.23 to -0.93) | 4 | 0
Fasting glucose, mg/dL
<12 | -1.44 (-2.97 to 0.09) | 8 | 36
12–24 | -2.08 (-3.29 to -0.88) | 22 | 80
>24 | -1.89 (-3.73 to -0.04) | 4 | 22
Diabetes incidence, RR
<12 | 1.70 (0.76 to 3.81) | 1 | NA
12–24 | 0.58 (0.37 to 0.89) | 8 | 32
>24 | 0.61 (0.46 to 0.79) | 6 | 61
Adiposity, Hedges g
<12 | -0.30 (-0.42 to -0.17) | 20 | 71
12–24 | -0.26 (-0.35 to -0.16) | 34 | 80
>24 | -0.40 (-0.73 to -0.07) | 6 | 92

Abbreviations: CI = confidence interval; NA = not available; RR = relative risk.

Table 20 Pooled Effect Sizes for Intermediate Health Outcomes by Intervention Type

Followup, months | Healthy Diet + Physical Activity | | | Healthy Diet Only | | | Physical Activity Only
Followup, months | Effect Size (95% CI) | K | I^2^, % | Effect Size (95% CI) | K | I^2^, % | Effect Size (95% CI) | K | I^2^, %
Total cholesterol, mg/dL
<12 | -4.01 (-7.97 to -0.05) | 4 | 0 | -4.18 (-8.53 to 0.18) | 5 | 38 | -8.53 (-21.39 to 4.33) | 3 | 51
12–24 | -5.43 (-7.97 to -2.89) | 22 | 61 | -3.75 (-6.50 to -1.01) | 9 | 24 | 0.25 (-3.80 to 4.31) | 3 | 20
>24 | -7.03 (-16.46 to 2.40) | 4 | 85 | NR | -- | -- | NR | -- | --
Low-density lipoprotein cholesterol, mg/dL
<12 | -2.53 (-5.43 to 0.38) | 6 | 0 | -2.34 (-6.65 to 1.96) | 4 | 44 | -3.18 (-16.97 to 10.61) | 2 | 38
12–24 | -3.69 (-5.98 to -1.40) | 17 | 43 | -4.27 (-7.84 to -0.70) | 7 | 40 | 3.90 (-2.05 to 9.85) | 1 | NA
>24 | -5.73 (-25.40 to 13.94) | 2 | 92 | NR | -- | -- | NR | -- | --
High-density lipoprotein cholesterol, mg/dL
<12 | 1.13 (-0.69 to 2.95) | 3 | 30 | -0.20 (-1.52 to 1.12) | 2 | 0 | 0.48 (-4.65 to 5.61) | 2 | 50
12–24 | 0.98 (0.25 to 1.70) | 14 | 56 | -0.85 (-2.64 to 0.94) | 3 | 0 | -0.17 (-1.66 to 1.32) | 2 | 0
>24 | 0.02 (-0.40 to 0.44) | 4 | 8 | NR | -- | -- | NR | -- | --
Triglycerides, mg/dL
<12 | -13.99 (-28.40 to 0.42) | 3 | 20 | NR | -- | -- | -16.98 (-30.57 to -3.38) | 2 | 0
12–24 | -8.33 (-13.80 to -2.86) | 10 | 38 | -17.86 (-33.10 to -2.62) | 3 | 0 | 2.66 (-21.63 to 26.94) | 1 | NA
>24 | -14.09 (-24.50 to -3.68) | 2 | 33 | NR | -- | -- | NR | -- | --
Systolic blood pressure, mm Hg
<12 | -2.20 (-4.39 to -0.02) | 8 | 67 | NR | -- | -- | -2.12 (-11.82 to 7.57) | 3 | 90
12–24 | -2.06 (-3.03 to -1.08) | 27 | 50 | -3.34 (-7.48 to 0.80) | 2 | 67 | -0.54 (-3.64 to 2.56) | 2 | 23
>24 | -2.35 (-3.48 to -1.23) | 4 | 0 | NR | -- | -- | NR | -- | --
Diastolic blood pressure, mm Hg
<12 | -1.82 (-3.67 to 0.03) | 5 | 69 | NR | -- | -- | -1.10 (-5.58 to 3.38) | 2 | 45
12–24 | -1.30 (-1.93 to -0.68) | 21 | 48 | -1.90 (-3.35 to -0.46) | 2 | 0 | -1.40 (-3.36 to 0.56) | 1 | NA
>24 | -1.58 (-2.23 to -0.93) | 4 | 0 | NR | -- | -- | NR | -- | --
Fasting glucose, mg/dL
<12 | -0.98 (-2.85 to 0.89) | 4 | 47 | NR | -- | -- | -2.47 (-4.70 to -0.24) | 4 | 0
12–24 | -1.86 (-3.24 to -0.49) | 18 | 74 | -3.65 (-4.35 to -2.94) | 2 | 0 | -1.80 (-6.88 to 3.28) | 2 | 62
>24 | -1.89 (-3.73 to -0.04) | 4 | 22 | NR | -- | -- | NR | -- | --
Adiposity, Hedges g
<12 | -0.36 (-0.56 to -0.16) | 10 | 84 | -0.20 (-0.36 to -0.05) | 6 | 29 | -0.24 (-0.51 to 0.03) | 4 | 0
12–24 | -0.24 (-0.35 to -0.14) | 25 | 77 | -0.44 (-0.87 to -0.01) | 6 | 88 | -0.05 (-0.16 to 0.06) | 3 | 0
>24 | -0.40 (-0.73 to -0.07) | 6 | 92 | NR | -- | -- | NR | -- | --
Diabetes incidence, RR
<12 | 1.70 (0.76 to 3.81) | 1 | NA | NR | -- | -- | NR | -- | --
12–24 | 0.54 (0.34 to 0.88) | 6 | 40 | NR | -- | -- | 0.66 (0.11 to 4.11) | 2 | 38
>24 | 0.61 (0.46 to 0.79) | 6 | 61 | NR | -- | -- | NR | -- | --

Abbreviations: CI = confidence interval; NA = not available; NR = not reported; RR = relative risk.

### Results in Persons With Dyslipidemia

Seventeen fair- to good-quality counseling trials (n=4,963) selected primarily for persons with dyslipidemia.67-83 An additional 24 fair- to good-quality trials (n=15,997) selected participants for a mixture of risk factors, including dyslipidemia, and reported intermediate outcome measures (Table 12). Of the 17 trials in persons with dyslipidemia, we rated only one trial72 as good quality and all the others as fair quality. For limitations in fair-quality trials, please see the “Quality” section under “Description of Included Studies.” All but three trials conducted in persons selected primarily for dyslipidemia evaluated diet-only counseling. One of these trials was conducted in persons with familial hyperlipidemia (PRO-FIT), one evaluated a telephone counseling intervention (CouPLES [Couples Partnering for Lipid Enhancing Strategies]), and one was an older trial from 1993 (RHPP) that included both diet and physical activity counseling.67-69 The mean age in these trials ranged from 40.5 to 71 years (Table 3). Most trials included a fair representation of both men and women, except for three trials in mostly (or entirely) men67,75,80 and one trial in entirely women.82 Average baseline total and LDL cholesterol ranged from 233 to 282 mg/dL and from 156 to 200 mg/dL, respectively, in persons who were not taking lipid-lowering medications. The majority of trials (k=13) evaluated medium-intensity interventions. All but one trial used a usual care, wait list, or attention control.67 In this trial, CouPLES, the control group physicians received email reminders emphasizing the use of lipid-lowering medications. All but three trials (earlier trials from the 1990s) were included in the meta-analyses.69,76,77 For a similar description of trials in populations with mixed risk factors, please see the section below, “Results in Persons With Mixed CVD Risk Factors.”

The majority of trials conducted in persons selected primarily for dyslipidemia reported outcome measures of total (k=9) and LDL cholesterol (k=8) at 12 to 24 months (Table 16). Fewer trials (k=5) reported outcomes at less than 12 months. No trials reported longer-term outcomes (>24 months). At 12 to 24 months, medium- to high-intensity diet-only counseling trials reduced total (k=9) and LDL cholesterol (k=8) by 3.31 mg/dL (95% CI, 5.98 to 0.64) and 3.93 mg/dL (95% CI, 7.23 to 0.62), respectively (Figures 2 and 3). Because most trials included persons who had not yet started medications, these results are most applicable to persons who are not yet taking lipid-lowering medication. Looking more broadly across all types of medium- to high-intensity interventions in persons selected for dyslipidemia or a mixture of CVD risk factors, counseling interventions reduced total (k=22) and LDL cholesterol (k=17) by 5.11 mg/dL (95% CI, 7.77 to 2.45) and 3.74 mg/dL (95% CI, 6.39 to 1.09), respectively (Figures 4 and 5), at 12 to 24 months. The statistical heterogeneity is much higher in these combined pooled analyses, which reflects the greater clinical heterogeneity in population and intervention characteristics. High-intensity counseling resulted in slightly larger pooled estimates of total and LDL cholesterol, but results were not statistically significantly different from effects of medium-intensity counseling (Appendix F Figures 1 and 3). Two trials in persons explicitly with dyslipidemia76,77 and three trials in mixed CVD risk populations reporting lipid outcomes120,129,130 that could not be included in the meta-analyses only reported short-term (<12 months) outcomes. We could not include one fair-quality trial in the meta-analyses, WISEWOMAN California (n=1,093), because of data limitations. This study found no statistically significant reduction in total cholesterol between persons receiving a high-intensity combined lifestyle counseling intervention and usual care at 12 months. The baseline total cholesterol in this population, however, was not elevated (mean, 198.1 mg/dL).108 We could not include one fair-quality trial in the meta-analyses, RHPP (n=1,197), because of data limitations. This study, however, found no statistically significant difference in total cholesterol between persons receiving a medium-intensity combined lifestyle counseling intervention and usual care at 30 months.69 Limited available data prevent any definitive conclusions about the efficacy of lifestyle counseling interventions beyond 24 months.

Figure 2 Pooled Analysis of Total Cholesterol in Persons With Dyslipidemia, Sorted by Length of Followup Time

Figure 2 is a forest plot depicting the change in total cholesterol levels in persons with dyslipidemia. This figure is discussed in the Results section.

Figure 3 Pooled Analysis of Low-Density Lipoprotein Cholesterol in Persons With Dyslipidemia, Sorted by Length of Followup Time

Figure 3 is a forest plot depicting the change in low-density lipoprotein levels in persons with dyslipidemia. This figure is discussed in the Results section.

Figure 4 Pooled Analysis of Total Cholesterol in Persons With Dyslipidemia or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 4 is a forest plot depicting the change in total cholesterol levels in persons with dyslipidemia or multiple risk factors. This figure is discussed in the Results section.

Figure 5 Pooled Analysis of Low-Density Lipoprotein Cholesterol in Persons With Dyslipidemia or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 5 is a forest plot depicting the change in low-density lipoprotein levels in persons with dyslipidemia or multiple risk factors. This figure is discussed in the Results section.

Fewer trials reported HDL cholesterol and triglycerides as outcome measures (Table 16). The trials that did report HDL cholesterol found no statistically significant effects. While there were statistically significant reductions in triglycerides, there was evidence of publication bias due to small-study effects. Many studies also reported weight measures (i.e., weight and/or BMI) as an outcome. Across all trials in persons with dyslipidemia or a mixture of CVD risk factors, medium- to high-intensity counseling can reduce measures of weight (k=18) by an SMD of 0.22 (95% CI, 0.35 to 0.10) (Figure 6). The statistical heterogeneity of this pooled analysis, however, was very high. Two earlier trials from the 1990s appear to be outliers, which contributes to the statistical heterogeneity.71,80

Figure 6 Pooled Analysis of Weight in Persons With Dyslipidemia or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 6 is a forest plot depicting the change in weight in persons with dyslipidemia or multiple risk factors. This figure is discussed in the Results section.

### Results in Persons With Hypertension

Fourteen (n=4,990) of 15 fair- to good-quality trials67,69-87 in persons selected primarily for hypertension and 24 fair- to good-quality trials (n=15,997) in persons selected for a mixture of risk factors, including hypertension, reported intermediate outcome measures (Table 13). Of the 13 trials in persons with hypertension, only two trials were of good quality116,117 and the others were fair-quality. For limitations in fair-quality trials, please see the “Quality” section under “Description of Included Studies.” Two trials had multiple intervention arms evaluating diet or physical activity only versus combined lifestyle counseling.117,128 Therefore, we included a total of 13 combined diet and physical activity counseling interventions, three diet-only counseling interventions, and two physical activity–only counseling interventions. The mean age in these trials ranged from 51 to 67 years and most included an even representation of both men and women, except for two trials in mostly (or entirely) men111,113 and one trial in entirely women.104 The majority of trials included persons who were taking antihypertension medications. Only three trials explicitly targeted persons who were not yet taking medications.111,116,127 Average baseline SBP and DBP ranged from 127 to 162 mm Hg and from 71 to 96 mm Hg, respectively, in persons taking medications and averaged approximately 144/87 mm Hg in persons not yet taking them (Table 4). Nine trials evaluated medium-intensity84,104,105,111,113, 128,133-135 and six trials evaluated high-intensity116,117,126, 127,136,137 counseling interventions. Most trials used a usual care or wait list control in which participants were assumed to receive usual care as a comparator group, except for four trials in which the control group received minimal interventions.76,113,126,134 Four trials could not be included in the meta-analyses because of limitations in how data were reported in the primary studies.117,126-128 For a similar description of trials in populations with mixed risk factors, please see the section below, “Results in Persons With Mixed CVD Risk Factors.”

Medium- to high-intensity diet and physical activity counseling interventions resulted in reductions in blood pressure up to 12 to 24 months. Only three trials (two included in the meta-analyses) reported outcomes beyond 24 months. At 12 to 24 months, counseling trials conducted exclusively in persons with hypertension reduced SBP (k=6) and DBP (k=6) by 2.29 mm Hg (95% CI, 3.82 to 0.76) and 1.22 mm Hg (95% CI, 2.53 to -0.08), respectively (Figures 7–8). While point estimates of reductions in SBP were greatest in the short term (<12 months), the confidence intervals overlap with estimates at 12 to 24 months. Trials included a range of participants who were and were not taking medications. Therefore, these findings are applicable to both persons who are and are not yet taking medication. Looking more broadly across persons selected explicitly for hypertension and a mixture of CVD risk factors, medium- to high-intensity counseling interventions reduced SBP (k=20) and DBP (k=16) by 1.99 mm Hg (95% CI, 3.15 to 0.83) and 1.23 mm Hg (95% CI, 1.91 to 0.56), respectively (Figures 9–10), at 12 to 24 months. Pooled effect sizes were similar for medium- and high-intensity counseling interventions (Appendix F Figures 5 and 7).

Figure 7 Pooled Analysis of Systolic Blood Pressure in Persons With Hypertension, Sorted by Length of Followup Time

Figure 7 is a forest plot depicting the change in systolic blood pressure in persons with hypertension. This figure is discussed in the Results section.

Figure 8 Pooled Analysis of Diastolic Blood Pressure in Persons With Hypertension, Sorted by Length of Followup Time

Figure 8 is a forest plot depicting the change in diastolic blood pressure in persons with hypertension. This figure is discussed in the Results section.

Figure 9 Pooled Analysis of Systolic Blood Pressure in Persons With Hypertension or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 9 is a forest plot depicting the change in systolic blood pressure in persons with hypertension or multiple risk factors. This figure is discussed in the Results section.

Figure 10 Pooled Analysis of Diastolic Blood Pressure in Persons With Hypertension or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 10 is a forest plot depicting the change in diastolic blood pressure in persons with hypertension or multiple risk factors. This figure is discussed in the Results section.

Of the seven trials that were not included in the meta-analyses (k=4 for hypertension, k=3 for mixed CVD risk factors), four trials only reported outcomes at 6 months.120,127,128,130 One fair-quality trial, WISEWOMAN California (n=1,093), could not be included in the meta-analyses because of data limitations. This trial found a statistically significant reduction in SBP between persons receiving a high-intensity combined lifestyle counseling intervention and usual care at 12 months. These findings are consistent with findings from meta-analyses.108 One fair-quality trial (n=337) conducted by Migneault and colleagues found no statistically significant reduction in SBP or DBP between a high-intensity combined lifestyle counseling intervention group and a minimal intervention control group (who received a 75-page resource manual in addition to a pedometer and scale) at 8 to 12 months.126 The nonstatistically significant reduction in SBP and DBP in this trial was consistent with the magnitude of results of trials included in the meta-analyses. Another good-quality trial, TONE (n=975), did not report SBP or DBP. Instead, this trial used a composite measure (proportion of participants free of CVD events, hypertension, or medications)117 and found that a high-intensity diet and physical activity counseling intervention increased the proportion of persons free of CVD events, hypertension, or medications compared with a usual care control group at 30 months (HR, 0.69 [95% CI, 0.59 to 0.81]). Limited available data prevent us from drawing definitive conclusions about the efficacy of lifestyle counseling interventions beyond 24 months.

Fewer trials reported lipid or glucose outcome measures (Table 17). Mostly combined diet and physical activity counseling interventions found reduced total (k=4) and LDL cholesterol (k=2) in persons with hypertension, as well as total (k=17) and LDL cholesterol (k=11) in persons with hypertension or a mixture of CVD risk factors. The magnitude of effect on lipid reduction was similar to that seen in persons who explicitly had dyslipidemia. Many studies also reported weight measures as an outcome. Across all trials in persons with hypertension or a mixture of CVD risk factors, medium- to high-intensity counseling can reduce measures of weight (k=16) by an SMD of 0.21 (95% CI, 0.34 to 0.08) (Figure 11). The statistical heterogeneity of this pooled analysis, however, is very high. Again, the effect size of the reduction in weight measures is similar to that seen in persons explicitly with dyslipidemia. One trial in particular, the Activity Diet and Blood Pressure Trial (ADAPT) (n=241), appears to be an outlier that contributes to the statistical heterogeneity.138

Figure 11 Pooled Analysis of Weight in Persons With Hypertension or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 11 is a forest plot depicting the change in weight in persons with hypertension or multiple risk factors. This figure is discussed in the Results section.

Other outcomes that were not included in meta-analyses were medication use and composite CVD risk scores (Tables 13 and 15). Three trials conducted exclusively in persons with hypertension (n=1,520) sought to reduce the use of antihypertension medication.116,117,138 Two good-quality trials conducted in the United States, PREMIER (n=304, hypertension subgroup only) and TONE (n=975), showed a statistically significant increase in the proportion of persons who were free of medication at 18 to 36 months.116,117 Participants in the PREMIER trial were not taking antihypertension medications and all participants in the TONE trial were taking them. In PREMIER, 21 percent of persons in the high-intensity counseling intervention group versus 41 percent of persons in the usual care control group were taking antihypertension medications at 18 months.116 In TONE, the mean interval from intervention start to withdrawal of medications was about 3 months. At 36 months, 93.2 percent of persons in the high-intensity combined diet and physical activity counseling intervention group versus 86.8 percent of persons in the control group had stopped taking antihypertension medications. One fair-quality trial, ADAPT (n=241), included participants who were taking antihypertension medications and found no difference in medication use requirement between the medium-intensity counseling intervention group and usual care control group at 36 months.138

Twelve of the included trials (n=6,781) used a composite CVD risk score as an outcome measure.100,102,103,108,116,120,123,132,133,138-140 Two of these trials were conducted exclusively in hypertensive populations116,138 and 10 were conducted in populations selected for a mixture of CVD risk factors.100,102,103,108,120,123,132,133,139,140 Overall, there was generally no difference in 10-year CVD risk as measured by the Framingham Risk Score or Systematic Coronary Risk Evaluation at 6 to 36 months. Two trials found a very small, albeit statistically significant, change in 10-year risk at 12 months.133,140 One trial, Improving Patient Adherence to Lifestyle Advice (n=615), was conducted in the Netherlands. This trial found a difference of 0.9 percent (p=0.023) in 10-year risk using the Systematic Coronary Risk Evaluation between a medium-intensity combined lifestyle counseling intervention group and usual care group.133 The baseline 10-year CVD risk was low in this population at approximately 5 percent. One good-quality trial (n=315) conducted by Wister and colleagues in Canada found a 1.8 percent difference (p<0.05) in 10-year risk using the Framingham Risk Score between a medium-intensity combined lifestyle counseling intervention group and usual care group.140 The baseline 10-year CVD risk was slightly higher in this trial population at 11 percent.

### Results in Persons With Impaired Fasting Glucose or Glucose Tolerance

Sixteen fair- to good-quality counseling trials (n=5,883) in persons selected primarily for impaired fasting glucose or glucose intolerance88-103 and an additional 24 fair- to good-quality trials (n=15,997) in persons selected for a mixture of risk factors, including elevated glucose or metabolic syndrome, reported intermediate outcome measures (Table 14). Of the 16 trials in persons with impaired fasting glucose or glucose intolerance, five trials were good-quality,86,87,89, 94,118 and the others were all rated as fair quality. For limitations in fair-quality trials, please see the “Quality” section under “Description of Included Studies.” The majority of trials (k=13) were combined diet and physical activity counseling trials; only one trial was diet-only counseling and two trials were physical activity–only counseling. The mean age in these trials ranged from 51 to 67 years (Table 5). Most trials had an even representation of both men and women, except for three trials in mostly (or entirely) men.93,97,98 Average baseline fasting blood glucose ranged from approximately 94 to 111 mg/dL. Measures of glucose tolerance (1- or 2-hour) and hemoglobin A1c were less commonly reported. None of the trials included participants who were taking glucose-lowering medications at trial entry. In general, the mean BMI ranged from 29 to 34 kg/m^2^. Both trials conducted in Japanese men had a mean baseline BMI of 24 kg/m^2^.93,97 The majority of trials (k=13) evaluated high-intensity interventions, two trials evaluated medium-intensity interventions, and one trial evaluated a low-intensity intervention. The medium-intensity combined lifestyle counseling intervention had 12 contacts over 24 months. The other medium-intensity intervention was a physical activity–only counseling intervention with only three contacts over 6 months. All trials used a usual care or wait list control in which participants were assumed to receive usual care as a comparator group, except for three trials that used minimal intervention control groups.89,93,98 All but one trial was included in the meta-analyses.97 This trial was quite different from the others in that it was the only low-intensity trial included and the only diet-only counseling intervention in this population. In addition, this trial was conducted in persons who were not overweight. For a similar description of trials in populations with mixed risk factors, please see the section below, “Results in Persons With Mixed CVD Risk Factors.”

The majority of trials in persons with impaired fasting glucose or glucose tolerance reported outcome measures of diabetes incidence (k=11) and fasting blood glucose (k=13) at 12 months or greater (Table 14). At 12 to 24 months, medium- to high-intensity (mostly high-intensity) counseling trials (k=6) reduced diabetes incidence by an average of 35 percent (RR, 0.65 [95% CI, 0.42 to 1.02]), albeit not statistically significant (Table 18). At longer-term followup greater than 24 months, high-intensity combined lifestyle interventions (k=5) reduced diabetes incidence by an average of 65 percent (RR, 0.55 [95% CI, 0.46 to 0.67]) (Figure 12). These findings were similar when the three trials in populations selected for mixed CVD risk factors that also reported diabetes incidence as an outcome were added, and results were statistically significant at both intermediate and long-term followup, with a reduction of diabetes incidence by an RR of 0.58 (95% CI, 0.37 to 0.89) at 12 to 24 months (k=8) and 0.61 (95% CI, 0.46 to 0.79) at greater than 24 months (k=6) (Figure 13). Meta-analyses for fasting glucose outcomes support the findings of a reduction in progression to diabetes. While medium- to high-intensity counseling interventions in persons with impaired fasting glucose or glucose tolerance (k=11) reduced fasting glucose by 2.05 mg/dL (95% CI, 3.86 to 0.24) at 12 to 24 months (Figure 14), the statistical heterogeneity is very high. In addition, there are a limited number of trials that report fasting glucose outcomes at greater than 24 months (Table 18).

Figure 12 Pooled Analysis of Diabetes Incidence in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance, Sorted by Length of Followup Time

Figure 12 is a forest plot depicting the incidence of diabetes in persons with impaired fasting glucose/impaired glucose tolerance. This figure is discussed in the Results section.

Figure 13 Pooled Analysis of Diabetes Incidence in Persons With Impaired Fasting Glucose, Impaired Glucose Tolerance, or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 13 is a forest plot depicting the incidence of diabetes in persons with impaired fasting glucose/impaired glucose tolerance or multiple risk factors. This figure is discussed in the Results section.

Figure 14 Pooled Analysis of Fasting Glucose in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance, Sorted by Length of Followup Time

Figure 14 is a forest plot depicting the change in fasting glucose in persons with impaired fasting glucose/impaired glucose tolerance. This figure is discussed in the Results section.

Figure 15 Pooled Analysis of Weight in Persons With Impaired Fasting Glucose, Impaired Glucose Tolerance, or Multiple Risk Factors, Sorted by Length of Followup Time

Figure 15 is a forest plot depicting the change in weight in persons with impaired fasting glucose/impaired glucose tolerance or multiple risk factors. This figure is discussed in the Results section.

Lipid and blood pressure outcomes were not as commonly reported (Table 18). Nonetheless, pooled results for these outcomes are generally consistent with findings in other populations. Many studies, however, also reported weight measures as an outcome. Across all trials in persons with impaired fasting glucose or glucose tolerance or a mixture of CVD risk factors, medium- to high-intensity counseling reduced measures of weight (k=24) by an SMD of 0.21 (95% CI, 0.29 to 0.13), similar to the magnitude of reduction seen in other included populations (Table 18). The statistical heterogeneity of this pooled analysis, however, is very high.

### Results in Persons With Mixed Cardiovascular Risk Factors

Of the total 26 trials conducted in populations that were selected for a mixture of cardiovascular risk factors, 24 fair- to good-quality trials (n=15,997) reported intermediate outcome measures (Table 15). Only three of these trials were of good quality,139-141 however, and the remaining trials were all rated as fair quality. The majority of these trials (k=20) evaluated combined diet and physical activity counseling interventions, although six trials evaluated physical activity–only counseling interventions. The mean age in these trials ranged from 47 to 68 years and most trials included a fair representation of both men and women, except for one early trial exclusively in men112 and two trials entirely in women (Table 6).108,110 The proportion of persons with hypertension ranged from 9 to 100 percent, with an average SBP of 125 to 158 mm Hg and DBP of 73 to 91 mm Hg. The proportion of persons with dyslipidemia ranged from 13 to 88 percent, with an average baseline total cholesterol of 185 to 259 mg/dL and LDL cholesterol of 112 to 178 mg/dL. The proportion of persons with impaired fasting glucose or glucose tolerance was not commonly reported. The proportion of persons with diabetes ranged from 0 to 45 percent. The baseline fasting glucose ranged from 93 to 148 mg/dL. The majority of persons in all trials had an average BMI that identified them as overweight to obese. The majority of trials (k=17) evaluated medium-intensity interventions. While most trials used usual care or a wait list control as a comparator group, five trials used a minimal intervention as the control group.100,102, 107,114,122 Five trials were not included in the meta-analyses because of limitations in reporting of outcome data in the primary studies.108,120,129-131

Outcomes in trials that selected persons based on any number of CVD risk factors are discussed in conjunction with other populations. Please see the above sections, “Results in Persons With Dyslipidemia,” “Results in Persons With Hypertension,” and “Results in Persons With Impaired Fasting Glucose or Glucose Tolerance.”

### Results by Intervention Type

The majority of included trials evaluated combined lifestyle interventions with messages to improve diet and increase physical activity (49 intervention arms). Eighteen trials included counseling interventions that focused on diet alone, 14 of which were conducted in persons primarily selected for dyslipidemia, three in persons selected for hypertension, and only one in persons selected for impaired fasting glucose. Only 10 trials evaluated interventions that focused on increasing physical activity alone (Table 2). As a result, the findings of benefit on intermediate health outcomes are most robust for combined lifestyle counseling (Table 20). Medium- to high-intensity combined lifestyle counseling interventions reduced total cholesterol (k=22) (5.43 mg/dL [95% CI, 7.97 to 2.89]), LDL cholesterol (k=17) (3.69 mg/dL [95% CI, 5.98 to 1.40]), and triglycerides (k=10) (8.33 mg/dL [95% CI, 13.80 to 2.86]) and increased HDL cholesterol (k=14) (0.98 mg/dL [95% CI, 0.25 to 1.70]) at 12 to 24 months in persons selected for dyslipidemia or any number of CVD risk factors (Figures 16 and 17; Table 20). Very few trials, however, reported followup after 24 months and the reported effects generally did not seem to last at longer-term followup. Medium- to high-intensity diet-only counseling interventions also reduced total cholesterol (k=9) (3.75 mg/dL [95% CI, 6.50 to 1.01]), LDL cholesterol (k=7) (4.27 mg/dL [95% CI, 7.84 to 0.70]), and triglycerides (k=3) (17.86 mg/dL [95% CI, 33.10 to 2.62]). While the reduction in total cholesterol for diet-only counseling interventions may be smaller than for combined lifestyle interventions, the reduction in LDL cholesterol for these interventions appeared to be the same as for combined lifestyle interventions. None of these trials reported longer-term followup. Overall, while high-intensity counseling resulted in slightly larger pooled estimates of total and LDL cholesterol, confidence interval estimates were overlapping (Appendix F Figures 1 and 3).

Figure 16 Pooled Analysis of Total Cholesterol for Combined Healthy Diet and Physical Activity Interventions in All Risk Groups, Sorted by Length of Followup Time

Figure 16 is a forest plot depicting the change in total cholesterol for combined healthy diet and physical activity interventions in all risk groups. This figure is discussed in the Results section.

Figure 17 Pooled Analysis of Low-Density Lipoprotein Cholesterol for Combined Healthy Diet and Physical Activity Interventions in All Risk Groups, Sorted by Length of Followup Time

Figure 17 is a forest plot depicting the change in low-density lipoprotein for combined healthy diet and physical activity interventions in all risk groups. This figure is discussed in the Results section.

Combined lifestyle interventions also reduced blood pressure, glucose, diabetes incidence, and measures of weight at both intermediate and longer-term followup. Medium- to high-intensity combined lifestyle counseling interventions reduced SBP (k=27) (2.06 mm Hg [95% CI, 3.03 to 1.08]) and DBP (k=21) (1.30 mm Hg [95% CI, 1.93 to 0.68]). These trials also reduced fasting glucose (k=18) (1.86 mg/dL [95% CI, 3.24 to 0.49]), diabetes incidence (k=6) (RR, 0.54 [95% CI, 0.34 to 0.88]), and measures of weight (k=25) (SMD, 0.24 [95% CI, 0.35 to 0.14]) at 12 to 24 months in persons selected for CVD risk factors (Figures 18–21). Pooled effect sizes for blood pressure, glucose, and measures of weight were similar for medium- versus high-intensity counseling interventions (Appendix F). Trials reporting a reduction in diabetes incidence were mostly high-intensity counseling interventions. While fewer trials reported followup after 24 months, reductions in these outcomes persisted at longer-term followup. Trials evaluating diet-only counseling interventions did not commonly measure other intermediate health outcomes.

Figure 18 Pooled Analysis of Systolic Blood Pressure for Combined Healthy Diet and Physical Activity Interventions in All Risk Groups, Sorted by Length of Followup Time

Figure 18 is a forest plot depicting the change in systolic blood pressure for combined healthy diet and physical activity interventions in all risk groups. This figure is discussed in the Results section.

Figure 19 Pooled Analysis of Diastolic Blood Pressure for Combined Healthy Diet and Physical Activity Interventions in All Risk Groups, Sorted by Length of Followup Time

Figure 19 is a forest plot depicting the change in diastolic blood pressure for combined healthy diet and physical activity interventions in all risk groups. This figure is discussed in the Results section.

Figure 20 Pooled Analysis of Fasting Glucose for Combined Healthy Diet and Physical Activity Interventions in All Risk Groups, Sorted by Length of Followup Time

Figure 20 is a forest plot depicting the change in fasting glucose for combined healthy diet and physical activity interventions in all risk groups. This figure is discussed in the Results section.

Figure 21 Pooled Analysis of Diabetes Incidence for Combined Healthy Diet and Physical Activity Interventions in All Risk Groups, Sorted by Length of Followup Time

Figure 21 is a forest plot depicting the incidence of diabetes for combined healthy diet and physical activity interventions in all risk groups. This figure is discussed in the Results section.

The included evidence base (k=10) for physical activity–only counseling interventions is much more sparse and less convincing. The majority of these interventions were medium-intensity (k=8), as opposed to high-intensity (k=2) interventions. Four trials were designed to specifically target older adults.98,104,123,130 Six of the 10 trials were conducted in populations with mixed CVD risk factors, two were conducted in persons explicitly with impaired fasting glucose, and two were conducted in persons with hypertension. Therefore, the reported outcome measures varied across these trials and pooled analyses for each outcome included few studies, in general. Two fair-quality trials (n=232) only reported short-term outcomes at 6 months and both trials evaluated medium-intensity counseling interventions in persons selected for hypertension.104,128 One very small trial (n=24) in women showed a small, but statistically significant, improvement in SBP.104 Another trial (n=208) conducted in both men and women, however, found no change in SBP or DBP (Table 13).128 Two fair-quality trials (n=400) were conducted in older adults with impaired fasting glucose.98,99 Neither of these trials found a benefit in lipids, glucose, or measures of weight at 12 to 24 months. Finally, six trials were conducted in persons selected for a mixture of CVD risk factors, five of which reported intermediate outcome measures. 122,123,130, 131,141 Four fair-quality trials (n=1,955) reported no changes in short-term (6 to 12 months) intermediate health outcomes (including lipids, glucose, and measures of weight).122,123,130,131 One good-quality trial (n=101) conducted by Kallings and colleagues that evaluated a medium-intensity counseling intervention aimed at Swedish older adults found a very small, but statistically significant, benefit on total cholesterol, hemoglobin A1c, and measures of weight. However, this trial did not find an effect on measures of blood pressure or LDL cholesterol.141 Given the limited number of trials and clinical heterogeneity among populations, interventions, and outcomes measured, it is still unclear if medium- or high-intensity counseling interventions aimed at increasing physical activity alone can improve lipids, blood pressure, glucose, and measures of weight in persons with CVD risk factors.

### Exploration of Heterogeneity

Our review purposefully includes a wide range of healthy lifestyle counseling trials to improve cardiovascular health published over the past two decades. The main dimensions of clinical heterogeneity included variation in populations studied, interventions evaluated, and study characteristics (including outcomes measured). We a priori specified the major dimensions of heterogeneity and present results stratified by populations targeted and outcomes measured (e.g., trials targeting persons with dyslipidemia generally measured lipid outcomes), as well as stratified by intervention type (i.e., combined lifestyle, diet only, physical activity only). We used exploratory meta-regressions and visual inspection of forest plots to examine if other important a priori–specified variables influenced study effects. Based on this preliminary exploration of heterogeneity, we performed meta-regressions on lipids (total and LDL cholesterol, triglycerides), blood pressure (SBP and DBP), fasting glucose, and measures of weight outcomes using all data available from the 57 trials included in the meta-analyses. None of the factors we examined appeared to consistently influence effect size across all outcomes. Year of publication appeared to explain some statistical heterogeneity for effects on LDL cholesterol, blood pressure (SBP and DBP), and weight, such that more recent studies had smaller effects on LDL, blood pressure, and weight reduction than earlier studies. High-intensity interventions appeared to explain some statistical heterogeneity for effects on LDL cholesterol (but not on other outcomes), such that higher-intensity interventions had greater LDL cholesterol reduction compared with less intensive interventions. Finally, study quality appeared to explain some statistical heterogeneity for effects on SBP and triglycerides, but not for other outcomes. That is, better-quality studies had smaller effects than studies with more risk for bias. Overall, the differences in effect sizes, as modified by these variables, were very small and likely not clinically significant.

We also assessed if trials targeting specific a priori subpopulations or that included subgroup analyses of these populations showed similar or differential findings of benefit on intermediate health outcomes. In general, there were a limited number of trials that included subgroup analyses by sex, age, or race/ethnicity. Nonetheless, we believe our findings are broadly applicable to men and women, middle- and older-aged adults, as well as nonwhite persons, based on available evidence and a body of evidence that includes an adequate representation of these populations. Nine trials were conducted in men only (or nearly all men)67,75,80,93,97,98,111-113 and four trials were conducted in women only.82,104,108,110 Direct comparisons of results among these trials are difficult because of the differences in population characteristics (other than sex), interventions, outcomes, and lengths of followup across these studies. Only five of the included studies reported results for intermediate health outcomes stratified by sex.71,87,89,142,143 There was no difference in benefit on reduction of cholesterol or diabetes incidence between men and women in the Diet and Exercise for Elevated Risk trial (n=189), which evaluated a high-intensity diet-only counseling intervention to reduce cholesterol, or in DPP (n=2,161), which evaluated a high-intensity combined lifestyle counseling intervention to prevent diabetes.71,89 ADAPT (n=241) evaluated a medium-intensity combined lifestyle counseling intervention to reduce blood pressure and demonstrated some differences between sexes at 4 months. These differences, however, did not persist at 12 months. Additionally, there was no statistically significant benefit in blood pressure reduction in the intervention group compared with the control group for either men or women at 36 months.142 One good-quality trial, E-LITE (Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care) (n=241), which evaluated a high-intensity combined lifestyle intervention in persons with impaired fasting glucose or metabolic syndrome, found statistically significant weight loss for men, but not women, at 15 months.87 Subgroup analyses by sex for other measured intermediate health outcomes (i.e., blood pressure, lipids, fasting blood glucose) were not reported. PREMIER (n=810) evaluated a high-intensity combined lifestyle intervention in persons with prehypertension and hypertension. Subgroup analyses for PREMIER did not report findings separately for persons with hypertension only. Nonetheless, blood pressure reductions at 6 months were greater for black men compared with black women, but no sex differences were noted for whites.143

Included trials generally included populations of middle-aged adults that accurately reflect the distribution of CVD risk factors in the general population. Overall, we did not find a large variation in mean ages across studies, which ranged from 40 to 71 years. Nine trials specifically targeted older adults or the average mean age of the population was 65 years or older.69,98,99,112, 113,117, 127,130,141 Although direct comparison across trials targeting older adults and those with younger mean ages is difficult because of clinical heterogeneity among trials, the high-intensity combined lifestyle counseling interventions in older adults did improve intermediate health outcomes similar to those in middle-aged adults. Physical activity–only counseling interventions targeting older adults generally (except for one trial conducted by Kallings and colleagues) did not improve intermediate health outcomes, similar to the results of studies conducted in middle-aged adults. Two trials included subgroup analyses that compared older adults with middle-aged adults.89,123 DPP, for example, evaluated a high-intensity combined lifestyle intervention to prevent diabetes and found no statistically significant interaction for age (25 to 44 years, 45 to 59 years, and 60 years or older) on reduction of diabetes incidence between the intervention and control groups.89 The Green Prescription Programme, which evaluated a medium-intensity physical activity–only counseling intervention, found no significant difference between younger and older participants (ages 65 to 79 years) and generally found no statistically significant differences between intervention and control groups for blood pressure outcomes.123

Of the trials conducted in the United States, 20 trials were conducted in populations that included between 4.4 and 100 percent nonwhite persons.67,72-74,81,82,89,98,108,110,113,117,123,126,127,129,135,136 Two trials explicitly targeted Latino Americans94,108 and two trials explicitly targeted black Americans.126,135 DPP (45% nonwhite participants) conducted post-hoc subgroup analyses by race/ethnicity and found no statistically significant interaction on diabetes incidence.89 PREMIER (34% black participants) also conducted subgroup analyses, although they were performed on the entire trial population (including persons with prehypertension). Nonetheless, subgroup analyses showed the greatest blood pressure reductions at 6 months for black men, followed by whites (men and women), and the smallest blood pressure reductions for black women.143

### Publication Bias

For quantitative analyses, we assessed for publication bias using funnel plots and Egger's test. We found no evidence for significant publication bias except for triglyceride outcomes (Egger's test p=0.02). Therefore, the findings of benefit on reductions in triglycerides for counseling interventions should be interpreted with caution, as the true effects are likely less optimistic than our estimated effects. In general, one should interpret any findings for outcomes with only a very limited number of trials (i.e., only a small representation of included studies reported a certain outcome), with caution because of possible selective reporting of that outcome and limited reproduction of the specific outcome effect across trials.

## KQ 3 Do Primary Care–Relevant Behavioral Counseling Interventions for Healthy Diet and/or Physical Activity Improve Diet and Physical Activity Behavioral Outcomes in Adults With Known CVD Risk Factors?

### Overall Results

Sixty-one of the included trials reported behavioral outcomes (Tables 1 and 2). Three of these trials reported only behavioral outcomes (KQ 3) and did not report intermediate health outcomes (KQ 2).105,109,114 Overall, objectively measured and self-reported changes in dietary intake and physical activity were concordant with intermediate outcome findings (Tables 16–19). In several instances in which trials did not find any benefit in intermediate health outcomes, trials demonstrated statistically significant improvements in dietary intake (e.g., fat, saturated fat, fruit and vegetable, total energy) and various measures of self-reported physical activity in the short and intermediate term. In selected trials conducted in persons who were already taking medications to lower cholesterol or blood pressure, counseling interventions appeared to improve dietary intake (e.g., sodium, fat, saturated fat, fruit and vegetable, total energy) and various measures of self-reported physical activity despite a lack of benefit on lipid measures or blood pressure. Many physical activity–only counseling trials only reported short-term outcomes. Four of five trials that reported behavioral outcomes at 12 to 24 months found statistically significant improvements in self-reported physical activity. We did not conduct quantitative pooled analyses because of sparse reporting of objectively measured behavior change (e.g., urinary sodium, VO_2_max) and the heterogeneity in self-reported measures of behavior change. Given the robust and consistent findings of benefit on intermediate health outcomes, our summary of results for this question focuses on discrepant or added information that behavioral outcomes provided.

### Detailed Results for Behavioral Outcomes

In trials targeting persons with dyslipidemia, all but two trials68,76 that reported on dietary intake of fat and/or saturated fat found a statistically significant decrease in consumption at 6 to 24 months, even in trials that did not find a statistically significant benefit on total or LDL cholesterol (Table 21; Appendix G Table 2). Only two trials targeting persons with dyslipidemia included those who were already taking lipid-lowering medications,67,68 which may make it more difficult to detect an improvement in serum lipid measurements (e.g., total or LDL cholesterol). One fair-quality trial, CouPLES (n=255), was conducted in a VA population in which approximately 46 percent were already taking lipid-lowering medications, and evaluated a medium-intensity combined lifestyle telephone counseling intervention.67 At 11 months, although there were no statistically significant differences in medication use or LDL cholesterol, the intervention group reported statistically significant improvements in fat (approximately 11 g fewer per day) and saturated fat (approximately 4 g fewer per day) intake, as well as total energy intake (approximately 200 kcal fewer per day). In another fair-quality trial, PRO-FIT (n=340), Dutch persons with confirmed familial hyperlipidemia, 69 percent of whom were taking lipid-lowering medications, were randomized to receive a medium-intensity combined lifestyle intervention.68 At 12 months, there were no statistically significant differences in saturated fat, fruit, or vegetable intake, as well as no statistically significant differences in intermediate health outcomes between those who received counseling and those who received usual care. The findings of improvement in dietary and physical activity outcomes were consistent with intermediate health outcomes in trials targeting persons with hypertension. In trials with no statistically significant benefit on blood pressure outcomes, these trials still found improvements in urinary sodium and self-reported dietary intake (including fat, saturated fat, and fruit/vegetable) and self-reported physical activity at 6 to 24 months (Table 22; Appendix G Table 2). Five of these trials (n=2,335) evaluated medium- to high-intensity counseling interventions exclusively in persons taking antihypertension medications.117,126,128,136, 138 Four of the five trials reported no difference in blood pressure and one trial did not report blood pressure outcomes.117 All of the four trials (n=1,698) that reported urinary sodium found a statistically significant decrease in urinary sodium at 6 to 36 months.117,128,136,138 Two (n=449) of the four trials that reported physical activity change showed a small, but statistically significant, increase in physical activity (approximately 40 minutes more per week) at 6 and 36 months.128,138 Two trials (n=515) also reported other measures of dietary intake and found small, but statistically significant, improvements in saturated fat and fruit and/or vegetable intake at 18 and 36 months.136,138 One trial only reported behavioral outcomes.105 This fair-quality trial conducted in the Netherlands (n=1,629) evaluated low- and medium-intensity mailed and/or telephone interventions with diet and physical activity counseling. This trial found that the medium-intensity telephone intervention (with or without mailed component) improved both physical activity (approximately 50 minutes more per week) and fruit/vegetable (approximately 0.25 more servings per day) intake at 18 months.

Table 21 Behavioral Counseling Trials in Persons With Dyslipidemia or Elevated Cholesterol: Key Question 3 Outcomes

Study, Year Quality | N | Followup Time, months | Fat Intake | Saturated Fat Intake | Cholesterol Intake | Fiber | Other Behavioral Outcomes
Healthy diet and physical activity interventions
CouPLES, 2013^67^ Fair | 255 | Short: 11 | g/d ↑ % Fat ↑ | g/d ↑ %SF ↔ | Mg/d ↔ | g/d ↔ | Total energy (kcal/d) ↑ Frequency of moderate PA/wk ↔ Duration of moderate-intensity PA/wk ↔
CouPLES, 2013^67^ Fair | 255 | Intermediate: NA | -- | -- | -- | -- | --
CouPLES, 2013^67^ Fair | 255 | Long: NA | -- | -- | -- | -- | --
PRO-FIT, 2012^68^ Fair | 340 | Short: NA | -- | -- | -- | -- | --
PRO-FIT, 2012^68^ Fair | 340 | Intermediate: 12 | NR | g/d ↔ | NR | NR | Fruit intake (servings/d) ↔ Vegetable intake (g/d) ↔ Moderate-/vigorous-intensity PA (min/wk) ↔
PRO-FIT, 2012^68^ Fair | 340 | Long: NA | -- | -- | -- | -- | --
RHPP Trial, 1993^69^ Fair | 1,197 | Short: NA | -- | -- | -- | -- | --
RHPP Trial, 1993^69^ Fair | 1,197 | Intermediate: NA | -- | -- | -- | -- | --
RHPP Trial, 1993^69^ Fair | 1,197 | Long: 30 | NR | NR | NR | NR | NR
Healthy diet–only interventions
Anderson, 1992^70^ Fair | 177 | Short: NA | -- | -- | -- | -- | --
Anderson, 1992^70^ Fair | 177 | Intermediate: 12 | % Fat ↑ | % SF ↑ | Mg/d ↔ | g/d ↑ | Total energy (kJ/d) ↔ % MUFA ↑ % PUFA ↔ % Protein ↔ % Carbohydrates (no difference) Exercise, total energy (kJ^*^kg/lb^*^d) ↑
Anderson, 1992^70^ Fair | 177 | Long: NA | -- | -- | -- | -- | --
Ammerman, 2003^74^ Keyserling, 1999^174^ Fair | 468 | Short: 6 | NR | NR | NR | NR | NR
Ammerman, 2003^74^ Keyserling, 1999^174^ Fair | 468 | Intermediate: 12 | NR | NR | NR | NR | DRA score ↑
Ammerman, 2003^74^ Keyserling, 1999^174^ Fair | 468 | Long: NA | -- | -- | -- | -- | --
Bloemberg, 1991^75^ Fair | 80 | Short: 6 | % Fat ↑ | % SF ↑ | Mg/mJ ↑ | g/mJ ↑ | % Protein ↔ % MUFA ↑ % PUFA ↑ % Carbohydrates: increase
Bloemberg, 1991^75^ Fair | 80 | Intermediate: NA | -- | -- | -- | -- | --
Bloemberg, 1991^75^ Fair | 80 | Long: NA | -- | -- | -- | -- | --
DEER, 1998^71^ | 189 | Short: NA | -- | -- | -- | -- | --
DEER, 1998^71^ | 189 | Intermediate: 12^*^ | % Fat ↑ | % SF ↑ | Mg/d ↑ | NR | Total energy (kcal/d) ↑ % Carbohydrates: increase % MUFA ↑ % PUFA ↔
DEER, 1998^71^ | 189 | Long: NA | -- | -- | -- | -- | --
Delahanty, 2001^72^ Good | 90 | Short: 6 | % Fat ↑ | % SF ↑ | Mg/dL ↑ | g/d ↔ | Total energy (kcal/d) ↔ % MUFA ↑ % PUFA ↔ Total PA (min/week) ↔
Delahanty, 2001^72^ Good | 90 | Intermediate: 12 | % Fat ↔ | % SF ↔ | Mg/dL ↔ | g/d ↔ | Total energy (kcal/d) ↔ % MUFA ↔ % PUFA ↔ Total PA (min/week) ↔
Delahanty, 2001^72^ Good | 90 | Long: NA | -- | -- | -- | -- | --
Hyman, 1998^76^ Fair | 123 | Short: 6 | Fat intake score^†^ ↔ | NR | NR | NR | NR
Hyman, 1998^76^ Fair | 123 | Intermediate: NA | -- | -- | -- | -- | --
Hyman, 1998^76^ Fair | 123 | Long: NA | -- | -- | -- | -- | --
Johnston, 1995^77^ Fair | 179 | Short: 6 | NR | NR | NR | NR | NR
Johnston, 1995^77^ Fair | 179 | Intermediate: NA | -- | -- | -- | -- | --
Johnston, 1995^77^ Fair | 179 | Long: NA | -- | -- | -- | -- | --
Moy, 2001^73^ Fair | 235 | Short: NA | -- | -- | -- | -- | --
Moy, 2001^73^ Fair | 235 | Intermediate: 24 | g/d ↑ % Fat ↑ | g/d ↑ % SF ↑ | Mg/d ↑ | NR | Total energy (kcal) ↑
Moy, 2001^73^ Fair | 235 | Long: NA | -- | -- | -- | -- | --
Neil, 1995^78^ Fair | 309 | Short: 6 | NR | NR | NR | NR | NR
Neil, 1995^78^ Fair | 309 | Intermediate: NA | -- | -- | -- | -- | --
Neil, 1995^78^ Fair | 309 | Long: NA | -- | -- | -- | -- | --
NFPMP, 2002^79^ Fair | 143 | Short: 6 | % Fat ↑ | % SF ↑ | Mg/d ↑ | NR | Total energy (MJ/d) ↑ % MUFA ↑ % Un-SF ↔ % no exercise, % <3 times/wk, % exercise >3 times/wk ↔
NFPMP, 2002^79^ Fair | 143 | Intermediate: 12 | % Fat ↑ | % SF ↑ | Mg/d ↑ | NR | Total energy (MJ/d) ↑ % MUFA ↑ % Un-SF ↔ % no exercise, % <3 times/wk, % exercise >3 times/wk ↔
NFPMP, 2002^79^ Fair | 143 | Long: NA | -- | -- | -- | -- | --
ODES, 1995^80^ Fair | 98 | Short: NA | -- | -- | -- | -- | --
ODES, 1995^80^ Fair | 98 | Intermediate: 12 | % Fat ↑ g/d ↑^‡^ | % SF ↑ g/d ↑^‡^ | Mg/d ↑^‡^ | NR | Total energy (kJ/d) ↑ Protein (g/d)↑ ‡ Carbohydrates (g/d): increase^‡^ Sugar (g/d) ↑ ‡ MUFA (g/d) ↑ ‡ PUFA (g/d) ↑^‡^
ODES, 1995^80^ Fair | 98 | Long: NA | -- | -- | -- | -- | --
Southeast Cholesterol Project, 1997^81^ Fair | 372 | Short: 7 | NR | NR | NR | NR | NR
Southeast Cholesterol Project, 1997^81^ Fair | 372 | Intermediate: 12 | NR | NR | NR | NR | DRA score ↑
Southeast Cholesterol Project, 1997^81^ Fair | 372 | Long: NA | -- | -- | -- | -- | --
Stevens, 2003^82^ Fair | 616 | Short: NA | -- | -- | -- | -- | --
Stevens, 2003^82^ Fair | 616 | Intermediate: 12 | % Fat ↑ Kristal fat score ↑ | % SF ↑ | NR | NR | Number of fruit/vegetable servings ↑ % MUFA ↑ % PUFA ↑
Stevens, 2003^82^ Fair | 616 | Long: NA | -- | -- | -- | -- | --
Tomson, 1995^83^ Tomson, 1994^175^ Fair | 92 | Short: NA | -- | -- | -- | -- | --
Tomson, 1995^83^ Tomson, 1994^175^ Fair | 92 | Intermediate: 12 | NR | NR | NR | NR | NR
Tomson, 1995^83^ Tomson, 1994^175^ Fair | 92 | Long: NA | -- | -- | -- | -- | --

* Outcomes reported by sex; no differences between sexes.

† 9-item research scale.

‡ Men-only subgroup analysis.

Abbreviations: CouPLES = Couples Partnering for Lipid Enhancing Strategies; DEER = Diet and Exercise for Elevated Risk; DRA = Developmental Reading Assessment; MUFA = monounsaturated fatty acid; N = study population; NA = not available; NFPMP = Nijmegen Family Practices Monitoring Program; NR = not reported; PA = physical activity; PUFA = polyunsaturated fatty acid; SF = saturated fat; Un-SF = unsaturated fat.

Table 22 Behavioral Counseling Trials in Persons With Hypertension: Key Question 3 Outcomes

Study, Year Quality | N | Followup Time, months | Urinary Sodium or Sodium Intake | PA Outcomes | Other Behavioral Outcomes
Healthy diet and physical activity interventions
ADAPT, 2006^138^ Fair | 241 | Short: NA | -- | -- | --
ADAPT, 2006^138^ Fair | 241 | Intermediate: 12 | g/d ↑ | At least moderate-intensity exercise (mean hr/wk) ↔ | Total energy (MJ) ↔ % Fat ↑ % SF ↑ % PUFA ↔ % MUFA ↑ Cholesterol (mg/d) ↔ Fiber (g/d) ↑ % Protein ↑ % Carbohydrates: increase Servings per day of low-fat dairy ↔ Servings per day of fish ↔ Servings per day of meat ↔ Servings per day of fruits/vegetables ↔
ADAPT, 2006^138^ Fair | 241 | Long: 36 | g/d ↔ | At least moderate-intensity exercise (mean hr/wk) ↑ | Total energy (MJ) ↔ % Fat ↔ % SF ↑ % PUFA ↔ % MUFA ↔ Cholesterol (mg/d) ↔ Fiber (g/d) ↔ % Protein ↔ % Carbohydrates: no difference Servings per day of fish ↑ Servings per day of fruits ↔ Servings per day of vegetables ↑
Applegate, 1992^127^ Fair | 56 | Short: 6 | NR | NR | NR
Applegate, 1992^127^ Fair | 56 | Intermediate: NA | -- | -- | --
Applegate, 1992^127^ Fair | 56 | Long: NA | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD- & PA-only sections) | 208 | Short: 6 | Salt frequency score ↑ 24-hr urinary sodium ↑ | Total PA (kJ/kg/d) ↑ Moderate PA (kJ/kg/d) ↑ | NR
Arroll, 1995^128^ Fair (Also arms in HD- & PA-only sections) | 208 | Intermediate: NA | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD- & PA-only sections) | 208 | Long: NA | -- | -- | --
Bosworth, 2009^84^ Fair | 477 | Short: NA | -- | -- | --
Bosworth, 2009^84^ Fair | 477 | Intermediate: 12 | NR | NR | NR
Bosworth, 2009^84^ Fair | 477 | Long: 24 | NR | NR | NR
HIP, 2009^136^ Fair | 574 | Short: 6^*^ | 24-hr urinary sodium: MD ↔, Pt ↔ | Moderate to vigorous PA (min/wk): MD ↔, Pt ↔ | Total energy (kcal): MD ↔, Pt ↑ % Fat ↑ % SF ↑ Cholesterol (mg/d): MD ↔, Pt ↑ Servings of fruits/vegetables ↑ Fiber (g/d): MD ↔, Pt ↑ % Protein: MD ↔, Pt ↑ % Carbohydrates: increase Servings of dairy: MD ↔, Pt ↑
HIP, 2009^136^ Fair | 574 | Intermediate: 18^*^ | 24-hr urinary sodium: MD ↑, Pt ↔ | Moderate to vigorous PA (min/wk): MD ↔, Pt ↔ | Total energy (kcal) ↔ % Fat ↑ % SF: MD ↔, Pt ↑ Cholesterol (mg/d) ↔ Servings of fruits/vegetables: MD ↔, Pt ↑ Fiber (g/d) ↔ % Protein ↔ % Carbohydrates: increase Servings of dairy ↔
HIP, 2009^136^ Fair | 574 | Long: NA | -- | -- | --
HTTP, 1993^134^ Fair | 200 | Short: NA | -- | -- | --
HTTP, 1993^134^ Fair | 200 | Intermediate: 18 | NR | NR | NR
HTTP, 1993^134^ Fair | 200 | Long: NA | -- | -- | --
Hyman, 2007^135^ Fair | 281 | Short: 6 | 24-hr urinary sodium ↔ | Pedometer steps per day ↔ | % current smoker (urine cotinine) ↔
Hyman, 2007^135^ Fair | 281 | Intermediate: 18 | 24-hr urinary sodium ↔ | Pedometer steps per day ↔ | % current smoker (urine cotinine) ↔
Hyman, 2007^135^ Fair | 281 | Long: NA | -- | -- | --
LIHEF, 2002^137^ Fair | 715 | Short: NA | -- | -- | --
LIHEF, 2002^137^ Fair | 715 | Intermediate: 12 + 24^‡^ | Mg/dL ↑ | % Participating in moderate PA at least 3 times/wk for 30 min ↑ | Total energy (kcal) ↔ % Fat ↑ % SF ↑ % MUFA ↑ % PUFA ↔ Cholesterol (mg) ↑ Fiber (g) ↑^¶^
LIHEF, 2002^137^ Fair | 715 | Long: NA | -- | -- | --
Migneault, 2012^126^ Fair | 337 | Short: 8 | NR | Moderate or greater PA (min/wk) ↔ >150 min/wk of moderate or greater PA (%) ↔ Total energy expenditure (kcal/d) ↑ | Composite diet score^§^ ↑
Migneault, 2012^126^ Fair | 337 | Intermediate: 12 | NR | Moderate or greater PA (min/wk) ↔ >150 min/wk of moderate or greater PA (%) ↔ Total energy expenditure (kcal/d) ↔ | Composite diet score^§^ ↔
Migneault, 2012^126^ Fair | 337 | Long: NA | -- | -- | --
PREMIER, 2003^116^ Good | 304 | Short: 6 | 24-hr urinary sodium ↔ | Fitness (heart rate at stage 2 or last available heart rate at stage 1) ↔ | % SF ↔ % Low-fat dairy║ ↔ Servings of fruits/vegetables ↑ Servings of dairy ↔
PREMIER, 2003^116^ Good | 304 | Intermediate: 18 | NR | NR | NR
PREMIER, 2003^116^ Good | 304 | Long: NA | -- | -- | --
Rodriguez, 2012^113^ Fair (poor for diet) | 533 | Short: 6 | NR | PA hr/wk ↔ | NR
Rodriguez, 2012^113^ Fair (poor for diet) | 533 | Intermediate: 12 | NR | PA hr/wk ↔ | NR
Rodriguez, 2012^113^ Fair (poor for diet) | 533 | Long: NA | -- | -- | --
TONE, 1998^117^ Good (Also arm in HD-only section) | 975 | Short: 9 | 24-hr urinary sodium ↑ | NR | NR
TONE, 1998^117^ Good (Also arm in HD-only section) | 975 | Intermediate: 18 | 24-hr urinary sodium ↑ | NR | NR
TONE, 1998^117^ Good (Also arm in HD-only section) | 975 | Long: 36 | 24-hr urinary sodium ↑ | NR | NR
Vitalum105 Fair | 1,629 | Short: 6 | NR | PA hr/wk: IG1 ↑ IG2 ↔ IG3 ↑ | Servings per day of fruits, vegetables: IG1 ↑, ↑ IG2 ↑, ↑ IG3 ↑, NR
Vitalum105 Fair | 1,629 | Intermediate: 18 | NR | PA hr/wk: IG1 ↔ IG2 ↔ IG3 ↑ | Servings per day of fruits, vegetables: IG1 ↑, ↑ IG2 ↑, ↑ IG3 ↑, ↔
Vitalum105 Fair | 1,629 | Long: NA | -- | -- | --
Healthy diet–only interventions
Arroll, 1995^128^ Fair (Also arms in HD+PA & PA-only sections) | 208 | Short: 6 | Salt frequency score ↑ 24-hr urinary sodium ↑ | Total PA (kJ/kg/d) ↔ Moderate PA (kJ/kg/d) ↔ | NR
Arroll, 1995^128^ Fair (Also arms in HD+PA & PA-only sections) | 208 | Intermediate: NA | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD+PA & PA-only sections) | 208 | Long: NA | -- | -- | --
Beckman, 1995^111^ Fair | 64 | Short: 6 | 24-hr urinary sodium ↑ | NR | NR
Beckman, 1995^111^ Fair | 64 | Intermediate: 12 | 24-hr urinary sodium ↑ | NR | NR
Beckman, 1995^111^ Fair | 64 | Long: NA | -- | -- | --
TONE, 1998^117^ Good (Also arm in HD+PA section) | 975 | Short: 9 | 24-hr urinary sodium ↑ | NR | NR
TONE, 1998^117^ Good (Also arm in HD+PA section) | 975 | Intermediate: 18 | 24-hr urinary sodium ↑ | NR | NR
TONE, 1998^117^ Good (Also arm in HD+PA section) | 975 | Long: 30 | 24-hr urinary sodium ↑ | NR | NR
Physical activity–only interventions
Arroll, 1995^128^ Fair (Also arms in HD+PA & HD-only sections) | 208 | Short: 6 | Salt frequency score ↔ 24-hr urinary sodium ↔ | Total PA (kJ/kg/d) ↑ Moderate PA (kJ/kg/d) ↑ | NR
Arroll, 1995^128^ Fair (Also arms in HD+PA & HD-only sections) | 208 | Intermediate: NA | -- | -- | --
Arroll, 1995^128^ Fair (Also arms in HD+PA & HD-only sections) | 208 | Long: NA | -- | -- | --
Moreau, 2001^104^ Fair | 24 | Short: 6 | NR | Pedometer steps per day ↑ | Total energy (kcal) ↔
Moreau, 2001^104^ Fair | 24 | Intermediate: NA | -- | -- | --
Moreau, 2001^104^ Fair | 24 | Long: NA | -- | -- | --

* Results are for both physicians and patients unless otherwise noted.

† Only reported at 3 to 24 weeks (composite), did not collect data on control group.

‡ Outcomes for 12 and 24 months unless otherwise noted.

§ Based on fat, saturated fat, fiber, fruit/vegetable, and salt intake.

║ METs group only.

¶ Significant at 24 months, not significant at 12 months.

Abbreviations: ADAPT = Activity Diet and Blood Pressure Trial; HD = healthy diet; HIP = Hypertension Improvement Project; HTTP = Hypertension Teaching and Treatment Programme; IG = intervention group; LIHEF = Lifestyle Intervention against Hypertension in Eastern Finland; MD = physician; MUFA = monounsaturated fatty acid; N = study population; NA = not available; NR = not reported; PA = physical activity; pt = patient; PUFA = polyunsaturated fatty acid; SF = saturated fat; TONE = Trial of Non-Pharmacological Interventions in the Elderly.

Trials targeting persons with impaired fasting glucose or glucose tolerance found improvements in behavioral change, which is consistent with findings of benefit on intermediate health outcomes (Table 23; Appendix G Table 2). Seven trials (n=2,127) without consistent statistically significant improvements in intermediate outcomes show that counseling interventions of any intensity could improve self-reported behavioral outcomes.85,86,88,92,97,99 All of the five trials (n=1,727) that reported dietary intake showed a small, but statistically significant, improvement in diet (using different measures, including fat, saturated fat, fiber, energy, and a composite score) at 6 to 18 months.85,86,88,92,97 Three (n=1,325) of the six trials that reported physical activity showed a statistically significant improvement in physical activity (using different measures, including total physical activity [minutes/week], percent meeting physical activity goal of 150 minutes per week, and moderate to vigorous physical activity [MET/minutes-week]).88,98,99

Table 23 Behavioral Counseling Trials in Persons With Impaired Fasting Glucose or Impaired Glucose Tolerance: Key Question 3 Outcomes

Study, Year Quality | N | Followup Time, months | Fat Intake | Saturated Fat Intake | Cholesterol Intake | PA Outcomes | Other Behavioral Outcomes
Healthy diet and physical activity interventions
APHRODITE, 2011^88^ Fair | 925 | Short term: 6 | ↔ | ↑ | NR | Total PA (min/wk) ↑ Average- to high-intensity activity (min/wk) ↔ | Total energy intake (kcal/d) ↔ Fiber intake (g/MJ) ↑
APHRODITE, 2011^88^ Fair | 925 | Intermediate: 18 | ↔ | ↑ | NR | Total PA (min/wk) ↑ Average to high intensity activity (min/wk) ↔ | Total energy intake (kcal/d) ↔ Fiber intake (g/MJ) ↑
APHRODITE, 2011^88^ Fair | 925 | Long term: NA | -- | -- | -- | -- | --
DPP, 2002^89^ Good | 2,161 | Short term: NA | -- | -- | -- | -- | --
DPP, 2002^89^ Good | 2,161 | Intermediate: 12 + 24 months^§^ | ↑ | ↑ | NR | PA (MET-hr/wk) ↑ | Total energy ↑ % PUFA ↑ % Carbohydrates: increase Fiber (g/d) ↑ Fruits (servings/d) ↑ Vegetables (servings/d) ↔ Fish (servings/d) ↔ Red meat (servings/d) ↑ Dairy (servings/d) ↑ Sweets (servings/d) ↑
DPP, 2002^89^ Good | 2,161 | Long term: 36 | NR | NR | NR | PA (MET-hr/wk) ↑ | NR
EDIPS, 2001^90^ Fair | 78 | Short term: 6 | ↑ | ↔ | NR | Vigorous activity >3 times/wk ↑ Vigorous activity ≥1 times/wk ↑ | Total energy (kcal/d) ↔ MUFA (g/d) ↑ PUFA (g/d) ↑ Sucrose (g/d) ↔ Fiber (g/d) ↔
EDIPS, 2001^90^ Fair | 78 | Intermediate: 24 | ↑ | NR | NR | Regular activity ≥1 times/wk ↑ Vigorous activity ≥1 times/wk ↑ | Fiber (g/d) ↔
EDIPS, 2001^90^ Fair | 78 | Long term: NA | -- | -- | -- | -- | --
EDIPS-Newcastle, 2009^91^ Fair | 102 | Short term: NA | -- | -- | -- | -- | --
EDIPS-Newcastle, 2009^91^ Fair | 102 | Intermediate: 12 | ↔ | NR | NR | Physical activity score^†^ ↔ | % Carbohydrates: no difference % Fiber ↔
EDIPS-Newcastle, 2009^91^ Fair | 102 | Long term: 36^‡^ | ↔ | NR | NR | Physical activity score^†^ ↔ | % Carbohydrates: no difference % Fiber ↔
E-LITE, 2013^87^ Good | 162 | Short: 6 | NR | NR | NR | NR | NR
E-LITE, 2013^87^ Good | 162 | Intermediate: 15 | NR | NR | NR | NR | NR
E-LITE, 2013^87^ Good | 162 | Long: NA | -- | -- | -- | -- | --
FDPS, 2001^118^ Good | 522 | Short term: 12 | ↑ | ↑ | ↑ | Increased PA ↑ Meeting goal of PA >4 hr/wk ↑ Total PA (min/wk) ↔ Moderate to vigorous PA (min/wk) ↑ | Increased consumption of vegetables ↑ Decreased consumption of sugar ↑ Decreased consumption of salt↑ Total energy intake ↑ % Carbohydrates: increase % MUFA ↑ % PUFA ↔ Fiber (g) ↔ Fiber (g/1,000 kcal) ↑
FDPS, 2001^118^ Good | 522 | Intermediate: 24 | NR | NR | NR | NR | NR
FDPS, 2001^118^ Good | 522 | Long term: 36 | ↑ | ↑ | ↔ | Total PA (min/wk) ↔ Moderate to vigorous PA (min/wk) ↑ | Total energy intake ↑ % Carbohydrates: increase % MUFA ↑ % PUFA ↔ Fiber (g) ↔ Fiber (g/1,000 kcal) ↑
HLC, 2011^92^ Fair | 307 | Short: 6 | NR | NR | NR | Total PA (min/wk) ↔ | Composite diet measure^*^ ↑
HLC, 2011^92^ Fair | 307 | Intermediate: NA | -- | -- | -- | -- | --
HLC, 2011^92^ Fair | 307 | Long: NA | -- | -- | -- | -- | --
Kosaka, 2005^93^ Fair | NR | Short term: 12 | NR | NR | NR | NR | NR
Kosaka, 2005^93^ Fair | NR | Intermediate: 24 | NR | NR | NR | NR | NR
Kosaka, 2005^93^ Fair | NR | Long term: 48 | NR | NR | NR | NR | NR
Live Well, Be Well, 2012^86^ Good | 238 | Short: 6 | g/d ↑ | NR | NR | Total PA (hr/wk) ↔ Total PA (MET-hr/wk) ↔ Walking (hr/wk) ↔ | Total energy (kcal/d) ↔ Fiber (g/d) ↔ Daily frequency of fruit and vegetables ↑
Live Well, Be Well, 2012^86^ Good | 238 | Intermediate: 12 | g/d ↔ | NR | NR | Total PA (hr/wk) ↔ Total PA (MET-hr/wk) ↔ Walking (hr/wk) ↔ | Total energy (kcal/d) ↔ Fiber (g/d) ↔ Daily frequency of fruit and vegetables ↑
Live Well, Be Well, 2012^86^ Good | 238 | Long: NA | -- | -- | -- | -- | --
LLDP94 Good | 312 | Short: NA | -- | -- | -- | -- | --
LLDP94 Good | 312 | Intermediate: 12 | % ↑ | % ↔ | NR | Leisure time PA (min/wk) ↔ | Total energy (kcal/d) ↔ % Carbohydrates: no difference % Protein ↔ Fiber (g/d) ↔
LLDP94 Good | 312 | Long: NA | -- | -- | -- | -- | --
Melbourne DPS, 2012^85^ Fair | 92 | Short: NA | -- | -- | -- | -- | --
Melbourne DPS, 2012^85^ Fair | 92 | Intermediate: 12 | % ↔ | % ↑ | NR | % meeting goal of moderate PA for 30 min/d ↔ | Fiber (g/d) ↑
Melbourne DPS, 2012^85^ Fair | 92 | Long: NA | -- | -- | -- | -- | --
PREDIAS, 2009^95^ Fair | 182 | Short term: NA | -- | -- | -- | -- | --
PREDIAS, 2009^95^ Fair | 182 | Intermediate: 12 | NR | NR | NR | PA (min/wk) ↑ | NR
PREDIAS, 2009^95^ Fair | 182 | Long term: NA | -- | -- | -- | -- | --
SLIM149 Fair | 147 | Short term: NA | -- | -- | -- | -- | --
SLIM149 Fair | 147 | Intermediate: 12 + 24║ | ↑ | ↑ | NR | VO_2_max (l/min) ↑ | Total energy ↔^¶^ % CHO: Increase % MUFA↑^#^ % PUFA ↔^#^ % Protein↔ Fiber ↔^¶^
SLIM149 Fair | 147 | Long term: 36–72 | ↑ | ↑ | NR | PA d/wk ↔ | Fiber ↑
Healthy diet–only interventions
Watanabe, 2003^97^ Fair | 173 | Short term: NA | -- | -- | -- | -- | --
Watanabe, 2003^97^ Fair | 173 | Intermediate: 12 | NR | NR | NR | NR | Total energy ↑^**^
Watanabe, 2003^97^ Fair | 173 | Long term: NA | -- | -- | -- | -- | --
Physical activity–only interventions
Enhanced Fitness Trial, 2012^98^ Fair | 302 | Short term: NA | -- | -- | -- | -- | --
Enhanced Fitness Trial, 2012^98^ Fair | 302 | Intermediate: 12 | NR | NR | NR | Endurance (min/wk) ↑ Strength (min/wk) ↔ % Meeting goal of 150 min/wk ↑ Cardiorespiratory fitness ↔^††^ | NR
Enhanced Fitness Trial, 2012^98^ Fair | 302 | Long term: NA | -- | -- | -- | -- | --
Prepare Trial, 2009^99^ Fair | 98 | Short term: 6^‡‡^ | NR | NR | NR | Steps per day ↑^§§^ Self-reported walking (MET-min/wk) ↑^§§^ Moderate to vigorous PA (MET-min/wk) ↑^§§^ | NR
Prepare Trial, 2009^99^ Fair | 98 | Intermediate: 12 | NR | NR | NR | Steps per day ↑^§§^ Self-reported walking (MET-min/wk) ↑ Moderate to vigorous PA (MET-min/wk) ↑^§§^ | NR
Prepare Trial, 2009^99^ Fair | 98 | Long term: NA | -- | -- | -- | -- | --

* Based on 16-item Food Choices Questionnaire.

† Score based on METs per activity using 3-day PA diaries.

‡ Mean followup.

§ Dietary behavioral outcomes only at 12 months, PA behavioral outcomes at 12 and 24 months.

║ For 12 and 24 months unless otherwise noted.

¶ ↑ at 12 months.

# Only reported for 12 months.

** Overintake/underintake fraction.

†† Measured by 6 minute walk test.

‡‡ For IG1 and IG2 unless otherwise noted.

§§ ↔ for IG1.

Abbreviations: APHRODITE = Active Prevention in High-Risk Individuals of Diabetes Type 2 in and Around Eindhoven; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EDIPS = European Diabetes Prevention Study; E-LITE = Evaluation of Lifestyle Interventions to Treat Elevated Cardiometabolic Risk in Primary Care; FDPS = Finnish Diabetes Prevention Study; HLC = Healthy Living Course; LLDP = Lawrence Latino Diabetes Prevention Project; MET = metabolic equivalent; MUFA = monounsaturated fatty acid; N = study population; NA = not available; NR = not reported; PA = physical activity; PREDIAS = Prevention of Diabetes Self-Management Program; PUFA = polyunsaturated fatty acid; SLIM = Study on Lifestyle Intervention and IGT Maastricht.

In trials in persons selected for a combination of risk factors, findings of behavioral change were again consistent with findings of benefit on intermediate health outcomes (Table 24; Appendix G Table 2). Eight medium- to high-intensity counseling trials found no consistent statistically significant benefit on intermediate or behavioral outcomes. Five of these trials evaluated a combined lifestyle counseling intervention (n=1,829) and three were physical activity–only counseling trials (n=1,077).86,100,102,122,130,131,139,144 Six medium- to high-intensity counseling trials, five combined lifestyle trials (n=6,681), and one physical activity–only counseling trial (n=878) found no consistent statistically significant benefit on intermediate health outcomes, but demonstrated improvement in self-reported diet and/or physical activity behaviors. The physical activity–only trial, the Green Prescription Programme, reported improvement in diet (e.g., total energy, unsaturated fat to fat ratio, fish intake, meals per day with a serving of vegetables, and a composite diet score) and physical activity (e.g., total energy expenditure, leisure time physical activity, minutes per week of moderate to vigorous activity, meeting recommended physical activity levels, and steps per day) behaviors.123 In the five trials (n=6,681) reporting dietary outcomes, medium- to high-intensity combined lifestyle counseling improved selected dietary outcome measures (including saturated fat to fat ratio, meeting fruit and vegetable intake recommendations, portions of fruits and vegetables per day, vegetables per day, and composite dietary measures) at 12 and 60 months.103,107,110,121,132 In five (n=3,506) of the six trials that reported physical activity outcomes, medium- to high-intensity counseling interventions improved selected physical activity outcomes (including steps per day, minutes per week of moderate to vigorous physical activity, percent meeting physical activity goal of 150 minutes per week, physical activity assessment score) at 6 and 12 months.103,110,121,123,132

Table 24 Behavioral Counseling Trials in Persons With Mixed Cardiovascular Risk Factors: Key Question 3 Outcomes

Study, Year | Quality | N | Followup Time, months | Healthy Diet Behavioral Outcomes | Physical Activity Outcomes
Healthy diet and physical activity interventions
Bo, 2007^146^ | Fair | 375 | Short: NA | -- | --
Bo, 2007^146^ | Fair | 375 | Intermediate: 12 | Total energy (kcal/d) ↔ % Fat ↑ % SF ↑ % PUFA ↑ % Carbohydrates: increase % Protein ↔ % Fiber ↑ | Metabolic equivalent of activity (hr/wk) ↑
Bo, 2007^146^ | Fair | 375 | Long: NA | -- | --
Cochrane, 2012^102^ | Fair | 601 | Short: NA | -- | --
Cochrane, 2012^102^ | Fair | 601 | Intermediate: 12 | Primary Prevention Toolkit Diet Score ↔ | Primary Prevention Toolkit PA Score ↔
Cochrane, 2012^102^ | Fair | 601 | Long: NA | -- | --
Edelman, 2006^129^ | Fair | 154 | Short: 10 | NR | Total PA (d/wk) ↑
Edelman, 2006^129^ | Fair | 154 | Intermediate: NA | -- | --
Edelman, 2006^129^ | Fair | 154 | Long: NA | -- | --
EUROACTION, 2008^106^ | Fair | 2,384 | Short: NA | -- | --
EUROACTION, 2008^106^ | Fair | 2,384 | Intermediate: 12 | % Eating oily fish (≥3 times/wk) ↔ % Eating fish (≥20 g/d) ↔ % Eating fruits/vegetables (≥400 g/d) ↑ | % Participating in PA (≥30 min ≥4 times/wk) ↑ % with PA change ↑
EUROACTION, 2008^106^ | Fair | 2,384 | Long: NA | -- | --
GOAL, 2009^139^ | Good | 457 | Short: NA | -- | --
GOAL, 2009^139^ | Good | 457 | Intermediate: 12 | Total energy (kcal) ↔ % Fat ↔ % SF ↔ % Protein ↔ Cholesterol (mg) ↔ Vegetables (g) ↔ Fruits (g) ↔ | Total PA (min/wk) ↔ Moderate- to heavy-intensity PA (min/wk) ↔
GOAL, 2009^139^ | Good | 457 | Long: 36 | Total energy (kcal) ↔ % Fat ↔ % SF ↔ % Protein ↔ Cholesterol (mg) ↔ Vegetables (g) ↔ Fruits (g) ↔ | Total PA (min/wk) ↔ Moderate- to heavy-intensity PA (min/wk) ↔ % Meeting recommended 150 min/wk PA ↔ % Meeting recommended 60 min/wk vigorous PA ↔
Hardcastle, 2008^168^ | Fair | 334 | Short: 6 | % Fat ↑ Fruits/vegetables per day ↔ | PA MET-min/wk ↑ Vigorous PA MET-min/wk ↔ Moderate PA MET-min/wk ↔ Walking MET-min/wk ↑
Hardcastle, 2008^168^ | Fair | 334 | Intermediate: 18 | % Fat ↑ Fruits/vegetables per day ↔ | PA MET-min/wk ↔ Moderate PA MET-min/wk ↔ Walking MET-min/wk ↑
Hardcastle, 2008^168^ | Fair | 334 | Long: NA | -- | --
HIPS, 2012^103^ | Fair | 814 | Short: 6 | Portions fruits/vegetables per day ↑ | PA Score^‡‡^ ↑
HIPS, 2012^103^ | Fair | 814 | Intermediate: 12 | Portions fruits/vegetables per day ↔ | PA Score^‡‡^ ↑
HIPS, 2012^103^ | Fair | 814 | Long: NA | -- | --
Hoorn, 2013^132^ | Fair | 622 | Short: 6 | Fruits (pieces/d) ↔ Met recommended fruit intake (2 pieces/d) ↑ Vegetables (g/d) ↔ Met recommended vegetable intake (200 g/d) ↑ | Vigorous PA MET-min/wk ↔ Moderate PA MET-min/wk ↔ % Meeting recommended PA levels (150 min/wk moderate PA) ↑
Hoorn, 2013^132^ | Fair | 622 | Intermediate: 12 | Fruit (pieces/d) ↔ Met recommended fruit intake (2 pieces/d) ↑ Vegetables (g/d) ↔ Met recommended vegetable intake (200 g/d) ↑ | Vigorous PA MET-min/wk ↔ Moderate PA MET-min/wk ↔ % Meeting recommended PA levels (150 min/wk moderate PA) ↑
Hoorn, 2013^132^ | Fair | 622 | Long: NA | -- | --
IMPALA, 2009^133^ | Fair | 615 | Short: NA | -- | --
IMPALA, 2009^133^ | Fair | 615 | Intermediate: 12 | Fat score ↑ Met recommended fat intake ↔ Fruit (pieces/wk) ↔ Met recommended fruit intake (200 g/d) ↔ Vegetables (Tbsp/d) ↔ Met recommended vegetable intake (200 g/d) ↑ | Total PA (min/wk) ↔ Met recommended PA levels ↔
IMPALA, 2009^133^ | Fair | 615 | Long: NA | -- | --
Inter99, 2008^107^ | Fair | 4,053 | Short: NA | -- | --
Inter99, 2008^107^ | Fair | 4,053 | Intermediate: 12^**^ | % SF: men ↑, women ↔ Total energy (kJ/d) ↔ Un-SF fat ratio ↑ Fish intake (g/d) ↔ Fruit intake (women) ↓ | Total PA (min/wk): men ↑^††^, women ↔^††^
Inter99, 2008^107^ | Fair | 4,053 | Long: 60^*^ | % SF ↔ Un-SF fat ratio ↑ Fish intake (g/d) ↑ Fruit intake (women) ↔ | Total PA at 36 months (min/wk) ↔
Logan Healthy Living, 2009^114^ | Fair | 434 | Short: 12 | % Fat ↑ % SF ↑ Fiber (g/d) ↑ Fruit/vegetable intake (servings/d) ↑ | Total PA (min/wk) ↔ Moderate to vigorous PA sessions/wk ↔ % Meeting PA guidelines (≥150 min, ≥5 sessions/wk) ↔^††^
Logan Healthy Living, 2009^114^ | Fair | 434 | Intermediate: 18 | % Fat ↑ % SF ↑ Fiber (g/d) ↑ Fruit/vegetable intake (servings/d) ↑ | Total PA (min/wk) ↔ Moderate to vigorous PA sessions/wk ↔
Logan Healthy Living, 2009^114^ | Fair | 434 | Long: NA | -- | --
Nilsson, 1992^119^ | Fair | 63 | Short: NA | -- | --
Nilsson, 1992^119^ | Fair | 63 | Intermediate: 12 | Total energy (kcal) ↑ Protein (g) ↔ Carbohydrates (g) (no difference) Fat (g) ↑ Fiber (g) ↑ SF (g) ↑ MUFA (g) ↑ PUFA (g) ↔ Cholesterol (mg) ↑ Change in dietary habits^‡^ ↑ | Change in PA^‡^ ↑^††^
Nilsson, 1992^119^ | Fair | 63 | Long: NA | -- | --
PEGASE, 2008^120^ | Fair | 640 | Short: 6 | NR^§^ | NR^§^
PEGASE, 2008^120^ | Fair | 640 | Intermediate: NA | -- | --
PEGASE, 2008^120^ | Fair | 640 | Long: NA | -- | --
PHPP, 2007^121^ | Fair- | 99 | Short: NA | -- | --
PHPP, 2007^121^ | Fair- | 99 | Intermediate: 12 | Total energy (kcal/d) ↔ Meals/d with vegetable ↑ | Steps/d ↑
PHPP, 2007^121^ | Fair- | 99 | Long: NA | -- | --
RIS, 1994^115^ | Good KQ1 Fair KQ2 | 508 | Short: NA | -- | --
RIS, 1994^115^ | Good KQ1 Fair KQ2 | 508 | Intermediate: 12 | NR | NR
RIS, 1994^115^ | Good KQ1 Fair KQ2 | 508 | Long: 79 | NR | NR
Rodriguez-Cristobal, 2012^173^ | Fair | 436 | Short: NA | -- | --
Rodriguez-Cristobal, 2012^173^ | Fair | 436 | Intermediate: 24 | NR | NR
Rodriguez-Cristobal, 2012^173^ | Fair | 436 | Long: NA | -- | --
SPRING, 2012^100^ | Fair | 201 | Short: NA | -- | --
SPRING, 2012^100^ | Fair | 201 | Intermediate: 12 | NR | % Physically inactive ↔
SPRING, 2012^100^ | Fair | 201 | Long: NA | -- | --
WISEWOMAN California, 2010^108^ | Fair | 1093 | Short: NA | -- | --
WISEWOMAN California, 2010^108^ | Fair | 1093 | Intermediate: 12 | NR | Level of exercise, moderate or vigorous ↑^††^
WISEWOMAN California, 2010^108^ | Fair | 1093 | Long: NA | -- | --
WISEWOMAN NC, 2008^110^ | Fair | 236 | Short: 6 | Composite Diet Score║↑ | Moderate PA (min/d) ↔ PA assessment, moderate ↑ PA assessment, vigorous ↑ PA assessment, all activity ↑
WISEWOMAN NC, 2008^110^ | Fair | 236 | Intermediate: 12 | Composite Diet Score║↑ | Moderate PA min/d ↔ PA assessment, moderate ↑ PA assessment, vigorous ↔ PA assessment, all activity ↔
WISEWOMAN NC, 2008^110^ | Fair | 236 | Long: NA | -- | --
Wister, 2007^140^ | Good | 315 | Short: NA | -- | --
Wister, 2007^140^ | Good | 315 | Intermediate: 12 | Composite diet score^¶^ ↑ | Composite PA score^¶^ ↔
Wister, 2007^140^ | Good | 315 | Long: NA | -- | --
Physical activity–only interventions
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ | Fair | 878 | Short: NA | -- | --
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ | Fair | 878 | Intermediate: 12 | NR | Total energy expenditure (kcal/kg/wk) ↑ Leisure PA expenditure (kcal/kg/wk) ↑ Moderate or vigorous exercise (min/wk) ↑ % Meeting recommended PA levels (2.5 hr/wk moderate or vigorous PA) ↑
Green Prescription Programme (Walk to Heart, Health & Activity study), 2003^123^ | Fair | 878 | Long: NA | -- | --
NERS, 2012^109^ | Fair, poor for QOL | 2,160 | Short: NA | -- | --
NERS, 2012^109^ | Fair, poor for QOL | 2,160 | Intermediate: 12 | NR | Total PA (min/wk)^#^ ↑
NERS, 2012^109^ | Fair, poor for QOL | 2,160 | Long: NA | -- | --
PAC, 2011^122^ | Fair | 120 | Short: 6 | NR | Leisure-time activity score ↑ Total leisure activity ↔ Total activity counts/min ↔ Moderate or vigorous activity (min/d) ↔ VO_2_ peak (LO_2_min-1) ↔
PAC, 2011^122^ | Fair | 120 | Intermediate: NA | -- | --
PAC, 2011^122^ | Fair | 120 | Long: NA | -- | --
PACE, 2005^131^ | Fair | 771 | Short: 6 | NR | NR^††^
PACE, 2005^131^ | Fair | 771 | Intermediate: 12 | NR | Total PA (min/wk) ↔ Leisure PA (min/wk) ↔ Met ACSM/CDC guidelines ↔
PACE, 2005^131^ | Fair | 771 | Long: NA | -- | --
Kallings, 2009^141^ | Good | 101 | Short: 6 | NR | Total PA (steps/d) ↔ Increase of ≥3,000 steps/d ↔ Moderate-intensity PA ≥30 min 5 times/wk ↑ Vigorous-intensity PA ≥20 min 3 times/wk ↑ Muscle strengthening ≥2 times/wk on moderate-high intensity ↔ Sessions/wk of at least moderate PA ↑ Min/wk of at least moderate PA ↑
Kallings, 2009^141^ | Good | 101 | Intermediate: NA | -- | --
Kallings, 2009^141^ | Good | 101 | Long: NA | -- | --
LIFE, 2010^130^ | Fair | 186 | Short: 11 | NR | VO_2_max (mL/kg/min) ↔ Objective measure of muscle fitness ↔ Objective measure of muscle strength ↔ Objective measure of muscle endurance ↑
LIFE, 2010^130^ | Fair | 186 | Intermediate: NA | -- | --
LIFE, 2010^130^ | Fair | 186 | Long: NA | -- | --

* Based on 16-item Food Choices Questionnaire.

‡ Visual Analogue Scale.

§ Not abstracted because of poor quality.

║ Based on Dietary Risk Assessment.

¶ Based on meeting ACSM guidelines.

# Text states “borderline statistical significance”; p=NR.

** Outcomes for men and women unless otherwise noted.

†† Only raw data reported; p=NR.

‡‡ Based on self-reported questionnaire; combined assessment of duration of vigorous and moderate PA.

Abbreviations: ACSM = American College of Sports Medicine; CDC = Centers for Disease Control and Prevention; GOAL = Groningen Overweight and Lifestyle Study; HD = healthy diet; HIPS = Health Improvement and Prevention Study; IMPALA = Improving Patient Adherence to Lifestyle Advice; LIFE = Lifestyle Interventions and Independence for Elder; MUFA = monounsaturated fatty acid; N = study population; NA = not available; NERS = National Exercise Referral Scheme; NR = not reported; PA = physical activity; PAC = Physical Activity Counseling; PACE = Physician-based Assessment and Counseling for Exercise; PEGASE = Pan European Grid Advanced Simulation and State Examination; PHPP = Physician-motivated Health Promotion Program; PUFA = polyunsaturated fatty acid; QOL = quality of life; RIS = Risk Factor Intervention Study; SF = saturated fat; SPRING = Self-monitoring and Prevention of Risk Factors; Un-SF = unsaturated fat; VO_2_ = oxygen consumption.

Two trials (n=2,594) reported only behavioral outcomes.109,114 One fair-quality trial, Logan Healthy Living (n=434), evaluated a medium-intensity telephone-only combined lifestyle counseling intervention and found statistically significant improvements in fat, saturated fat, fiber, and fruit/vegetable intake at up to 18 months. This trial, however, did not find a statistically significant improvement in physical activity behaviors.114 The other fair-quality trial, NERS (n=2,160), evaluated a medium-intensity physical activity–only counseling intervention and found an improvement in total physical activity (approximately 35 minutes more per week) at 12 months.109

Ten trials evaluated medium- to high-intensity physical activity–only counseling interventions.98, 99,104,109,122,123,128,130,131,141 Overall, while there was no consistent benefit observed for intermediate health outcomes, the limited number of trials and heterogeneity among these trials did not allow for any definitive conclusion of lack of benefit on intermediate outcomes for physical activity–only counseling interventions. Findings for behavioral outcomes in these trials are generally consistent with the findings for intermediate health outcomes (Tables 21–24; Appendix G Table 2). The two trials (n=125) that demonstrated a benefit on intermediate health outcomes showed an increase in self-reported physical activity outcomes.104,141 Trials that found no benefit on intermediate outcomes found no statistically significant benefit on self-reported physical activity outcomes (including total or leisure physical activity, percent meeting physical activity guidelines). Five of the 10 trials only reported short-term outcomes (<12 months).104,122, 128,130,141 Three of these counseling trials (n=608) used objective measures of cardiorespiratory fitness and found no statistically significant benefit at 6 to 12 months.98,122,130 Self-reported measures of physical activity varied across trials—the most commonly reported measures included total energy expenditure, steps per day, minutes per week of total or moderate to vigorous physical activity, and percent meeting physical activity goal (150 minutes/week). Five (n=4,209) of 10 trials reported outcomes at 12 months or greater.98,99,109,123,131 Four (n=3,439) of these five trials found statistically significant improvements in self-reported physical activity outcomes at 12 to 24 months.98,99,109,123 One of these trials, NERS (n=2,160), only reported behavioral outcomes.109 This trial was conducted in the United Kingdom and evaluated a medium-intensity physical activity–only counseling intervention that also offered access to low-cost exercise classes. This trial found an improvement in total physical activity (approximately 35 minutes more per week) at 12 months.

Four trials reported subgroup analyses for behavioral outcomes that allow for direct comparisons of findings between men and women, as well as older and middle-aged adults.107, 109,123,145 While two of these trials (n=5,381) suggest that men had greater improvement in self-reported physical activity change at 12 months,107,123 two trials (n=2,401) found no difference by sex in physical activity outcomes at 12 or 36 months.109,145 Two trials (n=3,038) suggest no statistically significant differences in behavioral outcomes by age, such that older adults also appear to benefit from counseling aimed at improving physical activity levels.109,123

## KQ 4 What Are the Adverse Effects of Healthy Diet and/or Physical Activity Behavioral Counseling Interventions in Adults With Known CVD Risk Factors?

### Overall Results

We narrowly focused this question on harms of counseling interventions, rather than broadly on harms of dietary or physical activity changes themselves. We examined the 74 trials included for KQs 1 through 3 for harms, as defined by the study authors, or any paradoxical change in outcomes (e.g., worsening of blood pressure, lipids, glucose, measures of weight, dietary intake, physical activity) (Tables 1 and 2). While we searched for additional studies examining harms of healthy lifestyle counseling interventions, we did not find any such studies.

Overall, the harms of included counseling interventions were very sparsely reported, although we did not a priori hypothesize that these counseling interventions would result in serious harms (i.e., unexpected or unwanted medical attention). Only 10 of the included trials explicitly mentioned harms or lack of harms (Tables 1 and 2). In general, the included interventions did not have significant adverse effects. While four trials reported increased complaints in persons receiving behavioral counseling attributed to an increase in physical activity,89,98,123,130 there were generally no serious injuries, except for one trial targeting older adults.98 We found no consistent evidence for paradoxical changes in intermediate or behavioral outcomes. While nine of the 13 trials that reported carbohydrate intake reported an increase in carbohydrate intake, this increase was generally accompanied by dietary improvements in fat, saturated fat, fiber, and fruits and vegetables, without an overall increase in sugar or total calories consumed.71,75,80,89,96,118,138,146,147

### Detailed Results for Harms

Six fair- to good-quality trials (n=2,420) that evaluated medium- to high-intensity combined diet and physical activity counseling interventions specifically reported no adverse events during the trial.92,94,96,116,117,146 The mean age of participants in these trials ranged from 52 to 66 years. While four trials report “no adverse events,” they did not offer any additional details.92,94, 96,146 The PREMIER (n=304, hypertension subgroup only) trial was aimed at lowering blood pressure in persons (mean age, 52 years) who were not yet taking medications and reported no differences between intervention arms in serious adverse events, including cardiovascular or musculoskeletal events, at 6 months.116 TONE (n=975) was aimed at lowering blood pressure in persons (mean age, 66 years) who were already taking antihypertension medications; it reported no differences between intervention arms in “excessive” weight loss, physical injury, palpitations, chest pain, dizziness, edema, headaches, and “any” adverse events at 36 months.117

Six fair- to good-quality trials (n=3,961) that evaluated different medium- to high-intensity counseling interventions specifically reported adverse events during the trial.89,98,113,114,123,130 The Logan Healthy Living trial (n=434) was aimed at persons with hypertension or diabetes in Australia with a mean age of 58 years. This trial reported that three persons allocated to the intervention arm, a medium-intensity telephone-counseling intervention, died of unknown causes during the 18-month trial.114 No additional details are reported. Another trial conducted by Rodriguez and colleagues (n=533) evaluated a medium-intensity combined lifestyle counseling intervention in persons with hypertension (mean age, 67 years). The authors reported that nine participants were withdrawn during the 12-month trial by research staff because of an adverse event that would affect study participation, but no additional details (including how many participants in each arm) are given.113 DPP (n=2,161), a high-intensity combined lifestyle counseling intervention aimed at preventing diabetes in overweight persons with impaired fasting glucose (mean age, 51 years), reported slightly more musculoskeletal complaints (i.e., myalgia, arthritis, arthralgia) in the intervention group receiving a high-intensity counseling intervention at 2.8 years (24.1 vs. 21.1 events per 100 person-years in the intervention and control groups, respectively; p<0.02).89 Gastrointestinal symptoms (diarrhea, flatulence, nausea, vomiting) were more common in the control group. The trial reported no differences in hospitalizations between the intervention arms. Three trials evaluating physical activity–only counseling interventions reported complaints due to increased exercise.98,123,130 The Lifestyle Intervention and Independence for Elders trial (n=186) was aimed at older adults with a mean age of 67 years. This trial reported that one participant in the high-intensity counseling group withdrew because of fatigue attributed to exercise at 11 months.130 The Enhanced Fitness Trial (n=302), which was also aimed at older adults at the VA with a mean age of 67 years, reported a total of 691 adverse events during the 12-month trial, 650 (94%) of which were classified as nonserious (e.g., aches, pain, sore muscles, headaches, minor injuries).98 Of the 64 (6%) events classified as serious (life threatening or requiring hospitalization), two events were attributed to physical activity. Both of these events occurred in the intervention group receiving a high-intensity counseling intervention—one person had angina while on a treadmill requiring hospitalization and the other person fell from the treadmill and broke his femur. A third physical activity counseling trial (n=878), the Green Prescription Programme, with a mean age of 58 years, reported increased “bodily pain” at 12 months (p=0.02) as measured by the SF-36 in the medium-intensity counseling intervention group compared with the wait list control group.123 The authors stated, however, that there was no difference between the trial arms in falls, injuries, or hospital admissions at 12 months.

In examining the included trials, we found no consistent evidence that behavioral counseling resulted in unwanted paradoxical effects in intermediate or behavioral outcomes. Two fair-quality trials with a number of methodological limitations had paradoxical findings in intermediate health outcomes.83,92 One small trial (n=92) conducted in Sweden in participants with a mean age of 42 years found lower HDL cholesterol at 12 months in the intervention group receiving a medium-intensity dietary counseling intervention compared with the usual care control group.83 The authors note, however, that more women were included in the control group (accounting for higher HDL cholesterol in the control group) and results were not adjusted for sex differences. Another trial (n=307), Healthy Living Course, aimed at persons with impaired fasting glucose, reported a greater incidence of diabetes in the high-intensity counseling intervention group (n=24) than the control group (n=7) at 6 months (p=not reported).92 We found no evidence that medium- or high-intensity counseling interventions negatively affected dietary intake or physical activity. Thirteen trials reported carbohydrate intake as a self-reported dietary outcome.70,71,75,89,91,94,118,119, 138,146-149 Four trials (n=654) reported no change in carbohydrate intake,70,90,94,119 while nine (n=4,387) of the 13 trials reported an increase in consumption of carbohydrates in the intervention group compared with the control group at 6 to 36 months.71,75, 80,89,96,118,138,146,147 The increased consumption of carbohydrates was generally accompanied by corresponding dietary improvements in decreased consumption of fat and saturated fats and increased consumption of fiber and fruits and vegetables. None of these trials reported an overall increase in total calories consumed. In fact, most often an increased consumption of carbohydrates was accompanied by a decrease in total calories consumed. Therefore, we did not consider the increase in carbohydrate consumption in the intervention group to represent a harm. In ADAPT (n=241), the authors suggest that a decrease in high-fat dairy products in the intervention group that was not replaced with low-fat dairy products could potentially result in a decrease in calcium consumption.138