# Methods

## Scope and Purpose

This systematic review was designed to complement the systematic review supporting the 2012 USPSTF recommendation that focused on healthy lifestyle counseling for individuals without pre-existing CVD or its risk factors.55 For this review, we adapted our previous analytic framework and key questions to address the benefits and harms of primary care–relevant counseling interventions to improve diet and physical activity in adults with known cardiovascular risk factors (e.g., hypertension, dyslipidemia, impaired fasting glucose or glucose tolerance, metabolic syndrome), but without pre-existing CVD.

## Analytic Framework and Key Questions

Using the USPSTF's methods (detailed in Appendix A),56 we developed an analytic framework (Figure 1) and four key questions (KQs):

1. Do primary care–relevant behavioral counseling interventions for healthy diet and/or physical activity improve CVD health outcomes (e.g., prevent morbidity and mortality) in adults with known CVD risk factors (e.g., hypertension, dyslipidemia, impaired fasting glucose, metabolic syndrome)?
  a. Are there population or intervention characteristics that influence the effectiveness of the interventions?
2. Do primary care–relevant behavioral counseling interventions for physical activity and/or healthy diet improve intermediate outcomes associated with CVD (e.g., blood pressure, lipids, glucose, weight) in adults with known CVD risk factors (e.g., hypertension, dyslipidemia, impaired fasting glucose, metabolic syndrome)?
  a. Are there population or intervention characteristics that influence the effectiveness of the interventions?
3. Do primary care–relevant behavioral counseling interventions for physical activity and/or healthy diet change associated health behaviors in adults with known CVD risk factors (e.g., hypertension, dyslipidemia, impaired fasting glucose, metabolic syndrome)?
  a. Are there population or intervention characteristics that influence the effectiveness of the interventions?
4. What are the adverse effects of primary care–relevant behavioral counseling interventions for physical activity and/or healthy diet in adults with known CVD risk factors (e.g., hypertension, dyslipidemia, impaired fasting glucose, metabolic syndrome)?

Figure 1 Analytic Framework: Behavioral Counseling to Promote a Healthy Lifestyle for Cardiovascular Disease Prevention in Persons With Cardiovascular Risk Factors

Abbreviations: CVD = cardiovascular disease; BMI = body mass index.

Figure 1 is the proposed analytic framework that depicts the four Key Questions (KQs) to be addressed in the systematic review. The figure illustrates how behavioral counseling interventions for healthy diet and/or physical activity may improve cardiovascular disease (CVD) health outcomes (KQ1) in adults (aged ≥18 years) with known CVD risk factors. The figure also depicts how these interventions may influence intermediate health outcomes associated with CVD (KQ2) or associated health behaviors (KQ3). In addition, the figure depicts whether these interventions have any potential harms (KQ4).

## Data Sources and Searches

We designed this review to serve as an extension of our prior systematic review that was completed in 2009.^55^ As such, we examined all included and excluded studies from that systematic review, paying particular attention to excluded studies in persons with CVD risk factors. The literature search for this systematic review includes searches from MEDLINE, PubMed, PsycInfo, the Database of Abstracts of Reviews of Effects, and the Cochrane Central Register of Controlled Trials from January 2001 through October 2013. We also searched for recent relevant existing systematic reviews on healthy lifestyle counseling in persons with CVD risk factors from January 2008 through January 2013 in MEDLINE, the Cochrane Database of Systematic Reviews, and the Database of Abstracts of Reviews of Effects, and publications from the Institute of Medicine, the Agency for Healthcare Research and Quality (AHRQ), and the National Institute of Health and Clinical Excellence. We worked with a medical librarian to develop our search strategy (Appendix A Table 1) and all searches were limited to articles published in the English language. We managed the literature search results using version 12.0 of Reference Manager® (Thomson Reuters, New York, NY), a bibliographic management software database.

To ensure the comprehensiveness of our search strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published before the timeframe of or not identified in our literature searches. We also supplemented our database searches with suggestions from experts and searched Clinicaltrials.gov to identify relevant ongoing trials (Appendix B).

## Study Selection

Two investigators independently reviewed the titles and abstracts of 7,218 identified articles to determine if the study met the inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A Figure 1). Two reviewers then independently evaluated 553 full-text articles of potentially included studies against the complete inclusion and exclusion criteria (Appendix A Table 1). We resolved disagreements by discussion and consultation with a third reviewer, if necessary. Excluded studies and reasons for their exclusion are listed in Appendix C.

We developed an a priori set of inclusion and exclusion criteria (Appendix A Table 1). We included studies in adults who had at least one cardiovascular risk factor, including hypertension, dyslipidemia, impaired fasting glucose or glucose tolerance, and metabolic syndrome. We excluded trials in persons with known CVD (i.e., coronary artery disease [CAD], cerebrovascular disease, peripheral artery disease), severe chronic kidney disease, and diabetes. While diabetes is a strong risk factor for CVD,8,9 we considered existing diabetes to be a CVD risk equivalent. As such, we excluded trials evaluating lifestyle counseling interventions for the management of diabetes. While many included trials targeted persons with a combination of risk factors, including smoking and obesity, we did not find any diet and/or exercise counseling trials that selected persons exclusively based on smoking history. We excluded populations in which obesity was the only CVD risk factor, as these trials recruited persons exclusively for obesity with a primary aim of weight loss or weight management. These trials were excluded because this evidence base is covered by a separate systematic review conducted for the USPSTF;57 the USPSTF issued a separate recommendation statement in 2012 for the management of obesity in adults.58 We also excluded populations with increased risk for CVD (e.g., due to physical inactivity, prehypertension), but without traditional CVD risk factors. Again, these trials were covered by a separate systematic review55 and are addressed in the 2012 USPSTF recommendation on healthy lifestyle behavioral counseling.59

We included behaviorally-based counseling interventions to promote a healthy diet, physical activity, or both. Counseling interventions could be delivered alone or as part of a multicomponent intervention. Interventions had to be either conducted in primary care or judged to be feasible for delivery or referral from primary care. Therefore, we excluded interventions delivered through nonreferable community settings (e.g., work sites, churches). We included physical activity interventions that incorporated activities such as walking, cycling, swimming, or resistance training. We included healthy diet interventions aiming to change dietary behavior or improve or maintain cardiovascular health through a balanced diet (e.g., appropriate calorie intake; increased fruits and vegetables, whole grains, and fiber; balanced fats intake; and decreased sodium). We excluded interventions that were primarily aimed at evaluating if behavior change (i.e., improved diet or increased physical activity) resulted in physiologic or health benefits, as opposed to including interventions aimed at evaluating if counseling could change behavior. Therefore, we generally excluded interventions that focused on providing controlled diets or supervised physical activity. However, we included counseling interventions if they provided limited samples of foods or access to (optional) guided physical activity. We excluded counseling interventions primarily aimed at weight loss, falls or fracture prevention, or cognitive functioning, rather than CVD prevention.

Given the maturity and volume of literature, we focused on the most rigorous and most applicable evidence. Therefore, we limited studies of efficacy or effectiveness to fair- to good-quality randomized, controlled trials or controlled clinical trials that were conducted in developed countries and whose results were published in 1990 or later. Included trials had to compare an active intervention with usual care, a minimal intervention, or an attention control group. Because usual care for persons with known cardiovascular risk factors includes lifestyle counseling, we allowed included trials to use comparator groups that received nontailored printed materials, a single annual session (limited to 45 to 60 minutes), or two to three brief sessions annually (limited to 15 minutes each). We required that included trials have a followup duration of 6 months or greater. We examined health outcomes, including morbidity or mortality related to CVD. Intermediate health outcomes, or physiologic outcomes, included blood pressure, total cholesterol, LDL cholesterol, HDL cholesterol, fasting serum glucose, glucose tolerance, hemoglobin A1c, weight, and body mass index (BMI). Consistent with current USPSTF methods, true health outcomes (KQ 1) are those that are experienced by the patient. Therefore, we considered disease incidence (e.g., diabetes) and changes in CVD risk score as intermediate outcomes (KQ 2), as opposed to health outcomes (KQ 1), for this review. We accepted a number of behavioral outcomes, including self-reported dietary intake, self-reported physical activity, or objectively measured markers of behavior change, such as VO_2_max and urinary sodium. We also included observational studies that reported serious harms (i.e., adverse events resulting in unexpected or unwanted medical attention), but did not include case series or case reports.

## Data Extraction and Quality Assessment

One reviewer extracted data from all included studies rated as fair or good quality into a standard evidence table. A second reviewer checked the data for accuracy. The reviewers abstracted population characteristics (e.g., details about baseline demographics and baseline CVD risk), study design elements (e.g., recruitment procedures, inclusion/exclusion criteria, duration of followup and attrition), intervention and control characteristics (e.g., content, format, setting, number and length of sessions, duration, provider), any behavioral outcomes related to healthy diet and physical activity, and intermediate health outcomes (e.g., blood pressure, lipids, glucose tolerance, measures of weight, medication use, diabetes incidence, composite CVD risk), as well as patient health outcomes (e.g., mortality, CVD events, quality of life [QOL]) and harms (Appendix D Tables 1–9; Appendix E Table 1).

Two reviewers independently appraised all articles that met inclusion criteria using the USPSTF's design-specific quality criteria,60 which we supplemented with the National Institute for Health and Clinical Excellence methodology checklists (Appendix A Table 2).61 We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria well. A fair-quality study did not meet, or it was unclear if it met, at least one criterion, but also had no known important limitation that could invalidate its results. A poor-quality study had important limitations, or a fatal flaw, that would invalidate results. We excluded poor-quality studies from this review. Poor-quality studies had important limitations, including one or more of the following risks for bias: very high attrition (>40%), with or without differential attrition between intervention arms; lack of randomization, with biased assignment of participants to intervention arms, often with differences in or no reporting of baseline characteristics, per protocol analyses only; and poor description of methods that did not allow for adequate quality assessment.

## Data Synthesis and Analysis

Because of the clinical heterogeneity across this body of evidence, we separately analyzed identified evidence according to how populations were targeted or defined (i.e., dyslipidemia, hypertension, impaired fasting glucose or glucose tolerance, or mixed risk factors), as well as according to type of intervention evaluated (i.e., focus on dietary counseling alone, physical activity alone, or both diet and physical activity counseling). We used summary tables to describe key characteristics of trials capturing the major sources of heterogeneity among included trials and results for the multiple outcomes reported for each trial.

We conducted random-effects meta-analyses using the DerSimonian and Laird method to estimate the effect size of counseling on intermediate health outcomes (KQ 2) (i.e., weight or BMI; systolic and diastolic blood pressure; total, HDL, or LDL cholesterol; triglycerides; fasting blood glucose; and diabetes incidence).62 Other measures of adiposity (i.e., waist circumference) and glucose (i.e., hemoglobin A1c, 1- or 2-hour glucose tolerance) were not as commonly reported. We conducted qualitative synthesis of health outcomes (KQ 1) and harms (KQ 4) given the sparse reporting of these outcomes. We also conducted qualitative syntheses of behavioral outcomes (KQ 3) (e.g., self-reported physical activity; objectively measured fitness; intake of total energy, fat, saturated fat, fiber, fruits and vegetables; and urinary sodium as a measure of sodium intake) because of the wide variation in reporting of these outcome measures across included trials. Outcome analyses were also stratified by length of followup after randomization. Short-term followup included outcome measurements from 6 to less than 12 months. Intermediate-term followup included outcome measurements from 12 to 24 months. Long-term followup included outcome measurements after 24 months. Because the interventions were quite variable in their duration, the length of followup does not reflect duration of effect postintervention. We also used intervention intensity as a key characteristic of heterogeneity. Low-intensity interventions were estimated to include 30 minutes or less of contact with providers. These trials generally included only a single contact, two very brief contacts, or mail-only interventions. Medium-intensity interventions were estimated to involve greater than 30 minutes, but less than 6 hours, of contact with providers (e.g., 1-hour group meeting monthly for up to 6 months). High-intensity interventions were estimated to involve greater than 6 hours of contact. Because many articles did not report detailed information about the duration of contact, these categorizations often involved some reviewer judgment. As such, at least one other team member reviewed the studies' categorizations, and we resolved discrepancies through discussion.

For all intermediate health outcomes, we pooled the difference in change from baseline to followup between groups. We converted all outcomes to a common metric (e.g., mg/dL, mm Hg, lb) using standard conversion factors.63 We calculated the pooled weighted mean difference separately for short-, intermediate-, and long-term followup. For weight outcomes, we estimated a standardized mean difference because measures could be either weight (lb) or BMI (kg/m^2^). If there were multiple intervention arms, we selected the most intensive or comprehensive arm to include in the meta-analysis. If the active intervention arms were of similar intensity and comprehensiveness, we calculated combined means and standard deviations using standard formulas. We adjusted results for cluster-randomized trials, but did not report adjusting for the clustering effect.

We assessed the presence of statistical heterogeneity among the studies using standard chi-squared tests and the magnitude of heterogeneity was estimated using the I^2^ statistic.64 In instances of 10 or more studies, we formally assessed for publication bias, whether the distribution of the effect sizes was symmetric with respect to the precision measure, using funnel plots and Egger's linear regression method.65,66

We used stratified analyses and visual inspection of forest plots arranged by effect size and/or meta-regressions (combining all studies included for KQ 2) to examine the effect of a priori–specified primary sources of heterogeneity on effect size: study population, intervention type, intervention intensity (including number of contacts and duration of intervention), length of followup, overall methodologic quality of study, year of publication, country setting (United States vs. other), type of control group, and population risk (including average age, percent smokers, percent with hypertension, percent with dyslipidemia, percent with diabetes, average systolic blood pressure [SBP], average LDL cholesterol, average BMI, medication use). For each of the intermediate health outcomes, we also used meta-regressions to examine whether population, intervention focus, intervention intensity (high vs. not high), publication year, study quality (rated on a 4-point scale), and mean age of the study sample were associated with effect size. We conducted two sets of models when examining intervention by intensity, year, study quality, and age—one controlling for population (using the multiple risk factors population as the reference group) and one controlling for intervention focus (using the combined healthy diet plus physical activity interventions as the reference group). We performed all analyses using Stata 11.2 (StataCorp, College Station, TX).

## Expert Review and Public Comment

A draft research plan was available for public comment from January 29 to February 25, 2013 that included the analytic framework, KQs, and inclusion criteria. We made no substantive changes to our review methods based on comments received. A draft version of this report was reviewed by six invited content experts as well as federal partners from the CDC, Centers for Medicare & Medicaid Services, National Institutes of Health, U.S. Department of Veterans Affairs (VA), and the Military Health Service. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and subsequently addressed, as appropriate, in this final version of the report. Additionally, a full draft report was posted for public comment on the USPSTF's Web site from May 13 to June 9, 2014. We received comments from five unique individuals or organizations. All comments were reviewed and considered. No new substantive issues were brought up during the public comment periods that were not previously considered. No major changes were made to the text in the final report. Minor editorial suggestions/corrections were addressed as appropriate.

## USPSTF Involvement

The authors worked with three USPSTF liaisons at key points throughout the review process to refine the inclusion criteria, address methodological decisions on applicable evidence, and resolve issues around the scope of the final evidence synthesis. AHRQ funded this research under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project and assisted in external review of the draft evidence synthesis.