# Introduction

## Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2002 and 2003 recommendations on primary care–relevant behavioral counseling to promote a healthy diet and physical activity in adults with traditional risk factors for cardiovascular disease (CVD).

## Definitions

### Healthy Diet

A healthy diet promotes health and reduces an individual's risk for chronic disease through nutritious eating patterns. For the purposes of this review, we will include any dietary counseling interventions that promote a balanced diet (e.g., appropriate energy content); balance of fats (e.g., consumption of mono and poly unsaturated fats, omega-3 fats, avoidance of excess saturated fat, avoidance of trans fat); increased consumption of fruits and vegetables; increased consumption of legumes; increased consumption of lean proteins; increased consumption of nonfat or low-fat dairy; balance of carbohydrates (e.g., consumption of whole grain and fiber; avoidance of excess refined carbohydrates, including excess sweetened beverages); and avoidance of excess sodium. This guidance is generally consistent with dietary recommendations of a number of groups, including the Institute of Medicine, the World Health Organization, the U.S. Department of Health and Human Services (DHHS), the U.S. Department of Agriculture, the Academy of Nutrition and Dietetics (previously the American Dietetic Association), the Centers for Disease Control and Prevention (CDC), the American Heart Association (AHA) and American College of Cardiology (ACC), the American Cancer Society, and the American Diabetes Association. We did not review dietary counseling interventions that only focused on micronutrient intake, vitamin and/or antioxidant supplementation, or alcohol moderation.

### Physical Activity

Although no internationally accepted definition of physical activity exists, American researchers have defined physical activity as “bodily movement produced by the contraction of skeletal muscle that increases energy expenditure above the basal level.”1 DHHS and other organizations2-4 recommend that adults age 18 years and older should engage in at least 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity aerobic physical activity per week, in addition to engaging in strengthening activities at least twice per week. Based on these definitions, this review focused on counseling interventions promoting aerobic- or strength-related physical activity. We did not review counseling that focused primarily on flexibility or balance.

### Cardiovascular Risk Factors

Risk factors for CVD are well established and include both modifiable and nonmodifiable components. Modifiable risk factors include: dyslipidemia or hyperlipidemia (referred to as dyslipidemia in this report), hypertension, diabetes, overweight and obesity, smoking, lack of physical activity, and unhealthy diet.5-7 Nonmodifiable risk factors include: age, sex, and family history.5,6

This review focuses on patients who are at high risk for CVD, which we defined as having one or more of the following risk factors: dyslipidemia, hypertension, impaired fasting glucose/impaired glucose tolerance, and/or metabolic syndrome. Metabolic syndrome is a clustering of metabolic risk factors that include abdominal obesity, dyslipidemia, increased blood pressure, insulin resistance, or glucose intolerance. While diabetes is a strong risk factor for CVD,8,9 we considered existing diabetes to be a CVD risk equivalent. As such, we did not review studies primarily aimed at patients with diabetes or pre-existing coronary heart disease, cerebrovascular disease, peripheral artery disease, or severe chronic kidney disease.

## Prevalence and Burden of Preventable Illness

Diseases associated with modifiable risk factors are the leading causes of illness and death in the United States.10 CVD is the leading cause of death in the United States and nearly a quarter of CVD deaths are considered avoidable.11,12 Declines in cardiovascular mortality in recent decades have been attributed to improvements in modifiable risk factors, including reductions in blood pressure, cholesterol, and physical inactivity.13

A substantial portion of the U.S. population has at least one modifiable risk factor for CVD. In 2009–2010, for example, the overall age-adjusted prevalence of hypertension among U.S. adults was approximately 29 percent.14 During this same time period, an estimated 13 percent of adults had high total cholesterol and 21 percent had low high-density lipoprotein (HDL) cholesterol.15 In 2007–2010, the overall prevalence of high low-density lipoprotein (LDL) cholesterol was 27 percent in the United States.16 National Health and Nutrition Examination Survey (NHANES) data from 2005–2006 indicate that about 30 percent of U.S. adults have impaired fasting glucose or impaired glucose tolerance.17 Likewise, 2003–2006 NHANES data show a 34 percent prevalence of metabolic syndrome.18 In 2011, 19 percent of U.S. adults smoked cigarettes.19 While the prevalence of hypertension and dyslipidemia has declined in the United States, these conditions are still very common, and adequate control of these risk factors remains suboptimal.14,20,21

Cardiovascular risk factors and CVD burden is not equally distributed across the U.S. population. Certain groups experience a higher prevalence of risk factors and rates of avoidable death from CVD, including older adults, men, persons with low income, and some racial/ethnic groups.12,14,15, 17,22 Selected examples of the large variation in the distribution of risk factors include: the prevalence of hypertension is approximately 67 percent in adults age 60 years and older and just 7 percent in younger adults ages 18 to 39 years,14 and the prevalence of hypertension is 40 percent in blacks compared with 26 percent in Hispanics and 27 percent in nonHispanic whites.14 Similarly, poor Americans are nearly twice as likely to smoke as the nonpoor (28% vs. 16%).19 Finally, the avoidable death rate for CVD among blacks is almost twice that of whites.12

## Dietary and Physical Activity Behaviors in the United States

Observational research consistently shows that a healthy diet and physical activity are associated with benefits in important health outcomes, including reductions in cardiovascular events and all-cause mortality.23-31 Despite this convincing evidence, however, U.S. adults do not comply with healthy diet and physical activity recommendations.32,33 According to NHANES data from 2005–2006, greater than 30 percent of men and 32 percent of women do not engage in any leisure time physical activity. Previous years of NHANES data reveal that rates of physical activity did not significantly improve from 1999 to 2006 for men or women.34 Similarly, greater than 81 percent of men and 70 percent of women eat a poor diet, which is defined by inadequate consumption of fruits/vegetables, fish, and whole grains and excess intake of sodium and sweets/sugar-sweetened beverages.34 Adherence to an ideal diet has improved only minimally from 1999 to 2008 (0.3% to 0.6% for men and 0.9% to 1.4% for women).34 Some research shows that high-risk adults are even less likely to adhere to healthy lifestyle behaviors than their lower-risk counterparts. An analysis of NHANES data from 2001 to 2006 found that adults with hypertension or dyslipidemia were less likely to adhere to five healthy lifestyle habits (including consuming five or more fruits/vegetables per day, regular exercise, maintaining a healthy weight, moderate alcohol consumption, and not smoking) than adults with no CVD or its risk factors (5% and 8%, respectively, vs. 11%).35 Secondary analysis of 1999–2004 NHANES data for adults with hypertension found that 20 percent of individuals adhered to DASH (Dietary Approaches to Stop Hypertension) dietary recommendations, which emphasize fruits, vegetables, whole grains, and low-fat dairy consumption while limiting sugar-sweetened foods and beverages, reducing red meat consumption, and avoiding added fats.36

There is also a marked disparity in healthy diet and physical activity behaviors by important subpopulations. Persons of lower socioeconomic status or those with lower educational attainment tend to exercise less, eat fewer fruits and vegetables, and eat fewer foods rich in dietary fiber compared with those in a higher socioeconomic position or with higher educational attainment.37-39 Nonwhites tend to exercise less than whites,39,40 and blacks consume fewer servings of fruits and vegetables than whites.37,41,42 Physical activity rates are lower in older persons and women than in younger persons and men.39,43 Major barriers to healthy eating include: low income, food marketing, lack of accessible and accurate information on what constitutes a healthy diet, poor accessibility to affordable healthy foods, lack of opportunity to experiment and to develop cooking skills (e.g., poor literacy, reduced access to well-equipped kitchens, homelessness, poor educational attainment), and sociocultural factors (e.g., family or cultural food norms, family resistance, lack of support, and child care demands can all inhibit dietary change). Major barriers to physical activity in adults include: high costs of exercise facilities, exercise equipment, and sports teams; poor access to facilities; and unsafe or unsupportive environments.39,44 Psychosocial barriers to physical activity include: anxiety about unfamiliar settings for exercise, poor body image, lack of social support for exercise, low self-efficacy for maintaining an exercise program, and lack of belief in the benefits of exercise.39

## Current Clinical Practice in the United States

Consistent with the 2002 USPSTF recommendation, the American Academy of Family Physicians recommends that primary care physicians or other qualified professionals provide intensive behavioral dietary counseling for adults with dyslipidemia and other known risk factors for cardiovascular and diet-related chronic disease.45 The American College of Physicians has endorsed the USPSTF recommendation and other organizations, including the AHA and Academy of Nutrition and Dietetics, have produced similar guidance.46-49

Although patients perceive family doctors as one of the most reliable sources of information on food and nutrition,50 dietary counseling practices of primary care clinicians fall short of recommendations, even for patients at high risk for CVD. A 2002 survey showed that among adults with hypertension, just 21 percent reported being advised by a physician or other health professional to start a diet or change their eating habits and 22 percent reported receiving advice to reduce their sodium intake.51 A direct observation study of family medicine visits found that although diet was discussed in 31 percent of visits, offers of assistance and followup were infrequent (17% and 10% of visits, respectively).52

Despite improvements in physician advice to encourage physical activity over the past decade, the prevalence of physical activity counseling remains low. The 2010 National Health Interview Survey, for example, showed that approximately 44 percent of adults with hypertension reported that their physician recommended they exercise (up from 34% in 2000).53 This survey found a higher proportion of physical activity advice among adults with chronic conditions, including CVD and diabetes, compared with the overall population (32%). A recent systematic review of providers' attitudes toward physical activity counseling found that most primary care providers agree that such counseling is important and that they have a role in promoting physical activity to their patients.54 Barriers to physical activity counseling cited by providers, however, are substantial and include: lack of time, lack of knowledge or training about physical activity counseling, and lack of success with changing patient behavior.54

## Previous USPSTF Recommendations

In 2012, the USPSTF updated the recommendation for adults without pre-existing CVD or its risk factors, concluding that the average benefit of behavioral counseling interventions in primary care to promote a healthy diet and/or physical activity for CVD prevention is small, and that clinicians may consider selectively providing or referring individual patients for medium- or high-intensity behavioral counseling interventions (C recommendation).

The 2012 recommendation did not address counseling in persons with known traditional CVD risk factors. In 2002, the USPSTF issued separate recommendations for healthy diet and physical activity counseling, both of which included persons with cardiovascular risk factors (as well as unselected persons). In 2002, the USPSTF recommended intensive behavioral dietary counseling for adult patients with hyperlipidemia and other known risk factors for cardiovascular and diet-related chronic disease (B recommendation). It concluded, however, that the evidence was insufficient to recommend for or against behavioral counseling in primary care settings to promote physical activity (I statement).

In 2012, the USPSTF issued a related recommendation on screening for and management of adult obesity. It recommended screening all adults for obesity, and that clinicians should offer or refer obese patients to intensive, multicomponent behavioral interventions (B recommendation).

As a result, we conducted this systematic review to support the USPSTF in updating its 2002 recommendations on primary care–relevant behavioral counseling to promote a healthy diet and physical activity in patients with known CVD risk factors. This review was designed to complement the existing systematic reviews that supported the 2012 USPSTF recommendations and, therefore, does not include healthy lifestyle interventions aimed at persons without CVD risk factors or interventions primarily aimed at weight loss or weight management.