# Detailed Results of Final Health Outcomes and Behavioral Outcomes

Appendix G Table 1 Health Outcomes (KQ 1 Results): Cardiovascular Disease

Appendix G Table 2 Health Outcomes (KQ 1 Results): Self-Reported Quality of Life and Depression Symptoms

Appendix G Table 3 Behavioral Outcomes (KQ 3 Results): Healthy Diet

Appendix G Table 4 Behavioral Outcomes (KQ 3 Results): Physical Activity