# Additional Meta-Analysis Figures

Appendix F Figure 1 Pooled Analysis of Total Cholesterol in All Risk Groups Combined, Sorted by Intervention Intensity

Appendix F Figure 1 is a forest plot depicting the change in total cholesterol in all risk groups combined. This figure is discussed in the Results section.

Appendix F Figure 2 Pooled Analysis of Total Cholesterol in All Risk Groups Combined, Sorted by Intervention Intensity and Excluding Physical Activity–Only Interventions

Appendix F Figure 2 is a forest plot depicting the change in total cholesterol in all risk groups combined, excluding physical activity only interventions. This figure is discussed in the Results section.

Appendix F Figure 3 Pooled Analysis of Low-Density Lipoprotein Cholesterol in All Risk Groups Combined, Sorted by Intervention Intensity

Appendix F Figure 3 is a forest plot depicting the change in low-density lipoprotein in all risk groups combined. This figure is discussed in the Results section.

Appendix F Figure 4 Pooled Analysis of Low-Density Lipoprotein Cholesterol in All Risk Groups Combined, Sorted by Intervention Intensity and Excluding Physical Activity–Only Interventions

Appendix F Figure 4 is a forest plot depicting the change in low-density lipoprotein in all risk groups combined, excluding physical activity only interventions. This figure is discussed in the Results section.

Appendix F Figure 5 Pooled Analysis of Systolic Blood Pressure in All Risk Groups Combined, Sorted by Intervention Intensity

Appendix F Figure 5 is a forest plot depicting the change in systolic blood pressure in all risk groups combined. This figure is discussed in the Results section.

Appendix F Figure 6 Pooled Analysis of Systolic Blood Pressure in All Risk Groups Combined, Sorted by Intervention Intensity and Excluding Physical Activity–Only Interventions

Appendix F Figure 6 is a forest plot depicting the change in systolic blood pressure in all risk groups combined, excluding physical activity only interventions. This figure is discussed in the Results section.

Appendix F Figure 7 Pooled Analysis of Diastolic Blood Pressure in All Risk Groups Combined, Sorted by Intervention Intensity

Appendix F Figure 7 is a forest plot depicting the change in diastolic blood pressure in all risk groups combined. This figure is discussed in the Results section.

Appendix F Figure 8 Pooled Analysis of Diastolic Blood Pressure in All Risk Groups Combined, Sorted by Intervention Intensity and Excluding Physical Activity–Only Interventions

Appendix F Figure 8 is a forest plot depicting the change in diastolic blood pressure in all risk groups combined, excluding physical activity only interventions. This figure is discussed in the Results section.

Appendix F Figure 9 Pooled Analysis of Fasting Glucose in All Risk Groups Combined, Sorted by Intervention Intensity

Appendix F Figure 9 is a forest plot depicting the change in fasting glucose in all risk groups combined. This figure is discussed in the Results section.

Appendix F Figure 10 Pooled Analysis of Fasting Glucose in All Risk Groups Combined, Sorted by Intervention Intensity and Excluding Physical Activity–Only Interventions

Appendix F Figure 10 is a forest plot depicting the change in fasting glucose in all risk groups combined, excluding physical activity only interventions. This figure is discussed in the Results section.

Appendix F Figure 11 Pooled Analysis of Adiposity in All Risk Groups Combined, Sorted by Intervention Intensity

Appendix F Figure 11 is a forest plot depicting the change in adiposity in all risk groups combined. This figure is discussed in the Results section.

Appendix F Figure 12 Pooled Analysis of Adiposity in All Risk Groups Combined, Sorted by Intervention Intensity and Excluding Physical Activity–Only Interventions

Appendix F Figure 12 is a forest plot depicting the change in adiposity in all risk groups combined, excluding physical activity only interventions. This figure is discussed in the Results section.