# Detailed Results of Intermediate Outcomes

Appendix D Table 1 Results of Included Studies for Systolic Blood Pressure

Appendix D Table 2 Results of Included Studies for Diastolic Blood Pressure

Appendix D Table 3 Results of Included Studies for Total Cholesterol

Appendix D Table 4 Results of Included Studies for Low-Density Lipoprotein Cholesterol

Appendix D Table 5 Results of Included Studies for High-Density Lipoprotein Cholesterol

Appendix D Table 6 Results of Included Studies for Triglycerides

Appendix D Table 7 Results of Included Studies for Fasting Plasma Glucose

Appendix D Table 8 Results of Included Studies for Adiposity

Appendix D Table 9 Results of Included Studies for Diabetes Incidence