# Excluded Studies

This is a listing of studies excluded from the review by key question (KQ). If a study was included for one KQ, but excluded for others, it would still be listed here with the excluded KQs noted.

Exclusion Code
E1. Study relevance; a. Does not focus on counseling intervention; b. Primary aim is weight loss; c. Not focused on cardiovascular disease
E2. Setting; a. Human Development Index not >0.9; b. Not generalizable to primary care
E3. Population; a. Children, pregnant women, symptomatic patients, ≥50% with coronary heart disease or diabetes; b. Biased recruitment or not generalizable to primary care; c. Healthy Diet: specialized diet; d. Physical Activity: specialized physical activity required; e. The majority (≥50%) of participants do not meet high-risk criteria
E4: No relevant outcomes
E5: Not one of the specified interventions; a. Yoga or tai chi based intervention
E6: Study design; a. Not a trial; b. Less than 6 months followup; c. Comparative effectiveness; d. Physical Activity: CG told not to exercise
E7: Study quality; a. Poor reporting; b. Problematic baseline comparability; c. Unblinded assessment; d. High/differential attrition; e. Other issues
E8: Precedes search (i.e., main outcomes published before 1990)
E9. Publication not in English

1 Aadahl M, von Huth SL, Pisinger C, et al. Five-year change in physical activity is associated with changes in cardiovascular disease risk factors: the Inter99 study. Prev Med. Apr. 2009;48(4):326-31. KQ2E3e. [pmid: 19463487].
2 Absetz P, Valve R, Oldenburg B, et al. Type 2 diabetes prevention in the “real world”: one-year results of the GOAL Implementation Trial 1. Diabetes Care. Oct. 2007;30(10):2465-70. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a. [pmid: 17586741].
3 Aggarwal B, Liao M, Allegrante JP, et al. Low social support level is associated with non-adherence to diet at 1 year in the Family Intervention Trial for Heart Health (FIT Heart). Journal of Nutrition Education & Behavior. Nov. 2010;42(6):380-8. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20696617].
4 Aggarwal B, Liao M, Mosca L. Predictors of physical activity at 1 year in a randomized controlled trial of family members of patients with cardiovascular disease. Journal of Cardiovascular Nursing. Nov. 2010;25(6):444-9. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20856131].
5 Aittasalo M, Miilunpalo S, Kukkonen HK, et al. A randomized intervention of physical activity promotion and patient self-monitoring in primary health care. Prev Med. 2006;42(1):40-6. KQ3E3e. [pmid: 16297442].
6 Aizawa K, Shoemaker JK, Overend TJ, et al. Effects of lifestyle modification on central artery stiffness in metabolic syndrome subjects with pre-hypertension and/or pre-diabetes. Diabetes Research & Clinical Practice. Feb. 2009;83(2):249-56. KQ2E6a, KQ3E6a. [pmid: 19097666].
7 Aizer A, Gaziano JM, Cook NR, et al. Relation of vigorous exercise to risk of atrial fibrillation. American Journal of Cardiology. Jun. 1. 2009;103(11):1572-7. KQ4E3e. [pmid: 19463518].
8 Aldana SG, Greenlaw RL, Diehl HA, et al. Effects of an intensive diet and physical activity modification program on the health risks of adults. Journal of the American Dietetic Association. 2005;105(3):371-81. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 15746824].
9 Aldana SG, Greenlaw RL, Diehl HA, et al. The behavioral and clinical effects of therapeutic lifestyle change on middle-aged adults. Preventing Chronic Disease. 2006;3(1):A05. KQ2E3e, KQ3E3e. [pmid: 16356358].
10 Alexander GL, McClure JB, Calvi JH, et al. A randomized clinical trial evaluating online interventions to improve fruit and vegetable consumption. American Journal of Public Health. Feb. 2010;100(2):319-26. KQ3E3e. [pmid: 20019315].
11 Alli C, Avanzini F, Bettelli G, et al. Feasibility of a long-term low-sodium diet in mild hypertension. J Hum Hypertens. Aug. 1992;6(4):281-6. KQ1E7, KQ2E7, KQ3E7, KQ4E7. [pmid: 1433163].
12 Almeida-Pittito B, Hirai AT, Sartorelli DS, et al. Impact of a 2-year intervention program on cardiometabolic profile according to the number of goals achieved. [References]. Brazilian Journal of Medical and Biological Research. Nov. 2010;43(11):1088-94. KQ2E2a. [pmid: 21088806].
13 Ammerman AS, Keyserling T, Atwood J, et al. High-quality nutrition counselling for hypercholesterolaemia by public health nurses in rural areas does not affect total blood cholesterol. Evidence Based Healthcare. 2003;7(4):187-9. PMID: None. KQ2E6a, KQ3E6a.
14 Andersen LJ, Randers MB, Westh K, et al. Football as a treatment for hypertension in untrained 30-55-year-old men: a prospective randomized study. Scandinavian Journal of Medicine & Science in Sports. Apr. 2010;20(Suppl 1):98-102. KQ2E5. [pmid: 20210907].
15 Andersson EK, Moss TP. Imagery and implementation intention: A randomised controlled trial of interventions to increase exercise behaviour in the general population. Psychology of Sport and Exercise. 2011;12(2):63-70. PMID: None. KQ3E3e.
16 Arciero PJ, Gentile CL, Martin PR, et al. Increased dietary protein and combined high intensity aerobic and resistance exercise improves body fat distribution and cardiovascular risk factors. International journal of sport nutrition and exercise metabolism. 2006;16(4):373-92. KQ2E3e. [pmid: 17136940].
17 Armit CM, Brown WJ, Marshall AL, et al. Randomized trial of three strategies to promote physical activity in general practice. Prev Med. Feb. 2009;48(2):156-63. KQ2E3e, KQ3E3e. [pmid: 19100282].
18 Armitage CJ, Arden MA. A volitional help sheet to increase physical activity in people with low socioeconomic status: A randomised exploratory trial. Psychology & Health. Dec. 2010;25(10):1129-45. KQ3E6b. [pmid: 20309777].
19 Ayres K, Conner M, Prestwich A, et al. Exploring the question-behaviour effect: randomized controlled trial of motivational and question-behaviour interventions. British Journal of Health Psychology. Feb. 2013;18(1):31-44. KQ3E4. [pmid: 22519696].
20 Bakx JC, Stafleu A, Van Staveren WA, et al. Long-term effect of nutritional counseling: a study in family medicine. Am J Clin Nutr. Jun. 1997;65(6 Suppl):1946S-50S. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 9174500].
21 Barclay C, Procter KL, Glendenning R, et al. Can type 2 diabetes be prevented in UK general practice? A lifestyle-change feasibility study (ISAIAH). The British journal of general practice : the journal of the Royal College of General Practitioners. 2008;58(553):541-7. KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 18682012].
22 Beavers KM, Beavers DP, Nesbit BA, et al. Effect of an 18 month physical activity and weight loss intervention on body composition in overweight and obese older adults. Obesity (Silver Spring). 2013. Aug. 20. PMID:. [doi: 10.1002/oby.20607]. KQ2E5.
23 Bennett GG, Warner ET, Glasgow RE, et al. Obesity treatment for socioeconomically disadvantaged patients in primary care practice. Arch Intern Med. Apr. 9. 2012;172(7):565-74. KQ1E1b, KQ2E1b, KQ3E1b, KQ4E1b. [pmid: 22412073].
24 Bennett JA, Perrin NA, Hanson G, et al. Healthy aging demonstration project: nurse coaching for behavior change in older adults 1. Res Nurs Health. Jun. 2005;28(3):187-97. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 15884026].
25 Bennett JA, Young HM, Nail LM, et al. A telephone-only motivational intervention to increase physical activity in rural adults: a randomized controlled trial. Nursing Research. 2008;57(1):24-32. KQ3E3e. [pmid: 18091289].
26 Berry SE, Mulla UZ, Chowienczyk PJ, et al. Increased potassium intake from fruit and vegetables or supplements does not lower blood pressure or improve vascular function in UK men and women with early hypertension: a randomised controlled trial. British Journal of Nutrition. Dec. 2010;104(12):1839-47. KQ2E6b. [pmid: 20673378].
27 Bickmore TW, Silliman RA, Nelson K, et al. A Randomized Controlled Trial of an Automated Exercise Coach for Older Adults. J Am Geriatr Soc. 2013. Sep. 3. KQ3E3e. [pmid: 24001030].
28 Blaufox MD, Lee HB, Davis B, et al. Renin predicts diastolic blood pressure response to nonpharmacologic and pharmacologic therapy. JAMA. Mar. 4. 1992;267(9):1221-5. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 1538559].
29 Blumenthal JA, Sherwood A, Gullette EC, et al. Exercise and weight loss reduce blood pressure in men and women with mild hypertension: effects on cardiovascular, metabolic, and hemodynamic functioning. Arch Intern Med. Jul. 10. 2000;160(13):1947-58. KQ1E4, KQ2E5, KQ3E4, KQ4E4. [pmid: 10888969].
30 Blumenthal JA, Babyak MA, Hinderliter A, et al. Effects of the DASH diet alone and in combination with exercise and weight loss on blood pressure and cardiovascular biomarkers in men and women with high blood pressure: the ENCORE study. Arch Intern Med. Jan. 25. 2010;170(2):126-35. KQ2E5. [pmid: 20101007].
31 Borschmann K, Moore K, Russell M, et al. Overcoming barriers to physical activity among culturally and linguistically diverse older adults: a randomised controlled trial. Australasian Journal on Ageing. Jun. 2010;29(2):77-80. KQ3E3a. [pmid: 20553538].
32 Bosak KA, Yates B, Pozehl B. Effects of an Internet physical activity intervention in adults with metabolic syndrome. Western Journal of Nursing Research. Feb. 2010;32(1):5-22. KQ2E6b, KQ3E6b. [pmid: 19357421].
33 Bouchonville M, Armamento-Villareal R, Shah K, et al. Weight loss, exercise or both and cardiometabolic risk factors in obese older adults: results of a randomized controlled trial. Int J Obes (Lond). 2013. Jul. 4. KQ2E1c. [pmid: 23823329].
34 Bray GA, Jablonski KA, Fujimoto WY, et al. Relation of central adiposity and body mass index to the development of diabetes in the Diabetes Prevention Program. Am J Clin Nutr. May. 2008;87(5):1212-8. KQ2E4. [pmid: 18469241].
35 Brekke HK, Jansson PA, Månsson JE, et al. Lifestyle changes can be achieved through counseling and follow-up in first-degree relatives of patients with type 2 diabetes. Journal of the American Dietetic Association. 2003;103(7):835-43. KQ2E3e, KQ3E3e. [pmid: 12830021].
36 Brekke HK, Jansson PA, Lenner RA. Long-term (1- and 2-year) effects of lifestyle intervention in type 2 diabetes relatives. Diabetes Research and Clinical Practice. 2005;70(3):225-34. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 15885845].
37 Bridgewater LE, Lodge MA, Reid RD. Description of a behavioural counselling strategy for risk factor modification in a Family Heart Health randomized controlled trial: preliminary results. Journal of Cardiopulmonary Rehabilitation and Prevention. 2009;29(5):335. PMID: None. KQ1E4, KQ2E4, KQ3E4, KQ4E4.
38 Broekhuizen K, Poppel MN, Koppes LL, et al. A tailored lifestyle intervention to reduce the cardiovascular disease risk of individuals with Familial Hypercholesterolemia (FH): design of the PRO-FIT randomised controlled trial. BMC Public Health. 2010;10:69. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 20156339].
39 Buman MP, Giacobbi PR Jr, Dzierzewski JM, et al. Peer volunteers improve long-term maintenance of physical activity with older adults: a randomized controlled trial. Journal of Physical Activity & Health. Sep. 2011;8(Suppl 2):S257-S266. KQ3E3e. [pmid: 21918240].
40 Burke L, Jancey J, Howat P, et al. Physical activity and nutrition program for seniors (PANS): protocol of a randomized controlled trial. BMC Public Health. 2010;10:751. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 21129226].
41 Burke L, Lee AH, Jancey J, et al. Physical activity and nutrition behavioural outcomes of a home-based intervention program for seniors: a randomized controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 2013;10:14. KQ3E3e. [pmid: 23363616].
42 Burke LE, Dunbar-Jacob J, Orchard TJ, et al. Improving adherence to a cholesterol-lowering diet: a behavioral intervention study. Patient Education & Counseling. Apr. 2005;57(1):134-42. KQ1E4, KQ2E6b, KQ3E6b, KQ4E4. [pmid: 15797163].
43 Burke V, Giangiulio N, Gillam HF, et al. Physical activity and nutrition programs for couples: a randomized controlled trial. Journal of Clinical Epidemiology. 2003;56(5):421-32. KQ2E3e, KQ3E3e. [pmid: 12812815].
44 Burke V, Beilin LJ, Cutt HE, et al. Moderators and mediators of behaviour change in a lifestyle program for treated hypertensives: a randomized controlled trial (ADAPT). Health Education Research. 2007;23(4):583-91. KQ2E4. [pmid: 17890759].
45 Busnello FM, Bodanese LC, Pellanda LC, et al. Nutritional intervention and the impact on adherence to treatment in patients with metabolic syndrome. Arquivos Brasileiros de Cardiologia. Sep. 2011;97(3):217-24. KQ2E2a. [pmid: 21739068].
46 Byfield CL. Development and evaluation of a lifestyle physical activity intervention for obese sedentary women. Colorado State University. PhD Thesis. 2001. KQ1E1b,KQ2E1b, KQ3E1b, KQ4E1b.
47 Caggiula AW, Christakis G, Farrand M, et al. The multiple risk intervention trial (MRFIT). IV. Intervention on blood lipids. Prev Med. Jul. 1981;10(4):443-75. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 7027238].
48 Calfas KJ, Sallis JF, Zabinski MF, et al. Preliminary evaluation of a multicomponent program for nutrition and physical activity change in primary care: PACE+ for adults. Prev Med. 2002;34(2):153-61. KQ3E6b. [pmid: 11817910].
49 Camhi SM, Stefanick ML, Katzmarzyk PT, et al. Metabolic syndrome and changes in body fat from a low-fat diet and/or exercise randomized controlled trial. Obesity. Mar. 2010;18(3):548-54. KQ2E3e. [pmid: 19798074].
50 Campbell K, Foster-Schubert K, Xiao L, et al. Injuries in sedentary individuals enrolled in a 12-month, randomized, controlled, exercise trial. Journal of Physical Activity & Health. Feb. 2012;9(2):198-207. KQ4E3e. [pmid: 22368219].
51 Capewell S, O'Flaherty M. Can dietary changes rapidly decrease cardiovascular mortality rates?. European Heart Journal. May. 2011;32(10):1187-9. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 21367835].
52 Carr LJ, Bartee RT, Dorozynski CM, et al. Eight-month follow-up of physical activity and central adiposity: results from an Internet-delivered randomized control trial intervention. Journal of Physical Activity & Health. Jul. 2009;6(4):444-55. KQ1E7d, KQ2E7d, KQ3E7d, KQ4E7d. [pmid: 19842458].
53 Carroll JK, Lewis BA, Marcus BH, et al. Computerized tailored physical activity reports. A randomized controlled trial. Am J Prev Med. 2010;39:148-56. KQ3E3e. [pmid: 20621262].
54 Carroll JK, Lewis BA, Marcus BH, et al. Eight-month follow-up of physical activity and central adiposity: results from an Internet-delivered randomized control trial intervention. Am J Prev Med. Aug. 2010;39(2):148-56. KQ3E3a. [pmid: 20621262].
55 Carroll S, Borkoles E, Polman R. Short-term effects of a non-dieting lifestyle intervention program on weight management, fitness, metabolic risk, and psychological well-being in obese premenopausal females with the metabolic syndrome. Applied physiology, nutrition, and metabolism = Physiologie appliquée, nutrition et métabolisme. 2007;32(1):125-42. KQ1E4, KQ2E5, KQ1E4. [pmid: 17332789].
56 Castro CM, Pruitt LA, Buman MP, et al. Physical activity program delivery by professionals versus volunteers: the TEAM randomized trial. Health Psychology. May. 2011;30(3):285-94. KQ3E3e. [pmid: 21553972].
57 Chandratilleke MG, Carson KV, Picot J, et al. Physical training for asthma. [Review]. Cochrane Database of Systematic Reviews. 2012;(5):CD001116. KQ4E3e. [pmid: 22592674].
58 Chang AK, Fritschi C, Kim MJ. Nurse-led empowerment strategies for hypertensive patients with metabolic syndrome. Contemporary Nurse. Aug. 2012;42(1):118-28. KQE5, KQ2E5, KQ3E5, KQ4E5. [pmid: 23050578].
59 Chapman J, Armitage CJ. Do techniques that increase fruit intake also increase vegetable intake? Evidence from a comparison of two implementation intention interventions. [References]. Appetite. Feb. 2012;58(1):28-33. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 22001024].
60 Chellini E, Gorini G, Carreras G, et al. The Pap smear screening as an occasion for smoking cessation and physical activity counselling: baseline characteristics of women involved in the SPRINT randomized controlled trial. BMC Public Health. 2011;11:906. KQ1E5, KQ2E5, KQ3E5, KQ4E5. [pmid: 22151834].
61 Chiang CY, Sun FK. The effects of a walking program on older Chinese American immigrants with hypertension: a pretest and posttest quasi-experimental design. Public Health Nursing. May. 2009;26(3):240-8. KQ2E6b, KQ3E6b. [pmid: 19386059].
62 Claes N, Jacobs N. The PreCardio-study protocol--a randomized clinical trial of a multidisciplinary electronic cardiovascular prevention programme. BMC Cardiovascular Disorders. 2007;7:27. KQ1E2b, KQ2E2b, KQ3E2b. [pmid: 17784946].
63 Coghill N, Cooper AR. The effect of a home-based walking program on risk factors for coronary heart disease in hypercholesterolaemic men. A randomized controlled trial. Prev Med. Jun. 2008;46(6):545-51. KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 18316115].
64 Coghill N, Cooper AR. Motivators and de-motivators for adherence to a program of sustained walking. Prev Med. Aug. 2009;49(1):24-7. KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 19426757].
65 Coleman KJ, Ngor E, Reynolds K, et al. Initial validation of an exercise “vital sign” in electronic medical records 4. Med Sci Sports Exerc. Nov. 2012;44(11):2071-6. KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a. [pmid: 22688832].
66 Colle B, Brusaferro S. Cardiovascular risk reduction: impact of an international project. Annali di igiene : medicina preventiva e di comunità. 2008;20(3 Suppl 1):43-8. KQ2E9, KQ3E9. [pmid: 18773604].
67 Cook NR, Cutler JA, Obarzanek E, et al. Long term effects of dietary sodium reduction on cardiovascular disease outcomes: Observational follow-up of the trials of hypertension prevention (TOHP). British Medical Journal. 2007;334(7599):885-8. KQ1E3e. [pmid: 17449506].
68 Cooper JN, Columbus ML, Shields KJ, et al. Effects of an intensive behavioral weight loss intervention consisting of caloric restriction with or without physical activity on common carotid artery remodeling in severely obese adults. Metabolism: Clinical & Experimental. Nov. 2012;61(11):1589-97. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c. [pmid: 22579053].
69 Costa B, Barrio F, Cabre JJ, et al. Delaying progression to type 2 diabetes among high-risk Spanish individuals is feasible in real-life primary healthcare settings using intensive lifestyle intervention. Diabetologia. May. 2012;55(5):1319-28. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a. [pmid: 22322921].
70 Couper MP, Alexander GL, Zhang N, et al. Engagement and retention: measuring breadth and depth of participant use of an online intervention. Journal of Medical Internet Research. 2010;12(4):e52. KQ3E3e. [pmid: 21087922].
71 Craigie AM, Barton KL, Macleod M, et al. A feasibility study of a personalised lifestyle programme (HealthForce) for individuals who have participated in cardiovascular risk screening. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2011;52(5):387-9. KQ2E6b, KQ3E6b. [pmid: 21419792].
72 Critchley CR, Hardie EA, Moore SM. Examining the psychological pathways to behavior change in a group-based lifestyle program to prevent type 2 diabetes. Diabetes Care. Apr. 2012;35(4):699-705. KQ1E4. [pmid: 22338102].
73 Crowe FL, Key TJ, Appleby PN, et al. Dietary fibre intake and ischaemic heart disease mortality: the European Prospective Investigation into Cancer and Nutrition-Heart study. European Journal of Clinical Nutrition. Aug. 2012;66(8):950-6. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a. [pmid: 22617277].
74 Curtis PJ, Adamson AJ, Mathers JC. Effects on nutrient intake of a family-based intervention to promote increased consumption of low-fat starchy foods through education, cooking skills and personalised goal setting: the Family Food and Health Project. British Journal of Nutrition. Jun. 2012;107(12):1833-44. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 22017999].
75 Dale KS, Mann JI, McAuley KA, et al. Sustainability of lifestyle changes following an intensive lifestyle intervention in insulin resistant adults: Follow-up at 2-years. Asia Pacific Journal of Clinical Nutrition. 2009;18(1):114-20. KQ2E5, KQ3E5. [pmid: 19329404].
76 Dansinger ML, Gleason JA, Griffith JL, et al. Comparison of the Atkins, Ornish, Weight Watchers, and Zone diets for weight loss and heart disease risk reduction: a randomized trial. JAMA. Jan. 5. 2005;293(1):43-53. PMID: 293/1/43 [pii]. [doi: 10.1001/jama.293.1.43]. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c. [pmid: 15632335].
77 Dapp U, Anders JAM, von Renteln-Kruse W, et al. A randomized trial of effects of health risk appraisal combined with group sessions or home visits on preventive behaviors in older adults. The Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 2011;66A(5):591-8. KQ3E3e. [pmid: 21350242].
78 Darker CD, French DP, Eves FF, et al. An intervention to promote walking amongst the general population based on an ‘extended’ theory of planned behaviour: a waiting list randomised controlled trial. Psychology & Health. Jan. 2010;25(1):71-88. KQ3E3e. [pmid: 20391208].
79 Davey SG, Bracha Y, Svendsen KH, et al. Incidence of type 2 diabetes in the randomized multiple risk factor intervention trial. Ann Intern Med. Mar. 1. 2005;142(5):313-22. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 15738450].
80 Davis BR, Oberman A, Blaufox MD, et al. Lack of effectiveness of a low-sodium/high-potassium diet in reducing antihypertensive medication requirements in overweight persons with mild hypertension. TAIM Research Group. Trial of Antihypertensive Interventions and Management. Am J Hypertens. Oct. 1994;7(10 Pt 1):926-32. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 7826557].
81 De CK, Spittaels H, Cardon G, et al. Web-based, computer-tailored, pedometer-based physical activity advice: development, dissemination through general practice, acceptability, and preliminary efficacy in a randomized controlled trial. Journal of Medical Internet Research. 2012;14(2):e53. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 22532102].
82 Delgadillo AT, Grossman M, Santoyo-Olsson J, et al. Description of an academic community partnership lifestyle program for lower income minority adults at risk for diabetes. Diabetes Educator. Jul. 2010;36(4):640-50. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 20576836].
83 Delichatsios HK, Friedman RH, Glanz K, et al. Randomized trial of a “talking computer” to improve adults' eating habits. American journal of health promotion : AJHP. 2001;15(4):215-24. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 11349340].
84 Dennison CR, Post WS, Kim MT, et al. Underserved urban african american men: hypertension trial outcomes and mortality during 5 years 1. Am J Hypertens. Feb. 2007;20(2):164-71. KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a. [pmid: 17261462].
85 Diaz-Lopez A, Bullo M, Martinez-Gonzalez MA, et al. Effects of Mediterranean diets on kidney function: a report from the PREDIMED trial. American Journal of Kidney Diseases. Sep. 2012;60(3):380-9. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a. [pmid: 22541738].
86 Djuric Z, Vanloon G, Radakovich K, et al. Design of a Mediterranean exchange list diet implemented by telephone counseling. Journal of the American Dietetic Association. 2008;108(12):2059-65. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 19027409].
87 Djuric Z, Ellsworth JS, Ren J, et al. A randomized feasibility trial of brief telephone counseling to increase fruit and vegetable intakes. Prev Med. May. 2010;50(5-6):265-71. KQ2E6b, kQ3E6b. [pmid: 20226809].
88 Dubbert PM, Cushman WC, Meydrech EF, et al. Effects of dietary instruction and sodium excretion feedback in hypertension clinic patients. Behav Ther. 1995;26(4):721-32. PMID: None. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.
89 Dubbert PM, Cooper KM, Kirchner KA, et al. Effects of nurse counseling on walking for exercise in elderly primary care patients. The journals of gerontology Series A, Biological sciences and medical sciences. 2002;57(11):M733-M740. KQ2E4, KQ3E6c. [pmid: 12403802].
90 Duncan MJ, Vandelanotte C, Rosenkranz RR, et al. Effectiveness of a website and mobile phone based physical activity and nutrition intervention for middle-aged males: trial protocol and baseline findings of the ManUp Study. BMC Public Health. 2012;12:656. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 22894747].
91 Dutton GR, Napolitano MA, Whiteley JA, et al. Is physical activity a gateway behavior for diet? Findings from a physical activity trial. Prev Med. 2008;46(3):216-21. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 18234327].
92 Eakin EG, Bull SS, Riley KM, et al. Resources for health: a primary-care-based diet and physical activity intervention targeting urban Latinos with multiple chronic conditions. Health psychology : official journal of the Division of Health Psychology, American Psychological Association. 2007;26(4):392-400. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 17605558].
93 Elley CR, Garrett S, Rose SB, et al. Cost-effectiveness of exercise on prescription with telephone support among women in general practice over 2 years. British Journal of Sports Medicine. Dec. 2011;45(15):1223-9. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 21081641].
94 Ellingsen I, Hjermann I, Abdelnoor M, et al. Dietary and antismoking advice and ischemic heart disease mortality in men with normal or high fasting triacylglycerol concentrations: a 23-y follow-up study. The American journal of clinical nutrition. 2003;78(5):935-40. KQ1E8, KQ2E8, KQ3E8. [pmid: 14594779].
95 Ellingsen I, Hjerkinn EM, Arnesen H, et al. Follow-up of diet and cardiovascular risk factors 20 years after cessation of intervention in the Oslo Diet and Antismoking Study. European Journal of Clinical Nutrition. Mar. 2006;60(3):378-85. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 16306931].
96 Endevelt R, Lemberger J, Bregman J, et al. Intensive dietary intervention by a dietitian as a case manager among community dwelling older adults: the EDIT study. Journal of Nutrition, Health & Aging. Aug. 2011;15(8):624-30. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 21968856].
97 Engberg S, Vistisen D, Lau C, et al. Progression to impaired glucose regulation and diabetes in the population-based Inter99 study. Diabetes Care. Apr. 2009;32(4):606-11. KQ2E3e. [pmid: 19114617].
98 Engberg S, Glumer C, Witte DR, et al. Differential relationship between physical activity and progression to diabetes by glucose tolerance status: the Inter99 Study. Diabetologia. Jan. 2010;53(1):70-8. KQ2E4, KQ3E4. [pmid: 19898830].
99 Eriksson MK, Franks PW, Eliasson M. A 3-year randomized trial of lifestyle intervention for cardiovascular risk reduction in the primary care setting: the Swedish Bjorknas study. PLoS ONE [Electronic Resource]. 2009;4(4):e5195. KQ2E5, KQ3E5, KQ4E5. [pmid: 19365563].
100 Estabrooks PA, Smith-Ray RL, Almeida FA, et al. Move More: Translating an efficacious group dynamics physical activity intervention into effective clinical practice. International Journal of Sport and Exercise Psychology. 2011;9(1):4-18. PMID: None. KQ4E3e.
101 Evans AT, Rogers LQ, Peden JG Jr, et al. Teaching dietary counseling skills to residents: patient and physician outcomes. The CADRE Study Group. Am J Prev Med. Jul. 1996;12(4):259-65. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a. [pmid: 8874689].
102 Fahrenwald NL, Atwood JR, Walker SN, et al. A randomized pilot test of “Moms on the Move”: a physical activity intervention for WIC mothers. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2004;27(2):82-90. KQ3E3e. [pmid: 15026292].
103 Fappa E, Yannakoulia M, Ioannidou M, et al. Telephone counseling intervention improves dietary habits and metabolic parameters of patients with the metabolic syndrome: a randomized controlled trial. The Review of Diabetic Studies. 2012;9(1):36-45. KQ1E4, KQ2E7d, KQ3E7d, KQ4E4. [pmid: 22972443].
104 Fappa E, Yannakoulia M, Skoumas Y, et al. Promoting only the consumption of healthy foods may be an alternative stategy for treating patients with the metabolic syndrome. Metabolism: Clinical & Experimental. Oct. 2012;61(10):1361-9. KQ1E4, K12E7d, KQ3E7d, KQ4E4. [pmid: 22503163].
105 Ferrara AL, Pacioni D, Di F V, et al. Lifestyle educational program strongly increases compliance to nonpharmacologic intervention in hypertensive patients: a 2-year follow-up study. Journal of Clinical Hypertension. Nov. 2012;14(11):767-72. KQ2E6c, KQ3E6c. [pmid: 23126348].
106 Ferrer RL, Mody-Bailey P, Jaen CR, et al. A medical assistant-based program to promote healthy behaviors in primary care. Annals of Family Medicine. Nov. 2009;7(6):504-12. KQ2E3e, KQ3E3e. [pmid: 19901309].
107 Fitzsimons CF, Baker G, Gray SR, et al. Does physical activity counselling enhance the effects of a pedometer-based intervention over the long-term: 12-month findings from the Walking for Wellbeing in the west study. BMC Public Health. 2012;12:206. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 22429600].
108 Foy CG, Vitolins MZ, Case LD, et al. Incorporating prosocial behavior to promote physical activity in older adults: Rationale and design of the Program for Active Aging and Community Engagement (PACE). Contemporary Clinical Trials. Sep. 2013;36(1):284-97. KQ3E3e. [pmid: 23876672].
109 Francis SL, Taylor ML. A social marketing theory-based diet-education program for women ages 54 to 83 years improved dietary status. Journal of the American Dietetic Association. Dec. 2009;109(12):2052-6. KQ3E3e. [pmid: 19942023].
110 Francis SL, Taylor ML, Haldeman LM. Nutrition education improves morale and self-efficacy for middle-aged and older women. [References]. Journal of Nutrition for the Elderly. Jul. 2009;28(3):272-86. KQ2E3e, KQ3E3e. [pmid: 21184370].
111 Gabriel KK, Conroy MB, Schmid KK, et al. The impact of weight and fat mass loss and increased physical activity on physical function in overweight, postmenopausal women: results from the Women on the Move Through Activity and Nutrition study. Menopause. Jul. 2011;18(7):759-65. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 21705864].
112 Garcia-Ortiz L, Grandes G, Sanchez-Perez A, et al. Effect on cardiovascular risk of an intervention by family physicians to promote physical exercise among sedentary individuals. Revista Espanola de Cardiologia. Nov. 2010;63(11):1244-52. KQ2E3e. [pmid: 21070720].
113 García OL, Grandes G, Sánchez PA, et al. Effect on cardiovascular risk of an intervention by family physicians to promote physical exercise among sedentary individuals. Revista española de cardiología. 2010;63:1244-52. PMID: None. KQ2E3e.
114 Geleijnse JM, Witteman JC, Bak AA, et al. Long-term moderate sodium restriction does not adversely affect the serum HDL/total cholesterol ratio. J Hum Hypertens. Dec. 1995;9(12):975-9. KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a. [pmid: 8746642].
115 Geller KS, Mendoza ID, Timbobolan J, et al. The decisional balance sheet to promote healthy behavior among ethnically diverse older adults. Public Health Nursing. May. 2012;29(3):241-6. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 22512425].
116 Gerber JB, Bloom PA, Ross JS. The physical activity contract--tailored to promote physical activity in a geriatric outpatient setting: a pilot study. Journal of the American Geriatrics Society. Mar. 2010;58(3):604-6. KQ3E6b. [pmid: 20398129].
117 Getchell WS, Svetkey LP, Appel LJ, et al. Summary of the Dietary Approaches to Stop Hypertension (DASH) Randomized Clinical Trial. Curr Treat Options Cardiovasc Med. Dec. 1999;1(4):295-300. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 11096495].
118 Gidlow CJ, Cochrane T, Davey R, et al. One-year cardiovascular risk and quality of life changes in participants of a health trainer service. Perspect Public Health. 2013. May. 8. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a. [pmid: 23656746].
119 Gillison F, Greaves C, Stathi A, et al. ‘Waste the waist’: The development of an intervention to promote changes in diet and physical activity for people with high cardiovascular risk. [References]. British Journal of Health Psychology. May. 2012;17(2):327-45. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 22107451].
120 Gine-Garriga M, Martin C, Martin C, et al. Referral from primary care to a physical activity programme: establishing long-term adherence? A randomized controlled trial. Rationale and study design. BMC Public Health. 2009;(9):31. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 19161605].
121 Godin G, Belanger-Gravel A, Amireault S, et al. The effect of mere-measurement of cognitions on physical activity behavior: a randomized controlled trial among overweight and obese individuals. International Journal of Behavioral Nutrition & Physical Activity. 2011;8:2. KQ3E3e. [pmid: 21223565].
122 Goodrich DE, Larkin AR, Lowery JC, et al. Adverse events among high-risk participants in a home-based walking study: a descriptive study. International Journal of Behavioral Nutrition & Physical Activity. 2007;4:20. KQ4E6c. [pmid: 17521443].
123 Gorbach SL, Morrill-LaBrode A, Woods MN, et al. Changes in food patterns during a low-fat dietary intervention in women. J Am Diet Assoc. Jun. 1990;90(6):802-9. KQ1E5, KQ2E5, KQ3E5, KQ4E5. [pmid: 2345252].
124 Gorini G, Carreras G, Giordano L, et al. The Pap smear screening as an occasion for smoking cessation and physical activity counselling: effectiveness of the SPRINT randomized controlled trial. BMC Public Health. 2012;12:740. KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a. [pmid: 22950883].
125 Grandes G, Sanchez A, Sanchez-Pinilla RO, et al. Effectiveness of physical activity advice and prescription by physicians in routine primary care: a cluster randomized trial. Arch Intern Med. Apr. 13. 2009;169(7):694-701. KQ3E3e. [pmid: 19364999].
126 Grandes G, Sanchez A, Montoya I, et al. Two-year longitudinal analysis of a cluster randomized trial of physical activity promotion by general practitioners. PLoS ONE [Electronic Resource]. 2011;6(3):e18363. KQ3E3e. [pmid: 21479243].
127 Granner ML, Liguori G, Kirkner GJ, et al. Health care provider counseling for physical activity among black and white South Carolinians. Journal of the South Carolina Medical Association. 2001;97:338-41. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a. [pmid: 11534474].
128 Greaves CJ, Middlebrooke A, O'Loughlin L, et al. Motivational interviewing for modifying diabetes risk: a randomised controlled trial. The British journal of general practice : the journal of the Royal College of General Practitioners. 2008;58(553):535-40. KQ3E3e. [pmid: 18682011].
129 Green BB, McAfee T, Hindmarsh M, et al. Effectiveness of telephone support in increasing physical activity levels in primary care patients. Am J Prev Med. 2002;22(3):177-83. KQ3E3e. [pmid: 11897462].
130 Greenberger HM. Modifiers of the effectiveness of a diet intervention in family members of cardiovascular disease patients. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2011;(9-B). PMID: None. KQ1E3e, KQ2E3e, KQ3E3e.
131 Guillaumie L, Godin G, Manderscheid JC, et al. The impact of self-efficacy and implementation intentions-based interventions on fruit and vegetable intake among adults. Psychology & Health. 2012;27(1):30-50. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 21678169].
132 Hansen AW, Gronbaek M, Helge JW, et al. Effect of a Web-based intervention to promote physical activity and improve health among physically inactive adults: a population-based randomized controlled trial. Journal of Medical Internet Research. 2012;14(5):e145. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 23111127].
133 Hardcastle S, Taylor A, Bailey M, et al. A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Education and Counseling. 2008;70(1):31-9. KQ1E4, KQ4E4. [pmid: 17997263].
134 Hardeman W, Kinmonth AL, Michie S, et al. Impact of a physical activity intervention program on cognitive predictors of behaviour among adults at risk of Type 2 diabetes (ProActive randomised controlled trial). International Journal of Behavioral Nutrition & Physical Activity. 2009;6:16. KQ3E3e. [pmid: 19292926].
135 Hardeman W, Kinmonth AL, Michie S, et al. Theory of planned behaviour cognitions do not predict self-reported or objective physical activity levels or change in the ProActive trial. British Journal of Health Psychology. Feb. 2011;16(Pt:1):1-50. KQ3E3e. [pmid: 21226781].
136 Harrison RA, Roberts C, Elton PJ. Does primary care referral to an exercise programme increase physical activity one year later? A randomized controlled trial. Journal of Public Health. Mar. 2005;27(1):25-32. KQ3E3a. [pmid: 15564275].
137 Hatzitolios AI, Athyros VG, Karagiannis A, et al. Implementation of strategy for the management of overt dyslipidemia: the IMPROVE-dyslipidemia study. International Journal of Cardiology. May. 29. 2009;134(3):322-9. KQ2E6a. [pmid: 19268376].
138 Helland-Kigen KM, Raberg Kjollesdal MK, Hjellset VT, et al. Maintenance of changes in food intake and motivation for healthy eating among Norwegian-Pakistani women participating in a culturally adapted intervention. Public Health Nutrition. Jan. 2013;16(1):113-22. KQ3E3e. [pmid: 22781507].
139 Hellenius ML, de FU, Berglund B, et al. Diet and exercise are equally effective in reducing risk for cardiovascular disease. Results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis. Oct. 1993;103(1):81-91. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 8280188].
140 Henkin Y, Shai I, Zuk R, et al. Dietary treatment of hypercholesterolemia: do dietitians do it better? A randomized, controlled trial. Am J Med. Nov. 2000;109(7):549-55. KQ2E6c. [pmid: 11063956].
141 Herman C, Thompson J, Wolfe V, et al. Six-month results from a healthy lifestyles diabetes primary prevention program among urban Native American women. American Public Health Association 134th.Annual Meeting & Exposition. Nov 4 2006. Boston,MA. 2006. PMID: None. KQ2E3e.
142 Hertogh EM, Vergouwe Y, Schuit AJ, et al. Behavioral changes after a 1-yr exercise program and predictors of maintenance. Medicine & Science in Sports & Exercise. May. 2010;42(5):886-92. KQ1E5, KQ2E5, KQ3E5, KQ4E5. [pmid: 19996989].
143 Hillier FC, Batterham AM, Nixon CA, et al. A community-based health promotion intervention using brief negotiation techniques and a pledge on dietary intake, physical activity levels and weight outcomes: lessons learnt from an exploratory trial. Public Health Nutrition. Aug. 2012;15(8):1446-55. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 22122753].
144 Hillsdon M, Thorogood M, White I, et al. Advising people to take more exercise is ineffective: a randomized controlled trial of physical activity promotion in primary care. International Journal of Epidemiology. 2002;31(4):808-15. KQ2E4, KQ3E4. [pmid: 12177026].
145 Hind D, Scott EJ, Copeland R, et al. A randomised controlled trial and cost-effectiveness evaluation of “booster” interventions to sustain increases in physical activity in middle-aged adults in deprived urban neighbourhoods. BMC Public Health. 2010;10:3. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20047672].
146 Hirvensalo M, Heikkinen E, Lintunen T, et al. The effect of advice by health care professionals on increasing physical activity of older people. Scandinavian Journal of Medicine Science & Sports. 2003;13:231-6. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E4. [pmid: 12859605].
147 Holme I, Hostmark AT, Anderssen SA. ApoB but not LDL-cholesterol is reduced by exercise training in overweight healthy men. Results from the 1-year randomized Oslo Diet and Exercise Study. Journal of Internal Medicine. Aug. 2007;262(2):235-43. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 17645591].
148 Horner-Johnson W, Drum CE, Abdullah N. A randomized trial of a health promotion intervention for adults withdisabilities. Disability & Health Journal. Oct. 2011;4(4):254-61. KQ3E3e. [pmid: 22014673].
149 Hosper K, Deutekom M, Stronks K. The effectiveness of “Exercise on Prescription” in stimulating physical activity among women in ethnic minority groups in the Netherlands: protocol for a randomized controlled trial. BMC Public Health. 2008;8:406. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 19077190].
150 Howard BV, Van HL, Hsia J, et al. Low-fat dietary pattern and risk of cardiovascular disease: the Women's Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. Feb. 8. 2006;295(6):655-66. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 16467234].
151 Howard BV, Curb JD, Eaton CB, et al. Low-fat dietary pattern and lipoprotein risk factors: the Women's Health Initiative Dietary Modification Trial 1. Am J Clin Nutr. Apr. 2010;91(4):860-74. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 20164311].
152 Hughes SL, Seymour RB, Campbell RT, et al. Best-practice physical activity programs for older adults: findings from the national impact study. American Journal of Public Health. Feb. 2009;99(2):362-8. KQ1E5, KQ2E5, KQ3E5, KQ4E5. [pmid: 19059858].
153 Hyman DJ, Herd JA, Ho KS, et al. Maintenance of cholesterol reduction using automated telephone calls. Am J Prev Med. Mar. 1996;12(2):129-33. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c. [pmid: 8777066].
154 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. Jan. 1990;150(1):153-62. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 2404477].
155 Inoue S, Odagiri Y, Wakui S, et al. Randomized controlled trial to evaluate the effect of a physical activity intervention program based on behavioral medicine. Zasshi/Tokyo Ika Daigaku. 2003;61(2):154-65. KQ3E5. [pmid: 15479705].
156 Irvine AB, Gelatt VA, Seeley JR, et al. Web-based intervention to promote physical activity by sedentary older adults: randomized controlled trial. Journal of Medical Internet Research. 2013;15(2):e19. KQ2E3e, KQ3E3e. [pmid: 23470322].
157 Jackson J, Mandel D, Blanchard J, et al. Confronting challenges in intervention research with ethnically diverse older adults: The USC Well Elderly II Trial. Clinical Trials. 2009;6(1):90-101. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 19254939].
158 Jacobs AD, Ammerman AS, Ennett ST, et al. Effects of a tailored follow-up intervention on health behaviors, beliefs, and attitudes. Journal of Women's Health. Jun. 2004;13(5):557-68. KQ1E7e, KQ2E7e, KQ3E7e. [pmid: 15257847].
159 Jacobs N, Evers S, Ament A, et al. Cost-utility of a cardiovascular prevention program in highly educated adults: intermediate results of a randomized controlled trial. International Journal of Technology Assessment in Health Care. Jan. 2010;26(1):11-9. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20059776].
160 Jacobs N, De B I, Thijs H, et al. Effect of a cardiovascular prevention program on health behavior and BMI in highly educated adults: a randomized controlled trial. Patient Education & Counseling. Oct. 2011;85(1):122-6. KQ2E3e, KQ3E3e. [pmid: 20888728].
161 Jacobs N, Clays E, De BD, et al. Effect of a tailored behavior change program on a composite lifestyle change score: a randomized controlled trial. Health Education Research. Oct. 2011;26(5):886-95. KQ2E3e, KQ3E3e. [pmid: 21712501].
162 Jantchou P, Morois S, Clavel-Chapelon F, et al. Animal protein intake and risk of inflammatory bowel disease: The E3N prospective study. American Journal of Gastroenterology. Oct. 2010;105(10):2195-201. KQ4E3e. [pmid: 20461067].
163 Jehn ML, Patt MR, Appel LJ, et al. One year follow-up of overweight and obese hypertensive adults following intensive lifestyle therapy. J Hum Nutr Diet. Oct. 2006;19(5):349-54. KQ1E1b, KQ2E1b, KQ3E1b, KQ4E1b. [pmid: 16961681].
164 Jiang Y, Maddison R, McRobbie H, et al. Can exercise enhance smoking cessation outcomes? A pragmatic randomized controlled trial (fit2quit Study). Clinical Trials. 2012;9(4):484-5. PMID: None. KQ3E5.
165 Jimmy G, Martin BW. Implementation and effectiveness of a primary care based physical activity counselling scheme. Patient Education and Counseling. 2005;56(3):323-31. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 15721975].
166 Johansen KS, Bjorge B, Hjellset VT, et al. Changes in food habits and motivation for healthy eating among Pakistani women living in Norway: results from the InnvaDiab-DEPLAN study. Public Health Nutrition. Jun. 2010;13(6):858-67. KQ3E3e. [pmid: 19941691].
167 Jolly K, Duda JL, Daley A, et al. Evaluation of a standard provision versus an autonomy promotive exercise referral programme: rationale and study design. BMC Public Health. 2009;9:176. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 19505293].
168 Jula A, Ronnemaa T, Rastas M, et al. Long-term nopharmacological treatment for mild to moderate hypertension. J Intern Med. Jun. 1990;227(6):413-21. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b. [pmid: 2191071].
169 Jula AM, Karanko HM. Effects on left ventricular hypertrophy of long-term nonpharmacological treatment with sodium restriction in mild-to-moderate essential hypertension. Circulation. Mar. 1994;89(3):1023-31. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a. [pmid: 8124787].
170 Kallings LV. Physical activity on prescription: studies on physical activity level, adherence, and cardiovascular risk factors. Stockholm, Sweden. Karolinska Institutet. 2008. PMID: None. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e.
171 Kawano M, Shono N, Yoshimura T, et al. Improved cardio-respiratory fitness correlates with changes in the number and size of small dense LDL: randomized controlled trial with exercise training and dietary instruction. Internal Medicine. 2009;48(1):25-32. KQ2E5. [pmid: 19122353].
172 Kegler MC, Alcantara I, Veluswamy JK, et al. Results from an intervention to improve rural home food and physical activity environments. Progress in Community Health Partnerships. 2012;6(3):265-77. KQ2E3e, KQ3E3e. [pmid: 22982840].
173 Kelders SM, Van Gemert-Pijnen JE, Werkman A, et al. Effectiveness of a Web-based intervention aimed at healthy dietary and physical activity behavior: a randomized controlled trial about users and usage. Journal of Medical Internet Research. 2011;13(2):e32. KQ3E3e. [pmid: 21493191].
174 Kemmler W, von SS, Engelke K, et al. Exercise decreases the risk of metabolic syndrome in elderly females. Medicine & Science in Sports & Exercise. Feb. 2009;41(2):297-305. KQ2E5. [pmid: 19127197].
175 Kennedy MF, Meeuwisse WH. Exercise counselling by family physicians in Canada. Prev Med. 2003;37:226-32. KQ1E6a, KQ2E6a, KQ3E6a. [pmid: 12914828].
176 Kerr DA, Pollard CM, Howat P, et al. Connecting Health and Technology (CHAT): protocol of a randomized controlled trial to improve nutrition behaviours using mobile devices and tailored text messaging in young adults. BMC Public Health. 2012;12:477. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 22726532].
177 Ketola E, Makela M, Klockars M. Individualised multifactorial lifestyle intervention trial for high-risk cardiovascular patients in primary care. Br J Gen Pract. Apr. 2001;51(465):291-4. KQ2E3a, KQ3E3a. [pmid: 11458482].
178 Khare MM, Huber R, Carpenter RA, et al. A lifestyle approach to reducing cardiovascular risk factors in underserved women: design and methods of the Illinois WISEWOMAN Program. Journal of Women's Health. 2009;18(3):409-19. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 19821324].
179 Khare MM, Carpenter RA, Huber R, et al. Lifestyle intervention and cardiovascular risk reduction in the Illinois WISEWOMAN Program. Journal of Women's Health. 2012;21(3):294-301. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 22136298].
180 Kim BH, Newton RA, Sachs ML, et al. The effect of guided relaxation and exercise imagery on self-reported leisure-time exercise behaviors in older adults. Journal of Aging & Physical Activity. Apr. 2011;19(2):137-46. KQ3E6b. [pmid: 21558568].
181 Kim C, Draska M, Hess ML, et al. A web-based pedometer programme in women with a recent history of gestational diabetes. Diabetic Medicine. Feb. 2012;29(2):278-83. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 21838764].
182 Kim J, Bea W, Lee K, et al. Effect of the telephone-delivered nutrition education on dietary intake and biochemical parameters in subjects with metabolic syndrome. Clinical Nutrition Research. Jul. 2013;2(2):115-24. KQ2E6b, KQ3E6b. [pmid: 23908978].
183 Kim Y, Pike J, Adams H, et al. Telephone intervention promoting weight-related health behaviors. Prev Med. Mar. 2010;50(3):112-7. KQ3E3e. [pmid: 20006642].
184 King AC, Castro CM, Buman MP, et al. Behavioral Impacts of Sequentially versus Simultaneously Delivered Dietary Plus Physical Activity Interventions: the CALM Trial. Annals of Behavioral Medicine. Oct. 2013;46(2):157-68. KQ3E3e. [pmid: 23609341].
185 Kinmonth AL, Wareham NJ, Hardeman W, et al. Efficacy of a theory-based behavioural intervention to increase physical activity in an at-risk group in primary care (ProActive UK): a randomised trial. Lancet. 2008;371(9606):41-8. KQ3E3e. [pmid: 18177774].
186 Kirwan M, Duncan MJ, Vandelanotte C, et al. Using smartphone technology to monitor physical activity in the 10,000 Steps program: a matched case-control trial. Journal of Medical Internet Research. 2012;14(2):e55. KQ3E6a. [pmid: 22522112].
187 Kitaoka K, Nagaoka J, Matsuoka T, et al. Dietary intervention with cooking instructions and self-monitoring of the diet in free-living hypertensive men. Clinical & Experimental Hypertension (New York). 2013;35(2):120-7. KQ2E6b, KQ3E6b. [pmid: 22799766].
188 Kjelsberg MO, Cutler JA, Dolecek TA. Brief description of the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. Jan. 1997;65(1 Suppl):191S-5S. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 8988937].
189 Knutsen SF, Knutsen R. The Tromso Survey: the Family Intervention study--the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. Mar. 1991;20(2):197-212. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 2057468].
190 Ko LK, Campbell MK, Lewis MA, et al. Information processes mediate the effect of a health communication intervention on fruit and vegetable consumption. Journal of Health Communication. Mar. 2011;16(3):282-99. KQ3E3e. [pmid: 21132593].
191 Koelewijn-van-Loon MS, Weijden T, Ronda G, et al. Improving lifestyle and risk perception through patient involvement in nurse-led cardiovascular risk management: a cluster-randomized controlled trial in primary care. Prev Med. 2010;50(1-2):35-44. KQ2E6b, KQ3E6b. [pmid: 19944713].
192 Koelewijn-van Loon MS, Eurlings JW, Winkens B, et al. Small but important errors in cardiovascular risk calculation by practice nurses: a cross-sectional study in randomised trial setting. Int J Nurs Stud. Mar. 2011;48(3):285-91. KQ2E4, KQ3E4. [pmid: 20439105].
193 Koizumi D, Rogers NL, Rogers ME, et al. Efficacy of an accelerometer-guided physical activity intervention in community-dwelling older women. Journal of Physical Activity & Health. Jul. 2009;6(4):467-74. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 19842461].
194 Kolt GS, Schofield GM, Kerse N, et al. Effect of telephone counseling on physical activity for low-active older people in primary care: a randomized, controlled trial. Journal of the American Geriatrics Society. 2007;55(7):986-92. KQ3E3e. [pmid: 17608869].
195 Koopman H, Spreeuwenberg C, Westerman RF, et al. Dietary treatment of patients with mild to moderate hypertension in a general practice: a pilot intervention study (2). Beyond three months. J Hum Hypertens. Aug. 1990;4(4):372-4. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 2258877].
196 Korhonen M, Kastarinen M, Uusitupa M, et al. Advice from primary care physicians and nurses may improve diet in people with hypertension. Evidence based Cardiovascular Medicine {EVID BASED CARDIOVASC MED}. 2003;7:94-6. PMID: None. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.
197 Korhonen MH, Litmanen H, Rauramaa R, et al. Adherence to the salt restriction diet among people with mildly elevated blood pressure. Eur J Clin Nutr. Nov. 1999;53(11):880-5. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 10557001].
198 Kovelis D, Zabatiero J, Furlanetto KC, et al. Short-term effects of using pedometers to increase daily physical activity in smokers: a randomized trial. Respiratory Care. Jul. 2012;57(7):1089-97. KQ3E6b. [pmid: 22272985].
199 Kreausukon P, Gellert P, Lippke S, et al. Planning and self-efficacy can increase fruit and vegetable consumption: a randomized controlled trial. Journal of Behavioral Medicine. Aug. 2012;35(4):443-51. KQ3E6b. [pmid: 21822980].
200 Kuller LH, Simkin-Silverman LR, Wing RR, et al. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32-7. KQ3E3e. [pmid: 11136682].
201 Kuller LH, Pettee Gabriel KK, Kinzel LS, et al. The Women on the Move Through Activity and Nutrition (WOMAN) study: final 48-month results. Obesity. Mar. 2012;20(3):636-43. KQ2E3e, KQ3E3e. [pmid: 21494228].
202 Kupka-Schutt L, Mitchell ME. Positive effect of a nutrition instruction model on the dietary behavior of a selected group of elderly. J Nutr Elder. 1992;12(2):29-53. KQ3E3e. [pmid: 1296987].
203 Laan EK, Kraaijenhagen RA, Peek N, et al. Effectiveness of a web-based health risk assessment with individually-tailored feedback on lifestyle behaviour: study protocol. BMC Public Health. 2012;12:200. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 22429308].
204 Lamb SE, Bartlett HP, Ashley A, et al. Can lay-led walking programmes increase physical activity in middle aged adults? A randomised controlled trial. Journal of Epidemiology and Community Health. 2002;56(4):246-52. KQ2E3e, KQ3E3e. [pmid: 11896130].
205 Lammes E, Rydwik E, Akner G. Effects of nutritional intervention and physical training on energy intake, resting metabolic rate and body composition in frail elderly. a randomised, controlled pilot study. Journal of Nutrition, Health & Aging. Feb. 2012;16(2):162-7. KQ3E5. [pmid: 22323352].
206 Langford HG, Davis BR, Blaufox D, et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. Feb. 1991;17(2):210-7. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 1671380].
207 Lee RE, Medina AV, Mama SK, et al. Health is Power: an ecological, theory-based health intervention for women of color. [Review]. Contemporary Clinical Trials. Nov. 2011;32(6):916-23. KQ3E4. [pmid: 21782975].
208 Leijon ME, Bendtsen P, Stahle A, et al. Factors associated with patients self-reported adherence to prescribed physical activity in routine primary health care. BMC Family Practice. 2010;11:38. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20482851].
209 Lesley ML. Social problem solving training for African Americans: effects on dietary problem solving skill and DASH diet-related behavior change. Patient Education and Counseling. 2007;65(1):137-46. KQ3E4. [pmid: 16950591].
210 Lewis BA, Williams DM, Martinson BC, et al. Healthy for life: A randomized trial examining physical activity outcomes and psychosocial mediators. [References]. Annals of Behavioral Medicine. Apr. 2013;45(2):203-12. KQ3E3e. [pmid: 23229158].
211 Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. Sep. 2002;25(9):1504-10. KQ2E5, KQ3E5. [pmid: 12196418].
212 Lien LF, Brown AJ, Ard JD, et al. Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50(4):609-16. KQ1E4. [pmid: 17698724].
213 Lim HJ, Choi YM, Choue R. Dietary intervention with emphasis on folate intake reduces serum lipids but not plasma homocysteine levels in hyperlipidemic patients. Nutrition Research. 2008;28(11):767-74. KQ2E6b, KQ3E6b. [pmid: 19083486].
214 Lindahl B, Nilsson TK, Borch-Johnsen K, et al. A randomized lifestyle intervention with 5-year follow-up in subjects with impaired glucose tolerance: pronounced short-term impact but long-term adherence problems. [Erratum appears in Scand J Public Health. 2009 Jun;37(4):443]. Scandinavian Journal of Public Health. Jun. 2009;37(4):434-42. KQ2E5a, KQ3E5a, KQ4E5a. [pmid: 19181821].
215 Lindholm LH, Ekbom T, Dash C, et al. The impact of health care advice given in primary care on cardiovascular risk. CELL Study Group. BMJ. Apr. 29. 1995;310(6987):1105-9. KQ1E4, KQ2E6c, KQ3E6c, KQ4E4. [pmid: 7742677].
216 Lindholm LH, Ekbom T, Dash C, et al. Changes in cardiovascular risk factors by combined pharmacological and nonpharmacological strategies: the main results of the CELL Study. J Intern Med. Jul. 1996;240(1):13-22. KQ1E4, KQ2E6c, KQ3E6c, KQ4E4. [pmid: 8708586].
217 Lindström J, Peltonen M, Eriksson JG, et al. High-fibre, low-fat diet predicts long-term weight loss and decreased type 2 diabetes risk: the Finnish Diabetes Prevention Study. Diabetologia. 2006;49(5):912-20. KQ2E6a, KQ3E6a. [pmid: 16541277].
218 Lippke S, Schwarzer R, Ziegelmann JP, et al. Testing stage-specific effects of a stage-matched intervention: a randomized controlled trial targeting physical exercise and its predictors. Health Education & Behavior. Aug. 2010;37(4):533-46. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 20547760].
219 Little P, Dorward M, Gralton S, et al. A randomised controlled trial of three pragmatic approaches to initiate increased physical activity in sedentary patients with risk factors for cardiovascular disease. Br J Gen Pract. Mar. 2004;54(500):189-95. KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 15006124].
220 Luszczynska A, Schwarzer R, Lippke S, et al. Self-efficacy as a moderator of the planning-behaviour relationship in interventions designed to promote physical activity. Psychology & Health. Feb. 2011;26(2):151-66. KQ3E3a. [pmid: 21318927].
221 Ma J, King AC, Wilson SR, et al. Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Family Practice. 2009;10:71. KQ2E4, KQ3E4. [pmid: 19909549].
222 Macmillan F, Fitzsimons C, Black K, et al. Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Public Health. 2011;11:120. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 21333020].
223 Maindal HT, Toft U, Lauritzen T, et al. Three-year effects on dietary quality of health education: a randomized controlled trial of people with screen-detected dysglycaemia (The ADDITION study, Denmark). Eur J Public Health. Jun. 13. 2012;23(3):393-8. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a. [pmid: 23132875].
224 Malin SK, Gerber R, Chipkin SR, et al. Independent and combined effects of exercise training and metformin on insulin sensitivity in individuals with prediabetes. Diabetes Care. Jan. 2012;35(1):131-6. KQ2E5. [pmid: 22040838].
225 Mancuso CA, Choi TN, Westermann H, et al. Increasing physical activity in patients with asthma through positive affect and self-affirmation: a randomized trial. Arch Intern Med. Feb. 27. 2012;172(4):337-43. KQ4E3e. [pmid: 22269593].
226 Martinson BC, Sherwood NE, Crain AL, et al. Maintaining physical activity among older adults: 24-month outcomes of the Keep Active Minnesota randomized controlled trial. Prev Med. Jul. 2010;51(1):37-44. KQ3E3e. [pmid: 20382179].
227 Mascola AJ, Yiaslas TA, Meir RL, et al. Framing physical activity as a distinct and uniquely valuable behavior independent of weight management: A pilot randomized controlled trial from overweight and obese sedentary persons. [References]. Eating and Weight Disorders. Jun. 2009;14(2-3):e148-e152. KQ3E6b. [pmid: 19934630].
228 Mason C, Foster-Schubert KE, Imayama I, et al. Dietary weight loss and exercise effects on insulin resistance in postmenopausal women. Am J Prev Med. Oct. 2011;41(4):366-75. KQ2E5. [pmid: 21961463].
229 Mayer JA, Jermanovich A, Wright BL, et al. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. Mar. 1994;23(2):127-33. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 8047517].
230 Márquez-Celedonio FG, Téxon FO, Chávez NA, et al. Clinical effect of lifestyle modification on cardiovascular risk in prehypertensives: PREHIPER I study. Revista española de cardiología. 2009;62(1):86-90. KQ2E2a. [pmid: 19150019].
231 McAuley KA, Williams SM, Mann JI, et al. Intensive lifestyle changes are necessary to improve insulin sensitivity: a randomized controlled trial. Diabetes Care. Mar. 2002;25(3):445-52. KQ2E5, KQ3E5, KQ4E5. [pmid: 11874928].
232 McClure JB, Catz SL, Ludman EJ, et al. Feasibility and acceptability of a multiple risk factor intervention: the Step Up randomized pilot trial. BMC Public Health. 2011;11:167. KQ3E6b. [pmid: 21414216].
233 McGuire HL, Svetkey LP, Harsha DW, et al. Comprehensive lifestyle modification and blood pressure control: a review of the PREMIER trial. Journal of Clinical Hypertension. 2004;6(7):383-90. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 15249794].
234 McMurdo ME, Sugden J, Argo I, et al. Do pedometers increase physical activity in sedentary older women? A randomized controlled trial. Journal of the American Geriatrics Society. Nov. 2010;58(11):2099-106. KQ3E3e. [pmid: 21054290].
235 Meland E, Laerum E, Ulvik RJ. Effectiveness of two preventive interventions for coronary heart disease in primary care. Scand J Prim Health Care. Mar. 1997;15(1):57-64. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c. [pmid: 9101627].
236 Merom D, Bauman A, Phongsavan P, et al. Can a motivational intervention overcome an unsupportive environment for walking--findings from the Step-by-Step Study. Annals of Behavioral Medicine. Oct. 2009;38(2):137-46. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 19806414].
237 Merriam PA, Persuitte G, Olendzki BC, et al. Dietary intervention targeting increased fiber consumption for metabolic syndrome. Journal of the Academy of Nutrition & Dietetics. May. 2012;112(5):621-3. KQ2E4, KQ3E4. [pmid: 22709766].
238 Miettinen TA, Huttunen JK, Naukkarinen V, et al. Multifactorial primary prevention of cardiovascular diseases in middle-aged men. Risk factor changes, incidence, and mortality. JAMA. Oct. 18. 1985;254(15):2097-102. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 4046137].
239 Milkereit J, Graves JS. Follow-up dietary counseling benefits attainment of intake goals for total fat, saturated fat, and fiber. J Am Diet Assoc. May. 1992;92(5):603-5. KQ1E7e, KQ2E7e, KQ3E7e, KQ4E7e. [pmid: 1315350].
240 Miner JT. Enabling exercise prescription: Developing a comprehensive intervention strategy for exercise counseling and prescription in Family Medicine. Dissertation Abstracts International Section A: Humanities and Social Sciences. 2012;72(12-A):4438. PMID: None. KQ1E4, KQ2E4, KQ3E4, KQ4E4.
241 Miura S, Yamaguchi Y, Urata H, et al. Efficacy of a multicomponent program (patient-centered assessment and counseling for exercise plus nutrition [PACE+ Japan]) for lifestyle modification in patients with essential hypertension. Hypertension research : official journal of the Japanese Society of Hypertension. 2004;27(11):859-64. KQ2E7e, KQ3E7e. [pmid: 15824468].
242 Mochari-Greenberger H, Terry MB, Mosca L. Does stage of change modify the effectiveness of an educational intervention to improve diet among family members of hospitalized cardiovascular disease patients?. Journal of the American Dietetic Association. Jul. 2010;110(7):1027-35. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20630159].
243 Mochari-Greenberger H, Terry MB, Mosca L. Sex, age, and race/ethnicity do not modify the effectiveness of a diet intervention among family members of hospitalized cardiovascular disease patients. Journal of Nutrition Education & Behavior. Sep. 2011;43(5):366-73. KQ3E3e. [pmid: 21906549].
244 Mok Y, Won S, Kimm H, et al. Physical activity level and risk of death: the severance cohort study. Journal of Epidemiology. 2012;22(6):494-500. KQ4E6a. [pmid: 22850543].
245 Morey MC, Peterson MJ, Pieper CF, et al. The Veterans Learning to Improve Fitness and Function in Elders Study: a randomized trial of primary care-based physical activity counseling for older men. Journal of the American Geriatrics Society. Jul. 2009;57(7):1166-74. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 19467149].
246 Mosca L, Mochari H, Liao M, et al. A novel family-based intervention trial to improve heart health: FIT Heart: results of a randomized controlled trial. Circ Cardiovasc Qual Outcomes. 2008;1:98-106. PMID: None. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 20031796].
247 Mouttapa M, Robertson TP, McEligot AJ, et al. The Personal Nutrition Planner: a 5-week, computer-tailored intervention for women. Journal of Nutrition Education & Behavior. May. 2011;43(3):165-72. KQ2E6b, KQ3E6b. [pmid: 21550532].
248 MR FIT Research Team. Multiple risk factor intervention trial. Risk factor changes and mortality results. Multiple Risk Factor Intervention Trial Research Group. JAMA. Sep. 24. 1982;248(12):1465-77. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 7050440].
249 Mulholland Y, Nicokavoura E, Broom J, et al. Very-low-energy diets and morbidity: a systematic review of longer-term evidence. British Journal of Nutrition. 2012;108(5):832-51. KQ1E1b, KQ2E1b. [pmid: 22800763].
250 Mutrie N, Doolin O, Fitzsimons CF, et al. Increasing older adults' walking through primary care: Results of a pilot randomized controlled trial. Family Practice. 2012;29(6):633-42. KQ3E3e. [pmid: 22843637].
251 Nanri A, Tomita K, Matsushita Y, et al. Effect of six months lifestyle intervention in Japanese men with metabolic syndrome: randomized controlled trial. Journal of Occupational Health. 2012;54(3):215-22. KQ2E2b, KQ3E2b. [pmid: 22790524].
252 Neaton JD, Broste S, Cohen L, et al. The multiple risk factor intervention trial (MRFIT). VII. A comparison of risk factor changes between the two study groups. Prev Med. Jul. 1981;10(4):519-43. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 7027241].
253 Nelson MR, Alkhateeb AN, Ryan P, et al. Physical activity, alcohol and tobacco use and associated cardiovascular morbidity and mortality in the Second Australian National Blood Pressure study cohort. Age & Ageing. Jan. 2010;39(1):112-6. KQ1E1a. [pmid: 19903774].
254 Newton RL, Perri MG. A randomized pilot trial of exercise promotion in sedentary African-American adults. Ethnicity & Disease. 2004;14(4):548-57. KQ3E3e. [pmid: 15724775].
255 No ai. Development of an intervention to “Waste the waist”. Journal of Sport & Exercise Psychology. 2012;34(6):844-5. PMID: None. KQ1E6a, KQ2E6a, KQ3E6a.
256 Nolan RP, Upshur RE, Lynn H, et al. Therapeutic benefit of preventive telehealth counseling in the Community Outreach Heart Health and Risk Reduction Trial. The American journal of cardiology. 2011;107(5):690-6. KQ2E3a, KQ3E3a. [pmid: 21215382].
257 Noordman J, van der Weijden T, van DS. Communication-related behavior change techniques used in face-to-face lifestyle interventions in primary care: a systematic review of the literature. Patient Education and Counseling. 2012;89(2):227-44. KQ1E1a, KQ2E1a, KQ3E1a, KQ4E1a. [pmid: 22878028].
258 Norton LH, Norton KI, Lewis N, et al. Communication-related behavior change techniques used in face-to-face lifestyle interventions in primary care: a systematic review of the literature. The International Journal of Behavioral Nutrition and Physical Activity. 2011;8:133. KQ3E3e. [pmid: 22136578].
259 Norton LH, Norton KI, Lewis N, et al. A comparison of two short-term intensive physical activity interventions: Methodological considerations. [References]. The International Journal of Behavioral Nutrition and Physical Activity. 2011;8. KQ3E3e. [pmid: 22136578].
260 Oberman A, Wassertheil-Smoller S, Langford HG, et al. Pharmacologic and nutritional treatment of mild hypertension: changes in cardiovascular risk status. Ann Intern Med. Jan. 15. 1990;112(2):89-95. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 1967210].
261 Ockene IS, Hebert JR, Ockene JK, et al. Effect of training and a structured office practice on physician-delivered nutrition counseling: the Worcester-Area Trial for Counseling in Hyperlipidemia (WATCH). Am J Prev Med. Jul. 1996;12(4):252-8. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 8874688].
262 Oh EG, Bang SY, Hyun SS, et al. Effects of a 6-month lifestyle modification intervention on the cardiometabolic risk factors and health-related qualities of life in women with metabolic syndrome. Metabolism: Clinical & Experimental. Jul. 2010;59(7):1035-43. KQ2E8. [pmid: 20045151].
263 Okayama A, Chiba N, Ueshima H. Non-pharmacological intervention study of hypercholesterolemia among middle-aged people. Environmental Health and Preventive Medicine {ENVIRON HEALTH PREV MED}. 2004;9(4):165-9. KQ2E2b. [pmid: 21432327].
264 Panagiotakos D, Pitsavos C, Chrysohoou C, et al. Dietary patterns and 5-year incidence of cardiovascular disease: a multivariate analysis of the ATTICA study. Nutrition Metabolism & Cardiovascular Diseases. May. 2009;19(4):253-63. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 18722096].
265 Panunzio MF, Caporizzi R, Antoniciello A, et al. Randomized, controlled nutrition education trial promotes a Mediterranean diet and improves anthropometric, dietary, and metabolic parameters in adults. Annali di Igiene. Jan. 2011;23(1):13-25. KQ2E3e, KQ3E3e. [pmid: 21736003].
266 Park YH, Song M, Cho BL, et al. The effects of an integrated health education and exercise program in community-dwelling older adults with hypertension: a randomized controlled trial. Patient Education & Counseling. Jan. 2011;82(1):133-7. KQ2E6b. [pmid: 20434864].
267 Parra-Medina D, Wilcox S, Wilson DK, et al. Heart Healthy and Ethnically Relevant (HHER) Lifestyle trial for improving diet and physical activity in underserved African American women. Contemporary Clinical Trials. Jan. 2010;31(1):92-104. KQ3E3a. [pmid: 19781665].
268 Parra-Medina D, Wilcox S, Salinas J, et al. Results of the Heart Healthy and Ethnically Relevant Lifestyle trial: a cardiovascular risk reduction intervention for African American women attending community health centers. American Journal of Public Health. Oct. 2011;101(10):1914-21. KQ3E3a. [pmid: 21852629].
269 Peels DA, van Stralen MM, Bolman C, et al. Results of the Heart Healthy and Ethnically Relevant Lifestyle trial: a cardiovascular risk reduction intervention for African American women attending community health centers. Journal of Medical Internet Research. 2012;14(2):e39. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 22390878].
270 Pekmezi D, Dunsiger S, Gans K, et al. Rationale, design, and baseline findings from Seamos Saludables: a randomized controlled trial testing the efficacy of a culturally and linguistically adapted, computer- tailored physical activity intervention for Latinas. Contemporary Clinical Trials. Nov. 2012;33(6):1261-71. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 22789455].
271 Pekmezi DW, Neighbors CJ, Lee CS, et al. A culturally adapted physical activity intervention for Latinas: a randomized controlled trial. Am J Prev Med. Dec. 2009;37(6):495-500. KQ3E3e. [pmid: 19944914].
272 Pekmezi DW, Williams DM, Dunsiger S, et al. Feasibility of using computer-tailored and internet-based interventions to promote physical activity in underserved populations. Telemedicine Journal & E-Health. May. 2010;16(4):498-503. KQ3E3e. [pmid: 20507203].
273 Petersen CB, Severin M, Hansen AW, et al. A population-based randomized controlled trial of the effect of combining a pedometer with an intervention toolkit on physical activity among individuals with low levels of physical activity or fitness. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2012;54(2):125-30. KQ3E3e. [pmid: 22200586].
274 Peterson JA, Ward-Smith P. Choose to Move for Positive Living: physical activity program for obese women. Holistic Nursing Practice. May. 2012;26(3):120-8. KQ3E6a. [pmid: 22517347].
275 Petrella RJ, Lattanzio CN, Shapiro S, et al. Improving aerobic fitness in older adults: effects of a physician-based exercise counseling and prescription program. Canadian Family Physician. May. 2010;56(5):e191-e200. KQ2E3e, KQ3E3e. [pmid: 20463260].
276 Petrogianni M, Kanellakis S, Kallianioti K, et al. A multicomponent lifestyle intervention produces favourable changes in diet quality and cardiometabolic risk indices in hypercholesterolaemic adults. J Hum Nutr Diet. 2013. Mar. 20. [doi: 10.1111/jhn.12041]. KQ2E6b, KQ3E6b.
277 Pettman TL, Misan GMH, Owen K, et al. Self-management for obesity and cardio-metabolic fitness: description and evaluation of the lifestyle modification program of a randomised controlled trial. International Journal of Behavioral Nutrition and Physical Activity. 2008;5:53. KQ1E4, KQ2E5, KQ3E5. [pmid: 18954466].
278 Pignol AM. Self-management for obesity and cardio-metabolic fitness: description and evaluation of the lifestyle modification program of a randomised controlled trial. University of North Dakota. University of North Dakota. 2008. PMID: None. KQ3E3e.
279 Pignol AM. Effects of motivational interviewing on levels of physical activity in older adults. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;(4-B). PMID: None. KQ3E3e.
280 Pinto BM, Goldstein MG, Ashba J, et al. Randomized controlled trial of physical activity counseling for older primary care patients. Am J Prev Med. 2005;29(4):247-55. KQ3E3a. [pmid: 16242586].
281 Pisinger C, Ladelund S, Glumer C, et al. Five years of lifestyle intervention improved self-reported mental and physical health in a general population: the Inter99 study. Prev Med. Nov. 2009;49(5):424-8. KQ2E4, KQ3E4. [pmid: 19664653].
282 Poston WS, Haddock CK, Olvera NE, et al. Evaluation of a culturally appropriate intervention to increase physical activity. American Journal of Health Behavior. 2001;25(4):396-406. KQ3E3e. [pmid: 11488550].
283 Prestwich A, Perugini M, Hurling R. Can implementation intentions and text messages promote brisk walking? A randomized trial. Health Psychology. Jan. 2010;29(1):40-9. KQ2E6b. KQ3E6b. [pmid: 20063934].
284 Prestwich A, Conner MT, Lawton RJ, et al. Randomized controlled trial of collaborative implementation intentions targeting working adults' physical activity. Health Psychology. Jul. 2012;31(4):486-95. KQ3E3e. [pmid: 22468716].
285 Price HC, Griffin SJ, Holman RR. Impact of personalized cardiovascular disease risk estimates on physical activity-a randomized controlled trial. Diabetic Medicine. Mar. 2011;28(3):363-72. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b. [pmid: 21309847].
286 Prochaska JO, Velicer WF, Rossi JS, et al. Multiple risk expert systems interventions: impact of simultaneous stage-matched expert system interventions for smoking, high-fat diet, and sun exposure in a population of parents. Health psychology : official journal of the Division of Health Psychology, American Psychological Association. 2004;23(5):503-16. KQ3E3e. [pmid: 15367070].
287 Qian J, Wang B, Dawkins N, et al. Reduction of risk factors for cardiovascular diseases in African Americans with a 12-week nutrition education program. Nutrition Research. 2007;27(5):252-7. PMID: None. KQ2E6b, KQ3E6b.
288 Rasinaho M, Hirvensalo M, Tormakangas T, et al. Effect of physical activity counseling on physical activity of older people in Finland (ISRCTN 07330512). Health Promotion International. Dec. 2012;27(4):463-74. KQ3E3e. [pmid: 21911336].
289 Ratner RE, Christophi CA, Metzger BE, et al. Prevention of diabetes in women with a history of gestational diabetes: effects of metformin and lifestyle interventions. J Clin Endocrinol Metab. Dec. 2008;93(12):4774-9. KQ2E3e, KQ3E3e. [pmid: 18826999].
290 Råberg-Kjøllesdal MK, Hjellset VT, Bjørge B, et al. Intention to change dietary habits, and weight loss among Norwegian-Pakistani women participating in a culturally adapted intervention. Journal of immigrant and minority health / Center for Minority Public Health. 2011;13:1150-8. KQ3E3e. [pmid: 21082252].
291 Reed J, Malvern L, Muthukrishnan S, et al. An ecological approach with primary-care counseling to promote physical activity. Journal of Physical Activity & Health. 2008;5:169-83. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 18209262].
292 Reinhardt JA, van der Ploeg HP, Grzegrzulka R, et al. Implementing lifestyle change through phone-based motivational interviewing in rural-based women with previous gestational diabetes mellitus. Health Promotion Journal of Australia. Apr. 2012;23(1):5-9. KQ2E3e, KQ3E3e. [pmid: 22730940].
293 Rejeski WJ, Mihalko SL, Ambrosius WT, et al. Weight loss and self-regulatory eating efficacy in older adults: the cooperative lifestyle intervention program. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. May. 2011;66(3):279-86. KQ2E5, KQ3E5. [pmid: 21292809].
294 Rejeski WJ, Brubaker PH, Goff DC Jr, et al. Translating weight loss and physical activity programs into the community to preserve mobility in older, obese adults in poor cardiovascular health. Arch Intern Med. May. 23. 2011;171(10):880-6. KQ2E5, KQ3E5. [pmid: 21263080].
295 Reseland JE, Anderssen SA, Solvoll K, et al. Effect of long-term changes in diet and exercise on plasma leptin concentrations. Am J Clin Nutr. Feb. 2001;73(2):240-5. KQ1E4, KQ4E4. [pmid: 11157319].
296 Rikkonen T, Salovaara K, Sirola J, et al. Physical activity slows femoral bone loss but promotes wrist fractures in postmenopausal women: a 15-year follow-up of the OSTPRE study. Journal of Bone & Mineral Research. Nov. 2010;25(11):2332-40. KQ4E3e. [pmid: 20533310].
297 Robare JF, Milas NC, Bayles CM, et al. The key to life nutrition program: results from a community-based dietary sodium reduction trial. Public Health Nutrition. May. 2010;13(5):606-14. KQ3E6a. [pmid: 19781124].
298 Robare JF, Bayles CM, Newman AB, et al. The “10 keys” to healthy aging: 24-month follow-up results from an innovative community-based prevention program. Health Education & Behavior. Aug. 2011;38(4):379-88. KQ2E5, KQ3E5. [pmid: 21652780].
299 Roca-Cusachs A, Sort D, Altimira J, et al. The impact of a patient education programme in the control of hypertension. J Hum Hypertens. Oct. 1991;5(5):437-41. KQ1E7, KQ2E7, KQ3E7, KQ4E7. [pmid: 1770472].
300 Rodriguez Cristobal JJ, Panisello Royo JM, Alonso-Villaverde GC, et al. Group motivational intervention in overweight/obese patients in primary prevention of cardiovascular disease in the primary healthcare area. BMC Family Practice. 2010;11:23. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 20298557].
301 Rodríguez S I, Escortell ME, Rico BM, et al. EDUCORE project: a clinical trial, randomised by clusters, to assess the effect of a visual learning method on blood pressure control in the primary healthcare setting. BMC Public Health. 2010;10:449. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 20673325].
302 Romé A, Persson U, Ekdahl C, et al. Physical activity on prescription (PAP): costs and consequences of a randomized, controlled trial in primary healthcare. Scandinavian Journal of Primary Health Care. 2009;27:216-22. KQ2E6b, KQ3E6b. [pmid: 19929183].
303 Rosamond WD, Ammerman AS, Holliday JL, et al. Cardiovascular disease risk factor intervention in low-income women: the North Carolina WISEWOMAN project. Prev Med. 2000;2000(4):370-9. KQ1E7e, KQ2E7e, KQ3E7e, KQ4E7e. [pmid: 11006062].
304 Rose SB, Lawton BA, Elley CR, et al. The ‘Women's Lifestyle Study’, 2-year randomized controlled trial of physical activity counselling in primary health care: rationale and study design. BMC Public Health. 2007;7:166. KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 17645805].
305 Ruffin MT, Nease DE Jr, Sen A, et al. Effect of preventive messages tailored to family history on health behaviors: the Family Healthware Impact Trial. Annals of Family Medicine. Jan. 2011;9(1):3-11. KQ3E3e. [pmid: 21242555].
306 Saaristo T, Peltonen M, Keinanen-Kiukaanniemi S, et al. National type 2 diabetes prevention programme in Finland: FIN-D2D. Int J Circumpolar Health. Apr. 2007;66(2):101-12. KQ1E5, KQ2E5, KQ3E5, KQ4E5. [pmid: 17515250].
307 Sabti Z, Handschin M, Joss MK, et al. Evaluation of a physical activity promotion program in primary care. Family Practice. Jun. 2010;27(3):279-84. KQ3E3e. [pmid: 20332179].
308 Salkeld G, Phongsavan P, Oldenburg B, et al. The cost-effectiveness of a cardiovascular risk reduction program in general practice. Health Policy. Aug. 1997;41(2):105-19. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 10169297].
309 Schneider JK, Cook JH, Luke DA. Unexpected effects of cognitive-behavioural therapy on self-reported exercise behaviour and functional outcomes in older adults. Age & Ageing. Mar. 2011;40(2):163-8. KQ3E1a. [pmid: 21059615].
310 Serwe KM, Swartz AM, Hart TL, et al. Effectiveness of long and short bout walking on increasing physical activity in women. Journal of Women's Health. 2011;20(2):247-53. KQ3E6b. [pmid: 21314449].
311 Shahnazari M, Ceresa C, Foley S, et al. Nutrition-focused wellness coaching promotes a reduction in body weight in overweight US veterans. Journal of the Academy of Nutrition & Dietetics. Jul. 2013;113(7):928-35. KQ2E1b, KQ3E1b. [pmid: 23706353].
312 Simmons RK, van Sluijs EM, Hardeman W, et al. Who will increase their physical activity? Predictors of change in objectively measured physical activity over 12 months in the ProActive cohort. BMC Public Health. 2010;10:226. KQ3E3e. [pmid: 20433700].
313 Smeets T, Kremers SP, Brug J, et al. Effects of tailored feedback on multiple health behaviors. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2007;33(2):117-23. KQ3E6b. [pmid: 17447863].
314 Sohn AJ, Hasnain M, Sinacore JM. Impact of exercise (walking) on blood pressure levels in African American adults with newly diagnosed hypertension. Ethnicity & Disease. 2007;17(3):503-7. KQ2E6c, KQ3E6c, KQ4E6c. [pmid: 17985505].
315 Soureti A, Murray P, Cobain M, et al. Web-based risk communication and planning in an obese population: exploratory study. Journal of Medical Internet Research. 2011;13(4):e100. KQ3E6b. [pmid: 22126827].
316 Soureti A, Murray P, Cobain M, et al. Exploratory study of web-based planning and mobile text reminders in an overweight population. [References]. Journal of Medical Internet Research. Oct. 2011;13(4):232-42. KQ3E3e. [pmid: 22182483].
317 Spink KS, Wilson KS. Physician counseling and longer term physical activity. Journal of Primary Care & Community Health. Oct. 1. 2010;1(3):173-7. KQ3E3e.
318 St George A, Bauman A, Johnston A, et al. Effect of a lifestyle intervention in patients with abnormal liver enzymes and metabolic risk factors. Journal of Gastroenterology & Hepatology. Mar. 2009;24(3):399-407. KQ2E6b, KQ3E6b. [pmid: 19067776].
319 Stadler G, Oettingen G, Gollwitzer PM. Intervention effects of information and self-regulation on eating fruits and vegetables over two years. Health Psychology. May. 2010;29(3):274-83. KQ3E3e. [pmid: 20496981].
320 Staffileno BA, Braun LT, Rosenson RS. The accumulative effects of physical activity in hypertensive post-menopausal women. Journal of cardiovascular risk. 2001;8(5):283-90. KQ2E6b, KQ3E6b. [pmid: 11702034].
321 Staffileno BA, Minnick A, Coke LA, et al. Blood pressure responses to lifestyle physical activity among young, hypertension-prone African-American women. The Journal of cardiovascular nursing. 2007;22(2):107-17. KQ2E6b, KQ3E6b. [pmid: 17318036].
322 Stamler J, Briefel RR, Milas C, et al. Relation of changes in dietary lipids and weight, trial years 1-6, to changes in blood lipids in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. Jan. 1997;65(1 Suppl):272S-88S. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 8988942].
323 Staudter M, Dramiga S, Webb L, et al. Effectiveness of pedometer use in motivating active duty and other military healthcare beneficiaries to walk more. US Army Medical Department Journal. Jul. 2011:108-19. KQ2E3e, KQ3E3e. [pmid: 21805462].
324 Steptoe A, Perkins PL, McKay C, et al. Behavioural counselling to increase consumption of fruit and vegetables in low income adults: randomised trial. BMJ. 2003;326(7394):855. KQ3E3e. [pmid: 12702620].
325 Stevens VJ, Obarzanek E, Cook NR, et al. Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134(1):1-11. KQ1E3e, KQ2E3e, KQ3E3e. [pmid: 11187414].
326 Stewart AL, Verboncoeur CJ, McLellan BY, et al. Physical activity outcomes of CHAMPS II: a physical activity promotion program for older adults. The journals of gerontology Series A, Biological sciences and medical sciences. 2001;56(8):M465-M470. KQ3E3e. [pmid: 11487597].
327 Stralen MM, Vries H, Mudde AN, et al. The long-term efficacy of two computer-tailored physical activity interventions for older adults: main effects and mediators. Health psychology : official journal of the Division of Health Psychology, American Psychological Association. 2011;30:442-52. KQ3E3e. [pmid: 21639638].
328 Strandberg TE, Salomaa VV, Naukkarinen VA, et al. Long-term mortality after 5-year multifactorial primary prevention of cardiovascular diseases in middle-aged men. JAMA. Sep. 4. 1991;266(9):1225-9. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 1870247].
329 Strandberg TE, Salomaa VV, Vanhanen HT, et al. Mortality in participants and non-participants of a multifactorial prevention study of cardiovascular diseases: a 28 year follow up of the Helsinki Businessmen Study. Br Heart J. Oct. 1995;74(4):449-54. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 7488463].
330 Strath SJ, Swartz AM, Parker SJ, et al. A pilot randomized controlled trial evaluating motivationally matched pedometer feedback to increase physical activity behavior in older adults. Journal of Physical Activity & Health. Sep. 2011;8(Suppl 2):S267-S274. KQ3E6b. [pmid: 21918241].
331 Suurkula M, Agewall S, Fagerberg B, et al. Multiple risk intervention in high-risk hypertensive patients. A 3-year ultrasound study of intima-media thickness and plaques in the carotid artery. Risk Intervention Study (RIS) Group. Arterioscler Thromb Vasc Biol. Mar. 1996;16(3):462-70. KQ1E8, KQ2E8, KQ3E8, KQ4E8. [pmid: 8630674].
332 Svetkey LP, Stevens VJ, Brantley PJ, et al. Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. Mar. 12. 2008;299(10):1139-48. KQ1E1b, KQ2E1b, KQ3E1b, KQ4E1b. [pmid: 18334689].
333 Swanson CM, Bersoux S, Larson MH, et al. An outpatient-based clinical program for diabetes prevention: an update. Endocrine Practice. Mar. 2012;18(2):200-8. KQ2E6a. [pmid: 22068253].
334 Swearingin B. The comparison of the effects of lifestyle activity and structured cardiovascular exercise on obesity-related risk factors of African-American women ages 22--55. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;(12-B). PMID: None. KQ2E6b, KQ3E6b.
335 Teri L, McCurry SM, Logsdon RG, et al. A randomized controlled clinical trial of the Seattle Protocol for Activity in older adults. Journal of the American Geriatrics Society. Jul. 2011;59(7):1188-96. KQ3E5. [pmid: 21718259].
336 Tessaro I, Rye S, Parker L, et al. Effectiveness of a nutrition intervention with rural low-income women. American Journal of Health Behavior. 2007;31(1):35-43. KQ3E6b. [pmid: 17181460].
337 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. Mar. 4. 1992;267(9):1213-20. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 1586398].
338 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. Arch Intern Med. Mar. 24. 1997;157(6):657-67. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 9080920].
339 Thomas GN, Macfarlane DJ, Guo B, et al. Health promotion in older Chinese: a 12-month cluster randomized controlled trial of pedometry and “peer support”. Medicine & Science in Sports & Exercise. Jun. 2012;44(6):1157-66. KQ2E6d, KQ3E6d. [pmid: 22143109].
340 Thompson JL, Allen P, Helitzer DL, et al. Reducing diabetes risk in American Indian women. Am J Prev Med. 2008;34(3):192-201. KQ2E3e. [pmid: 18312806].
341 Toft U, Jakobsen M, Aadahl M, et al. Does a population-based multi-factorial lifestyle intervention increase social inequality in dietary habits? The Inter99 study. Prev Med. Jan. 2012;54(1):88-93. KQ4E4. [pmid: 22036837].
342 Toft UN, Kristoffersen LH, Aadahl M, et al. Diet and exercise intervention in a general population--mediators of participation and adherence: the Inter99 study. Eur J Public Health. 2006;17(5):455-63. KQ3E4. [pmid: 17170019].
343 Trovato GM, Pirri C, Martines GF, et al. Lifestyle interventions, insulin resistance, and renal artery stiffness in essential hypertension. Clinical and experimental hypertension. 2009;32:262-9. KQ2E6a, KQ3E6a. [pmid: 20662726].
344 Trovato GM, Pirri C, Martines GF, et al. Lifestyle interventions, insulin resistance, and renal artery stiffness in essential hypertension. Clinical & Experimental Hypertension (New York). 2010;32(5):262-9. KQ2E6a. [pmid: 20662726].
345 Trøseid M, Arnesen H, Hjerkinn EM, et al. Serum levels of interleukin-18 are reduced by diet and n-3 fatty acid intervention in elderly high-risk men. Metabolism: clinical and experimental. 2009;58:1543-9. KQ2E1a. [pmid: 19595382].
346 Tsai AC, Tsai HJ. The association of age, gender, body fatness and lifestyle factors with plasma C-reactive protein concentrations in older Taiwanese. Journal of Nutrition, Health & Aging. Jun. 2010;14(6):412-6. KQ2E6b. [pmid: 20617281].
347 Tudor-Locke C. Promoting Lifestyle Physical Activity: Experiences with the First Step Program. Am J Lifestyle Med. Jul. 1. 2009;3(1 Suppl):508-48. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 20161372].
348 Turner JE, Markovitch D, Betts JA, et al. Nonprescribed physical activity energy expenditure is maintained with structured exercise and implicates a compensatory increase in energy intake. The American journal of clinical nutrition. 2010;92(5):1009-16. KQ4E3e. [pmid: 20826629].
349 van Stralen MM, de VH, Mudde AN, et al. Efficacy of two tailored interventions promoting physical activity in older adults. Am J Prev Med. Nov. 2009;37(5):405-17. KQ3E3e. [pmid: 19840695].
350 van Stralen MM, de VH, Bolman C, et al. Exploring the efficacy and moderators of two computer-tailored physical activity interventions for older adults: a randomized controlled trial. Annals of Behavioral Medicine. May. 2010;39(2):139-50. KQ3E3e. [pmid: 20182833].
351 van Stralen MM, de VH, Mudde AN, et al. The long-term efficacy of two computer-tailored physical activity interventions for older adults: main effects and mediators. Health Psychology. Jul. 2011;30(4):442-52. KQ3E3e. [pmid: 21639638].
352 van Teeffelen WM, de Beus MF, Mosterd A, et al. Risk factors for exercise-related acute cardiac events. A case-control study. British Journal of Sports Medicine. Sep. 2009;43(9):722-5. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 19734508].
353 Vandelanotte C, Bourdeaudhuij I, Sallis JF, et al. Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2005;29(2):138-46. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 15823787].
354 Verheijden M, Bakx JC, Akkermans R, et al. Web-based targeted nutrition counselling and social support for patients at increased cardiovascular risk in general practice: randomized controlled trial. J Med Internet Res. Dec. 16. 2004;6(4):e44. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 15631968].
355 Vrdoljak D, Markovic BB, Puljak L, et al. Lifestyle intervention in general practice for physical activity, smoking, alcohol consumption and diet in elderly: A randomized controlled trial. Arch Gerontol Geriatr. 2013. Aug. 24. KQ3E3e. [pmid: 24012131].
356 Walden CE, Retzlaff BM, Buck BL, et al. Lipoprotein lipid response to the National Cholesterol Education Program step II diet by hypercholesterolemic and combined hyperlipidemic women and men. Arterioscler Thromb Vasc Biol. Feb. 1997;17(2):375-82. KQ1E7d, KQ2E7d, KQ3E7d, KQ4E7d. [pmid: 9081694].
357 Walker SN, Pullen CH, Hageman PA, et al. Maintenance of activity and eating change after a clinical trial of tailored newsletters with older rural women. Nursing Research. Sep. 2010;59(5):311-21. KQ3E3e. [pmid: 20697307].
358 Wang X, Hsu FC, Isom S, et al. Effects of a 12-month physical activity intervention on prevalence of metabolic syndrome in elderly men and women. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Apr. 2012;67(4):417-24. KQ2E5. [pmid: 22054949].
359 Wang YF, Yancy WS, Yu D, et al. The relationship between dietary protein intake and blood pressure: results from the PREMIER study. Journal of Human Hypertension. 2008;22(11):745-54. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 18580887].
360 Wassertheil-Smoller S, Oberman A, Blaufox MD, et al. The Trial of Antihypertensive Interventions and Management (TAIM) Study. Final results with regard to blood pressure, cardiovascular risk, and quality of life. Am J Hypertens. Jan. 1992;5(1):37-44. KQ1E1, KQ2E1, KQ3E1, KQ4E1. [pmid: 1736933].
361 Watson A, Bickmore T, Cange A, et al. An Internet-based virtual coach to promote physical activity adherence in overweight adults: Randomized controlled trial. [References]. Journal of Medical Internet Research. Jan. 2012;14(1):e1. KQ2E3e, KQ3E3e. [pmid: 22281837].
362 Wenrich TR, Brown JL, Wilson RT, et al. Impact of a community-based intervention on serving and intake of vegetables among low-income, rural Appalachian families. Journal of Nutrition Education & Behavior. Jan. 2012;44(1):36-45. KQE3e. [pmid: 22023910].
363 Werkman A, Hulshof PJ, Stafleu A, et al. Effect of an individually tailored one-year energy balance programme on body weight, body composition and lifestyle in recent retirees: a cluster randomised controlled trial. BMC Public Health. 2010;10:110. KQ3E3e. [pmid: 20205704].
364 Will JC, Massoudi B, Mokdad A, et al. Reducing risk for cardiovascular disease in uninsured women: combined results from two WISEWOMAN projects. Journal of the American Medical Women's Association. 2001;56(4):161-5. KQE7e, KQ2E7e, KQ3E7e. [pmid: 11759784].
365 Williams DM, Papandonatos GD, Jennings EG, et al. Does tailoring on additional theoretical constructs enhance the efficacy of a print-based physical activity promotion intervention?. Health Psychology. Jul. 2011;30(4):432-41. KQ3E3e. [pmid: 21574710].
366 Wilson DK, Trumpeter NN, St George SM, et al. An overview of the “Positive Action for Today's Health” (PATH) trial for increasing walking in low income, ethnic minority communities. Contemporary Clinical Trials. Nov. 2010;31(6):624-33. KQ1E4, KQ2E4, KQ3E4, KQ4E4. [pmid: 20801233].
367 Witmer JM, Hensel MR, Holck PS, et al. Heart disease prevention for Alaska Native women: a review of pilot study findings. Journal of Women's Health. 2004;13(5):569-78. KQ2E3e, KQ3E3e. [pmid: 15257848].
368 Wolf RL, Lepore SJ, Vandergrift JL, et al. Tailored telephone education to promote awareness and adoption of fruit and vegetable recommendations among urban and mostly immigrant black men: a randomized controlled trial. Prev Med. Jan. 2009;48(1):32-8. KQ3E3e. [pmid: 19010349].
369 Woodall WG, Buller DB, Saba L, et al. Effect of emailed messages on return use of a nutrition education website and subsequent changes in dietary behavior. Journal of Medical Internet Research. 2007;9(3):e27. KQ3E6b. [pmid: 17942389].
370 Woollard J, Burke V, Beilin LJ, et al. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. Journal of cardiovascular risk. 2003;10(1):31-40. KQ2E7, KQ3E7. [pmid: 12569235].
371 Wright JL, Sherriff JL, Dhaliwal SS, et al. Tailored, iterative, printed dietary feedback is as effective as group education in improving dietary behaviours: results from a randomised control trial in middle-aged adults with cardiovascular risk factors. International Journal of Behavioral Nutrition & Physical Activity. 2011;8:43. KQ3E6b. [pmid: 21595978].
372 Yancy WS Jr, Westman EC, McDuffie JR, et al. A randomized trial of a low-carbohydrate diet vs orlistat plus a low-fat diet for weight loss. Arch Intern Med. Jan. 25. 2010;170(2):136-45. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c. [pmid: 20101008].
373 Yates BC, Pullen CH, Santo JB, et al. The influence of cognitive-perceptual variables on patterns of change over time in rural midlife and older women's healthy eating. Social Science & Medicine. Aug. 2012;75(4):659-67. KQ3E3e. [pmid: 22365936].
374 Yen WJ, Lewis NM. MyPyramid-omega-3 fatty acid nutrition education intervention may improve food groups and omega-3 fatty acid consumption in university middle-aged women. Nutrition Research. Feb. 2013;33(2):103-8. KQ1E3e, KQ2E3e, KQ3E3e, KQ4E3e. [pmid: 23399660].
375 Zoellner JM, Connell CC, Madson MB, et al. H.U.B city steps: methods and early findings from a community-based participatory research trial to reduce blood pressure among African Americans. International Journal of Behavioral Nutrition & Physical Activity. 2011;8:59. KQ2E3e. [pmid: 21663652].