# Ongoing or Recently Completed Studies

Investigator, Study Name, Location | Number of Participants | Intervention | Outcomes | 2013 Status
Dr. Sheldon Tobe HBPS Canada (Heart and Stroke Foundation of Ontario) | 5,000 | Integrated model in which doctors, nurse practitioners, and pharmacists work together through use of evidence-informed tools, including a patient toolkit addressing lifestyle change information, to control BP in 11 family practice sites | BP | Ongoing
Götebergs University (no named PI) DIAVIP Sweden | 2,000 | Diabetes prevention in primary health care, with emphasis on low- vs. high-intensity PA compared with no intervention | HOMA IR | Not yet enrolling
Dr. Denis Pouchain ESCAPE France (College National des Generalistes Enseignants) | 1,836 | General practice–delivered prevention consultations, focused on diet and exercise, to reduce CVD risk factors in patients with HTN | LDL, HbA1c, BP, PA, diet, QoL, number of targets reached | Completed
Region Skåne (no named PI) The MEDIM Study Sweden | 1,244 | Lifestyle intervention including group counseling and PA for Iraqi immigrants with prediabetes | FBG, QALY | Not yet enrolling
Dr. Olugbenga Ogedegbe CAATCH Columbia University | 1,039 | Counseling patients to control HTN using a multicomponent intervention aimed at patients and providers within Community Health Centers | SBP, DBP, cost effectiveness | Completed
Dr. Nancy Kressin Boston University, Boston Medical Center | 870 | Patient-centered counseling for HTN, with or without cultural competency training for physicians, compared with usual care, to improve control of HTN | BP, % with controlled HTN, medication adherence | Ongoing
Dr. Melanie Davies UK (University Hospitals, Leicester) | 804 | Group educational program to increase PA and reduce risk for developing diabetes in adults at high risk for diabetes (based on “risk score”) | PA, FBG, HbA1c, adiposity (subset) | Recruiting
Dr. Melanie Davies PREVENTION UK (University Hospitals, Leicester) | 748 | Educational program focusing on lifestyle, PA, and food choices in individuals at high risk for diabetes | Diabetes incidence, FBG, METS, CVD risk, HbA1c | Enrolling
Dr. Esperanza Escortell EDUCORE Spain (Servicio Madrileno de Salud) | 736 | Use of the EDUCORE program, a visual aid educational intervention, to improve blood pressure control in patients with hypertension in 22 primary health care centers in Madrid | SBP, DBP, BP control, CVD risk score, TC | Completed
Dr. Beti Thompson Fred Hutchinson Cancer Research Center | 430 | Education-based, lay health educator-led intervention designed to educate participants with elevated HbA1c levels about diabetes and diet and lifestyle changes | PA, diet, HbA1c | Completed
Dr. Robert Reid FHHP-RCT Canada (University of Ottawa Heart Institute) | 426 | 12-week lifestyle change program for increased exercise and improved nutrition and weight management, with telephone-based motivational counseling in high-risk adults | SBP, TC, HDL, LDL, PA, diet, body composition | Completed
Dr. Robert Nolan I-START Canada (University Health Network, Toronto) | 387 | Internet-based behavioral counseling for adaptive lifestyle change for subjects diagnosed with hypertension (I-START) | SBP, DBP, PA, diet, vagal-heart rate | Completed
Dr. Andrea Kriska Healthy Lifestyle Project University of Pittsburgh | 351 | DPP-adapted program delivered in a community-based setting. In person vs. DVD session for group lifestyle education focused on weight loss and increasing PA levels for individuals at high risk for diabetes | Weight, BP, FBG, lipids, PA, QoL | Recruiting
Dr. Prabath Nanayakkara WISH The Netherlands (Vrije University Medical Center) | 300 | Tailored lifestyle advice through Web-based feedback system for adults with hypertension | SBP, DBP | Recruiting
Dr. Gladys Block ALIVE-PD Kaiser Permanente-Northern California, Berkeley Analytics | 268 | Lifestyle intervention with multichannel delivery, including email/Web goal setting to improve PA, diet and weight loss for patients with prediabetes | FBG, HbA1c, weight, PA, diet | Not yet enrolling
Dr. Robert Zweiker Austria (Medical University of Graz) | 256 | Structured educational program, including lifestyle and dietary habits, for patients with hypertension | BP, morbidity associated with CVD events | Completed
Dr. Olugbenga Ogedegbe COACH New York University School of Medicine | 250 | Comprehensive therapeutic lifestyle intervention delivered through group-based counseling and motivational interviewing in seniors with hypertension age 60 years and older | SBP, DBP, PA, weight, diet | Ongoing
Dr. Olugbenga Ogedegbe TLC-Clinic New York University School of Medicine | 200 | Primary care practice–based lifestyle intervention delivered through group-based counseling and motivational interviewing and focused on PA, diet, and weight management for hypertension | SBP, DBP, PA, diet, weight, sodium | Ongoing
Dr. Antti Jula Finland (National Institute for Health and Welfare) | 144 | Comprehensive intervention on blood pressure control in a primary care setting, with a focus on lifestyle guidance | SBP, DBP | Completed
Dr. Lena Holm Sweden (Karolinksa Institutet) | 141 | Group seminars and motivational interviewing to change lifestyle factors, including PA and diet, in patients with high blood pressure | BP, PA, diet, BMI, abdominal circumference | Completed
Dr. Theodore Kotchen Medical College of Wisconsin | 120 | Lifestyle counseling focusing on behavior change for diet and PA to reduce BP in patients with hypertension | SBP, DBP | Recruiting
Dr. Robert Ackermann Northwestern University | 92 | Group-based adaptation of DPP, delivered by DPP-trained YMCA staff in YMCA facilities | Weight loss, PA, diet | Completed
Dr. Devin Mann ADAPT Mt. Sinai Medical Center, Boston University | 80 | Use of electronic medical records to enhance lifestyle behavior change counseling in a primary care setting | PA, HbA1c | Recruiting
Dr. Kamlesh Khunti TRIMS UK (University of Leicester) | 80 | Group education program for individuals with diagnosable METS based on lifestyle changes (diet and increased PA) to decrease risk for diabetes or CVD | METS prevalence, FBG, HDL, BP, PA, Diet, QoL, Framingham risk score | Completed
Dr. Namratha Kandula Northwestern University | 60 | Heart disease prevention group sessions focusing on PA, diet, weight, and stress for adults with at least one CHD risk factor | PA, diet, SBP, DBP, lipids, weight | Recruiting
Dr. Marie-France Longlois Canada (Université de Sherbrooke) | 60 | Use of interdisciplinary treatment program, including nurse, endocrinologist, nutritionist, and psychologist to discuss diet, PA, and psychological and medication-related issues | METS, weight, diet intake, PA, QoL, cost effectiveness | Completed
Dr. Adam Bernstein FRESH Study The Cleveland Clinic | 27 | Diet instruction, PA, culinary education, and stress management for patients with prediabetes | Correlation between participation and health of participants | Completed

Abbreviations: BMI = body mass index; BP = blood pressure; CHD = coronary heart disease; CVD = cardiovascular disease; DBP = diastolic blood pressure; FBG = fasting blood glucose; HOMA-IR = homeostasis model assessment insulin resistance; HTN = hypertension; LDL = low-density lipoprotein; METS = metabolic syndrome; PA = physical activity; QALY = wuality-adjusted life years; QOL = quality of life; SBP = systolic blood pressure; TC = total cholesterol.