# Detailed Methods

## Literature Search Strategies

Databases searched
- MEDLINE
- Cochrane Database of Systematic Reviews (CDSR)
- Cochrane Central Register of Controlled Trials (CENTRAL)
- Database of Abstracts of Reviews of Effects (DARE)
- PsycInfo
- PubMed

Key
- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- adj# = adjacent within x number of words
- pt = publication type
- * = truncation
- md = methodology
- kw = keyword
- id = key phrase identifier
- hw = subject heading word
- up = update code

### Ovid Medline

Database: Ovid MEDLINE without Revisions <1996 to January Week 5 2013>, Ovid MEDLINE Daily Update <February 06, 2013>, Ovid MEDLINE In-Process & Other Non-Indexed Citations <February 06, 2013>

Search Strategy:

--------------------------------------------------------------------------------

1. Diet, Reducing/ (4116)
2. Diet, Fat-Restricted/ (2322)
3. Diet, Mediterranean/ (1170)
4. Diet, Sodium-Restricted/ (1671)
5. Diet, Carbohydrate-Restricted/ (658)
6. Caloric Restriction/ (3011)
7. Fruit/ (17529)
8. Vegetables/ (8398)
9. Diet Therapy/ (1386)
10. Food Habits/ (12503)
11. Exercise/ (49022)
12. Exercise Therapy/ (14088)
13. Motor Activity/ (42897)
14. Physical Fitness/ (12137)
15. Walking/ (15439)
16. (diet or dietary).ti. (50362)
17. (fruit$ or vegetable$).ti. (13806)
18. (exercise or physical activity).ti. (52839)
19. walking.ti. (6115)
20. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 (224973)
21. Counseling/ (14120)
22. Directive Counseling/ (975)
23. “Behavior-Therapy”/ (9261)
24. Cognitive Therapy/ (12320)
25. “Referral and Consultation”/ (28304)
26. Persuasive Communication/ (1910)
27. Social Control, Informal/ (1702)
28. Risk Reduction Behavior/ (5842)
29. Life Style/ (28852)
30. Motivation/ (27011)
31. Social Support/ (36654)
32. Feedback, Psychological/ (1895)
33. Self Efficacy/ (10309)
34. Health Knowledge, Attitudes, Practice/ (57028)
35. Health Behavior/ (25308)
36. Health Education/ (22824)
37. Health Promotion/ (36905)
38. Patient Education as Topic/ (45924)
39. counsel$.ti,ab. (43803)
40. advice.ti,ab. (21419)
41. (behavio$ adj (therap$ or chang$ or modification$)).ti,ab. (22790)
42. referral.ti,ab. (41636)
43. (life style or lifestyle).ti,ab. (40855)
44. motivation$.ti,ab. (32949)
45. health behavio$.ti,ab. (8461)
46. health education.ti,ab. (10316)
47. health promotion.ti,ab. (13023)
48. patient education.ti,ab. (7409)
49. nonpharmacologic intervention$.ti,ab. (412)
50. non pharmacologic intervention$.ti,ab. (79)
51. 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 (433088)
52. 20 and 51 (34659)
53. limit 52 to (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial) (5261)
54. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (155819)
55. Meta-Analysis as Topic/ (10422)
56. (control$ adj3 trial$).ti,ab. (109522)
57. random$.ti,ab. (498170)
58. clinical trial$.ti,ab. (152619)
59. 54 or 55 or 56 or 57 or 58 (699757)
60. 52 and 59 (6940)
61. 53 or 60 (8350)
62. limit 61 to “all child (0 to 18 years)” (2185)
63. limit 61 to “all adult (19 plus years)” (5666)
64. 62 not 63 (1164)
65. 61 not 64 (7186)
66. limit 65 to animals (153)
67. limit 65 to humans (6939)
68. 66 not 67 (46)
69. 65 not 68 (7140)
70. limit 69 to english language (6828)
71. limit 70 to yr=“2009 - 2013” (2780)
72. (harm or harms or harmful or harmed).ti,ab. (43331)
73. (risky behavior$ or risky behaviour$).ti,ab. (1462)
74. (adverse effects or mortality).fs. (937883)
75. Mortality/ (14354)
76. Morbidity/ (11716)
77. death/ (3972)
78. Athletic injuries/ (10205)
79. Malnutrition/ (5670)
80. nutritional defici$.ti,ab. (2107)
81. (death or deaths).ti,ab. (355179)
82. fracture$.ti,ab,hw. (110433)
83. 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 (1355651)
84. 52 and 83 (4148)
85. case-control studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ (756491)
86. case control$.ti,ab. (57859)
87. cohort.ti,ab. (184566)
88. longitudinal.ti,ab. (92373)
89. (follow-up or followup).ti,ab. (423455)
90. prospective$.ti,ab. (311455)
91. (comparison group$ or CG$).ti,ab. (200550)
92. observational.ti,ab. (58624)
93. retrospective studies/ (347399)
94. retrospective$.ti,ab. (279868)
95. database$.ti,ab. (153517)
96. nonrandomi$.ti,ab. (6428)
97. population$.ti,ab. (721935)
98. 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 (2204688)
99. 84 and 98 (2060)
100. limit 99 to “all child (0 to 18 years)” (355)
101. limit 99 to “all adult (19 plus years)” (1484)
102. 100 not 101 (128)
103. 99 not 102 (1932)
104. limit 103 to animals (69)
105. limit 103 to humans (1901)
106. 104 not 105 (10)
107. 103 not 106 (1922)
108. limit 107 to english language (1794)
109. 70 or 108 (8126)
110. limit 109 to yr=“2009 - 2013” (3260)
111. remove duplicates from 110 (3257)

### Cochrane Database of Systematic Reviews

#1 diet:ti from 2001 to 2013, in Cochrane Reviews (Reviews only) 15
#2 diets:ti from 2001 to 2013, in Cochrane Reviews (Reviews only) 15
#3 dietary:ti from 2001 to 2013, in Cochrane Reviews (Reviews only) 31
#4 exercis*:ti from 2001 to 2013, in Cochrane Reviews (Reviews only) 69
#5 “physical activity”:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 52
#6 fruit*:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 21
#7 vegetable*:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 17
#8 (#1 or #2 or #3 or #4 or #5 or #6 or #7) from 2001 to 2013, in Cochrane Reviews (Reviews only) 169
#9 Counsel*:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 154
#10 (Behavio* next therap*):ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 181
#11 (cognitive next therap*):ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 61
#12 advice:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 135
#13 (Behavio* next chang*):ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 134
#14 (Behavio* next modification*):ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 22
#15 Referral:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 45
#16 “life style”:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 12
#17 lifestyle:ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 72
#18 (nonpharmacologic next intervention*):ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 0
#19 (“non pharmacologic” next intervention*):ti,ab,kw from 2001 to 2013, in Cochrane Reviews (Reviews only) 4
#20 (#9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19) from 2001 to 2013, in Cochrane Reviews (Reviews only) 552
#21 (#8 and #20) from 2001 to 2013, in Cochrane Reviews (Reviews only) 53

### CENTRAL

#1 diet:ti from 2001 to 2013, in Trials 1816
#2 diets:ti from 2001 to 2013, in Trials 1816
#3 dietary:ti from 2001 to 2013, in Trials 1641
#4 exercis*:ti from 2001 to 2013, in Trials 6805
#5 “physical activity”:ti,ab,kw from 2001 to 2013, in Trials 3270
#6 fruit*:ti,ab,kw from 2001 to 2013, in Trials 1228
#7 vegetable*:ti,ab,kw from 2001 to 2013, in Trials 1115
#8 (#1 or #2 or #3 or #4 or #5 or #6 or #7) from 2001 to 2013, in Trials 13472
#9 Counsel*:ti,ab,kw from 2001 to 2013, in Trials 3856
#10 (Behavio* next therap*):ti,ab,kw from 2001 to 2013, in Trials 3394
#11 (cognitive next therap*):ti,ab,kw from 2001 to 2013, in Trials 3158
#12 advice:ti,ab,kw from 2001 to 2013, in Trials 1390
#13 (Behavio* next chang*):ti,ab,kw from 2001 to 2013, in Trials 952
#14 (Behavio* next modification*):ti,ab,kw from 2001 to 2013, in Trials 169
#15 Referral:ti,ab,kw from 2001 to 2013, in Trials 2235
#16 “life style”:ti,ab,kw from 2001 to 2013, in Trials 1286
#17 lifestyle:ti,ab,kw from 2001 to 2013, in Trials 2224
#18 (nonpharmacologic next intervention*):ti,ab,kw from 2001 to 2013, in Trials 23
#19 (“non pharmacologic” next intervention*):ti,ab,kw from 2001 to 2013, in Trials 9
#20 (#9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19) from 2001 to 2013, in Trials 14027
#21 (#8 and #20) from 2001 to 2013, in Trials 2224

### DARE (via CRD)

1. (diet*) OR (fruit*) OR (vegetable*) IN DARE WHERE PD FROM 01/01/2009 TO 02/07/2013
2. (physical adj activity) OR (exercise*) OR (walking) IN DARE WHERE PD FROM 01/01/2009 TO 02/07/2013
3. #1 OR #2
4. (counsel*) OR (advice) OR (advise*) OR (behavio* NEAR chang*) OR (behavio* NEAR modif*) IN DARE WHERE PD FROM 01/01/2009 TO 02/07/2013
5. (lifestyle) OR (life ADJ style) OR (behavio* NEAR intervention*) OR (behavio* NEAR therap*) OR (cognitive NEAR therap*) OR (referral) IN DARE WHERE PD FROM 01/01/2009 TO 02/07/2013
6. #4 OR #5
7. #3 AND #6

PsycINFO <1806 to January Week 5 2013>

Search Strategy:

--------------------------------------------------------------------------------

1. Diets/ (8146)
2. Dietary Restraint/ (1236)
3. Eating Behavior/ (6300)
4. fruit$.ti,ab,id,hw. (11022)
5. vegetable$.ti,ab,id,hw. (2806)
6. Exercise/ (13063)
7. Physical Activity/ (7903)
8. Aerobic Exercise/ (1012)
9. Walking/ (2858)
10. or/1-9 (45307)
11. behavior therapy/ (11986)
12. cognitive behavior therapy/ (9346)
13. cognitive therapy/ (11261)
14. Cognitive Techniques/ (1461)
15. Behavior Modification/ (9825)
16. Behavior Change/ (8714)
17. Lifestyle Changes/ (788)
18. Lifestyle/ (6480)
19. Persuasive Communication/ (4312)
20. Motivation/ (33531)
21. Motivational Interviewing/ (968)
22. Self Efficacy/ (13055)
23. Health Knowledge/ (4845)
24. Health Behavior/ (14164)
25. Health Education/ (8945)
26. Health Promotion/ (12642)
27. Client Education/ (2813)
28. counseling/ (17861)
29. counseling.id. (37498)
30. counselling.id. (720)
31. advice.ti,ab,id,hw. (13481)
32. or/11-31 (189067)
33. 10 and 32 (8659)
34. controlled trial$.ti,ab,id,hw. (17354)
35. clinical trial$.ti,ab,id,hw. (20489)
36. random$.ti,ab,id,hw. (116082)
37. treatment outcome clinical trial.md. (23389)
38. or/34-37 (139067)
39. 33 and 38 (1573)
40. (harm or harms or harmful or harmed).ti,ab,id,hw. (24081)
41. (risky behavior$ or risky behaviour$).ti,ab,id,hw. (1922)
42. adverse effect$.ti,ab,id,hw. (9522)
43. mortality.ti,ab,id,hw. (22585)
44. morbidity.ti,ab,id,hw. (14902)
45. death.ti,ab,id,hw. (60424)
46. Nutritional Defici$.ti,ab,id,hw. (2290)
47. fracture$.ti,ab,id,hw. (2671)
48. cardiovascular.ti,ab,id,hw. (21923)
49. injur$.ti,ab,id,hw. (56183)
50. or/40-49 (187313)
51. 33 and 50 (837)
52. case control$.ti,ab,id,hw. (5692)
53. cohort.ti,ab,id,hw. (30010)
54. longitudinal.ti,ab,id,hw. (68065)
55. (follow-up or followup).ti,ab,id,hw. (79721)
56. prospective$.ti,ab,id,hw. (38228)
57. (comparison group$ or CG$).ti,ab,id,hw. (60433)
58. observational.ti,ab,id,hw. (14926)
59. retrospective$.ti,ab,id,hw. (23785)
60. database$.ti,ab,id,hw. (3148452)
61. nonrandomi$.ti,ab,id,hw. (537)
62. population$.ti,ab,id,hw. (216217)
63. or/52-62 (3154437)
64. 51 and 63 (829)
65. 39 or 64 (2243)
66. limit 65 to (100 childhood <birth to age 12 yrs> or 120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>) (361)
67. limit 65 to (“300 adulthood <age 18 yrs and older>” or 320 young adulthood <age 18 to 29 yrs> or 340 thirties <age 30 to 39 yrs> or 360 middle age <age 40 to 64 yrs> or “380 aged <age 65 yrs and older>” or “390 very old <age 85 yrs and older>”) (1607)
68. 66 not 67 (228)
69. 65 not 68 (2015)
70. limit 69 to english language (1985)
71. limit 70 to yr=“2001 - 2013” (1634)
72. (200907$ or 200908$ or 200909$ or 20091$ or 2010$ or 2011$ or 2012$ or 2013$).up. (696356)
73. 71 and 72 (780)

### PubMed, publisher-supplied

#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #23 AND #24 AND publisher[sb] Filters: English
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #23 AND #24 AND publisher[sb]
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #23 AND #24
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search trial[tiab] OR trials[tiab] OR random*[tiab] OR metaanaly*[tiab] OR “meta analysis”[tiab] OR “meta analyses”[tiab] OR “meta analytic”[tiab] OR systematic[tiab]
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND #22
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #x00023;6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search coronary[ti] OR cardiovascular[ti] OR hypertension[ti] OR “blood pressure”[ti]
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “patient education” [tiab]
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health promotion” [tiab]
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health education” [tiab]
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health behaviours” [tiab]
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health behaviour” [tiab]
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health behaviors” [tiab]
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “health behavior” [tiab]
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search motivation* [tiab]
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “life style”[tiab] OR lifestyle[tiab]
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search referral[tiab]
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search behavio*[tiab] AND modification*[tiab]
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search behavio*[tiab] AND change[tiab]
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search behavio*[tiab] AND therapy[tiab]
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search advice[tiab]
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search counsel*[tiab]
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 OR #2 OR #3 OR #4
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search walking[ti]
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search exercise[ti] OR “physical activity”[ti]
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search fruit*[ti] OR vegetable*[ti]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search diet[ti] OR dietary[ti]

Appendix A Figure 1 Literature Flow Diagram

Figure 4 is a flow chart that summarizes the search and selection of articles. There were 11,398 citations identified by searching MEDLINE, PsycInfo, Cochrane Center Register of Controlled Trials (CCRCT), and PubMed. An additional 498 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 7,218 unique citations were screened at the title/abstract stage. The full-text of 553 citations were examined for inclusion for one or more of the four Key Questions. The following number of article were included for Key Question 1 (k=16), Key Question 2 (k=71), Key Question 3 (k=61), and Key Question 4 (k=10). Reasons for excluding the other articles are available in Appendix C.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Condition definition | Healthy diet is one designed to improve or maintain optimal health, which includes:; - Appropriate energy (calorie) content; - Balance of fats (consumption of mono and poly unsaturated fats, omega-3 fats, avoidance of excess saturated fat, avoidance of transfat); - Fruits and vegetables; - Legumes; - Lean proteins; - Non- or low-fat dairy; - Balance of carbohydrates (consumption of whole grain and fiber, avoidance of excess refined carbohydrates, including excess sweetened beverages); - Balance of sodium (avoidance of excess sodium); Physical activity may involve either:; - Aerobic activities that involve repeated use of large muscles, such as walking, cycling, and swimming; - Resistance training designed to improve physical strength | Aspects of a healthy diet that are out of scope include:; - Dietary calcium and other vitamin, micronutrient, and antioxidant supplementation; - Alcohol moderation; Aspects of physical activity that are out of scope include:; - Balance; - Flexibility; - Gait; - Sedentary behaviors
Populations | Adults, at least 50% of whom have known CVD risk factors, including hypertension, metabolic syndrome, or impaired fasting glucose, such that >50% of the population is taking medication; mean systolic blood pressure of >140 mm Hg, diastolic blood pressure of >90 mm Hg, LDL cholesterol of >160 mg/dL or total cholesterol >200 mg/dL; or trial inclusion criteria specifies that population has one or more CVD risk factors | - Children and adolescents; - Parents (if intended behavior change is directed toward children); - Persons with any acute disease (other than hypertension or dyslipidemia); - Persons with known CVD or diabetes mellitus, such that >50% of participants have known CVD, severe chronic kidney disease, or diabetes; - Pregnant women with gestational diabetes; - Persons in institutions; - Persons with severe and persistent mental illness; - Persons with cognitive impairment
Settings | - Primary care (including obstetrics/gynecology, internal medicine, family practice, military health clinics) or otherwise generalizable to primary care; - Trials conducted in countries listed as “high” on the Human Development Index | Settings not generalizable to primary care (e.g., inpatient hospital units, emergency departments, nursing homes and other institutionalized settings, school-based programs, occupational settings, and other community-based settings); dental clinics
Interventions | - Any behaviorally-based counseling intervention alone or as part of a larger multicomponent intervention on healthy diet and nutrition, physical activity, or both, including ≥1 of the following elements: assessment with feedback, advice, collaborative goal setting, assistance, or arranging further contacts; - Either conducted in a primary care setting or judged to be feasible in primary care: 1) involves individual-level identification of being a patient or in need of intervention; 2) usually involves primary care physicians, other physicians, nurses, nurse practitioners, physician assistants, or other clinical staff (i.e., nutritionists, dieticians, physiotherapists, health educators), or the intervention will be seen as connected to the health care system by the participant; - Or must be primary care referable, such that it is available for referral in most communities; - Limited guided physical activity (i.e., 1 to 2 sessions) or provision of food samples allowed if intention is to teach or demonstrate healthy lifestyle principles; - Optional or access to guided physical activity or exercises classes allowed | - Noncounseling interventions (e.g., use of incentives, supervised exercise with the goal of assessing effects of exercise); - Interventions providing controlled diets; - Counseling interventions aimed at weight loss or weight maintenance, falls prevention, depression, cognitive functioning, or disease prevention other than CVD/diabetes mellitus; - Prenatal or postnatal dietary counseling; - Counseling interventions that are primarily community, nonreferral (e.g., occupational/ worksite or school-based); social marketing (e.g., media campaigns); - Policy (e.g., local or state public/health policy); - Interventions focused exclusively on reducing sedentary behavior (e.g., reduced television or screen time); - Interventions that use yoga or tai chi
Comparisons | - No intervention (e.g., wait-list control, usual care), minimal intervention (e.g., pamphlets, 1 annual session presenting information similar to usual care in a primary care setting), or attention control (e.g., similar format and intensity intervention on a different content area); - CG can receive 1 visit annually (limited to 45–60 min) or 2–3 brief sessions annually (limited to 15 min each), but no personalized prescription based on standardized assessment. CG may receive generic print materials twice yearly, but a more extensive print-based workbook would be considered comparative effectiveness and therefore excluded. CGs that received limited feedback on assessments were included | - Comparative effectiveness trials without a control (as defined above); - Physical activity only: studies in which the CG is instructed not to exercise
Outcomes | - KQ 1: Distal health outcomes (i.e., morbidity related to CVD, mortality); - KQ 2: Intermediate outcomes (i.e., blood pressure, hypertension, total cholesterol, LDL cholesterol or ratio of total/HDL cholesterol, serum fasting glucose or glucose tolerance, hemoglobin A1c, diabetes, weight, body mass index, hyperlipidemia); - KQ 3: Behavioral outcomes (i.e., physical activity, dietary intake or dietary patterns), self-reported or objectively measured; - KQ 4: Adverse outcomes, including any harms requiring medical attention (e.g., nutritional deficiencies, musculoskeletal injuries, cardiovascular events) | - Knowledge, attitudes, self-efficacy, functioning, quality of life; - Physical activity only: studies limited to balance or flexibility outcomes; - Less than 6 months or 60% followup
Study Designs | - Fair- to good-quality studies; - KQs 1–3: Systematic reviews, RCTs, CCTs (RCTs only before 2001); - KQ 4: Systematic reviews, RCTs, CCTs, comparative cohorts, population-based case-control studies | - Poor-quality studies; - KQs 1–3: Any observational studies; - KQ 4: Ecological studies, case-series, case reports
Publication Date | Trials published from 1990 to present | Trials whose primary results were published before 1990, in which the interventions were generally conducted in the 1970s

Abbreviations: CCT = controlled clinical trial; CVD =cardiovascular disease; HDL = high-density lipoprotein; KQ = key question; LDL = low-density lipoprotein; RCT = randomized, controlled trial.

Appendix A Table 2 Quality Assessment Criteria

Design | USPSTF Quality Rating Criteria60 | NICE Methodology Checklists61
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance, especially for systematic reviews | - Study addresses an appropriate and clearly focused question; - Methodology is described; - Literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Randomized, controlled trials | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes are considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment method is used; - Subjects and investigators are kept blind about treatment allocation; - Treatment and CGs are similar at the start of the trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of individuals or clusters recruited into each treatment arm of the study that dropped out before the study was completed is reported; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes are considered | - Study addresses an appropriate and clearly focused question; - Two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many of the people asked to take part did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each treatment arm of the study that dropped out before the study was completed is reported; - Comparison is made between full participants and those lost to followup, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is made blind to exposure status; - When blinding is not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided