# REFERENCES

1 Hutcheon JA, Lisonkova S, Joseph KS. Epidemiology of pre-eclampsia and the other hypertensive disorders of pregnancy. Best Pract Res Clin Obstet Gynaecol. 2011;25(4):391-403. [pmid: 21333604].
2 Trogstad L, Magnus P, Stoltenberg C. Pre-eclampsia: risk factors and causal models. Best Pract Res Clin Obstet Gynaecol. 2011;25(3):329-42. [pmid: 21349772].
3 Steegers EA, von Dadelszen P, Duvekot JJ, et al. Pre-eclampsia. Lancet. 2010;376(9741):631-44. [pmid: 20598363].
4 American College of Obstetricians and Gynecologists. ACOG practice bulletin. Diagnosis and management of preeclampsia and eclampsia. Number 33, January 2002. Obstet Gynecol. 2002;99(1):159-67. [pmid: 16175681].
5 Lazdam M, de la Horra A, Diesch J, et al. Unique blood pressure characteristics in mother and offspring after early onset preeclampsia. Hypertension. 2012;60(5):1338-45. [pmid: 23045462].
6 Huppertz B. Placental origins of preeclampsia: challenging the current hypothesis. Hypertension. 2008;51(4):970-5. [pmid: 18259009].
7 Ghulmiyyah L, Sibai B. Maternal mortality from preeclampsia/eclampsia. Semin Perinatol. 2012;36(1):56-9. [pmid: 22280867].
8 Berg CJ, Callaghan WM, Syverson C, et al. Pregnancy-related mortality in the United States, 1998 to 2005. Obstet Gynecol. 2010;116(6):1302-9. [pmid: 21099595].
9 MacKay AP, Berg CJ, Atrash HK. Pregnancy-related mortality from preeclampsia and eclampsia. Obstet Gynecol. 2001;97(4):533-8. [pmid: 11275024].
10 Waterstone M, Bewley S, Wolfe C. Incidence and predictors of severe obstetric morbidity: case-control study. BMJ. 2001;322(7294):1089-93. [pmid: 11337436].
11 Kuklina EV, Ayala C, Callaghan WM. Hypertensive disorders and severe obstetric morbidity in the United States. Obstet Gynecol. 2009;113(6):1299-306. [pmid: 19461426].
12 Callaghan WM, Creanga AA, Kuklina EV. Severe maternal morbidity among delivery and postpartum hospitalizations in the United States. Obstet Gynecol. 2012;120(5):1029-36. [pmid: 23090519].
13 Lain KY, Roberts JM. Contemporary concepts of the pathogenesis and management of preeclampsia. JAMA. 2002;287(24):3183-6. [pmid: 12076198].
14 Fisher J, Astbury J, Smith A. Adverse psychological impact of operative obstetric interventions: a prospective longitudinal study. Aust N Z J Psychiatry. 1997;31(5):728-38. [pmid: 9400879].
15 Soet JE, Brack GA, DiIorio C. Prevalence and predictors of women's experience of psychological trauma during childbirth. Birth. 2003;30(1):36-46. [pmid: 12581038].
16 Harper MA, Espeland MA, Mayer R, et al. Racial disparity in pregnancy-related mortality following a live birth outcome. Ann Epidemiol. 2004;14(4):274-9. [pmid: 15066607].
17 Martin JA, Hamilton BE, Ventura SJ, et al. Births: final data for 2009. Natl Vital Stat Rep. 2011;60(1):1-70. [pmid: 22670489].
18 Tucker MJ, Berg CJ, Callaghan WM, et al. The Black-White disparity in pregnancy-related mortality from 5 conditions: differences in prevalence and case-fatality rates. Am J Public Health. 2007;97(2):247-51. [pmid: 17194867].
19 Bateman BT, Shaw KM, Kuklina EV, et al. Hypertension in women of reproductive age in the United States: NHANES 1999-2008. PLoS One. 2012;7(4):e36171. [pmid: 22558371].
20 Healy AJ, Malone FD, Sullivan LM, et al. Early access to prenatal care: implications for racial disparity in perinatal mortality. Obstet Gynecol. 2006;107(3):625-31. [pmid: 16507934].
21 Mbah AK, Alio AP, Marty PJ, et al. Recurrent versus isolated pre-eclampsia and risk of feto-infant morbidity outcomes: racial/ethnic disparity. Eur J Obstet Gynecol Reprod Biol. 2011;156(1):23-8. [pmid: 21316142].
22 Egbor M, Ansari T, Morris N, et al. Morphometric placental villous and vascular abnormalities in early- and late-onset pre-eclampsia with and without fetal growth restriction. BJOG. 2006;113(5):580-9. [pmid: 16579806].
23 Esplin MS, Fausett MB, Fraser A, et al. Paternal and maternal components of the predisposition to preeclampsia. N Engl J Med. 2001;344(12):867-72. [pmid: 11259719].
24 McDonald SD, Malinowski A, Zhou Q, et al. Cardiovascular sequelae of preeclampsia/eclampsia: a systematic review and meta-analyses. Am Heart J. 2008;156(5):918-30. [pmid: 19061708].
25 Skjaerven R, Wilcox AJ, Klungsoyr K, et al. Cardiovascular mortality after pre-eclampsia in one child mothers: prospective, population based cohort study. BMJ. 2012;345:e7677. [pmid: 23186909].
26 Davis EF, Lazdam M, Lewandowski AJ, et al. Cardiovascular risk factors in children and young adults born to preeclamptic pregnancies: a systematic review. Pediatrics. 2012;129(6):e1552-e1561. [pmid: 22614768].
27 Roberts JM, Bell MJ. If we know so much about preeclampsia, why haven't we cured the disease?. J Reprod Immunol. 2013;99(1-2):1-9. [pmid: 23890710].
28 Cnossen JS, Morris RK, ter Riet G, et al. Use of uterine artery Doppler ultrasonography to predict pre-eclampsia and intrauterine growth restriction: a systematic review and bivariable meta-analysis. CMAJ. 2008;178(6):701-11. [pmid: 18332385].
29 Stepan H, Unversucht A, Wessel N, et al. Predictive value of maternal angiogenic factors in second trimester pregnancies with abnormal uterine perfusion. Hypertension. 2007;49(4):818-24. [pmid: 17261644].
30 Thangaratinam S, Rogozinska E, Jolly K, et al. Effects of interventions in pregnancy on maternal weight and obstetric outcomes: meta-analysis of randomised evidence. BMJ. 2012;344:e2088. [pmid: 22596383].
31 Grill S, Rusterholz C, Zanetti-Dallenbach R, et al. Potential markers of preeclampsia—a review. Reprod Biol Endocrinol. 2009;7:70. [pmid: 19602262].
32 Duckitt K, Harrington D. Risk factors for pre-eclampsia at antenatal booking: systematic review of controlled studies. BMJ. 2005;330(7491):565. [pmid: 15743856].
33 Rogvi R, Forman JL, Damm P, et al. Women born preterm or with inappropriate weight for gestational age are at risk of subsequent gestational diabetes and pre-eclampsia. PLoS One. 2012;7(3):e34001. [pmid: 22479500].
34 Villamor E, Cnattingius S. Interpregnancy weight change and risk of adverse pregnancy outcomes: a population-based study. Lancet. 2006;368(9542):1164-70. [pmid: 17011943].
35 Adeney KL, Williams MA. Migraine headaches and preeclampsia: an epidemiologic review. Headache. 2006;46(5):794-803. [pmid: 16643583].
36 Bushnell CD, Jamison M, James AH. Migraines during pregnancy linked to stroke and vascular diseases: US population based case-control study. BMJ. 2009;338:b664. [pmid: 19278973].
37 Poon LC, Kametas NA, Chelemen T, et al. Maternal risk factors for hypertensive disorders in pregnancy: a multivariate approach. J Hum Hypertens. 2010;24(2):104-10. [pmid: 19516271].
38 Audibert F, Boucoiran I, An N, et al. Screening for preeclampsia using first-trimester serum markers and uterine artery Doppler in nulliparous women. Am J Obstet Gynecol. 2010;203(4):383-8. [pmid: 20691410].
39 Park FJ, Leung CH, Poon LC, et al. Clinical evaluation of a first trimester algorithm predicting the risk of hypertensive disease of pregnancy. Aust N Z J Obstet Gynaecol. 2013;53(6):532-9. [pmid: 23919594].
40 North RA, McCowan LM, Dekker GA, et al. Clinical risk prediction for pre-eclampsia in nulliparous women: development of model in international prospective cohort. BMJ. 2011;342:d1875. [pmid: 21474517].
41 Chappell LC, Seed P, Enye S, et al. Clinical and geographical variation in prophylactic and therapeutic treatments for pre-eclampsia in the UK. BJOG. 2010;117(6):695-700. [pmid: 20175876].
42 Heilmann L, Wacker J, Rath W. Diagnosis and treatment of hypertensive disorders during pregnancy in Germany: results of a survey in German obstetric clinics. Geburtshilfe und Frauenheilkunde. 2004;64(6):589-99.
43 Khedun SM, Moodley J, Naicker T, et al. How do South African obstetricians manage hypertensive disorders of pregnancy—a survey. S Afr Med J. 2000;90(2):156-60. [pmid: 10745971].
44 Wide-Swensson D, Montal S, Ingemarsson I. How Swedish obstetricians manage hypertensive disorders in pregnancy. A questionnaire study. Acta Obstet Gynecol Scand. 1994;73(8):619-24. [pmid: 7941985].
45 Redman CW. Hypertension in pregnancy: the NICE guidelines. Heart. 2011;97(23):1967-9. [pmid: 21990386].
46 World Health Organization. WHO Recommendations for Prevention and Treatment of Pre-Eclampsia and Eclampsia. World Health Organization. 2011. [pmid: 23741776].
47 Duley L, Henderson-Smart DJ, Meher S, et al. Antiplatelet agents for preventing pre-eclampsia and its complications. Cochrane Database Syst Rev. 2007;(2):CD004659. [pmid: 17443552].
48 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
49 Askie LM, Duley L, Henderson-Smart DJ, et al. Antiplatelet agents for preventing pre-eclampsia and its complications. Lancet. 2007;369(9575):1791-8. [pmid: 17512048].
50 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
51 National Institute for Health and Clinical Excellence. The Guidelines Manual. London. National Institute for Health and Clinical Excellence. 2006.
52 Bradburn MJ, Deeks JJ, Altman DG. Metan-a command for meta-analysis in Stata. Sterne JA, editor. Meta-Analysis in Stata: An Updated Collection From the Stata Journal. College Station, TX. Stata Press. 1998:3-28.
53 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
54 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1187-97. [pmid: 21477993].
55 Borenstein M, Hedges LV, Higgins JPT, et al. Introduction to Meta-Analysis. West Sussex, England. Wiley & Sons. 2009.
56 Higgins JP, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. (updated March 2011). Cochrane Collaboration. 2011. Accessed at www.cochrane-handbook.org on 24 March 2014.
57 Caritis S, Sibai B, Hauth J, et al. Low-dose aspirin to prevent preeclampsia in women at high risk. N Engl J Med. 1998;338(11):701-5. [pmid: 9494145].
58 CLASP: a randomised trial of low-dose aspirin for the prevention and treatment of pre-eclampsia. Lancet. 1994;343(8898):619. [pmid: 7906809].
59 Ayala DE, Ucieda R, Hermida RC. Chronotherapy with low-dose aspirin for prevention of complications in pregnancy. Chronobiol Int. 2013;30(1-2):260-79. [pmid: 23004922].
60 Benigni A, Gregorini G, Frusca T, et al. Effect of low-dose aspirin on fetal and maternal generation of thromboxane by platelets in women at risk for pregnancy-induced hypertension. N Engl J Med. 1989;321(6):357-62. [pmid: 2664523].
61 Caspi E, Raziel A, Sherman D, et al. Prevention of pregnancy-induced hypertension in twins by early administration of low-dose aspirin: a preliminary report. Am J Reprod Immunol. 1994;31(1):19-24. [pmid: 8166943].
62 Gallery ED, Ross MR, Hawkins M, et al. Low-dose aspirin in high-risk pregnancy?. Hypertension Pregnancy. 1997;16(2):229-38.
63 Grab D, Paulus WE, Erdmann M, et al. Effects of low-dose aspirin on uterine and fetal blood flow during pregnancy: results of a randomized, placebo-controlled, double-blind trial. Ultrasound Obstet Gynecol. 2000;15(1):19-27. [pmid: 10776008].
64 Hermida RC, Ayala DE, Iglesias M, et al. Time-dependent effects of low-dose aspirin administration on blood pressure in pregnant women. Hypertension. 1997;30(3 Pt 2):589-95. [pmid: 9322987].
65 McParland P, Pearce JM, Chamberlain GV. Doppler ultrasound and aspirin in recognition and prevention of pregnancy-induced hypertension. Lancet. 1990;335(8705):1552-5. [pmid: 1972487].
66 Schiff E, Peleg E, Goldenberg M, et al. The use of aspirin to prevent pregnancy-induced hypertension and lower the ratio of thromboxane A2 to prostacyclin in relatively high risk pregnancies. N Engl J Med. 1989;321(6):351-6. [pmid: 2664522].
67 Vainio M, Kujansuu E, Iso-Mustajarvi M, et al. Low dose acetylsalicylic acid in prevention of pregnancy-induced hypertension and intrauterine growth retardation in women with bilateral uterine artery notches. BJOG. 2002;109(2):161-7. [pmid: 11888098].
68 Viinikka L, Hartikainen-Sorri AL, Lumme R, et al. Low dose aspirin in hypertensive pregnant women: effect on pregnancy outcome and prostacyclin-thromboxane balance in mother and newborn. Br J Obstet Gynaecol. 1993;100(9):809-15. [pmid: 8217999].
69 Villa P, Kajantie E, Raikkonen K, et al. Aspirin in the prevention of pre-eclampsia in high-risk women: a randomised placebo-controlled PREDO trial and a meta-analysis of randomised trials. BJOG. 2013;120(1):64-74. [pmid: 23126307].
70 Wallenburg HC, Dekker GA, Makovitz JW, et al. Low-dose aspirin prevents pregnancy-induced hypertension and pre-eclampsia in angiotensin-sensitive primigravidae. Lancet. 1986;1(8471):1-3. [pmid: 2867260].
71 Yu CK, Papageorghiou AT, Parra M, et al. Randomized controlled trial using low-dose aspirin in the prevention of pre-eclampsia in women with abnormal uterine artery Doppler at 23 weeks' gestation. Ultrasound Obstet Gynecol. 2003;22(3):233-9. [pmid: 12942493].
72 Sibai BM, Caritis SN, Thom E, et al. Prevention of preeclampsia with low-dose aspirin in healthy, nulliparous pregnant women. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. N Engl J Med. 1993;329(17):1213-8. [pmid: 8413387].
73 Hauth JC, Goldenberg RL, Parker CR Jr, et al. Low-dose aspirin therapy to prevent preeclampsia. Am J Obstet Gynecol. 1993;168(4):1083-91. [pmid: 8475955].
74 Subtil D, Goeusse P, Puech F, et al. Aspirin (100 mg) used for prevention of pre-eclampsia in nulliparous women: the Essai Regional Aspirine Mere-Enfant study (Part 1). BJOG. 2003;110(5):475-84. [pmid: 12742332].
75 Rotchell YE, Cruickshank JK, Gay MP, et al. Barbados Low Dose Aspirin Study in Pregnancy (BLASP): a randomised trial for the prevention of pre-eclampsia and its complications. Br J Obstet Gynaecol. 1998;105(3):286-92. [pmid: 9532988].
76 Davies NJ, Gazvani MR, Farquharson RG, et al. Low-dose aspirin in the prevention of hypertensive disorders of pregnancy in relatively low-risk nulliparous women. Hypertension Pregnancy. 1995;14(1):49-55.
77 Jensen MS, Rebordosa C, Thulstrup AM, et al. Maternal use of acetaminophen, ibuprofen, and acetylsalicylic acid during pregnancy and risk of cryptorchidism. Epidemiology. 2010;21(6):779-85. [pmid: 20805751].
78 Keim SA, Klebanoff MA. Aspirin use and miscarriage risk. Epidemiology. 2006;17(4):435-9. [pmid: 16755260].
79 Newnham JP, Godfrey M, Walters BJ, et al. Low dose aspirin for the treatment of fetal growth restriction: a randomized controlled trial. Aust N Z J Obstet Gynaecol. 1995;35(4):370-4. [pmid: 8717556].
80 Leslie GI, Gallery ED, Arnold JD, et al. Neonatal outcome in a randomized, controlled trial of low-dose aspirin in high-risk pregnancies. J Paediatr Child Health. 1995;31(6):549-52. [pmid: 8924310].
81 Bujold E, Roberge S, Lacasse Y, et al. Prevention of preeclampsia and intrauterine growth restriction with aspirin started in early pregnancy: a meta-analysis. Obstet Gynecol. 2010;116(2 Pt 1):402-14. [pmid: 20664402].
82 Wen SW, Smith G, Yang Q, et al. Epidemiology of preterm birth and neonatal outcome. Semin Fetal Neonatal Med. 2004;9(6):429-35. [pmid: 15691780].
83 Saigal S, Doyle LW. An overview of mortality and sequelae of preterm birth from infancy to adulthood. Lancet. 2008;371(9608):261-9. [pmid: 18207020].
84 McIntire DD, Bloom SL, Casey BM, et al. Birth weight in relation to morbidity and mortality among newborn infants. N Engl J Med. 1999;340(16):1234-8. [pmid: 10210706].
85 Crump C, Sundquist K, Sundquist J, et al. Gestational age at birth and mortality in young adulthood. JAMA. 2011;306(11):1233-40. [pmid: 21934056].
86 Malacrida C, Boulton T. The best laid plans? Women's choices, expectations and experiences in childbirth. Health (London). 2014;18(1):41-59. [pmid: 23426792].
87 Beck CT, Gable RK, Sakala C, et al. Postpartum depressive symptomatology: results from a two-stage US national survey. J Midwifery Womens Health. 2011;56(5):427-35. [pmid: 23181639].
88 Rowe-Murray HJ, Fisher JR. Operative intervention in delivery is associated with compromised early mother-infant interaction. BJOG. 2001;108(10):1068-75. [pmid: 11702839].
89 Rep A, Ganzevoort W, Bonsel GJ, et al. Psychosocial impact of early-onset hypertensive disorders and related complications in pregnancy. Am J Obstet Gynecol. 2007;197(2):158-6. [pmid: 17689633].
90 Poel YH, Swinkels P, de Vries JI. Psychological treatment of women with psychological complaints after pre-eclampsia. J Psychosom Obstet Gynaecol. 2009;30(1):65-72. [pmid: 19308785].
91 Hoedjes M, Berks D, Vogel I, et al. Poor health-related quality of life after severe preeclampsia. Birth. 2011;38(3):246-55. [pmid: 21884233].
92 Engelhard IM, van Rij M, Boullart I, et al. Posttraumatic stress disorder after pre-eclampsia: an exploratory study. Gen Hosp Psychiatry. 2002;24(4):260-4. [pmid: 12100837].
93 Gaugler-Senden IP, Duivenvoorden HJ, Filius A, et al. Maternal psychosocial outcome after early onset preeclampsia and preterm birth. J Matern Fetal Neonatal Med. 2012;25(3):272-6. [pmid: 21557690].
94 Valdiviezo C, Garovic VD, Ouyang P. Preeclampsia and hypertensive disease in pregnancy: their contributions to cardiovascular risk. Clin Cardiol. 2012;35(3):160-5. [pmid: 22389120].
95 Bellamy L, Casas JP, Hingorani AD, et al. Pre-eclampsia and risk of cardiovascular disease and cancer in later life: systematic review and meta-analysis. BMJ. 2007;335(7627):974. [pmid: 17975258].
96 Lykke JA, Langhoff-Roos J, Sibai BM, et al. Hypertensive pregnancy disorders and subsequent cardiovascular morbidity and type 2 diabetes mellitus in the mother. Hypertension. 2009;53(6):944-51. [pmid: 19433776].
97 Mongraw-Chaffin ML, Cirillo PM, Cohn BA. Preeclampsia and cardiovascular disease death: prospective evidence from the child health and development studies cohort. Hypertension. 2010;56(1):166-71. [pmid: 20516394].
98 Aukes AM, De Groot JC, Wiegman MJ, et al. Long-term cerebral imaging after pre-eclampsia. BJOG. 2012;119(9):1117-22. [pmid: 22703533].
99 Wiegman MJ, De Groot JC, Jansonius NM, et al. Long-term visual functioning after eclampsia. Obstet Gynecol. 2012;119(5):959-66. [pmid: 22525906].
100 Lo JO, Mission JF, Caughey AB. Hypertensive disease of pregnancy and maternal mortality. Curr Opin Obstet Gynecol. 2013;25(2):124-32. [pmid: 23403779].
101 Sibai B, Dekker G, Kupferminc M. Pre-eclampsia. Lancet. 2005;365(9461):785-99. [pmid: 15733721].
102 Goffinet F, Breart G, Uzan S. ECPPA: randomised trial of low dose aspirin for the prevention of maternal and fetal complications in high risk pregnant women. Br J Obstet Gynaecol. 1996;103(7):719-20. [pmid: 8688404].
103 Jaddoe VW, van Duijn CM, van der Heijden AJ, et al. The Generation R Study: design and cohort update until the age of 4 years. Eur J Epidemiol. 2008;23(12):801-11. [pmid: 19101808].
104 Varvarigou AA. Intrauterine growth restriction as a potential risk factor for disease onset in adulthood. J Pediatr Endocrinol Metab. 2010;23(3):215-24. [pmid: 20480719].
105 England L, Zhang J. Smoking and risk of preeclampsia: a systematic review. Front Biosci. 2007;12:2471-83. [pmid: 17127256].
106 CLASP Collaborative Group. Low dose aspirin in pregnancy and early childhood development: follow up of the Collaborative Low dose Aspirin study in Pregnancy. CLASP Collaborative Group. Br J Obstet Gynaecol. 1995;102(11):861-8. [pmid: 8534620].
107 Tikkanen M, Riihimaki O, Gissler M, et al. Decreasing incidence of placental abruption in Finland during 1980-2005. Acta Obstet Gynecol Scand. 2012;91(9):1046-52. [pmid: 22582999].
108 Tikkanen M, Gissler M, Metsaranta M, et al. Maternal deaths in Finland: focus on placental abruption. Acta Obstet Gynecol Scand. 2009;88(10):1124-7. [pmid: 19707898].
109 Ananth CV, Wilcox AJ. Placental abruption and perinatal mortality in the United States. Am J Epidemiol. 2001;153(4):332-7. [pmid: 11207150].
110 Tikkanen M, Nuutila M, Hiilesmaa V, et al. Clinical presentation and risk factors of placental abruption. Acta Obstet Gynecol Scand. 2006;85(6):700-5. [pmid: 16752262].
111 Ananth CV, Oyelese Y, Yeo L, et al. Placental abruption in the United States, 1979 through 2001: temporal trends and potential determinants. Am J Obstet Gynecol. 2005;192(1):191-8. [pmid: 15672024].
112 PubMed Health. Placenta Abruptio. Bethesda, MD. U.S. National Library of Medicine. 2012. Accessed at http://www.ncbi.nlm.nih.gov/pubmedhealth/PMH0001903/ on 24 March 2014.
113 Nakhai-Pour HR, Berard A. Major malformations after first-trimester exposure to aspirin and NSAIDs. Expert Rev Clin Pharmacol. 2008;1(5):605-16. [pmid: 24422733].
114 Coomarasamy A, Braunholtz D, Song F, et al. Individualising use of aspirin to prevent pre-eclampsia: a framework for clinical decision making. BJOG. 2003;110(10):882-8. [pmid: 14550356].
115 Hernandez RK, Werler MM, Romitti P, et al. Nonsteroidal antiinflammatory drug use among women and the risk of birth defects. Am J Obstet Gynecol. 2012;206(3):228. [pmid: 22196851].
116 Forest JC, Charland M, Masse J, et al. Candidate biochemical markers for screening of pre-eclampsia in early pregnancy. Clin Chem Lab Med. 2012;50(6):973-84. [pmid: 22706239].
117 Audibert F. Screening for pre-eclampsia: the quest for the Holy Grail?. Lancet. 2005;365(9468):1367-9. [pmid: 15836870].
118 Mace G, Cynober E, Carbonne B. Ultrasound markers for the detection of women at risk of developing pre-eclampsia. Clin Chem Lab Med. 2012;50(6):1009-14. [pmid: 22149747].
119 Zhong Y, Tuuli M, Odibo AO. First-trimester assessment of placenta function and the prediction of preeclampsia and intrauterine growth restriction. Prenat Diagn. 2010;30(4):293-308. [pmid: 20166149].
120 Kuc S, Wortelboer EJ, van Rijn BB, et al. Evaluation of 7 serum biomarkers and uterine artery Doppler ultrasound for first-trimester prediction of preeclampsia: a systematic review. Obstet Gynecol Surv. 2011;66(4):225-39. [pmid: 21756405].
121 Giguere Y, Charland M, Bujold E, et al. Combining biochemical and ultrasonographic markers in predicting preeclampsia: a systematic review. Clin Chem. 2010;56(3):361-75. [pmid: 20044446].
122 Tuuli MG, Odibo AO. First- and second-trimester screening for preeclampsia and intrauterine growth restriction. Clin Lab Med. 2010;30(3):727-46. [pmid: 20638585].
123 Leslie K, Thilaganathan B, Papageorghiou A. Early prediction and prevention of pre-eclampsia. Best Pract Res Clin Obstet Gynaecol. 2011;25(3):343-54. [pmid: 21376671].
124 Cuckle HS. Screening for pre-eclampsia—lessons from aneuploidy screening. Placenta. 2011;32(Suppl):S42-8. [pmid: 21257082].
125 Bujold E, Morency AM, Roberge S, et al. Acetylsalicylic acid for the prevention of preeclampsia and intra-uterine growth restriction in women with abnormal uterine artery Doppler: a systematic review and meta-analysis. J Obstet Gynaecol Can. 2009;31(9):818-26. [pmid: 19941706].
126 Roberge S, Giguere Y, Villa P, et al. Early administration of low-dose aspirin for the prevention of severe and mild preeclampsia: a systematic review and meta-analysis. Am J Perinatol. 2012;29(7):551-6. [pmid: 22495898].
127 Fox C, Khan KS, Coomarasamy A. How to interpret randomised trials of test-treatment combinations: a critical evaluation of research on uterine Doppler test to predict, and aspirin to prevent, pre-eclampsia. BJOG. 2010;117(7):801-8. [pmid: 20482537].
128 Stampalija T, Gyte GM, Alfirevic Z. Utero-placental Doppler ultrasound for improving pregnancy outcome. Cochrane Database Syst Rev. 2010;(9):CD008363. [pmid: 20824875].
129 Barton JR, Sibai BM. Prediction and prevention of recurrent preeclampsia. Obstet Gynecol. 2008;112(2 Pt 1):359-72. [pmid: 18669736].
130 Sibai BM, Ewell M, Levine RJ, et al. Risk factors associated with preeclampsia in healthy nulliparous women. The Calcium for Preeclampsia Prevention (CPEP) Study Group. Am J Obstet Gynecol. 1997;177(5):1003-10. [pmid: 9396883].
131 Simon E, Caille A, Perrotin F, et al. Mixing nulliparous and multiparous women in randomised controlled trials of preeclampsia prevention is debatable: evidence from a systematic review. PLoS One. 2013;8(6):e66677. [pmid: 23826112].
132 Stout MJ, Goetzinger KR, Tuuli MG, et al. First trimester serum analytes, maternal characteristics and ultrasound markers to predict pregnancies at risk for preterm birth. Placenta. 2013;34(1):14-9. [pmid: 23199792].
133 Myatt L, Clifton RG, Roberts JM, et al. First-trimester prediction of preeclampsia in nulliparous women at low risk. Obstet Gynecol. 2012;119(6):1234-42. [pmid: 22617589].
134 Myatt L, Clifton RG, Roberts JM, et al. The utility of uterine artery Doppler velocimetry in prediction of preeclampsia in a low-risk population. Obstet Gynecol. 2012;120(4):815-22. [pmid: 22996099].
135 Trivedi NA. A meta-analysis of low-dose aspirin for prevention of preeclampsia. J Postgrad Med. 2011;57(2):91-5. [pmid: 21654128].
136 Bordeaux BC, Qayyum R, Yanek LR, et al. Effect of obesity on platelet reactivity and response to low-dose aspirin. Prev Cardiol. 2010;13(2):56-62. [pmid: 20377806].
137 Conde-Agudelo A, Althabe F, Belizan JM, et al. Cigarette smoking during pregnancy and risk of preeclampsia: a systematic review. Am J Obstet Gynecol. 1999;181(4):1026-35. [pmid: 10521771].
138 Perni UC, Wikstrom AK, Cnattingius S, et al. Interpregnancy change in smoking habits and risk of preeclampsia: a population-based study. Am J Hypertens. 2012;25(3):372-8. [pmid: 22113171].
139 Engel SM, Janevic TM, Stein CR, et al. Maternal smoking, preeclampsia, and infant health outcomes in New York City, 1995-2003. Am J Epidemiol. 2009;169(1):33-40. [pmid: 19001134].
140 Wikstrom AK, Stephansson O, Cnattingius S. Tobacco use during pregnancy and preeclampsia risk: effects of cigarette smoking and snuff. Hypertension. 2010;55(5):1254-9. [pmid: 20231527].
141 Llurba E, Sanchez O, Dominguez C, et al. Smoking during pregnancy: changes in mid-gestation angiogenic factors in women at risk of developing preeclampsia according to uterine artery Doppler findings. Hypertens Pregnancy. 2013;32(1):50-9. [pmid: 22988942].
142 Maynard SE, Min JY, Merchan J, et al. Excess placental soluble fms-like tyrosine kinase 1 (sFlt1) may contribute to endothelial dysfunction, hypertension, and proteinuria in preeclampsia. J Clin Invest. 2003;111(5):649-58. [pmid: 12618519].
143 Levine RJ, Maynard SE, Qian C, et al. Circulating angiogenic factors and the risk of preeclampsia. N Engl J Med. 2004;350(7):672-83. [pmid: 14764923].
144 Jeyabalan A, McGonigal S, Gilmour C, et al. Circulating and placental endoglin concentrations in pregnancies complicated by intrauterine growth restriction and preeclampsia. Placenta. 2008;29(6):555-63. [pmid: 18462791].
145 Kahn SR, Almeida ND, McNamara H, et al. Smoking in preeclamptic women is associated with higher birthweight for gestational age and lower soluble fms-like tyrosine kinase-1 levels: a nested case control study. BMC Pregnancy Childbirth. 2011;11:91. [pmid: 22074109].
146 Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. How Tobacco Smoke Causes Disease: The Biology and Behavioral Basis for Smoking-Attributable Disease. Atlanta. Centers for Disease Control and Prevention. 2010. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK53017/ on 24 March 2014.
147 Parazzini F, Bortolus R, Chatenoud L, et al. Followup of children in the Italian Study of Aspirin in Pregnancy. Lancet. 1994;343(8907):1235. [pmid: 7513779].
148 Chauhan SP, Gupta LM, Hendrix NW, et al. Intrauterine growth restriction: comparison of American College of Obstetricians and Gynecologists practice bulletin with other national guidelines. Am J Obstet Gynecol. 2009;200(4):409-6. [pmid: 19217594].
149 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin Number 12: Intrauterine Growth Restriction. Washington, DC. American College of Gynecologists and Obstetricians. 2000.
150 BMJ Evidence Centre. Assessment of Proteinuria. 2013. Accessed at http://bestpractice.bmj.com/best-practice/monograph/875.html on June 10, 2013.
151 Facchinetti F, Allais G, Nappi RE, et al. Migraine is a risk factor for hypertensive disorders in pregnancy: a prospective cohort study. Cephalalgia. 2009;29(3):286-92. [pmid: 19220309].
152 Dombrowski MP. Asthma and pregnancy. Obstet Gynecol. 2006;108(3 Pt1):667-81. [pmid: 16946229].
153 Mendola P, Laughon SK, Mannisto TI, et al. Obstetric complications among US women with asthma. Am J Obstet Gynecol. 2013;208(2):127-8. [pmid: 23159695].
154 Czerwinski S, Gollero J, Qiu C, et al. Migraine-asthma comorbidity and risk of hypertensive disorders of pregnancy. J Pregnancy. 2012;2012:858097. [pmid: 22934185].