# DISCUSSION

## Overall Summary

We found evidence that prophylaxis with low-dose aspirin beginning after the first trimester of pregnancy is beneficial for perinatal health outcomes in women at elevated risk of preeclampsia (Table 6). Specifically, we found a modestly reduced risk of preterm birth and IUGR in this group of women. While available evidence suggests that there is a reduced risk of perinatal mortality, the CI crossed null. The risk of incorrectly accepting a null result for perinatal mortality, however, is high because of low power to detect differences for this outcome. Consistent with lower risk of preterm birth (spontaneous or induced before 37 weeks) and IUGR, we also identified a significant difference in birth weight, but the evidence for this outcome is less convincing.

Table 6 Summary of Evidence for Benefits and Harms of Low-Dose Aspirin for Prevention of Morbidity and Mortality From Preeclampsia

Key Question(s) | # of Studies (k) | Design | Major Limitations | Consistency | Applicability | Overall Evidence | Summary of Findings
KQ1. Is there evidence that aspirin reduces adverse health outcomes in women at increased risk for preeclampsia? KQ1a. Does low-dose aspirin reduce maternal morbidity or mortality? | Maternal mortality k=5 n=9,668 | RCT | Only 1 event in all studies combined; insufficient power to determine effect. | Cannot determine | Applicable to U.S. prenatal and hospital settings. | 2 good, 3 fair Overall: Insufficient | 1 maternal death recorded in the aspirin group of the largest study (CLASP), occurring 2 days after delivery from pulmonary embolus.
KQ1. Is there evidence that aspirin reduces adverse health outcomes in women at increased risk for preeclampsia? KQ1a. Does low-dose aspirin reduce maternal morbidity or mortality? | Eclampsia, HELLP, organ/system damage or failure k=3 n=9,474 | RCT | Insufficient power to determine effect, outcomes not often or consistently reported. | Cannot determine | Applicable to U.S. prenatal and hospital settings. | 2 good, 1 fair Overall: Insufficient | 7 aspirin-allocated and 7 placebo-allocated cases of eclampsia were reported in the largest study, and 1 case of eclampsia reported in the control group of 1 small study. There was 1 case of HELLP syndrome in a study of 121 subjects.
KQ1. Is there evidence that aspirin reduces adverse health outcomes in women at increased risk for preeclampsia? KQ1a. Does low-dose aspirin reduce maternal morbidity or mortality? | Cesarean delivery k=10 n=10,419 | RCT | Most studies did not distinguish between elective Cesarean delivery vs. Cesarean delivery during labor. | Low heterogeneity (I^2^ =24.9%; p=0.21). 7 out of 10 studies had results in the direction of reduced risk. | Good applicability. Studies all conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. | 6 good, 4 fair Overall: Good | No difference in the rate of Cesarean delivery was observed (pooled RR, 0.92 [95% CI, 0.79 to 1.08]).
KQ1b. Is there evidence that aspirin reduces perinatal/fetal morbidity or mortality in women at increased risk for preeclampsia? | Perinatal mortality k=13 n=12,492 | RCT | The pooled analysis (k=10; n=12,240) had insufficient power to detect a modest effect of aspirin on perinatal mortality. A meta-analysis sample size of n=31,504 would be needed to obtain 80% power to detect an 18% reduction in perinatal mortality. | Most studies (13/15) reported perinatal mortality. 10 could be pooled as 3 had no events. High consistency (overall I^2^ =0%; p=0.78). The 2 largest studies (n=10,760) had consistent effects tending in the direction of an aspirin benefit. | Good applicability. Studies primarily conducted outside the U.S., but 1 large study based in the U.S. is included. The evidence does not offer guidance on the best method for identifying patients who would most benefit from prophylaxis. | 8 good, 5 fair Overall: Good | Given limited power, meta-analysis results cannot eliminate a reduced risk of perinatal mortality in women at elevated preeclampsia risk (pooled RR,^*^ 0.81 [95% CI, 0.65 to 1.01]).
KQ1b. Is there evidence that aspirin reduces perinatal/fetal morbidity or mortality in women at increased risk for preeclampsia? | Preterm birth (<37 weeks) k=10 n=11,779 | RCT | The effect sizes are smaller in larger studies, and there was evidence of significant small study effects, possibly indicating publication bias. Inability to disentangle the confounding of study size and other study characteristics of interest in stratified analyses. | 10/15 studies reported this outcome. Very good consistency, with all included trials showing effects in the same direction. Low to moderate heterogeneity (I^2^ =33.2%; p=0.14). | Good applicability. Most studies conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. Different management of labor across settings likely affect the outcome, but not differentially by experimental group. The body of evidence does not offer guidance on the best method for identifying patients who would most benefit from prophylaxis. | 8 good, 2 fair Overall: Fair to good | There was evidence that aspirin reduced the risk of preterm birth (pooled RR, 0.86 [95% CI, 0.76 to 0.98]) in women at elevated risk for preeclampsia. The magnitude of estimated benefit could be exaggerated by small study effects.
KQ1b. Is there evidence that aspirin reduces perinatal/fetal morbidity or mortality in women at increased risk for preeclampsia? | IUGR/SGA k=13 n=12,504 | RCT | Inconsistent definition of IUGR/SGA ranging from <3^rd^ to <10^th^ percentile birth weight for gestational age (<10^th^ percentile most common). The effect sizes are smaller in larger studies, and there was evidence of small study effects, possibly indicating publication bias. Diverse inclusion criteria were used and preeclampsia incidence varied widely across studies (8% to 30%). | 13/15 studies reported usable data for this outcome, eliminating only 151 patients. Low to moderate heterogeneity (I^2^ =36.9%; p=0.09) All but 1 trial, the large multisite trial conducted in the U.S., reported effects in the same direction. | Good applicability. Most studies were conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. The body of evidence does not offer guidance on the best method for identifying patients who would most benefit from prophylaxis. | 8 good, 5 fair Overall: Fair to good | There was evidence of a reduction in IUGR with aspirin (pooled RR, 0.80 [95% CI, 0.65 to 0.99]) in women at elevated risk for preeclampsia. The magnitude of estimated benefit could be exaggerated by small study effects
KQ1b. Is there evidence that aspirin reduces perinatal/fetal morbidity or mortality in women at increased risk for preeclampsia? | Birth weight k=13 n=10,968 | RCT | The effect sizes are smaller in larger studies, and there was evidence of small study effects, possibly indicating publication bias. | Moderate heterogeneity (I^2^ =60.0%; p=0.01). All except 1 small trial (n=86) reported effects in the same direction, favoring aspirin. Pooled estimates were not precise. | Fair applicability. This outcome was not reported in the largest U.S.-based trial. Most studies were conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. The body of evidence does not offer guidance on the best method for identifying patients who would most benefit from prophylaxis. | 6 good, 7 fair Overall: Fair | Aspirin increased the mean birth weight of infants by a pooled weighted mean difference of 129.8 g (95% CI, 36.2 to 223.3; n=10,712)^†^ This could reflect extension of length of gestation or reduction in IUGR, and would be consistent with a possible benefit in perinatal mortality. Estimated effect is not precise and may be exaggerated due to small study effects.
KQ2. Is there evidence that aspirin prevents preeclampsia in women at increased risk for preeclampsia? | Preeclampsia k=13 n=12,184 | RCT | Minor variations in the definition of preeclampsia used, especially the cutpoints used to diagnose proteinurea. Evidence of small study effects, possibly indicating publication bias. It is not possible to determine whether lower aspirin dosage might account for smaller effects observed in the 2 large trials. Diverse inclusion criteria were used and preeclampsia incidence varies widely (8% to 30%). | Except for 1 small trial (n=43), all studies reported effects in the same direction. The effect sizes and confidence intervals in the 2 largest studies are nearly identical. There is moderate heterogeneity (I^2^ =40.5; p=0.06). | Good applicability. Most studies were conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. The evidence does not offer guidance on the best method for identifying patients who would most benefit from prophylaxis. | 8 good, 5 fair Overall: Good | There is evidence of a modest reduction in preeclampsia for women at risk who take low-dose aspirin during pregnancy. Aspirin significantly reduces the risk of preeclampsia, by nearly a quarter when all included studies are pooled (RR, 0.76 [95% CI, 0.62 to 0.95]). Effect estimates could be overestimated due to small study effects. Although study-level results were not statistically significant, the 2 largest trials both estimated a 10% reduction in risk of preeclampsia; this estimate is consistent with the pooled result, but more conservative.
KQ3. What are the harms of aspirin use during pregnancy? (Includes trials of pregnant women not at elevated risk of preeclampsia) KQ3a. Are there harms to the woman or fetus/offspring from aspirin use during pregnancy? | Perinatal mortality Elevated preeclampsia risk k=13 n=12,492 Low preeclampsia risk k=5 n=10,726 Total n=23,218 | RCT | The pooled analysis for women in all risk groups had insufficient power to detect a modest beneficial or harmful effect of aspirin on the risk of perinatal mortality. Appropriately stratifying by risk of preeclampsia (increased vs. not increased) reduced power further. | Very low heterogeneity (I^2^ =0%; p=0.65), but because the outcome is rare, small studies are inconsistent in the direction of effect. There was a significant interaction between elevated risk and low-risk trials and perinatal mortality. In the 2 large trials with women at elevated risk, results were toward benefit. In the 3 large trials with women at low risk, results were in the direction of harm. Stratified analyses showed opposite directions of effect (further risk reduction in those at increased risk and increased risk on those not at increased risk), but were not powered adequately. | Good applicability. Evidence on the outcome are from RCTs of women at elevated risk of preeclampsia taking low-dose aspirin, and women not at elevated risk taking low-dose aspirin. Most studies were conducted outside the U.S., but would likely be similar to U.S. prenatal and hospital health care settings. | 12 good, 6 fair Overall: Good | An increase in the risk of perinatal mortality cannot be ruled out in pooled analysis of women at both elevated and low risk (RR,^*^ 0.91 [95% CI, 0.75 to 1.11]; n=22,848). However, when the pooled analysis was stratified by risk, summary effects were in opposite directions (toward increased perinatal risk in aspirin-using women at low risk and toward reduced perinatal mortality risk in aspirin-using women at elevated risk); thus, perinatal mortality was less of a concern after stratified analysis in those at elevated risk (RR,^*^ 0.81 [95% CI, 0.65 to 1.01]; n=12,240). Possible increased risk of perinatal mortality in low-risk women with use of aspirin (RR,^*^ 1.33 [95% CI, 0.90 to 1.96]; n=10,608) suggests caution.
| Abruptio placentae Elevated preeclampsia risk k=6 n=12,710 Low preeclampsia risk k=5 n=10,622 Total n=23,332 | RCT | Less than half (6/15) of elevated risk trials reported this outcome, and among these 3 had no abruption events. Severely underpowered analyses with potential publication bias in trials assessing women at elevated risk. Even when pooling trials in both low- and elevated-risk women (k=11; n=23,332) there was insufficient power. For the observed n and event rates, the pooled analysis had only 27% power; a sample size over 100,000 would be required to detect a 20% difference in abruption rates with 80% power. The study with the largest RR, indicating harm from aspirin, acknowledged that the abruption rate in the placebo group was unusually low; the event rate in the aspirin arm came closer to the general population risk of abruption. The multisite trial was U.S.-based, with a majority of participants identifying as racial or ethnic minorities (82%). | 3 trials reported no abruption events (all trials of women at elevated risk), 6 (2 in women at elevated risk; 4 in low-risk women) reported more events in the aspirin group, and 2 (1 elevated risk; 1 low risk) reported more events in the control arm. The 2 large trials in women with elevated risk (MFMU, CLASP) found inconsistent effects. Heterogeneity was low to moderate (I^2^ =36.4; p=0.14). | Good applicability. Evidence on the outcome are from RCTs of women at elevated risk of preeclampsia taking low-dose aspirin, and women not at elevated risk taking low-dose aspirin. Most studies were conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. | 9 good, 2 fair Overall: Fair to good | Given power limitations and small study effects, an increase in the risk of placental abruption for women taking low-dose aspirin during pregnancy cannot be ruled out (pooled RR,^*^ 1.19 [95% CI, 0.81 to 1.76]; n=22,988). Pooling limited to trials of women at elevated risk reduced the estimated risk associated with aspirin use, but reduced statistical power (RR,^*^ 1.09 [95% CI, 0.67 to 1.77]; n=12,366). Given a larger abruption risk with aspirin use in women at low risk (RR, 1.52 [95% CI, 0.68 to 3.29]), caution is warranted.
| Postpartum hemorrhage (≥500 mL blood loss) Elevated preeclampsia risk k=6 n=12,860 Low preeclampsia risk k=3 n=9,900 Total n=22,760 | RCT | The dosage of aspirin and the timing of use during pregnancy varied across studies. The MFMU trial instructed women to stop taking their medication if preeclampsia developed, whereas most protocols specified continued use until delivery. 5 studies stated specific endpoints (e.g., 10 days before the estimated date of delivery, 34 completed gestational weeks). | Only 6/15 studies in women at elevated risk reported this outcome and 4/6 could be pooled (2 had no events). 3/5 studies in low-risk women reported this outcome and all were pooled. Very low heterogeneity (I^2^ =0%; p=0.72). Consistent effects across multiple large studies. All studies of women at elevated risk close to null or toward reduced risk, all studies of women not at elevated risk close to null or toward harm. | Good applicability. Evidence on the outcome are from RCTs of women at elevated risk of preeclampsia taking low-dose aspirin, and women not at elevated risk taking low-dose aspirin. Most studies were conducted outside the U.S., but applicable to U.S. prenatal and hospital health care settings. | 9 good Overall: Fair | Evidence showed no increased risk of postpartum hemorrhage (pooled RR,^*^ 1.02 [95% CI, 0.96 to 1.09]; n=22,616) or increased blood loss for pregnant women taking low-dose aspirin. Results were consistent for women at elevated risk.
| Maternal blood loss Elevated preeclampsia risk k=4 n=416 Low preeclampsia risk k=2 n=2,332 Total n=2,748 | RCT | Few studies representing a small subset of available data reported this outcome, only 1 good-quality trial included the outcome. | All studies found either a slightly lower mean blood loss or equivalent amounts of blood loss between study groups. | Good applicability. | 1 good, 5 fair Overall: Fair to insufficient | We did not find evidence of maternal bleeding problems associated with low-dose aspirin use during pregnancy; however findings are not robust due to limited reporting. Meta-analysis was not conducted because there were few studies.
| Intracranial, intraventricular fetal bleeding Elevated preeclampsia risk k=6 n=12,433 Low preeclampsia risk k=4 n=10,024 Total n=22,457 | RCT | Very rare event, insufficient power to detect even small effects. Different outcomes were reported across studies, some specifically reported intraventricular hemorrhage diagnosed on MRI and others reported any fetal bleeding problem. | Low heterogeneity (I^2^ =13.8%; p=0.33). Although few of the studies reporting this outcome observed any events, the rates in studies that did were nearly equal. Only 1 study found more cases in the aspirin group than the placebo group. | Good applicability. Evidence on the outcome are from RCTs of women at elevated risk of preeclampsia taking low-dose aspirin, and women not at elevated risk taking low-dose aspirin. Most studies were conducted outside the U.S., but would likely be similar to U.S. prenatal and hospital health care settings. | 8 good, 2 fair Overall: Fair | We did not find evidence that aspirin use during pregnancy increased the risk of fetal or neonatal bleeding problems, such as intraventricular hemorrhage (pooled RR,^*^ 0.87 [95% CI, 0.58 to 1.28]; n=22,158). The largest RCT (CLASP) observed 33 cases of intraventricular hemorrhage in the aspirin group and 45 (0.7%) in the control group (0.9%).
| Birth defects k=1 n=47,400 | Perinatal cohort study | Details of the dose and frequency of aspirin use are unknown. Only 1 study meeting inclusion and risk of bias criteria was identified, and looks at only 1 type of birth defect in male offspring. | Only 1 study identified. | Some women in the study likely took higher single doses of aspirin, earlier in pregnancy, and with less regularity than would be the practice for prophylactic use of low-dose aspirin. | 1 good Overall: Insufficient | Aspirin use during pregnancy was not associated with cryptorchidism in male neonates.
| Neurological and early child development outcomes k=1 n=4,365 | RCT | Only 1 study meeting inclusion and risk of bias criteria was identified; other RCTs did not publish long-term followup data. | Only 1 study identified. | Data were from an RCT of women at risk of preeclampsia taking low-dose aspirin (60 mg); the findings are highly applicable. | 1 good Overall: Insufficient | There were no differences in motor development or growth at 18 months by exposure to aspirin vs. placebo.

* Some studies were excluded from this pooled analysis due to no events.

† Four studies did not report standard deviations for birth weights and were therefore excluded from this pooled analysis.

Abbreviations: CI = confidence Interval; CLASP = Collaborative Low-dose Aspirin Study in Pregnancy; HELLP = hemolysis, elevated liver enzymes, low platelet count; IUGR = intrauterine growth restriction; KQ = key question; RCT = randomized, controlled trial; RR = relative risk; SGA = small for gestational age.

The observed pooled result for preeclampsia prevention supports the causal pathway for the direct health outcome benefits observed: the risk of preeclampsia was reduced by nearly one quarter with low-dose aspirin use initiated after the first trimester. Nonetheless, our confidence in the magnitude of the pooled result is tempered by the fact that estimates from the two largest trials were very modest and not statistically significant. Based on those trials, however, a 10 percent or greater reduction in preeclampsia would be a conservative interpretation of this body of evidence, given the consistency of the effect size in the large trials and the results of pooled analysis. This reduction in preeclampsia, which may manifest as delayed onset for some women, likely underlies the observed reduction in poor perinatal health outcomes.

There do not appear to be significant harms associated with low-dose aspirin use during pregnancy, although we cannot disregard the possibility of increased abruption risk. Based on the included trials, we also did not identify a risk from other bleeding-related complications, such as postpartum hemorrhage, maternal blood loss, and neonatal intracranial or intraventricular bleeding. Findings from observational studies on cryptorchidism and miscarriage risk were null. While the evidence on long-term outcomes for offspring from in utero aspirin exposure (low-dose) is limited, followup data from one large RCT was reassuring.

The NNTs for preeclampsia, IUGR, and preterm birth calculated from the midrange of study estimates of risk for each outcome are less than 50 (Table 7). The NNT decreases to less than 25 at the higher levels of risk occurring in some included studies. Even at the lowest levels of risk, the NNT was 42 for preeclampsia, 71 for IUGR, and 65 for preterm birth. On the other hand, the NNH for abruption would be much higher (and estimated from a nonsignificant pooled effect). Considering data from all trials and assuming a 2 percent abruption rate, 294 women would need to be treated for one case of abruption to occur. Based on the estimate for women at risk of preeclampsia, even more women would need to be treated to potentially incur one additional case of abruption (NNH=417). The NNH values are helpful to bound potential harms, even in the absence of a statistically significant result for abruption.

Table 7 Number Needed to Treat for Three Levels of Risk for Preeclampsia, IUGR, and Preterm Birth

Outcome | Risk of outcome | RR | Absolute change in risk | Risk after change | NNT Benefit (95% CI) | NNT Harm (95% CI)
Preeclampsia | 0.10 | 0.76 | -0.02 | 0.08 | 42 (26, 200) | NA
Preeclampsia | 0.18 | 0.76 | -0.04 | 0.14 | 23 (15, 111) | NA
Preeclampsia | 0.23 | 0.76 | -0.06 | 0.17 | 18 (11, 87) | NA
IUGR | 0.07 | 0.80 | -0.01 | 0.06 | 71 (41, 1429) | NA
IUGR | 0.13 | 0.80 | -0.03 | 0.10 | 38 (22, 769) | NA
IUGR | 0.24 | 0.80 | -0.05 | 0.19 | 21 (12, 417) | NA
Preterm birth | 0.11 | 0.86 | -0.02 | 0.09 | 65 (38, 455) | NA
Preterm birth | 0.19 | 0.86 | -0.03 | 0.16 | 38 (22, 263) | NA
Preterm birth | 0.31 | 0.86 | -0.04 | 0.27 | 23 (13, 161) | NA
Abruption (in women at increased risk) | 0.015 | 1.12 | 0.002 | 0.017 | NA | 556 (145 harm to ∞ to 476 benefit)
Abruption (in women at increased risk) | 0.020 | 1.12 | 0.002 | 0.022 | NA | 417 (109 harm to ∞ to 357 benefit)
Abruption (across all risk levels) | 0.015 | 1.17 | 0.0026 | 0.018 | NA | 392 (139 harm to ∞ to 952 benefit)
Abruption (across all risk levels) | 0.020 | 1.17 | 0.0034 | 0.023 | NA | 294 (104 harm to ∞ to 714 benefit)

Abbreviations: IUGR = intrauterine growth restriction; NNT = number needed to treat; RR = relative risk.

## Other Systematic Reviews

The findings of our review are consistent with the results of the most recent Cochrane review,47 which included 65 trials (1965–2007). Our findings are also consistent with those from an individual meta-analysis49 that analyzed data from 31 RCTs (32,217 women; 32,819 infants). Both reviews were limited to trials of women at elevated risk for preeclampsia and included studies that combined aspirin with other antiplatelet medications. Neither review was limited to placebo-controlled trials. The Cochrane review reported on risk of bias but did not exclude studies for quality concerns. The individual meta-analysis, on the other hand, did exclude trials with high potential for bias. Our review found very similar effect estimates for preeclampsia, IUGR, preterm birth, and perinatal mortality, especially when compared with the individual meta-analysis. This result was apparent despite differences in study inclusion criteria and our extension of the search period. Only two new trials published since 2007 met our inclusion criteria.59,69 A more recent review that included 32 trials conducted in women at both average and elevated risk for preeclampsia found a substantially reduced risk of preeclampsia (RR, 0.47 [95% CI, 0.35 to 0.65]) and IUGR (RR, 0.44 [95% CI, 0.30 to 0.65]) when initiating treatment before 16 weeks.81 The nine studies included in the <16 weeks strata, however, all had fewer than 250 participants, and most had far fewer. As such, small-study effects may have influenced these findings. Similar to the other reviews, we found no difference in effects by aspirin dosage. Other published reviews of this topic have based their findings on smaller, select subsets of trials, and have provided limited explanation of reasons for exclusions.

There was a notable finding from the Askie (2007) individual patient meta-analysis that was not possible to assess in our meta-analysis because the variable was not available in the published literature.49 The individual patient-level analysis found a 21 percent (p=0.01) reduction in the need for assisted ventilation of infants after delivery in women assigned to the aspirin treatment group.

## Clinical Importance of Changes in Outcome Measures

While the estimated effect sizes were modest in pooled analyses, we found benefits for averting critical health outcomes. The possibility that a benefit for perinatal mortality is present could not be ruled out, and indeed the body of evidence weighs in favor of this being a true effect. While the significant benefits for preterm birth and IUGR would likely translate into reduced risk of perinatal mortality, the power to detect this rare outcome prevented us from detecting a statistically significant effect. In sensitivity analyses, however, we removed women entered into the CLASP trial based only on their risk for IUGR and not preeclampsia, and the benefit for perinatal mortality obtained statistical significance (Appendix F Figure 2). As discussed, there is considerable risk of incorrectly accepting a null finding for this outcome. Even if modestly effective, prophylaxis with low-dose aspirin in women at elevated risk of developing preeclampsia would likely prevent perinatal deaths, IUGR, and preterm birth.

There is considerable benefit to be gained from preventing IUGR and preterm birth because of short- and long-term health associated with these conditions. Preterm birth is the cause of 70 percent of neonatal mortality and 75 percent of neonatal morbidity in developed countries.82 Because the brain and lungs are the organs most affected by preterm birth, short- and long-term respiratory problems and neurological impairments are common in preterm infants.82 Compared with infants born at term, preterm neonates have higher rates of intraventricular hemorrhage, respiratory distress, infection, seizures, and hospital readmissions.82,83 With regard to IUGR, infants born at term (37 weeks) with low birth weight are more likely to have low Apgar scores, respiratory distress, seizures, and sepsis in the postnatal period and a greater risk of severe physical or neurological disability in adulthood.82,83,84 IUGR and SGA also have been associated with decreased cognitive function; lower educational, occupational, and economic attainment; and increased mortality in young adulthood.82,83,85

While we did not find evidence of direct maternal health benefits, prevention of poor perinatal health outcomes could confer considerable benefits to maternal (and possibly paternal) quality of life. Further, preventing preeclampsia in women could have benefits due to reductions in the medicalization of the pregnancy and birth processes.86 Medical interventions can affect mental or psychosocial health.14,15 There is evidence that obstetric interventions and pregnancy complications are associated with increased risk of posttraumatic stress and poorer mental health after childbirth.87-90 There is also evidence that preeclampsia is associated with poor psychosocial outcomes, posttraumatic stress syndrome, and postpartum depression,89,91-93 with fetal or neonatal morbidity and mortality contributing to this relationship. A broader concept of maternal health might also consider the stress of caring for a preterm infant admitted to neonatal intensive care or a child with long-term health problems associated with early birth.

A number of studies have found associations between preeclampsia and long-term cardiovascular health outcomes in women and their offspring.26,94 Current estimates suggest a possible doubling or tripling of cardiovascular disease risk in women who have had preeclampsia during any pregnancy.95,96 These risks are considerably higher in women who had early-onset preeclampsia.97 Long-term observational studies cannot ascertain whether differences in cardiovascular disease and mortality in women with a history of preeclampsia arise from underlying risk profiles that potentiate both, or whether preventing preeclampsia could reduce the risk of cardiovascular disease later in life. There is evidence that preeclampsia can cause transient and persistent endothelial injury, suggesting potential direct effects.94 Two recent case-control studies, for example, found a higher rate of white-matter lesions in women with a history of preeclampsia compared with matched controls.98,99 Subclinical damage to the brain and endothelial damage may occur from the cardiovascular strain and metabolic perturbations of preeclampsia. Whether these changes are responsible for increased long-term cardiovascular disease and mortality risk for the mother or affect the offspring of preeclamptic pregnancies is currently unknown. If this relationship were established, the lifetime benefit of aspirin prophylaxis to prevent preeclampsia or reduce its severity would be even greater than currently understood.

## Perspectives on the Large Trial Evidence on Benefits

The studies included in our systematic review had considerable variation in the methods they used for identifying women at elevated risk of preeclampsia, the dose of aspirin used, the timing of treatment initiation, and the sample size and geographic location of the trials (Appendix E). Two large trials provided the bulk of the data for pooled estimates of potential benefit.57,58 Three additional large studies were added for evaluation of harms.72,74,75 Smaller studies, many of which were rated as good quality, tended to have larger effect sizes. Therefore, we focus on consistency issues in the large trials, while acknowledging that the smaller trials also weigh into the pooled results and have important merits in terms of the ability to closely monitor and carry out study protocols. All of the large trials were national multisite studies57,72 or international collaborations,58,74 except one trial that we included only for harms.75

### MFMU Trial

The MFMU trial is a large U.S. trial that had considerable influence on the pooled results.57 The trial, however, has some unique characteristics relative to others included in our review. Briefly, the trial of 60 mg aspirin was conducted in women at elevated risk of preeclampsia (n=2,503). Eligible women were recruited at one of 13 study sites, were 13 to 26 weeks pregnant, and belonged to one of the following predefined preeclampsia risk categories: 1) pregestational diabetes mellitus (n=471), 2) chronic hypertension (n=744), 3) current multifetal gestation (n=688), and 4) preeclampsia in a prior pregnancy (n=606). Women with diabetes and hypertension were analyzed with the diabetes group, but women with multifetal pregnancies along with diabetes or hypertension were excluded. Unlike the other included trials, the MFMU protocol instructed women to stop taking their medication if they developed preeclampsia, which limits the ability to observe any benefits that might accompany aspirin use in women once the condition develops.

The risk criteria used and the population recruited resulted in high preeclampsia incidence during the trial; in the control group, one in five women were diagnosed (20%). The majority of women were racial and ethnic minorities; more than half were black, with smaller numbers of Hispanic and white participants. However, there was considerable variation in the racial/ethnic composition of the risk groups. For example, a majority of the participants with diabetes were white (53%), whereas 71 percent of the women with previous preeclampsia were black, 4 percent Hispanic, and 25 percent white. Among study participants with multifetal gestations, 50 percent were black, 18 percent Hispanic, and 32 percent white. Similarly, among those with chronic hypertension, 61 percent were black, 12 percent Hispanic, and 27 percent white. The average BMI reported at baseline indicates that many participants were overweight or obese, particularly in the chronic hypertension group (mean BMI, 33 kg/m^2^ [SD, 9]). In addition, reported smoking rates during pregnancy were high in women with diabetes (22%) and chronic hypertension (17%).

Women with chronic hypertension were the largest of the four at-risk groups enrolled in the MFMU trial. These participants also had the highest control-group rate of preeclampsia (25%) and the highest average BMI (mean BMI, 33 kg/m^2^ [SD, 9]) and age (mean age, 30 years [SD, 6]) compared with the other risk groups (i.e., diabetes, multifetal gestation, preeclampsia history). This was also the only at-risk group for which the overall rate of preeclampsia was higher in the treatment arm than in the placebo arm. Thus, while aspirin had no benefit on preeclampsia in this group, chronic hypertension clearly is a strong risk factor for preeclampsia. The diabetes and preeclampsia history at-risk groups had effect sizes consistent with the overall estimates of preeclampsia found in the CLASP study, while the estimate for multifetal gestations tended toward greater benefit (RR, 0.7 [95% CI, 0.5 to 1.1]). Consideration of subgroup effects was present from the beginning with the MFMU trial; study authors specified the four risk groups a priori, selected a sample size to allow for detection of a 50 percent reduction in preeclampsia incidence within risk groups, and randomized study subjects by clinic center and risk group. However, power was too low to support formal statistical tests of interaction for subgroup effects, as observed effects were far lower than those used in the power calculation.

There are a number of possible explanations for the chronic hypertension group having an inconsistent effect estimate compared with the other groups. First, the CIs for all risk groups contained the estimate for the hypertension group. As a result, chance differences could be responsible for these estimates, as multiple comparisons were made. The risk groups were defined a priori, however. Second, owing to the high BMI in this group, 60 mg of aspirin could have been an ineffective dose that may not have exerted any effect on the biochemical pathways influencing preeclampsia. Third, women with chronic hypertension may have a different subtype of preeclampsia that is less receptive to aspirin prophylaxis or may have been more likely to have subclinical preeclampsia at study enrollment. Indeed, 119 women had hypertension and proteinurea at the study start, and although insignificant, the magnitude of the estimated effect showed the least likelihood of a benefit of all subgroups reported (RR, 1.4 [95% CI, 0.8 to 2.6]). As others have suggested, preeclampsia may be an umbrella diagnosis that includes a number of different conditions that have similar manifestations but occur through different pathophysiologic pathways.100,101

The results of a large trial (n=1,009) that we excluded from this review because of setting (Brazil) also supports this interpretation.102 This RCT examined the effect of 60 mg aspirin compared with placebo in women at elevated preeclampsia risk. Chronic hypertension was one of this study's primary eligibility criteria (defined as “detected before or during pregnancy”), and nearly one half of study participants were enrolled for this reason. While the overall results of the trial were null for all outcomes, a pattern of lower effect estimates in women with chronic hypertension, similar to the MFMU results, was observed in the trial's detailed subgroup reporting. Although the authors prespecified subgroup analyses (and randomized the study accordingly), they did not report formal statistical tests of interaction for this subgroup, probably owing to insufficient power and null findings. Absolute and relative risk reductions were also not reported. While the high rates of preeclampsia in women with chronic hypertension make them an attractive subgroup for prophylaxis, data from trials with a high proportion of women enrolled with hypertension raise the possibility that aspirin prophylaxis may not be beneficial.

The MFMU findings for abruption, IUGR, and intracranial fetal bleeding had effect estimates directionally inconsistent with the body of evidence. It was the only trial of women at elevated preeclampsia risk to have an effect size less than 1 for abruption risk. This was also the only trial with an effect size greater than 1 for intracranial fetal bleeding, and it was one of only two studies that had an effect size greater than 1 for IUGR (the other trial65 was small [n=100] and had an equal number of IUGR cases in each study arm). While none of the risk estimates were significant, these inconsistencies further distinguish this study from the rest of the body of evidence. With regard to abruption, the MFMU trial had the smallest effect estimate for preterm birth prevention (RR, 0.93 [95% CI, 0.85 to 1.02]), and thus there was very little difference in the time at risk for abruption between the two study groups. In all of the other studies, more women in the aspirin arm experienced longer pregnancies, which extended the period during which abruption could occur.

### CLASP Trial

The largest included study was a multinational trial of 60 mg aspirin managed by a U.K.-based collaborating center (n=9,364).58 While the CLASP Collaboration included 16 diverse study sites (e.g., Malaysia, Spain, United Arab Emirates, Hong Kong, Canada, Germany, United States, Sweden), two thirds of the study participants were recruited in the United Kingdom and some sites contributed as few as seven participants (United States). CLASP was designed as a pragmatic trial, wherein women were enrolled to prevent or treat preeclampsia and IUGR based on personal and/or medical history. Prior preeclampsia or IUGR, chronic hypertension, renal disease, or other risk factors, such as age, family history, or multifetal pregnancy were identified risk factors for preeclampsia. The study authors indicated that the “fundamental criterion for entry was that the responsible clinician was uncertain whether or not to recommend aspirin in the individual pregnancy.” Treatment could begin as early as 12 weeks' gestation, and participants were instructed to continue the medication until delivery. Nearly two thirds of study participants began treatment before 20 weeks' gestation.

CLASP participants were categorized according to whether they were enrolled in the study for prophylactic or therapeutic reasons. For the purpose of our review, we included only the prophylactic participants in our pooled analyses where possible (7,974 women; 8,257 infants). This was not possible for abruption, hemorrhage, or intraventricular hemorrhage, for which prevention and treatment groups were not reported separately. The overall incidence of preeclampsia in the control arm of the trial population was 8 percent, relatively low but above the usual rates observed in the general population of obstetric patients (2% to 5%).

The CLASP trial outcomes were analyzed by attributes of participants, including the reason for study entry (preeclampsia with or without IUGR vs. IUGR only), gestation at entry, and parity. Based on baseline characteristics and results for women entered for prophylaxis of IUGR only, we postulated that including this subgroup might dampen the overall trial findings. Forty percent of women enrolled for prevention of IUGR only reported cigarette smoking, which was a much higher rate than in the group enrolled for prevention of preeclampsia (17%). Thus, some proportion of the women enrolled for IUGR prevention alone were likely included due to a history of IUGR caused by smoking or because they currently smoked, which many clinicians would have understood to be a risk for developing IUGR or SGA.103,104 Thus, some of these women would not be considered candidates for aspirin prophylaxis of preeclampsia or associated outcomes. The event rate for preeclampsia was very low and not affected by aspirin in the 1,094 women entered into the trial for prevention of IUGR only. For all other outcomes, however, the results were further toward null or harm in the IUGR only group compared with women entered to prevent preeclampsia. In effect, the IUGR only prophylaxis group dampened the estimation of aspirin benefit across outcomes. Indeed, the results for perinatal mortality preventive benefit in women at risk of preeclampsia became significant (RR, 0.79 [95% CI, 0.62 to 0.99]; I^2^ =0%) when we conducted sensitivity analyses removing the IUGR only prophylaxis participants from the meta-analysis. Pooled estimates for IUGR and preterm birth shifted further from null, and results for preeclampsia were unchanged. There were very few cases of preeclampsia in the IUGR only group, perhaps because smoking is associated with reduced rates of preeclampsia.105 Thus, the CLASP trial results could be interpreted as conservative for estimation of benefits, as could our main meta-analysis. We were unable to run the sensitivity analysis for any of the possible harms other than perinatal mortality because data were not reported by reason for study entry. Whether smoking and its effects on preeclampsia and IUGR might complicate the results of other included studies, whether reported or not, will be discussed in greater detail below.

The size of the CLASP trial permitted analyses that are not possible with smaller studies and suggest a trend in the benefit of aspirin for preeclampsia related to the timing of disease onset and its severity. Given that fewer women assigned to aspirin delivered preterm, there was a longer period in which women were at risk for developing preeclampsia. Thus, the CLASP authors posited that the magnitude of benefit for aspirin in preventing preeclampsia at earlier gestations may be underestimated by the overall pooled estimate. These authors found a trend toward increasing effect sizes for preeclampsia prevention and severity with lower gestational age at delivery (approximated by the need for antihypertension and/or anticonvulsion therapy). The result of this post hoc analysis suggests that women at risk for early preterm birth may obtain more benefit from aspirin, an observation worthy of further primary research.

## Risk of Harms From Low-Dose Aspirin Use During Pregnancy

Our review's findings related to harms are consistent with those of other reviews and large trials. We are unable to rule out the possibility of an elevated risk of rare harms, in part because of the rarity of the events and low power. Nonetheless, our findings confirm the importance of identifying a population of women at elevated risk of preeclampsia, as the two outcomes (perinatal mortality and placental abruption) for which estimates of increased risk approached clinical (but not statistical) significance were limited to or more strongly suggested in healthy populations at low or average risk for preeclampsia. That is, the risk of abruption and perinatal mortality both showed more than a 30 percent increase in events with aspirin use in healthy populations. This estimate is based on a small absolute number of events and was not statistically significant. In contrast, risk was either reduced (perinatal mortality) or showed a much smaller increase (abruption) in the trials of women at high risk for preeclampsia, which was also not statistically different from the null. Other adverse perinatal outcomes were examined in the two included studies, which found no increased risk of cryptorchidism in male infants or developmental delays in infancy through age 18 months.77,106

Our findings for placental abruption are consistent with those of other studies, although our interpretation may be a bit more conservative because we retained the possibility of increased abruption risk. A number of large studies and an individual-level meta-analysis49 have concluded that there is not an increased risk of abruption. Only one large trial in our review found a significantly increased risk of abruption.72 Characteristics of the study population could factor into the result, including: using nulliparity as the only preeclampsia risk criterion recruiting primarily racial and ethnic minority women (half of the study participants were black and nearly one third were Hispanic women), and an unusually low rate of abruption in the control arm (0.1%). National and international population-based studies report an abruption incidence of 0.5 to 1.4 percent in pregnant women.107-111 The rate of abruption generally is greater in black women than white women, and has been increasing in black women. A 2005 analysis of the National Hospital Discharge Survey data from 1979 through 2001 showed that the rates of abruption have increased in both white and black women.111

Abruption cases are also not always easy to diagnose. Likewise, given its rarity, small errors in reporting or detection could have a large influence on observed rates. A 2006 analysis of hospital discharge data from 1997 to 2001 in Finland (n=47,742) showed that, in confirmed cases of abruption, vaginal bleeding was present in 70 percent of cases; abdominal pain/uterine tenderness/uterine tetanic contractions/hypertonic uterus were present in 51 percent of cases; and bloody amniotic fluid was present in 50 percent of cases.110 In addition, fetal heart rate abnormalities were present in 69 percent of cases.110 The U.S. National Library of Medicine reports that diagnostic tests include ultrasound (either abdominal or vaginal), blood counts, and fetal monitoring.112 Definitive diagnosis requires examination of the placenta after delivery,107 and this was not uniformly reported in the body of evidence.

Given that preeclampsia may be associated with a risk of abruption in both white and black women,111 one would expect that reduced rates of preeclampsia with aspirin would also reduce rates of abruption; however, this relationship is not apparent in our data. This finding could raise concerns about the biological plausibility of beneficial findings. Conversely, the data might be explained by an increased gestational age in women taking aspirin, an outcome that was not available from the studies. Since an extension of pregnancy is associated with reductions in preterm birth, however, this slightly longer period at risk could result in a slightly elevated observation of abruption cases in the aspirin arm of the RCTs. If this were the case, the risk of abruption could not be said to be caused by aspirin, but instead by the extension of the period at risk due to desired prolongation of gestation with aspirin. Given these complexities, we are not able to either rule out or confirm a risk of abruption with aspirin prophylaxis in women at increased risk of preeclampsia using available data. We can suggest, however, that the NNH from abruption based on worst-case assumptions is considerably higher than the worst-case assumptions for NNT for all outcomes measured.

There is another body of literature that examines whether aspirin and nonsteroidal anti-inflammatory drugs increase the risk of birth defects. These findings are somewhat mixed, with many studies finding no increased risk, and there are important limitations to the literature.113,114 We excluded one large (n=20,461) case-control study115 of birth defects in the United States from our review because it ascertained aspirin exposure from parents when children were an average of age 18 months. The study would likely overestimate true risk because parents of children with birth defects are more likely to remember using aspirin and other potentially teratogenic medicines than parents of children with no birth defects. These data are worth mentioning, however, because this was a large study conducted in the United States whose other methods were acceptable. The study authors examined a wide range of birth defects and reported the adjusted odds of 12 different birth defects associated with aspirin use compared with no aspirin use. Specific adjustment variables varied, but usually included site, maternal age, race/ethnicity, folic acid supplementation, smoking, and other variables specific to the outcome of interest. While most birth defects were not elevated with aspirin use, odds increased by a factor of about 2 for anencephaly/craniorachischisis, anophthalmia/microphthalmia, cleft palate, amniotic bands/limb body wall, encephalocele, and bilateral cataracts. Despite the large sample, the number of events was generally small in the aspirin-exposed group (<8 except for cleft palate). As such, this study's power was limited and the results were statistically significant for only some of these outcomes. Thus, while the data are inconclusive and subject to ascertainment bias, they do suggest that if an association between aspirin and birth defects exists, it is likely small. Furthermore, aspirin prophylaxis for preeclampsia is initiated after the first trimester, when embryogenesis is complete. Therefore, some types of birth defects would not occur, whereas in observational studies unable to adjust for the timing or dose of aspirin exposure, they would be present.

## Discussion of Important Study Variables

Three study features varied considerably in the body of evidence and are important to consider in turn, as they have implications for interpreting the body of evidence and for clinical practice.

### Determination of Preeclampsia Risk

There is currently no consistent accepted method for identifying which pregnant women are at an elevated risk for preeclampsia. The included clinical trials employed a range of approaches for determining preeclampsia risk, and the degree to which the inclusion criteria resulted in a high-risk population can be assessed by comparing the preeclampsia incidence in the control group across studies. The incidence of preeclampsia observed across the included studies of women at elevated risk ranged from 8 to 30 percent. These differences are not trivial, as the benefits and harms of aspirin prophylaxis appear to vary with preeclampsia risk. These large differences in baseline risk in selected high-risk women, however, are made more complicated in their interpretation by a very lopsided distribution of sample sizes in this body of evidence into two large trials, a few medium trials, and many small trials. The largest trial exhibited the lowest preeclampsia incidence (7.5%) of participants diagnosed,58 while the second largest trial had close to the highest preeclampsia incidence (20%).57 At least four factors may account for this variability: 1) different methods for determining elevated preeclampsia risk; 2) different demographic characteristic risk profiles of population studied; 3) different cutpoints/definitions of preeclampsia; and 4) different exclusion criteria (i.e., variable inclusion or exclusion of women with chronic hypertension or multifetal pregnancies).

The importance of accurately identifying which women are most likely to benefit from aspirin prophylaxis is highlighted by the possibility of a perinatal mortality benefit in the pooled analysis of trials of women at elevated preeclampsia risk, and no benefit or possible harm in low- to average-risk women in the stratified pooled analysis. Stratified analyses by level of preeclampsia risk indicated that the estimated risk of perinatal mortality from low-dose aspirin is lower in the population of women selected because of risk factors for preeclampsia compared with women at average or low preeclampsia risk. However, the difficulty of identifying appropriate, high-risk women for prophylaxis is illustrated by two findings—the high variability of actual preeclampsia incidence in selected high-risk women in the studies and the similar preeclampsia incidence in the low-/average-risk group of studies with some of the studies aiming to enroll women at elevated risk.

Our review did not find evidence of a relationship between the incidence of preeclampsia in the control group and the effect of aspirin prophylaxis. We found the highest incidence of preeclampsia in studies employing a clinical test to select participants (alone or with other risk factor considerations), but the effect of aspirin was not found to be greater based on whether a clinical test versus pregnancy and medical history were used to select the trial population. Effect sizes were similar across a range of preeclampsia incidence levels in the larger studies. Of note, however, three small trials using clinical tests had very high preeclampsia incidence (22% to 30%) and observed some of the largest preventive benefits of aspirin reported in the review.66,67, 70 We observed a correlation between study size and preeclampsia incidence; given the small-study effects in the body of evidence, we are limited as to the conclusions that can be drawn until larger studies replicate the findings of these small trials.

For example, in the Yu trial,71 a measure of the uterine artery mean pulsatility index using transvaginal ultrasound uterine artery Doppler readings at 22 to 24 weeks of pregnancy identified a population of women at elevated risk of preeclampsia (19% incidence in the control group). In fact, only the trials using a clinical test as part of their preeclampsia risk criteria obtained preeclampsia incidence greater than 14 percent, except for the MFMU trial,57 which used medical history and obtained 20 percent incidence. Many of these trials, however, began later during pregnancy because the predictive tests were not as useful early in pregnancy. Preeclampsia incidence was considerably lower in all other trials using medical history risk factors; CLASP preeclampsia incidence was only 8 percent.58 The CLASP trial gave very loose instructions for determining trial eligibility, and uncertainty as to whether or not a patient might benefit from aspirin prophylaxis was an encouraged reason for inclusion.

While researchers continue to search for a physiologic or biochemical marker that can be used early in pregnancy to predict the development of preeclampsia, a suitable marker with good test performance characteristics remains elusive.31,116,117 Uterine artery Doppler wave patterns have been used to further identify women at risk of preeclampsia who will go on to develop preeclampsia, but the test performance characteristics have been disappointing, and do not meet international standards for reliability and accuracy.28,118 There is arguably value in employing a screening test with high false-positive rates to identify a population that would potentially benefit from aspirin prophylaxis, as long as the population is at greater risk of preeclampsia than would be identified by pregnancy history alone.28 Moreover, if patients identified using tests of uterine arterial pulsatility or notching are at risk of a subtype of preeclampsia that is more likely to respond to aspirin treatment than some of the history-based risk criteria (e.g., chronic hypertension, IUGR-only history), the markers may offer more benefit than the test performance characteristics suggest. Unfortunately, a review of systematic reviews of the evidence on the test performance of potential predictors of preeclampsia, including clinical examination (BMI and diastolic blood pressure), biochemical indicators, and ultrasound measures (i.e., uterine artery Doppler notching, pulsatility index, resistance index, and combinations), found low quality and high risk of bias in many of the studies.28 The authors summarized the state of the literature by stating “most tests claiming to predict preeclampsia have poor accuracy,” and highlighted the importance of finding tests that minimize false-negatives more than false-positives. There is also considerable excitement, although insufficient population-based evidence, regarding the use of a combination of Doppler ultrasound with biomarkers for better detection rates.119-124

Current understanding of the mechanisms of action for low-dose aspirin to prevent preeclampsia and some clinical trial evidence suggest that earlier commencement of therapy may be beneficial.125,126 Some studies of low-dose aspirin rely on uterine artery Doppler ultrasound to identify candidates for intervention.69 Problems with this test-treatment combination have been noted; namely, the value of the test cannot be inferred from these studies, even if there is a finding related to treatment.127 Moreover, a recent meta-analysis assessing the use of utero-placental Doppler ultrasound for improving pregnancy outcomes found no measurable benefit.128 This may be because there are not clear guidelines or preventive actions consistently applied following abnormal readings.

The MFMU trial's process for determining preeclampsia risk identified a high-incidence population using very clear and categorical medical history criteria.57 Investigators used medical and pregnancy characteristics or history to select women with pregestational diabetes, chronic hypertension, multifetal gestation, or prior preeclampsia. These factors are more strongly associated with elevated preeclampsia risk than some of the risk factors considered in other studies (e.g., age, BMI).32,59,64,69 In addition, the MFMU trial was predominantly conducted among racial/ethnic minorities, for whom there are documented disparities in preeclampsia rates in the United States. It remains unclear whether women with underlying chronic conditions, who indeed exhibit higher rates of preeclampsia, are uniformly likely to benefit from aspirin prophylaxis during pregnancy. The evidence we reviewed hinted at the possibility that risk of preeclampsia related to chronic hypertension is less responsive to aspirin prophylaxis, as discussed above. The manifestations and mechanisms of preeclampsia pathophysiology are understood to differ between women with prepregnancy cardiovascular conditions and those without such chronic conditions.101 The achievement of a high-incidence study population did not consistently result in a greater benefit of prophylaxis, underscoring the need to identify which of the elevated risk categories or individual characteristics account for the modest benefit observed in the pooling of trials.

A history of preeclampsia increases risk in subsequent pregnancies, and the severity is often greater with recurrence.129 It is difficult to ascertain, however, if basing prophylaxis solely on this criterion would identify a population at sufficiently elevated risk to obtain a population benefit. While many of the trials included in this review used prior preeclampsia as one of the inclusion criteria, the reasons for entry were various and results were rarely reported by entry risk criteria.

Multifetal gestation is associated with a twofold to threefold increased risk of preeclampsia.130 One included study in our review enrolled only women with twin pregnancies, but the sample size was insufficient to draw conclusions.61 The MFMU results for women enrolled with multifetal pregnancies, however, had a larger estimate of preeclampsia prevention than the other risk groups (RR, 0.7 [95% CI, 0.5 to 1.1])57 (formal statistical tests of subgroup differences were not conducted, since all effect estimates for the outcome were nonsignificant). Further research on the benefits for this known risk group is needed.

The current evidence base has tended to underrepresent nulliparous women by using prior pregnancy experiences as key risk selection criteria. While nulliparity is itself a modest risk factor for preeclampsia, the current evidence does not offer guidance for prophylaxis in healthy nulliparous women. Indeed, a recent systematic review of all studies evaluating interventions for preeclampsia prevention demonstrated the extent to which studies mix nulliparous and multiparous women without accounting for potential differences in baseline risk, causal mechanisms, and statistical power and NNTs according to the different disease prevalence.131 There is evidence from two large studies of healthy nulliparous women that the criteria for aspirin prophylaxis resulted in little benefit and elevated the risk of harms, suggesting the need for identifying subgroups at further elevated preeclampsia risk among nulliparous women.72,74 Recent efforts to develop multivariable risk prediction models for healthy nulliparous women hold promise but require further development and validation.40,132,133

Identification of a bilateral notch using uterine artery ultrasound has not been found to have good test performance characteristics in systematic reviews or recent studies,133,134 but combining multiple moderate predictors of risk may sufficiently identify a risk group that would benefit from aspirin among healthy nulliparous women. We conducted stratified analyses comparing women identified to be at risk using patient history versus those identified at risk using clinical tests (alone or in addition to patient history). Prevention of preeclampsia may have been greater in studies where clinical tests were employed. The greater benefit for preeclampsia prevention, however, did not extend to risk differences in health outcomes, and small study effects limit the conclusions that can be drawn. Further, clinical tests tended to be used later in pregnancy, suggesting numerous sources of potential confounding that could account for the difference.

The large individual-level meta-analysis conducted by the Perinatal Antiplatelet Review of International Studies (PARIS) Collaboration was unable to identify any risk group that benefited more from aspirin prophylaxis than others for preventing preeclampsia.47 The only risk factor attaining p<0.01 significance for interaction tests was prior hypertension disorder of pregnancy. Compared with women without this history, there was potentially a greater aspirin benefit for perinatal mortality. Overall, however, there is an absence of clear guidance on the subset of women at risk of preeclampsia most likely to obtain a preventive benefit for the range of outcomes considered. A threshold of expected preeclampsia incidence (e.g., 10% to 20%) for different risk factors and combinations of risk factors contributing to preeclampsia incidence may be worthwhile to consider for decisions regarding prophylaxis.

### Effects of Aspirin Dosage

The aspirin dosage used in the included trials ranged from 60 to 150 mg daily. Evaluation of differences in effect by the dose of aspirin using a 75 mg cutpoint revealed only one outcome with a significant difference; the preterm birth estimate of benefit was greater in studies using a dose of at least 75 mg. The results of all stratified analyses for dosage, however, were confounded by study size, as both of the large studies used only 60 mg of aspirin. Sorting forest plots of each outcome by aspirin dosage also did not present a pattern suggestive of a dose-response effect. The absence of convincing evidence for an effect of dosage is consistent with an individual meta-analysis based on studies of women at low and elevated preeclampsia risk that included all of the large studies we included in our review.49 More recent systematic reviews confirmed the same result.81,135 The recent Cochrane review, however, found greater benefit in studies using more than 75 mg aspirin doses compared with those using less.47 Unlike the Cochrane systematic review, our trial did not include trials with other antiplatelet medications, and we excluded studies of poor quality due to high risk of bias and those conducted outside of “High Development Index” countries that were included in the Cochrane review.

### Timing of Aspirin Treatment

Evidence from our meta-analysis did not find that initiating aspirin treatment before 16 weeks conferred more of a benefit than starting later. Consistent with our results, an individual-level meta-analysis tested whether there was a benefit to beginning aspirin treatment before 20 weeks' gestation versus 20 weeks or later and found no difference.49 In contrast, a review by Bujold81 found a significant difference related to treatment timing, with women starting treatment before 16 weeks having reduced preeclampsia risk but not those starting at 16 weeks' gestation or later. Unlike our review, the Bujold review included studies of women at low and elevated preeclampsia risk (32 trials) and was not limited to placebo-controlled trials. There is some evidence that preeclampsia may result from problems with the process of trophoblastic invasion completed around 16 weeks of gestation.3 Thus, initiating treatment before or during this process has been recommended due to the plausible mechanism of action.

We included two trials59,64 conducted by the same research group that randomized women to 100 mg aspirin or placebo and to taking the medication at different times of day: upon awakening, 8 hours after awakening, and at bedtime. These trials' results strongly support a difference in effect depending on the timing of administration relative to the sleep-wake cycle. No preventive benefit was observed for women who took the aspirin upon awakening, but starting times that were later during the day did confer a substantial benefit. The studies included 24-hour blood pressure monitoring and found differential effects on the moderation of blood pressure based on the time of day aspirin was taken.

### Other Factors Related to Aspirin Effectiveness

The effectiveness of prophylaxis may depend on how well the recommended dosage achieves its physiologic potential for a given woman's metabolism, physiology, and health behaviors. Variation in the average BMI of trial participants could complicate the evidence if the aspirin dose needs to be calibrated to individual physiological characteristics in order to be effective. One study used a protocol calibrating the dose to body weight (0.5 mg/kg), but this would have resulted in one of the lowest doses across all studies given the average weights reported.67 Nonetheless, application of this concept may need to be more nuanced. Beyond differences in volume distribution of aspirin by BMI, the antiplatelet activity of low-dose aspirin is not as effective in obese women due to increased platelet reactivity compared with nonobese women.136 Also, there is evidence that increasing the dosage of aspirin may not overcome higher platelet activity.136

## Limitations in the Body of Evidence

### Power

The most commonly reported harms and some of the benefits we evaluated were very rare events, which poses power constraints that limit our ability to draw conclusions (even after pooling) without an increased chance of incorrectly accepting a null hypothesis.

### Small-Study Effects

Although there was no evidence of small-study effects for a few outcomes, such as perinatal mortality, the body of evidence demonstrates a likely influence of publication bias, an observation that has been suggested and supported by others.47,49,57 Many small studies did not contribute to the pooled analysis due to no events for rare outcomes, such as perinatal mortality. This may contribute to the inconsistent results of the statistical tests for small-study effects on these outcomes.

### Interactions With Cigarette Smoking

Considerable accumulated evidence indicates that smoking reduces the risk of preeclampsia.105, 137 A 2012 study of data from the National Swedish Birth Register concluded that the risk of preeclampsia was reduced in women who smoked during pregnancy, and supported the causal interpretation of the observed inverse association between smoking during pregnancy and risk of preeclampsia.138 Similarly, a 2009 study of more than 600,000 singleton pregnancies in New York City found that smoking was associated with a reduced risk of preeclampsia. No association was found for preeclampsia superimposed on chronic hypertension, however, which suggests that smoking is protective against preeclampsia only in the absence of chronic hypertension. Additionally, smokers who develop preeclampsia-related disorders have no increased risk of adverse birth outcomes compared with nonsmokers who develop the same conditions.

The current understanding of the mechanism of action is an effect of smoking on reducing the circulating levels of antiangiogenic proteins (such as sFlt-1) that studies have shown occur with exposure to the carbon monoxide in inhaled tobacco products.137-144 A rise in these proteins is associated with the development of preeclampsia.143 There is also evidence of a negative interaction between smoking and preeclampsia with respect to preterm delivery and birth weight. Smokers who develop preeclampsia have a lower risk of preterm delivery and a lower adjusted mean difference in birth weight than expected based on the independent effects of smoking and preeclampsia.145 Thus, the relationship of smoking to preeclampsia and IUGR is complicated; smoking can cause IUGR and prevent preeclampsia, yet it may improve or at the very least make no difference for IUGR in women who have preeclampsia.

Advising women to stop smoking during pregnancy is standard practice and benefits maternal and child health.146 The evidence related to smoking and preeclampsia, however, raises some important research considerations for preeclampsia prevention with aspirin and the related research. We do not currently know if the effectiveness of aspirin prophylaxis is affected by smoking and whether the effect of aspirin is more modest or less modest than the effect of smoking (as no clinical trial of smoking will ever take place). The first question could be investigated, and these results would have implications for counseling patients on the importance of quitting smoking if recommending aspirin prophylaxis. If aspirin does not provide a net benefit in patients who smoke and do not quit during pregnancy, the risk of harms with aspirin should not be incurred. Thus, research is needed to better understand the common pathways and possible interactions or interference of smoking and aspirin prophylaxis. With regard to the research on aspirin and preeclampsia prevention, exposure to firsthand and secondhand smoke may need to be more carefully documented and analyzed as a potential effect-modifying variable.

## Limitations in Our Approach

Excluding studies determined to be at greater risk of bias (low quality) could have caused us to inadvertently exclude some valuable information. By limiting our analysis to fair- and good-quality studies, however, we are better able to distinguish true effects from random variation and are also less likely to draw erroneous conclusions based on study bias.

We included only one good-quality study evaluating longer-term effects (i.e., cognition, growth) of in utero low-dose aspirin exposure on the outcomes of offspring. There are additional observational studies in the literature that offer hypothesis generating evidence regarding aspirin exposure during pregnancy and long-term effects. These studies, however, have limited applicability and quality issues. These studies were not included in our review because they contain fatal flaws, such as ascertainment of exposure after the outcome is diagnosed or observed. Many studies reporting on associations between aspirin exposure and fetal and longer-term outcomes also do not contain information on the dosage, timing, or regularity of exposure. Therefore, the substantial RCT data on women taking low-dose aspirin during pregnancy are more applicable for ascertainment of harms than observational cohort data. The drawback of this evidence, however, is that it does not offer much information on potential long-term harms that would not be apparent at the time of delivery. Only the CLASP trial reported long-term followup data, and it did not report these data for the entire trial sample. Another RCT of 50 mg of aspirin, which was not included in our review due to differential followup between treatment arms and suspected potential for ascertainment bias, conducted 18-month followup and found no harms with regard to development, disease, or malformations.147

### Variation in Definitions of Outcomes

We pooled some outcomes that were defined differently across studies, with different thresholds for diagnosis. For example, IUGR and preeclampsia are not uniformly defined, as definitions are not standardized and have shifted over time. Attempts to diagnose IUGR rely on assessing whether an infant has realized its genetic growth potential. Assessment that an infant is SGA generally relies on assessment of normative weights for gestational age, with effort to adjust for race and sex. SGA neonates with birth weight below the 10th percentile or some other cutpoint are often judged to have IUGR.148 The American College of Obstetricians and Gynecologists considers healthy fetuses who are at the lower end of the growth spectrum as well as those who have not reached their genetic growth potential due to pathological or genetic issues to have IUGR if their birth weight is below the 10th percentile.149

Notably, in the studies we reviewed, the definition of IUGR ranged from below the 3rd percentile to below the 10th percentile of birth weight for gestational age, with the latter definition being the most commonly used. The CLASP trial used the definition of below the 3rd percentile for IUGR,58 and the large U.S. trial used the definition of below the 10th percentile.57 The Royal College of Obstetricians and Gynecologists does not differentiate between IUGR and SGA. The American College of Obstetricians and Gynecologists and the Royal College of Obstetricians and Gynecologists consider the abnormal condition to be estimated or actual weight below 10 percent. Some studies used 2 SDs below the mean weight for gestation as the lower cutoff. This practice appears to be more common in European countries. Some studies did not clearly define the criteria used.

While preterm birth was defined as less than 37 weeks in most of the pooled studies included in our analysis, some studies also considered the effect of aspirin on births before 34 weeks. The Askie meta-analysis also used this cutpoint, but estimated a risk very similar to our finding, with a 10 percent risk reduction and similar NNT.49 Similarly, preeclampsia is not always defined with the same cutpoints, especially for proteinuria.3 Two types of urine sampling were used for diagnosis of proteinuria in the included studies: a 24-hour urine sample test and a urine dipstick test. The 24-hour urine sample is accumulated, while the dipstick test uses two or more point-in-time measurements of urine protein. The dipstick lacks the specificity and sensitivity of the 24-hour urine sample.150 Among the studies included in our meta-analysis of proteinuric preeclampsia that described the diagnostic criteria, most used a cutpoint of 300 mg/24 hour or greater.57,59,61,67,68,71 Schiff and colleagues used a urine sample cutpoint of greater than 500 mg/24 hour.66 Several studies used dipstick tests with or without 24-hour urine sample testing; three studies defined preeclampsia with a dipstick test +2 reading,57,71 and two studies used +1 as the cutpoint.58,67 Other test cutpoints included a +3 dipstick and greater than 0.5 g/L proteinuria in the absence of urinary tract infection.69,70

The individual meta-analysis by Askie et al (2007) recoded the data from 26 trials to the same prespecified definition of preeclampsia, but found no difference in the results when analyses were conducted using the authors' own definitions.49

### Analytic Limitations

Preeclampsia is known to pose a risk of abruption.107 For severe preeclampsia, the risk has been found to be greater for black women than white women.111 The observed rates of abruption in the included aspirin trials are consistent with population-level rates and lower than some estimates for black women.111 Since none of the studies reported time-to-event analyses, the potential risk of abruption with aspirin could be influenced by a longer period at risk if pregnancy was extended, as suggested by the preterm birth and birth weight benefits of aspirin. We were unable to adjust for this possibility in the pooled analyses. Overall, time-to-event analyses may be preferable for this topic given that some outcomes (e.g., preterm birth) change the period the participant is at risk for other outcomes. Indeed, the CLASP findings related to a trend in effect sizes relative to the timing of preterm birth highlight the need to conduct more nuanced accounting for gestational time.58

## Applicability of the Evidence to Clinical Practice

Few studies in the review were conducted in the United States, but limiting our search to trials conducted in “High Development Index” countries should minimize dissimilarities in prenatal and obstetric care that would render the results of this analysis of limited applicability. If there is a prophylactic effect of aspirin on preeclampsia, a difference in health outcomes should be observed regardless of the setting, as long as the RCT is of good or fair quality. Differences in case management may increase or reduce the likelihood of observing a negative health outcome with preeclampsia, but this would not vary by study arm, only the total events.

The degree of compliance with the study treatment was variable across studies, and might also differ for women who would not choose to enroll in an RCT. If women recommended aspirin prophylaxis outside the context of an RCT are less likely to consistently follow the daily regimen, the modest effects we observed could be dampened. Alternatively, and perhaps more likely, women recommended aspirin prophylaxis outside of the RCT context who are told it has been found effective for preventing poor perinatal outcomes may have higher compliance than observed in an RCT. Of the 23 studies included in this systematic review, almost half (n=11) reported some information on study regimen compliance. Of these 11 studies, eight reported compliance measures, typically defined as a proportion of tablets taken, but measures varied across studies. The percentage of study participants who took at least 80 percent of their pills was reported in the MFMU (79%) and Sibai (70%) trials.57,72 The Yu trial reported the median percentage of tablets taken, which was 95 percent for both the intervention and control groups.71 The CLASP trial found that 88 percent of participants continued study treatment for at least 80 percent of the time between randomization and delivery.58 Overall, compliance rates were high.

In the absence of standard validated tools to identify women at increased risk of preeclampsia, there is a need for clinical guidance. We conducted a limited qualitative review of the evidence on preeclampsia risk factors, drawing upon overview articles,2,32,129 as well as the 2011 NICE and WHO guidelines for preeclampsia prevention, to describe an approach for risk stratifying prenatal care patients. Until a validated screening algorithm is available, factors that can be ascertained in a prenatal visit early in pregnancy are most useful for guiding aspirin prophylaxis decisions; we therefore focus on medical history indicators of risk.

Medical and personal history risk factors that were used in many of the clinical trials contributing to our evidence review, as well as those well-established in the published literature since those trials were conducted, are provided to help clinicians identify women most likely to obtain aspirin prophylaxis health benefits (Table 8). The consistency and strength of evidence varies for risk factors. Those included are aimed at identifying a patient population with absolute risk of preeclampsia of at least 8 percent, consistent with the lowest preeclampsia incidence observed in the control group for the studies in our review of aspirin benefits. It is expected that further updates to the approach for determining risk will be necessary. In the future, a validated screening algorithm for preeclampsia prediction in both nulliparous and multiparous women may become available. Additional moderate preeclampsia risk factors that have been identified in the literature include sleep-disordered breathing in pregnancy (i.e., apnea, snoring), history of migraine headache, low exposure to paternal sperm (e.g., fertility treatments), systolic blood pressure greater than 120 mm HG at 15 weeks' gestation (in nulliparous women), and substantial weight gain between pregnancies (i.e., BMI increase of 2+ points). Since this is an active area of research, the list included in Table 8 is likely to be modified.

Table 8 Preeclampsia Risk Factors Based on Patient Medical History^*^

Level of Risk | Risk Factors
High risk † Single risk factors consistently associated with the greatest risk of preeclampsia | Prior preeclampsia Multiple gestation pregnancy Chronic hypertension Type 1 or 2I diabetes Renal disease Autoimmune disease (i.e., systemic lupus erythematosus, antiphospholipid syndrome)
Moderate risk ‡ The presence of multiple moderate risk factors may be used by clinicians to identify women at high risk of preeclampsia | Never having borne children Obesity (i.e., BMI >30 kg/m^2^) Family history of preeclampsia (i.e., mother, sister) Sociodemographic characteristics (i.e., black race, low socioeconomic status) Age ≥35 years Personal history factors (e.g., born low birth weight or small for gestational age, previous adverse pregnancy outcome, >10-year pregnancy interval)
Low risk | Prior uncomplicated term delivery

* Includes only risk factors that can be obtained from the patient medical history. Clinical measures, such as uterine artery Doppler ultrasound, also may additionally be used by some clinicians to evaluate risk.

† Preeclampsia incidence rates would be expected to be 8% or greater in pregnant women with 1 or more of these risk factors.

‡ These risk factors are independently associated with moderate preeclampsia risk, some more consistently than others.

As noted by Simon et al (2013), most of the trials on the effectiveness of aspirin treatment combine nulliparous and multiparous women.131 The effects of aspirin are broadly indicated to apply to women considered at increased risk for preeclampsia. The ability to identify which nulliparous women are at high risk for preeclampsia is limited. The strongest predictor of preeclampsia is prior preeclampsia, which cannot apply to women in their first pregnancy. Recent efforts to develop a model based on clinical risk factors for identifying elevated preeclampsia risk in nulliparous women could eventually provide guidance.40 Once validated, this algorithm may assist in the identification of nulliparous women who may be candidates for aspirin prophylaxis.

## Future Research Needs

We identified three ongoing trials comparing aspirin use with placebo in the prevention of preeclampsia (Appendix B). These trials are scheduled to be completed in the coming years (2014 to 2015). One of these trials, a large French trial with an estimated enrollment of almost 5,000 subjects, will test the efficacy of low-dose aspirin (160 mg/day) in nulliparous pregnant women selected as high risk by the presence of a bilateral uterine artery notch before 16 weeks' gestation. Another study, a U.S. trial with an expected enrollment of 220 women, will estimate the efficacy of low-dose aspirin (81 mg/day) in pregnant women identified as high risk by a first trimester multiparameter predictive model. The third study, conducted in Spain with a targeted enrollment of 270 women, will evaluate whether low-dose aspirin (150 mg/day) improves trophoblastic development, assessed during the third trimester in women defined as high risk by abnormal uterine artery Doppler. Preeclampsia is a secondary outcome measure in this third trial.

We identified four other ongoing trials related to aspirin and preeclampsia. These studies would not be considered using our review criteria, either because they include intervention arms that combine aspirin with other potentially active therapies or because they include comparison arms that use active substances. Two of the four trials are using combination therapies that include aspirin and low-molecular-weight heparin, one trial is comparing different doses of aspirin in women with a previous history of preeclampsia, and one trial is comparing aspirin with a dietary supplement (folic acid).

The results of these ongoing studies will contribute to the body of evidence to improve our understanding of the effect of aspirin use on preeclampsia. As the trials refine unique clinical screening tools to identify women at elevated risk and use higher dosages of aspirin, they will contribute to the evidence base, as will studies investigating the mechanism of action. These studies all initiate aspirin use early during the second trimester and may consolidate the evidence on the optimal timing. Given that different dosages and risk selection approaches are used across studies, however, disentangling the source of benefits and/or harms will remain a challenge. In addition, apart from the French trial enrolling 5,000 women, the small trials will likely contend with power limitations unless their enrollment criteria successfully identify a subset of women for whom a greater benefit can be obtained than that observed in our meta-analysis. The French study will make a particularly important contribution if it is able to identify a subset of nulliparous women who are likely to experience preeclampsia and could benefit from prophylaxis.

The U.S. trial follows a trend in the literature on preeclampsia toward combining clinical testing with historical or pregnancy-related risk factors to determine women at high risk for preeclampsia. Current research seeks to validate a multiple variable model that has rigorous predictive value for preeclampsia. While none of these models has yet obtained the test performance validity level desired, they may identify women at sufficiently elevated risk for aspirin prophylaxis to be beneficial. There is considerable optimism, although insufficient population-based evidence, regarding the use of a combination of predictors, including maternal serum markers, pregnancy and medical risk factors, and ultrasound evaluation that would result in better test performance.119-124 The need for rigorous evaluation of the effectiveness of test treatment combinations has also been clearly argued.127

Research might also pursue ways of individualizing the aspirin dosage and timing of administration most likely to exert a benefit for patients. Research using direct measures of the activity of aspirin and examining whether taking aspirin before bedtime increases its preventive potential hint at interesting possibilities for future RCTs. The large ongoing French trial will be the first of its size to use a protocol instructing women to take their study medication before bed.

The manifestations and mechanisms of preeclampsia pathophysiology in women without chronic conditions and those with prepregnancy cardiovascular conditions are understood to differ.101 More primary research is needed to illuminate how preeclampsia arising from different risk factors develops and responds to aspirin intervention. The mixing of preeclampsia risk groups in RCTs is common and pragmatic. This approach, however, could mask important findings that would emerge with more homogenous and specific risk groups, unless a priori risk-based subgroups are built into sample size calculations and other aspects of study design. In addition, other interventions, such as diet and exercise modifications, could be more effective and present lower risk of harms for women at risk for preeclampsia because of high BMI.30

Finally, risk factors that are well-established in the literature were used as enrollment criteria for the RCTs we included. New literature exploring other medical history risk factors point to other possible risk factors that could be considered in future studies. For example, there is evidence of greater preeclampsia risk in women diagnosed with migraine headaches35,151 and with asthma;152,153 the risk may be particularly high for women with both conditions.154

## Conclusion

While our systematic review of the evidence identified a likely benefit of low-dose aspirin for the prevention of preeclampsia and perinatal morbidity, many questions important for informing clinical practice guidelines remain. Additional research is important to answer remaining uncertainties, particularly since few trials have been conducted in the United States or in black women, who suffer the highest burden from the disease. While available evidence hints at prevention of neonatal mortality and the significant morbidity associated with preterm birth and IUGR, harms associated with low-dose aspirin in pregnancy, particularly risk of abruption, are also a potential. Considerable evidence indicates that the rate and likelihood of those harms is considerably lower than the prophylactic benefits, particularly when women at higher risk for preeclampsia are successfully identified.

Our review suggests that the modest effect sizes seen in the two large trials are supported by the weight of the evidence, and we suggest that the CLASP and MFMU trials may even be at risk of underestimating the benefit due to the confounding influences of smoking, body weight, and aspirin dosage. While small-study effects were evident, the trials included in our review exhibit a fairly consistent pattern of effects indicative of some degree of benefit. It may be weaker in magnitude than the aggregate including small studies, but perhaps greater than the results of the CLASP and MFMU trials would suggest. The acknowledged challenge in applying the evidence on aspirin prophylaxis for preeclampsia to clinical practice remains predicting who is at risk and most likely to see a benefit from treatment.