# RESULTS

## Literature Search

Our literature search yielded 544 unique citations. From these, we reviewed the full text of 75 articles (Appendix A Figure 1). Of these, 21 studies (25 articles) met our inclusion criteria. We excluded the remaining 59 full-text articles (Appendix C).

We identified 15 studies (eight good-quality) that met inclusion criteria for KQ 1 (maternal and perinatal health), 13 studies (eight good-quality) that met inclusion criteria for KQ 2 (preeclampsia), and 21 studies (14 good-quality) that met criteria for KQ 3 (maternal, perinatal, and developmental harms). For KQs 1 and 2, we included only RCT studies of women at elevated risk of preeclampsia. For KQ 3, on the other hand, we also considered studies of healthy pregnant women. All included RCTs were placebo controlled. Details of study design and baseline demographics for each study are provided in Appendixes D and E.

## Overall Summary of Results (KQs 1 to 3)

We included one large U.S. trial57 (n=2,539), one large international trial coordinated from the United Kingdom58 (n=9,364), and 13 smaller trials from various countries59-71 to evaluate the benefits of aspirin on preeclampsia. Additionally, we included six RCTs of women not at increased risk for preeclampsia for KQ 3 (harms). These six RCTs included a good-quality multisite study conducted in the United States72 (n=3,135), a smaller U.S. study73 (n=606), a good-quality multisite study in France and Belgium74 (n=3,294), a good-quality hospital-based study in Barbados75 (n=3,647), a fair-quality U.K.-based study76 (n=122), and a small good-quality Australia-based RCT of fetal growth restriction treatment79 (n=51). We also included two observational studies, one in the United States and one in Denmark, for KQ 3 (harms). These studies were a good-quality cohort study77 that included 47,400 women enrolled during pregnancy and a good-quality case-control study78 that used data from a large prospective cohort study (n=3,129).

Trials included to assess benefits initiated aspirin treatment at a range of gestational time periods and used a variety of aspirin dosages (Appendix D Table 1). All included trials initiated aspirin treatment after the first trimester and often reported a range of weeks in which initiation occurred (e.g., 12 to 16 weeks' gestation). The most common treatment discontinuation date was delivery, but six trials57,62,66,69,71,74 stopped aspirin treatment before delivery, as early as 35 weeks69 or at the point when preeclampsia developed.57 Aspirin dosages ranged from 60 to 150 mg daily, with one trial reporting a dosage of 0.5 mg/kg daily (based on the average reported weight at baseline, the dose was calculated to be 49 mg daily).67 The majority of trials used either dosages of 60 mg (six trials58,60,70,72,73) or 100 mg (nine trials59,61-64,66,69,74,79).

Baseline characteristics and risk factors of included trials were often sparsely reported (Appendix D Table 2). Overall, the population of women included in the trials was young (mean age, 20.3 to 31 years) and predominantly white (assumed from trial country of origin and reported data). Three trials57,72,73 reported majority populations of black women (ranging from approximately 49% to 73%), which is important to consider given the reported increased risk of preeclampsia in black women. Nulliparity is an established moderate risk factor for preeclampsia; when reported, the number of women who were nulliparous ranged from 28 to 100 percent. A history of smoking and current smoking during pregnancy was reported in 10 trials57,58,65,70-72,74,76,79 and ranged from approximately 10 to 40 percent.

Only nine of the 21 studies included in this review reported any race/ethnicity data (Appendix G).57,62,65,66,71-73,76,78 Of these nine studies, all RCTs, except for one case-control study, reported the baseline comparability of the treatment groups by race/ethnicity.71-73 One trial reported the racial/ethnic composition (whites compared with nonwhites) of the four high-risk groups enrolled (i.e., diabetes, hypertension, multifetal gestation, previous preeclampsia).57 In that trial, there were considerable differences in the racial and ethnic composition of the risk groups. For example, 71 percent of study subjects with prior preeclampsia were black compared with only 39 percent in the diabetes group. Stratified risk results were reported in the text only for preeclampsia. Aspirin was ineffective for preventing preeclampsia in all four risk groups, regardless of race.

Based on pooled results, low-dose aspirin administered after the first trimester of pregnancy to women at elevated risk of preeclampsia modestly reduced the risk of preeclampsia and associated perinatal health outcomes (i.e., IUGR, preterm birth). Available evidence suggests that this reduction is at least a 10 percent risk reduction in preeclampsia (and perhaps a 24% reduction) (Figure 2). A meta-analysis revealed a 14 and 20 percent reduced risk of preterm birth and IUGR, respectively (Figures 3 and 4). The actual effect may be more modest, however, given the possible bias due to small-study effects. Consistent with findings of reduced preterm birth and IUGR, birth weight averaged 130 g more in infants whose mothers took low-dose aspirin. We did not find evidence of serious harms from aspirin use (i.e., no effect on perinatal mortality), although power was limited for such a rare event; individual trials were inconsistent, with nonstatistically significant findings in the direction of either modest benefit or harm. Pooling suggested a trend toward reduced (rather than increased) risk of perinatal mortality (RR, 0.92 [95% CI, 0.76 to 1.11]), with a tendency toward further reduced risk when pooling was limited to women at elevated risk for preeclampsia (Figure 5). Similarly, although more sparsely reported, available evidence suggested no effect of intracranial fetal bleeding with low-dose aspirin (RR, 0.84 [95% CI, 0.61 to 1.16]) (Figure 6). Although there was no overall effect of low-dose aspirin on other possible maternal harms (i.e., postpartum hemorrhage, Cesarean delivery), we could not rule out the possibility that it was associated with an increased risk of placental abruption because of sparse reporting, power limitations, and heterogeneity of populations in the studies reporting this outcome (RR, 1.17 [95% CI, 0.93 to 1.48]). Pooling only among trials enrolling higher-risk pregnant women (the target for aspirin intervention) somewhat attenuated the potential harm but reduced the precision, and results remained heterogeneous (RR, 1.12 [95% CI, 0.86 to 1.46]; I^2^=50.1%; p=0.14). Although not statistically significant, based on these estimates, the number needed to treat to harm (NNH) one person was 417 in women at high preeclampsia risk, assuming a baseline risk of 2.0 percent of women having an abruption (which was consistent with the Maternal-Fetal Medicine Unit [MFMU] trial). If a baseline risk of 1.5 percent is assumed (consistent with CLASP), then the NNH increases to 556 in women at risk of preeclampsia. The NNH across all trials, including women at low or average risk, was 297 assuming 2 percent abruption incidence, or 392 with 1.5 percent abruption incidence.72,76 Two observational studies on aspirin use during pregnancy had null findings for the potentially harmful outcomes considered, miscarriage and cryptorchidism.77,78

Included trials presented considerable variation in the timing of aspirin administration, although all trials initiated treatment after the first trimester (i.e., none before 12 weeks' gestation). We found no consistent effect of the timing or dosage of aspirin use. There was less variation in the instructions regarding when to stop aspirin prophylaxis. Of the 21 RCTs included in this review, the MFMU trial was the only one to instruct study subjects to terminate aspirin use if preeclampsia developed. Five studies explicitly stated termination dates (i.e., 2 weeks or 10 days before the estimated date of delivery, 34 completed gestational weeks, or 38 gestational weeks). Two studies did not clearly specify a termination point in their articles. The remaining 13 studies specified continued aspirin use until delivery. Planned discontinuation of aspirin versus continuation to delivery did not appear to be related to outcomes.

The evidence from this review was also unable to provide clear guidance on the ideal high-risk candidate for prophylaxis and how she might be identified in clinical practice. Methods for determining elevated risk of preeclampsia varied considerably across trials, which resulted in a highly variable incidence of preeclampsia in the control groups of each study (from 8% to 30%). Our exploratory analyses, however, found no consistent relationship between the effect sizes for any outcomes and the baseline risk of preeclampsia, although there was a correlation between the sample size and incidence of preeclampsia (as represented by the control group preeclampsia incidence).

## KQ 1 Is There Evidence That Aspirin Reduces Adverse Maternal or Perinatal Health Outcomes in Women at Increased Risk for Preeclampsia?

### Summary of Results

We did not find direct evidence that low-dose aspirin use improved any maternal health outcomes related to preeclampsia in women at elevated risk, although power was limited for these relatively rare events (Table 2). We did find evidence of improved perinatal health, however, with 20 percent lower rates of IUGR (95% CI, 0.65 to 0.99; k=13; n=12,504; I^2^=36.9%) and 14 percent lower rates of preterm birth (95% CI, 0.76 to 0.98; k=10; n=11,779; I^2^=33.2%) in women randomized to low-dose aspirin, and no effect or a possible slight reduction in perinatal mortality (Figures 3 and 4, Table 3). The presence of small-study effects in the body of evidence for these outcomes, however, might mean that the magnitude of benefit for all fetal outcomes is lower than the findings from pooled analyses indicated.

Table 2 Preeclampsia and Maternal Health Outcomes in Studies of Aspirin Prophylaxis in Pregnant Women

Study, Year Quality | Treatment group | N Analyzed | Preeclampsia incidence, n (%) | Organ/system injury or failure, n (%) | Cesarean delivery, n (%) | Mortality, n (%)
Ayala, 2012^59^ Good | IG | 176 | 11 (6.3) | NR | 41 (23.3)^*^ | NR
Ayala, 2012^59^ Good | CG | 174 | 22 (12.6) | NR | 50 (28.7)^*^ | NR
Caspi, 1994^61^ Good | IG | 24 | 0 (0) | NR | 10 (41.7) | NR
Caspi, 1994^61^ Good | CG | 23 | 2 (8.7) | NR | 7 (24.0) | NR
CLASP, 1994^58^ Good | IG | 4,659^†^ | 267 (6.7) | Eclampsia: 7 (0.2) | Prelabor Cesarean: IG: 1,007 (21.6) Intrapartum Cesarean: IG: 376 (8.1) | 1 (0.02)
CLASP, 1994^58^ Good | CG | 4,650^†^ | 302 (7.6) | Eclampsia: 7 (0.2) | Prelabor Cesarean: IG: 987 (21.2) Intrapartum Cesarean: IG: 423 (9.1) | 0 (0)
Gallery, 1997^62^ Fair | IG | 58 | NR | NR | NR | 0 (0)
Gallery, 1997^62^ Fair | CG | 50 | NR | NR | NR | 0 (0)
Hermida, 1997^64^ Good | IG | 50 | 3 (6.0) | NR | 12 (24.0) | NR
Hermida, 1997^64^ Good | CG | 50 | 7 (14.0) | NR | 10 (20.0) | NR
McParland, 1990^65^ Fair | IG | 48 | 1 (2.1) | NR | 0 (0) | NR
McParland, 1990^65^ Fair | CG | 52 | 10 (19.2) | NR | 7 (13.5) | NR
MFMU, 1998^57^ Good | IG | 1,254 | 226 (18.0) | NR | NR | NR
MFMU, 1998^57^ Good | CG | 1,249 | 250 (20.0) | NR | NR | NR
Schiff, 1989^66^ Good | IG | 34 | 1 (2.9)^§^ | NR | 5 (14.7) | NR
Schiff, 1989^66^ Good | CG | 31 | 7(22.6) | NR | 9 (29.0) | NR
Vainio, 2002^67^ Fair | IG | 43 | 2 (4.7) | NR | 7 (16.3) | 0 (0)
Vainio, 2002^67^ Fair | CG | 43 | 10 (23.3) | NR | 4 (9.3) | 0 (0)
Viinikka, 1993^68^ Fair | IG | 97 | 9 (9.3) | NR | 52 (53.6)^‡^ | NR
Viinikka, 1993^68^ Fair | CG | 100 | 11 (11.0) | NR | 60 (60)^‡^ | NR
Villa, 2012^69^ Fair | IG | 61 | 8 (13.1) | HELLP Syndrome: 0 (0) | Cesarean delivery during labor: 11 (18.0) Elective Cesarean: 3 (4.9) | 0 (0)
Villa, 2012^69^ Fair | CG | 60 | 11 (18.3) | HELLP Syndrome: 1 (0.02) | Cesarean delivery during labor: 14 (23.3) Elective Cesarean: 3 (5.0) | 0 (0)
Wallenburg, 1986^70^ Good | IG | 21 | 0 (0) | Eclampsia: 0 (0) | 1 (4.8) | 0 (0)
Wallenburg, 1986^70^ Good | CG | 23 | 7 (30.0) | Eclampsia: 1 (4.3) | 7 (30.4) | 0 (0)
Yu, 2003^71^ Good | IG | 276 | 49 (17.8) | NR | NR | NR
Yu, 2003^71^ Good | CG | 278 | 52 (18.7) | NR | NR | NR

* Calculated.

† All pregnancies with data.

‡ Reported as “induction or elective cesarean section.”

§ p<0.05 compared with CG.

Abbreviations: CG = control group; CLASP = Collaborative Low-dose Aspirin Study in Pregnancy; HELLP = hemolysis, elevated liver enzymes, low platelet count; IG = intervention group, NA = not applicable; NR = not reported.

Table 3 Fetal Health Outcomes in Studies of Aspirin Prophylaxis in Pregnant Women

Study, Year Quality | Treatment group | N Analyzed | Preterm birth (<37 weeks), n (%) | Mean (SD) birth weight, g | IUGR/SGA, n (%) | Complications, n (%) | Perinatal/neonatal mortality, n (%)
Ayala, 2012^59^ Good | IG | 176 | 7 (4.0)^*^ | 3,286 (519) | 16 (9.1)^*,†^ | NR | 2 (1.1)^*^
Ayala, 2012^59^ Good | CG | 174 | 20 (11.5)^*^ | 3,162 (580) | 32 (18.4)^*,†^ | NR | 5 (2.9)^*^
Benigni, 1989^60^ Fair | IG | 17 | 2 (11.8) | 2,922 (599) | 2 (11.8)^†^ | Ventilation: 0 (0) | 0 (0)
Benigni, 1989^60^ Fair | CG | 16 | 5 (31.3) | 2264 (1072) | 6 (37.5)^†^ | Ventilation: 3 (18.8) | 1 (6.3)
Caspi, 1994^61^ Good | IG | 48 | 11 (46.0)^§^ | 1st twin: 2,506 (623) 2nd twin: 2,499 (504) Both twins: 4,996 (1,038) | 6 (12.5)^‡^ | NR | 2 (4.2)
Caspi, 1994^61^ Good | CG | 46 | 14 (61)║ | 1st twin: 2,204 (533) 2nd twin: 2,011 (546) Both twins: 4,215 (1,027) | 11 (23.9)^‡^ | NR | 2 (4.3)
CLASP, 1994^58,¶^ Good | IG | 4,810 | 686 (17.2) | 3,024 (788) | 244 (5.9)# | Induced delivery: 1,460 (31.3) | 77 (1.9)
CLASP, 1994^58,¶^ Good | CG | 4,821 | 761 (19.1) | 2,991 (810) | 272 (6.6)# | Induced delivery: 1,406 (30.2) | 97 (2.3)
Gallery, 1997^62^ Fair | IG | 58 | 6 (11)^*^ | 3,292 (2,978–3,521)^**,‡‡^ | NR | NR | 4 (6.9)
Gallery, 1997^62^ Fair | CG | 50 | 8 (16)^*^ | 3,090 (2,621–3,511)^**^ | NR | NR | 2 (4.0)
Grab, 2000^63^ Fair | IG | 22 | NR | 3,150 (560–3,770)^††^ | NR | NR | NR
Grab, 2000^63^ Fair | CG | 21 | NR | 2,900 (800–4,070)^††^ | NR | NR | NR
Hermida, 1997^64^ Good | IG | 50 | 1 (2.0) | 3,265 (64) | 1 (2.0)^†^ | NR | 0 (0)
Hermida, 1997^64^ Good | CG | 50 | 5 (10.0) | 3,155 (96) | 2 (4.0)^†^ | NR | 0 (0)
McParland, 1990^65^ Fair | IG | 48 | NR | 3068 (555) | 7 (14.0)^##^ | NR | 1 (2.1)^*,§§^
McParland, 1990^65^ Fair | CG | 52 | NR | 2954 (852) | 7 (14.0)^##^ | NR | 3 (5.8)^*,§§^
MFMU, 1998^57^ Good | IG | 1,254 | 502 (40)^*^ | NR | 129 (10)^*,‡^ | NR | 43 (3.0)^*^
MFMU, 1998^57^ Good | CG | 1,249 | 537 (43)^*^ | NR | 108 (9)^*,‡^ | NR | 56 (5.0)^*^
Schiff, 1989^66^ Good | IG | 34 | 2 (5.9)^*^ | 3,037 (NR) | 2 (5.9)^‡^ | Admitted to NICU: 2 (5.9) Ventilary support needed: 1 (2.9) | 0 (0)
Schiff, 1989^66^ Good | CG | 32 | 6 (18.8)^*^ | 2,706 (NR)║║ | 6 (19.4)^‡^║║ | Admitted to NICU: 7 (21.9) Ventilary support needed: 3 (9.4) | 0 (0)
Vainio, 2002^67^ Fair | IG | 43 | NR | 3,462 (604) | 1 (2.3)^†^ | NR | 0 (0)
Vainio, 2002^67^ Fair | CG | 43 | NR | 3,553 (767) | 3 (7.0)^†^ | NR | 0 (0)
Viinikka, 1993^68^ Fair | IG | 97 | NR | 3,348 (707) | 4 (4.1)^¶¶^ | NR | 2 (2.1)
Viinikka, 1993^68^ Fair | CG | 100 | NR | 3,170 (665) | 9 (9.0)^¶¶^ | NR | 0 (0)
Villa, 2012^69^ Fair | IG | 61 | NR | 3,413 (630) | 2 (3.3)^¶¶^ | Umbilical artery pH <7.15: 7 (12.5) | 3 (4.9)^*^
Villa, 2012^69^ Fair | CG | 60 | NR | 3,321 (871) | 6 (10.0)^¶¶^ | Umbilical artery pH <7.15: 4 (7.4) | 1 (1.7)^*^
Wallenburg, 1986^70^ Good | IG | 21 | 0 (0) | 3,190 (2,380-4,320)^†,††^ | 4 (19.0)^†^ | NR | 1 (4.8)
Wallenburg, 1986^70^ Good | CG | 23 | 4 (17.3) | 3,040 (530-4,035)^†,††^ | 6 (26.0)^†^ | NR | 1 (4.3)
Yu, 2003^71^ Good | IG | 276 | 67 (24.3) | NR | 61 (22.1)^##^ | NR | 7 (2.5)
Yu, 2003^71^ Good | CG | 278 | 75 (27.0) | NR | 68 (24.4)^##^ | NR | 4 (1.4)

* Calculated.

† IUGR not defined.

‡ IUGR defined as birth weight <10th percentile.

§ N is the number of mothers (n=24).

║ N is the number of mothers (n=23).

¶ N analyzed represents all fetal outcomes; data presented for preterm birth are for study subjects entered for prophylaxis (IG: n=3,992; CG: n=3,982); data presented for IUGR/SGA and perinatal/neonatal mortality are for study subjects entered for prophylaxis (IG: n=4,123; CG: n=4,134); data presented for complications are for all pregnancies with data (IG: n=4,659; CG: n=4,650).

** Median (range).

†† Mean (range).

‡‡ These data were calculated without the four intrauterine deaths, as the extent of postmortem weight alteration could not be assessed (n=54).

§§ The one death in the IG was due to a cord accident at delivery, whereas the three in the CG were due to hypertension complications.

║║ N=31 (twins not counted individually for these outcomes).

¶¶ SGA defined as birth weight <2 SDs.

## IUGR defined as birth weight <5th percentile.

Abbreviations: CG = control group; CLASP = Collaborative Low-dose Aspirin Study in Pregnancy; IG = intervention group; IUGR = intrauterine growth restriction; NICU = neonatal intensive care unit; NR = not reported, SD = standard deviation; SGA = small for gestational age.

### Maternal Health Outcomes

Maternal health consequences of preeclampsia are extremely rare and include eclampsia, HELLP syndrome, organ failure, and death. Trial data did not allow us to test the effect of low-dose aspirin prophylaxis on these serious direct maternal health outcomes (Table 2). Pooled analysis (k=10 studies;58,59,61,64-70 n=10,419) indicated no difference in the Cesarean delivery rate for women taking aspirin compared with placebo (RR, 0.92 [95% CI, 0.79 to 1.08]; I^2^=24.9%) (Figure 7).

### Perinatal Health Outcomes

For perinatal mortality, the pooled estimate from 10 trials in high-risk women57-62,65,68,70,71 (n=12,240) suggested a potentially reduced risk with low-dose aspirin use (RR, 0.81 [95% CI, 0.65 to 1.01]; I^2^=0%) (Figure 5). Although pooled results do not firmly establish a mortality benefit, they significantly dampen concern about this potential serious harm from aspirin chemoprophylaxis. Six of the 10 included studies suggested less perinatal mortality in the aspirin group than in the placebo group (Table 3).57-61,65 Three of the four trials that estimated a possible harm had sample sizes of 100 or less per arm.62,68,70 While the fourth study that estimated a possible harm was somewhat larger (around 280 per arm), it also included the largest dose of aspirin (150 mg).71 This study also enrolled women later in pregnancy (22 to 24 weeks' gestation) and was the only study using readings of uterine artery pulsatility to determine preeclampsia risk. We discuss harms in more detail under KQ 3.

Given the consistency of risk estimates between the two large trials and a pooled result with very low heterogeneity, a 20 percent reduction in perinatal mortality would not be ruled out. Additionally, we found no evidence of a small-study effect for this outcome (Appendix F Figure 1). Instead, we point out a Type II risk of incorrectly accepting a null finding for perinatal mortality. Our power for detecting a beneficial effect for perinatal mortality was likely insufficient because the event is rare; post hoc power calculations suggest that pooled analysis had only 50 percent power to detect a 20 percent difference in mortality. Additionally, when we conducted sensitivity analyses removing the women who were enrolled in the CLASP trial based on elevated risk of IUGR only, the effect estimate and CI were significant (RR, 0.79 [95% CI, 0.62 to 0.99]; k=10; n=11,136) (Appendix F Figure 2).

While the pooled result suggested a 20 percent benefit in reduced risk of IUGR (RR, 0.80 [95% CI, 0.65 to 0.99]; k=13 trials;57-61,64-71 n=12,504), the estimates from the two large trials were not consistent (Figure 4).57,58 Indeed, the large U.S. trial was the only included study that reported an IUGR estimate greater than 1 (RR, 1.19 [95% CI, 0.93 to 1.52]).57 When we removed the large U.S. trial from our sensitivity analysis (since it was an outlier and the only one to stop aspirin upon the development of preeclampsia), the size of the effect remained similar (RR, 0.78 [95% CI, 0.64 to 0.93]) (Appendix F Figure 2). All other trials reporting IUGR had estimates indicating an aspirin benefit, but only one recent study conducted in Spain had significant results (RR, 0.49 [95% CI, 0.28 to 0.87]).59 For IUGR, heterogeneity was low to moderate with the large U.S. trial (I^2^=36.9%; p=0.09) and low without it (I^2^=10.7%; p=0.34) (Figure 4 and Appendix F Figure 3). We found evidence of a small-study effect based on the funnel plot and formal statistical test (Peter's p=0.018) (Appendix F Figure 4). Given the possibility of publication bias exaggerating the effect size and the inconsistency in the MFMU trial, it should be pointed out that further results could change this finding (to as much as a 51% reduction or a 31% increase in IUGR with aspirin use in high-risk women).

There was evidence of a 14 percent reduced risk of preterm birth (<37 weeks' gestation) (95% CI, 0.76 to 0.98; k=10; I^2^=33.2%) in a meta-analysis of 10 trials (n= 11,779) (Figure 3).57-62,64,66, 68,70,71 All included trials reported effects in the direction of an aspirin benefit, although only two attained significance—the largest trial, CLASP (RR, 0.90 [95% CI, 0.82 to 0.99]),58 and the recently published Ayala trial (RR, 0.35 [95% CI, 0.15 to 0.80]).59 Heterogeneity was low to moderate (I^2^=33.2%; p=0.14), and we identified evidence of small-study effects for the outcome from the funnel plot and formal statistical tests (Peter's p=0.05) (Appendix F Figure 5). Thus, the actual benefit could be attenuated somewhat with further research. In stratified analysis, there was evidence of a possible greater benefit with 75 mg of aspirin or more compared with less than 75 mg (p=0.04); however, the result is confounded by study size, as both of the large trials used 60 mg of aspirin (data not shown).

We found a difference in the mean birth weight of infants born to mothers taking low-dose aspirin compared with placebo, with those assigned to aspirin having an average birth weight 130 g greater than those assigned to placebo in pooled analysis (95% CI, 36.22 to 223.33) (Table 3, Figure 8). The CLASP trial, however, found an attenuated mean birth weight increase with aspirin (33 g [95% CI, 1.08 to 64.92]).58 Birth weight data were not reported for the large U.S. trial.57 There was moderate heterogeneity (I^2^=60.0%; p=0.01) in the pooled analysis of birth weight, and all but one trial67 (n=86, with a 23% incidence of preeclampsia in the placebo group) reported effects in the same direction (of benefit). We found evidence of small-study effects similar to those observed for other perinatal health outcomes. Given these limitations, we are not completely certain of the beneficial effect on mean birth weight with aspirin treatment suggested by the meta-analysis.

## KQ 2 Is There Evidence That Aspirin Prevents Preeclampsia in Women at Increased Risk for Preeclampsia?

### Summary of Results

Meta-analysis findings indicated that low-dose aspirin was effective for preventing preeclampsia in the included trials of women at elevated risk for preeclampsia (Figure 2 and Table 2). We must consider evidence of small-study effects, however, when evaluating this body of evidence, as the magnitude of the preventive benefit likely is smaller than the pooled estimate would suggest. Likewise, the optimal aspirin dosage and timing are not readily discerned from this body of evidence. Moreover, the available evidence was unable to offer much guidance on the best approach for identifying women at elevated preeclampsia risk and those for whom prophylaxis was most beneficial. Evidence of small-study effects limited our ability to draw definitive conclusions in stratified analyses because two large studies were often in the same strata.

### Preeclampsia Prevention

The pooled estimate (k=13; n=12,184) for preeclampsia incidence indicated a 24 percent reduction (RR, 0.76 [95% CI, 0.62 to 0.95]) with moderate heterogeneity across studies (I^2^=40.5%; p=0.064) (Figure 2). A significant reduction in preeclampsia was not observed in the two largest trials, although both estimated about a 10 percent reduction in preeclampsia.57,58 We found evidence of small-sample bias, with larger studies reporting smaller effect sizes (Appendix F Figure 6). Formal tests for small-study effects were significant (Peter's p=0.03). A downward trend in the size of the effect of aspirin on preeclampsia prevention was apparent in forest plots sorted by sample size and, to a lesser extent, by year of publication.

We did not find evidence in stratified comparisons that the timing of aspirin administration (<16 weeks) or the dose used had different effects on preeclampsia prevention (Appendix F Figures 7 and 8). The estimated risk reduction was greater in studies using more than 75 mg of aspirin (RR, 0.58 [95% CI, 0.36 to 0.95]) than those using less than 75 mg (RR, 0.85 [95% CI, 0.68 to 1.05]), but the CIs overlapped and the test for effect-size differences was not significant. Analysis of the effect of dosage, however, could be confounded by small-study effects, since both of the large studies used doses of 60 mg.57,58 The results of stratification are likely affected by the more modest effects seen in the two large studies relative to the remaining trials. Moreover, we did not find evidence of a dose-response relationship. Studies identifying women at elevated risk of preeclampsia using a clinical test, either alone or in addition to patient history, had a smaller pooled risk of preeclampsia than did studies relying solely on patient history (p=0.02) (data not shown). The six studies using clinical tests, however, were primarily small (n<150), except for one trial (n=554), and aspirin tended to be used later in pregnancy.

## KQ 3 What Are the Harms of Aspirin Use During Pregnancy?

### Summary of Results

We identified six RCTs that evaluated the harms of aspirin use to prevent preeclampsia in women at low or average preeclampsia risk72-76,79 (n=10,855) that were not included for KQs 1 or 2. These six trials were considered in combination with 13 RCTs of 13,489 women at elevated risk that we included in our evaluation of KQs 1 and 2 (Table 4).57-62,64-68, 70-71 We also included two good-quality observational studies that met our inclusion criteria.77,78 Based on data from these 19 RCTS and two observational trials, we found limited evidence of harms, particularly in women at high risk for preeclampsia, who would be the target population for aspirin chemoprophylaxis. While we could not rule out a risk of increased perinatal mortality with aspirin chemoprophylaxis due to power limitations, analyses limited to the intervention target population were reassuring, as the possible risk was attenuated and suggestive of potential benefit rather than harm. For abruption risk, there was no difference between groups in pooled analysis of all included studies of women at low, average, and high preeclampsia risk. Additionally, this effect size was attenuated when limited to women at elevated preeclampsia risk. Suggestion of a higher likelihood of harms when analyses are limited to low- or average-risk women suggests caution for aspirin chemoprophylaxis in such women. Comparison of other maternal and fetal bleeding outcomes between aspirin and placebo groups provided no evidence of harm from low-dose aspirin use beginning during the second trimester of pregnancy. Most studies instructed women to continue taking their allocated medication until delivery.

Table 4 Adverse Events Reported in Included RCTs of Aspirin Therapy in Pregnant Women

Study, Year Quality | Treatment group | N Analyzed | Perinatal Mortality (n, %) | Abruptio placentae, n (%) | Intracranial fetal bleeding, n (%) | Postpartum hemorrhage, n (%) | Mean (SD) EBL, ml | Other, n (%)
Ayala, 2012^59^ Good | IG | 176 | 2 (1.1)^*^ | NR | NR | 3 (1.7)^*^ | NR | Gestational HTN, % likely (95% CI): 14.8 (9.5 to 20.0) Antepartum hemorrhage: 6 (3.4)^*^
Ayala, 2012^59^ Good | CG | 174 | 5 (2.9)^*^ | NR | NR | 6 (3.4)^*^ | NR | Gestational HTN, % likely (95% CI): 28.2 (21.5 to 34.8) Antepartum hemorrhage: 9 (5.2)^*^
Benigni, 1989^60^ Fair | IG | 17 | 0 | NR | 0 (0) | NR | 400 (183) | NR
Benigni, 1989^60^ Fair | CG | 16 | 1 (6.3) | NR | 0 (0) | NR | 475 (185) | NR
Caspi, 1994^61^ Good | IG | 24 | 2 (8.3) | 0 (0) | NR | NR^†^ | NR^†^ | NR
Caspi, 1994^61^ Good | CG | 23 | 2 (8.7) | 0 (0) | NR | NR | NR | NR
CLASP, 1994^58^ Good | IG | Mothers: 4,659 Infants: 4,810 | 129 (2.7) | 86 (1.8) | Intraventricular hemorrhage: 33 (0.7) | Postpartum bleed ≥500 mL: 1,200 (25.8) | NR | Transfusion: 188 (4.0) Special care admission: 946 (19.7)
CLASP, 1994^58^ Good | CG | Mothers: 4,650 Infants: 4,821 | 136 (2.8) | 71 (1.5) | Intraventricular hemorrhage: 45 (0.9) | Postpartum bleed ≥500 mL: 1,182 (25.4) | NR | Transfusion: 147 (3.2) Special care admission: 1,016 (21.1)
CLASP, 1994^58^ Good 18 month followup | IG | 2,146 | NR | NR | NR | NR | NR | Gross motor failure: 9 (0.4) Fine motor failure: 28 (1.3) Height <3rd percentile: 236 (11.0) Weight <3rd percentile: 112 (5.2)
CLASP, 1994^58^ Good 18 month followup | CG | 2,219 | NR | NR | NR | NR | NR | Gross motor failure: 10 (0.5) Fine motor failure: 39 (1.8) Height <3rd percentile: 248 (11.2) Weight <3rd percentile: 129 (5.8)
Davies, 1995^76^ Fair | IG | 58 | 0 | 2 (3.4) | NR | NR | NR | Admission to NICU: IG: 1 (1.7)
Davies, 1995^76^ Fair | CG | 60 | 0 | 1 (1.6) | NR | NR | NR | Admission to NICU: CG: 2 (3.3)
Gallery, 1997^62^ Fair | IG | 58 | 4 (7) | NR | NR | NR | NR | 3 of the 4 perinatal deaths were preceded by antepartum hemorrhage
Gallery, 1997^62^ Fair | CG | 50 | 2 (4) | NR | NR | NR | NR | 1 of the 2 perinatal deaths was preceded by antepartum hemorrhage
Hauth, 1993^73^ Good | IG | 302 | 1 (0.3) | 1 (0.3) | NR | NR | NR | NR
Hauth, 1993^73^ Good | CG | 302 | 1 (0.3) | 0 (0) | NR | NR | NR | NR
Hermida, 1997^64^ Good | IG | 50 | 0 (0) | 0 (0) | 0 (0) | 0 (0) | NR | NR
Hermida, 1997^64^ Good | CG | 50 | 0 (0) | 0 (0) | 0 (0) | 0 (0) | NR | NR
McParland, 1990^65^ Fair | IG | 48 | 1 (2.1)^*,‡^ | NR | 0 (0) | NR | 289 (188) | NR
McParland, 1990^65^ Fair | CG | 52 | 3 (5.8)^*,‡^ | NR | 0 (0) | NR | 358 (228) | NR
MFMU, 1998^57^ Good | IG | 1,254 | 43 (3.0) | 17 (1)^*^ | Neonatal intraventricular hemorrhage: 25 (2)^*^ | 73 (6)^*^ | NR | NR
MFMU, 1998^57^ Good | CG | 1,249 | 56 (5.0) | 25 (2)^*^ | Neonatal intraventricular hemorrhage: 12 (1)^*^ | 77 (6)^*^ | NR | NR
Newnham, 1995^79^ Good | IG | Infants: 29 | NR | NR | Intraventricular hemorrhage: 2 (6.9) | NR | NR | Admission to NICU: 13 (44.8)
Newnham, 1995^79^ Good | CG | Infants: 30 | NR | NR | Intraventricular hemorrhage: 3 (10.0) | NR | NR | Admission to NICU: 7 (23.3)
Rotchell, 1998^75^ Good | IG | Mothers: 1,819 Infants: 1,834 | 15 (0.8)^*^ | 9 (0.5) | Intraventricular hemorrhage: 0 (0) | 178 (9.8) | NR | Fetal bleeding problems: IG: 9 (0.5) Other antepartum bleed: IG: 65 (3.6) Bleed (amount not known): IG: 173 (9.5) Transfusion: IG: 19 (1.0) Admission to special care nursery: IG: 272 (15.3)
Rotchell, 1998^75^ Good | CG | Mothers: 1,822 Infants: 1,841 | 11 (0.6)^*^ | 14 (0.8) | Intraventricular hemorrhage: 1 (0.1) | 175 (9.6) | NR | Fetal bleeding problems: CG: 9 (0.5) Other antepartum bleed: CG: 76 (4.2) Bleed (amount not known): CG: 188 (10.3) Transfusion: CG: 18 (1.0) Admission to special care nursery: CG: 293 (16.5)
Schiff, 1989^66^ Good | IG | 34 | 0 | NR | Intraventricular hemorrhage: 0 (0) | NR | NR | Cephalhematoma: 0 (0)
Schiff, 1989^66^ Good | CG | 32 | 0 | NR | Intraventricular hemorrhage: 0 (0) | NR | NR | Cephalhematoma: 1 (3.1)
Sibai, 1993^72^ Good | IG | Mothers: 1,485 Infants: 1,505 | 30 (2.0) | 11 (0.7) | Cerebral hemorrhage: 10 (0.7)^§^ | 45 (3.0) | 405 (215)∥ | Cephalohematoma: 68 (4.6) Any neonatal bleeding disorder: 104 (7.0) Admission to NICU: 132 (8.8) Blood transfusion required: Mother: 7 (0.5) Infant: 19 (1.3)
Sibai, 1993^72^ Good | CG | Mothers: 1,500 Infants: 1,519 | 21 (1.4) | 2 (0.1)^**^ | Cerebral hemorrhage: 11 (0.7)^§^ | 37 (2.5) | 404 (152)∥ | Cephalohematoma: 55 (3.7) Any neonatal bleeding disorder: 98 (6.5) Admission to NICU: 142 (9.3) Blood transfusion required: Mother: 10 (0.7) Infant: 20 (1.3)
Subtil, 2003^74^ Good | IG | Mothers: 1,634 Infants: 1,645 | 12 (0.7) | 13 (0.8) | 1 (0.06) | 63 (3.9) | NR | Major hemorrhage in baby: 2 (0.1) Transfer to NICU: 116 (7.1)
Subtil, 2003^74^ Good | CG | Mothers: 1,640 Infants: 1,660 | 11 (0.7) | 9 (0.5) | 6 (0.4) | 49 (3.0) | NR | Major hemorrhage in infant: 2 (0.1) Transfer to NICU: 111 (6.7)
Vainio, 2002^67^ Fair | IG | 43 | 0 | NR | NR | NR | 300 [250–450]^¶^ | NR
Vainio, 2002^67^ Fair | CG | 43 | 0 | NR | NR | NR | 350 [250–450]^¶^ | NR
Viinikka, 1993^68^ Fair | IG | 97 | 2 (2.1) | 0 (0) | NR | NR | 353 (100–2,500)^#^ | Admitted to NICU: 10 (10.3)
Viinikka, 1993^68^ Fair | CG | 100 | 0 (0) | 0 (0) | NR | NR | 346 (50–6,750)^#^ | Admitted to NICU: 21 (21)
Villa, 2012^69^ Fair | IG | 61 | NR | NR | NR | NR | NR | Miscarriage: 3 (3.9)
Villa, 2012^69^ Fair | CG | 60 | NR | NR | NR | NR | NR | Miscarriage: 1 (1.3)
Wallenburg, 1986^70^ Good | IG | 21 | 1 (4.8) | 1 suspected (but could not be confirmed) | NR | 0 (0) | NR | NR
Wallenburg, 1986^70^ Good | CG | 23 | 1 (4.3) | 0 | NR | 0 (0) | NR | NR
Yu 2003^71^ Good | IG | 276 | 7 (2.5) | 10 (3.6) | NR | 73 (26.4) | NR | Blood transfusion: 6 (2.2)
Yu 2003^71^ Good | CG | 278 | 4 (1.4) | 5 (1.8) | NR | 71 (25.5) | NR | Blood transfusion: 7 (2.5)

* Calculated n of events.

† Authors state that “no excessive bleeding was encountered…in the ASA group.”

‡ 1 death in the IG was due to a cord accident at delivery, whereas the 3 in the CG were due to hypertension complications.

§ Denominators used in these calculations exclude 25 spontaneous abortions and fetal deaths in the aspirin group and 14 in the placebo group (IG: n=1,480; CG: n=1,505).

∥ Estimated blood loss from vaginal deliveries only (IG: n=1,156; CG: n=1,160).

¶ Reported as blood loss at delivery (mL), median [lower and upper quartile].

# Reported as “bleeding during delivery,” mean mL (range).

** p=0.01.

Abbreviations: CG = control group; CLASP = Collaborative Low-dose Aspirin Study in Pregnancy; EBL = estimated blood loss; IG = intervention group; NR = not reported; NICU = neonatal intensive care unit; SD = standard deviation.

### Perinatal Mortality

We conducted a meta-analysis of perinatal mortality including 14 of the 18 trials57-62,65,68,70-75 of aspirin use in high- and average-risk women reporting perinatal mortality events (three additional high-risk trials64,66,67 and one average-risk trial76 reported on the outcome but had no events) (Figure 5). We identified no small-study effect on pooled estimates (Appendix F Figure 1). Pooled results suggested no effect on perinatal mortality (RR, 0.92 [95% CI, 0.76 to 1.11]; I^2^=0%), although the possibility of increased perinatal mortality could not be completely ruled out because of power limitations (Figure 5). There was, however, evidence of a difference in estimated risk according to whether the baseline population was recruited as high preeclampsia risk or not as high risk. The effect-size difference test by recruitment risk status was statistically significant (p=0.01). In analyses stratified by preeclampsia risk, perinatal mortality tended toward a reduction with aspirin use in women at elevated preeclampsia risk (RR, 0.81 [95% CI, 0.65 to 1.01]), but an increased risk with aspirin use in average-risk populations (RR, 1.33 [95% CI, 0.90 to 1.96]) (Appendix F Figure 9). These results support no or very low perinatal mortality harm likely with low-dose aspirin prophylaxis when limited to women at increased preeclampsia risk, but we have less confidence that increased perinatal mortality with aspirin use by average-risk pregnant women can be ruled out based on the evidence reviewed, as the CI included the possibility of an 11 percent increase.

### Placental Abruption

Eleven trials (n=23,332) reported placental abruption (six trials in women at increased preeclampsia risk57,58,61,64,68,71 and five trials in those at average risk72-76), with three high-risk trials reporting no events (Table 4, Figure 9).61,64,68 Overall pooled results were not significant for abruption risk from low-dose aspirin use during pregnancy (RR, 1.17 [95% CI, 0.93 to 1.48]), although the effect estimate was in the direction of harm. While studies were somewhat heterogeneous (I^2^=36.4%; p=0.14), the majority of studies estimated an increased risk of placental abruption with aspirin use. In analyses stratified by preeclampsia risk, the pooled estimate from studies of women at elevated preeclampsia risk showed no increased risk of abruption (RR, 1.12 [95% CI, 0.86 to 1.46]), nor did the estimate attain significance for studies of women at average preeclampsia risk (RR, 1.38 [95% CI, 0.84 to 2.28]), and the estimates were not significantly different (Appendix F Figure 10). We found no difference in the risk of abruption by aspirin dosage in stratified analysis (Appendix F Figure 11). When sensitivity analyses excluding the MFMU trial were conducted, because the protocol instructed women who developed preeclampsia to stop taking their medication, the risk estimate for the remaining four trials remained nonsignificant (RR, 1.35 [95% CI, 0.88 to 2.06]), but the effect size increased and heterogeneity was lower (I^2^=31.9%; p=0.20).

Only one trial (n=3,135), which assigned women to 60 mg aspirin, reported an extremely elevated risk of abruption (RR, 5.56 [95% CI, 1.23 to 25.02]).72 The study was conducted at seven U.S. sites, primarily in healthy nulliparous minority women. A number of differences in the study, including an unusually low abruption rate, may have contributed to the risk estimate. The estimate had very low precision, and the CI included the pooled effect estimate.

### Maternal Bleeding

Evidence from pooled analysis of nine trials (six elevated preeclampsia risk,57-59,64,70,71 three low preeclampsia risk72,74,75 [n=22,760]) indicated no increased risk of postpartum hemorrhage (RR, 1.02 [95% CI, 0.96 to 1.09]) (Figure 10). The result was the same regardless of the preeclampsia risk level, although all of the trials of women at elevated risk had an RR of less than 1 or very close to null.

We found no evidence that low-dose aspirin resulted in increased mean blood loss (n=2,748); all studies reporting the outcome found either slightly lower mean blood loss or equivalent amounts of blood loss between study groups. Only five trials60,65,67,68,72 reported mean blood loss (four included SDs), however, and only one of these was rated good quality (Table 4).72

### Fetal Intracranial Bleeding

We included 10 trials reporting on intracranial hemorrhage in neonates,57,58,60,64-66,72,74,75,79 with four of these trials observing no events in either study group (n=22,158) (Figure 6, Table 4).60,64-66 The outcome is rare, however, which limits our ability to detect treatment-group differences or observe events, particularly in smaller trials. No significant difference was reported in any trial, and all but one trial57 observed more events in the placebo group. The pooled relative risk was 0.84 (95% CI, 0.61 to 1.16). The heterogeneity of the pooled analysis was low (I^2^=27.1%; p=0.23), and there was not enough evidence to assess whether small-study effects were present, since only six studies reported events.57,58,72,74,75,79

In addition to reporting intracranial hemorrhage, some trials reported other types of bleeding events in neonates (i.e., cephalohematoma, any bleeding disorder). These results were rare, however, and the results were often inconsistent (Table 4). Two trials66,72 reported the incidence of cephalohematoma but found conflicting results. One large trial of average-risk nulliparous women72 (n=3,135) reported more events in neonates of mothers taking aspirin than neonates of mothers taking placebo (4.6% vs. 3.7%), while another trial of women at risk of developing preeclampsia66 (n=65) reported the opposite finding of more events in babies of mothers taking placebo (0% vs. 3.1%). Two large trials conducted in average-risk women reported rates of any neonatal bleeding disorder, but these trials also found inconsistent results. One of these trials72 (n=3,135) reported more events in neonates exposed to aspirin (7.0% vs. 6.5%), whereas the other trial75 (n=3,647) reported slightly more events in neonates of mothers taking placebo (0.5% vs. 0.6%). Neither of these differences were significant. Rates of major hemorrhage in the neonate were reported in one trial of average-risk women (n=3,294), but this trial found no difference between treatment groups.74

### Birth Defects and Developmental Outcomes

Only one study of possible birth defects from aspirin met our inclusion and quality criteria. This trial indicated that the rates of cryptorchidism were not different in male infants exposed and unexposed to aspirin in utero (Table 5).77 Followup data sites in the United Kingdom and Canada from the largest RCT on low-dose aspirin in women at elevated preeclampsia risk reported on developmental outcomes of the infants at age 12 months (n=4,168; U.K. followup data) and 18 months (n=4,365; U.K. and Ottawa followup data). This trial found no treatment-group differences in hospital visits, gross motor development, or height and weight measurements.

Table 5 Adverse Events Reported in Included Observational Studies of Aspirin Therapy in Pregnant Women

Study, Year Quality | Study design | N Analyzed | Perinatal Mortality (n, %) | Abruptio placentae, n (%) | Intracranial fetal bleeding, n (%) | Postpartum hemorrhage, n (%) | Mean (SD) EBL, ml | Other, n (%)
Jensen, 2010^77^ Good | Retrospective cohort | 47,400 | NR | NR | NR | NR | NR | Cryptorchidism: n, adjusted HR (95% CI) Unexposed: 904 (reference) Exposed: 76, 1.18 (0.93 to 1.49) Orchiopexy: n, adjusted HR (95% CI) Unexposed: 522 (reference) Exposed: 43, 1.15 (0.84 to 1.56)
Keim, 2006^78^ Good | Case-control of previously collected data | Cases: 542 Controls: 2,587 | NR | NR | NR | NR | NR | Miscarriage^*^: Cases: No Aspirin: 383 (71) Aspirin:159 (29) Controls: No Aspirin:1,711 (66) Aspirin: 876 (34)

* Aspirin use anytime during pregnancy.

Abbreviations: EBL = estimated blood loss; NR = not reported; SD = standard deviation.

### Other Reported Harms and Adverse Events

In addition to the main harms of aspirin evaluated across multiple studies, there were also reports on other harms. For the most part, these harms or the absence of harms provide assurance of the safety of aspirin during pregnancy. The large trial conducted in Barbados75 reported no differences between rates of prenatal hospital admission, duration of hospital stay, induction of labor, or transfusion. In neonates, this trial reported no differences in admission to the special care nursery, duration of hospital stay, or bleeding problems. Similarly, in a large U.S. trial,72 there were no significant differences in change in hematocrit or need for transfusions between the treatment and placebo groups. There were no cases of bleeding complications in women who received aspirin and epidural anesthesia. There were no differences in instances of cephalohematoma, cerebral hemorrhage, petechiae, purpura, excessive bleeding with circumcision, any bleeding disorders, or need for transfusion between the neonates in the two study groups. While less detail was provided, the same was reportedly true in the MFMU trial:57 there were no differences in any adverse events in either mothers or neonates that were related to aspirin prophylaxis. The CLASP trial provided considerably more detail with regard to discussion of harms.58 There was not a significant difference in rates of spontaneous labor, but women in the aspirin group were slightly less likely than the placebo group to require a Cesarean delivery during labor (p=0.08). In women who received epidural anesthesia, there was not a significant difference in instances of complications associated with the epidural between the study groups. In the aspirin-treated group, significantly more women received blood transfusions after delivery (4.0% vs. 3.2%). The increased use of transfusion was not associated with different rates or severity of postpartum hemorrhage. Finally, there were fewer cases of infants admitted to special care units in the treatment group (p=0.09), and the duration of stay was similar between treated and untreated infants.

Seven trials reported adverse events during the trial.58,62,65-67,69,71 These data were insufficient, however, to fairly evaluate differences between treatment groups within or across trials. In their followup to Gallery's study, Leslie and colleagues reported two neonatal deaths, both in the placebo group, one from severe hyaline membrane disease and one from Staphylococcus epidermis septicemia.80 One patient in Villa's trial experienced sudden deafness in one ear at 24 weeks' gestation. As a result, treatment was suspended and it was revealed that the patient was in the placebo group.69 In the CLASP trial, one woman in the treatment group died 2 days postdelivery of a pulmonary embolus.58 McParland and colleagues reported on one infant in the aspirin treatment group who died after a cord accident during labor.65 Schiff reported one case of maternal endometritis in the treatment group that led to a sepsis workup of the neonate.66 One neonate in the trial conducted by Vainio had hydrocephalus and meningomyelocele; this infant was enrolled in the treatment group.67 In most cases these singular adverse events were found to be unrelated to treatment. (Aspirin treatment begun after the stage of embryogenesis would not be related to certain types of malformations.) Two studies reported women dropping out of treatment due to itching of the throat and epigastric pain.67,71

### Reasons for Withdrawal

Trial participants withdrew from treatment for a variety of reasons. Participants frequently withdrew for nonmedical reasons, such as relocating, changing their minds about trial participation, or noncompliance with treatment. Medical reasons for withdrawal included conditions such as increased bleeding time, increased activity of aspartate amino transferase in serum, urticaria, or epigastric pain. Finally, women also withdrew from trials after miscarriage or the termination of pregnancy.