# METHODS

## Scope and Purpose

This systematic review provides updated evidence regarding the effectiveness of aspirin in preventing preeclampsia in women at increased risk for developing the condition, reducing adverse health outcomes in women at increased risk for preeclampsia, and assessing the harms of aspirin use during pregnancy. The USPSTF will use this review to update its 1996 recommendation on the prophylactic use of aspirin to prevent preeclampsia in pregnancy. This review includes all trials from the previous review that met current inclusion/exclusion criteria as well as more recently published studies.

## Key Questions and Analytic Framework

Following the methods of the USPSTF,48 we developed an Analytic Framework (Figure 1) and Key Questions (KQs) to guide the literature search, data abstraction, and evidence synthesis for this topic. The KQs are:

1. Is there evidence that aspirin reduces adverse maternal or perinatal health outcomes in women at increased risk for preeclampsia?
2. Is there evidence that aspirin prevents preeclampsia in women at increased risk for preeclampsia?
3. What are the harms of aspirin use during pregnancy?

Figure 1 Analytic Framework

* Abbreviated list of health outcomes. For full list of outcomes please see Appendix A Table 1.

Figure 1 is an analytic framework that depicts the three Key Questions described in the Methods section of the report. In general, the figure illustrates how the use of aspirin prophylaxis to prevent preeclampsia and related adverse maternal and fetal health outcomes as well as possible harms.

## Data Sources and Searches

In addition to considering all studies from the previous review for inclusion, we identified one good-quality patient-level meta-analysis published in 2007^49^ and one 2007 systematic Cochrane review47 that we used as source documents for studies to evaluate against our inclusion criteria. Additionally, we performed a comprehensive search of MEDLINE, PubMed, Database of Abstracts of Reviews of Effects, and the Cochrane Collaboration Registry of Controlled Trials for studies published between January 2006 and January 1, 2013. We worked with a medical librarian to develop our search strategy (Appendix A). All searches were limited to articles published in the English language. The literature search results were managed using version 12.0 of Reference Manager® (Thomson Reuters, New York, NY), a bibliographic management software database.

To ensure the comprehensiveness of our retrieval strategy, we reviewed the reference lists of included studies and relevant systematic reviews and meta-analyses to identify relevant articles that were published outside the search timeframe or not identified in our literature searches. In addition, we obtained references from outside experts. We also searched Federal agency trial registries and WHO's International Clinical Trials Registry Platform for ongoing and/or unpublished trials (Appendix B) and used news and table-of-contents alerts from Google (Google, Inc., Mountain View, CA) and ScienceDirect (Elsevier, Maryland Heights, MO) to help identify potentially eligible trials that were published during the period between bridge searches.

## Study Selection

Two reviewers independently reviewed the title and abstracts against inclusion and exclusion criteria for design, population, intervention, and outcomes (Appendix A). Two reviewers then independently evaluated the full-text article(s) of all potentially included studies against the complete inclusion and exclusion criteria. Disagreements in the abstract and/or full-text review were resolved by discussion and consultation with a third reviewer, if necessary. Excluded studies and reasons for exclusion are listed in Appendix C.

We developed an a priori set of criteria for inclusion and exclusion of studies based on our understanding of the literature (Appendix A Table 1). For KQs 1 and 2, examining the effectiveness of aspirin in preventing preeclampsia and/or adverse health outcomes, we included only RCTs of pregnant women at an elevated risk of preeclampsia based on patient characteristics and medical history. We did not specify risk criteria required for identifying participants in included studies, but included any study that employed a risk-selection approach aimed at achieving a study population with high preeclampsia prevalence. This could include a combination of risk factors based on medical history and/or clinical measurements known to be associated with the risk of preeclampsia, or in the case of pragmatic trials, the clinician's judgment of preeclampsia risk. Regarding nulliparity as a risk factor, preeclampsia occurs more often in first births than in subsequent births, but incidence rates are relatively low for nulliparous pregnant women (2% to 4%). Given modest to null benefits observed in prior trials of aspirin for nulliparous women and low pragmatism of assigning treatment to all, studies with nulliparity as the sole risk factor were not included in the evaluation of benefits of aspirin prophylaxis (KQs 1 and 2).

For KQ 3, examining the harms of aspirin use during pregnancy, we were more inclusive and considered RCTs and nonrandomized observational studies of pregnant women (healthy, nulliparous, or at increased preeclampsia risk), as well as fetuses or infants. We made this decision based on our view that the level of preeclampsia risk would not modify harms as it does benefits. In addition, we used broader inclusion criteria for harms because we did not want to restrict the opportunity to identify rare or unusual harms that could occur with aspirin use during pregnancy. For all KQs, we were interested in interventions that compared patients receiving 50 to 150 mg of aspirin with a placebo or “no treatment” group. This is a deviation from the 2008 review, which excluded “no treatment” groups. We included “no treatment” studies in the current review because there is good evidence of a pathophysiologic element in these intervention and we did not want to exclude potentially important evidence. However, to ensure that any effects observed were the result of the aspirin intervention and not some other factor, we excluded studies with interventions with nonaspirin antiplatelet medications or aspirin combined with another potentially active substance. We limited our included studies to those that were deemed good or fair quality by the USPSTF quality rating standards.50 We excluded poor-quality studies and those not published in English. In addition, we considered only studies set in countries defined by the Human Development Index as “very high human development” (>0.90). Reviewed outcomes are fully listed in Appendix A Table 1.

## Quality Assessment of Evidence

Two reviewers independently assessed the methodological quality of each study using predefined criteria developed by the USPSTF48 and supplemented with NICE methodology checklists for observational studies.51 Discordant quality ratings were resolved by discussion and consultation with a third reviewer, if necessary. We assigned each study a final quality rating of good, fair, or poor.

Good-quality RCTs had adequate randomization procedures and allocation concealment, blinded outcome assessment, reliable outcome measures, similar groups at baseline (i.e., little to no statistically significant differences between groups in baseline demographics and characteristics), and low attrition (≥90% of participants had followup data, with <10 percentage-point difference in loss to followup between groups). These trials used conservative data-substitution methods if missing data were inferred. Trials were downgraded to fair if they were unable to meet the majority of the good-quality criteria. Trials were rated as poor quality if attrition was greater than 40 percent or differed between groups by 20 percentage points. We also rated trials as poor quality if there were any other “fatal” flaws that seriously affected internal validity. We excluded poor-quality studies from this review (Appendix A Table 2 and Appendix C).

Good-quality observational studies exhibited unbiased selection of the nonexposed cohort and ascertainment of exposure preceding the outcome, and were conducted in populations without the outcome of interest at the beginning of the study. Further, these studies had reliable outcome measures, blinded assessment, low attrition, adjustment for potential confounders, and no other important threats to internal validity. Observational studies were downgraded to fair quality if they were unable to meet the majority of good-quality criteria. Poor-quality observational studies had multiple threats to internal validity and were excluded from the review.

## Data Extraction

One reviewer extracted data from all included studies rated as fair or good quality into a standard evidence table and a second reviewer checked the data for accuracy. Elements abstracted included population characteristics (e.g., baseline demographics, BMI, concurrent conditions, family or prior history of preeclampsia, smoking status), study design (e.g., recruitment procedures, inclusion/exclusion criteria, followup, and population adherence), intervention characteristics, and health outcomes of both the mother and fetus.

Health outcomes included the number of participants experiencing an event and incidence rates where appropriate. For KQ 1 (efficacy of aspirin in reducing adverse maternal and fetal/neonatal health outcomes), we abstracted the following maternal health outcomes when reported: organ/system injury or failures (e.g., HELLP syndrome), Cesarean delivery, and maternal mortality. In addition, we abstracted the following fetal health outcomes when reported: preterm birth (defined as birth before 37 weeks); gestational age; birth weight; IUGR/SGA; potential complications from Cesarean delivery, labor induction, or eclampsia prophylaxis (e.g., low Apgar score); and perinatal mortality. For KQ 2 (efficacy of aspirin in preventing preeclampsia), we abstracted the incidence of preeclampsia reported in each RCT. For KQ 3 (harms of aspirin use in pregnancy), we abstracted reports of abruptio placentae, intracranial fetal bleeding, postpartum hemorrhage or estimated blood loss, and any other major harm to the mother or fetus reported.

## Data Synthesis and Analysis

We created summary evidence tables for each of the main outcomes or sets of outcomes (i.e., preeclampsia incidence, maternal health outcomes, fetal health outcomes, and adverse events), along with important population characteristics and study design features. These tables were the basis of our qualitative synthesis, where we identified the range of results and looked for possible associations between study results and population or study characteristics.

In addition, we conducted meta-analyses to estimate the pooled effect size of each main outcome that was reported in at least one third of the trials for the relevant KQ (results shown in Figures 2–10). Additional forest plots showing key stratifications and sensitivity analyses are available in Appendix F Figures 1–15.

Figure 2 Pooled Analysis of Preeclampsia Sorted by Sample Size (Trials of Women at Risk of Preeclampsia)

Figure 2 is a forest plot depicting the relative risk for preeclampsia after aspirin prophylaxis. This figure is discussed in the Results section.

Figure 3 Pooled Analysis of Preterm Birth Sorted by Sample Size (Trials of Women at Risk of Preeclampsia)

Figure 3 is a forest plot depicting the relative risk for preterm birth after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Figure 4 Pooled Analysis of IUGR Sorted by Sample Size (Trials of Women at Risk of Preeclampsia)

Figure 4 is a forest plot depicting the relative risk for intrauterine growth restriction (IUGR) after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Figure 5 Pooled Analysis of Perinatal Mortality Sorted by Sample Size (All Trials)

Figure 5 is a forest plot depicting the relative risk for perinatal mortality after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Figure 6 Pooled Analysis of Intracranial Fetal Bleeding Sorted by Sample Size (All Trials)

Figure 6 is a forest plot depicting the relative risk for intracranial fetal bleeding after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Figure 7 Pooled Analysis of Cesarean Delivery Sorted by Sample Size (Trials of Women at Risk of Preeclampsia)

Figure 7 is a forest plot depicting the relative risk for Cesarean delivery after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Figure 8 Pooled Analysis of Mean Birth Weight Sorted by Sample Size (Trials of Women at Risk of Preeclampsia)

Figure 8 is a forest plot depicting the pooled analysis of mean birth weight after aspirin prophylaxis and sorted by sample size. This figure is discussed in the Results section.

Figure 9 Pooled Analysis of Abruption Sorted by Sample Size (All Trials)

Figure 9 is a forest plot depicting the relative risk for abruption sorted by sample size. This figure is discussed in the Results section.

Figure 10 Pooled Analysis of Postpartum Hemorrhage Sorted by Sample Size (All Trials)

Figure 10 is a forest plot depicting the relative risk for post-partum hemorrhage sorted by sample size. This figure is discussed in the Results section.

We used the metan procedure in Stata 11.2 (StataCorp, LP, College Station, TX) for all meta-analyses.52 For the outcome of birth weight we entered the mean birth weight in grams for each group and the associated standard deviations (SDs) to estimate the pooled weighted mean difference between groups. For dichotomous outcomes, we entered the number of events and nonevents and estimated risk ratios using the DerSimonian and Laird method for all outcomes except those in which less than 10 percent of participants experienced the event.53 The random-effects model is appropriate for the body of evidence we reviewed, because we do not assume that there is one true effect size, but rather a range of effect sizes that might be obtained depending on the diverse study characteristics and populations. For pooled analysis of rare events, we used a fixed-effects Mantel-Haenzel model or, if events were extremely rare (<1%), the Peto odds ratio to avoid bias associated with rare events.54 We also included prediction intervals in our forest plots, which provide a 95 percent estimate of where newly conducted trials would fall, assuming the between-study variability in the included trials held for new trials.55 The prediction intervals are shown on the forest plots by the horizontal lines that extend out from the diamond showing the 95 percent CI of the pooled effect.

We examined the I^2^ statistic as a measure of statistical heterogeneity. We applied the Cochrane Collaboration's rules of thumb for interpreting heterogeneity: less than 40 percent likely represents unimportant heterogeneity, 30 to 65 percent represents moderate heterogeneity, 50 to 90 percent represents substantial heterogeneity, and greater than 75 percent indicates considerable heterogeneity among the studies.56 In addition, we used funnel plots to examine small-study effects (possible indication of publication bias) and ran the Egger's test and, for dichotomous outcomes, Begg's test, to assess statistical significance of imbalance in study size and findings that would indicate a pattern. Funnel plots visually display the relationship between study size and effect size and direction. A funnel plot with few or no studies in the lower right quadrant indicates the absence of small studies from the body of published evidence. We also sorted forest plots by number of study participants to visually evaluate trends in effect sizes by study size. While small-study effects can arise from different causes, they often occur when small studies showing null or negative findings are left unpublished. This bias can result in an overestimation of the benefit of treatment and should be taken into account when interpreting meta-analyses.

We sought to recognize patterns in the study results using visual examination of forest plots sorted and stratified by potentially important prespecified study characteristics. Specifically, we examined the approach to preeclampsia risk status identification, aspirin dosage, timing of aspirin initiation, and study sample size according to a priori analytic plans. In addition, we conducted post hoc forest plot analyses to assess potential patterns in the year of publication, duration of aspirin treatment, and control group preeclampsia rate to identify potential associations with heterogeneity of treatment effects across studies. For a priori analyses, statistical tests of effect-size differences between strata were conducted to assess apparent differences in effect size by dosage (≤75 vs. >75 mg), timing of treatment initiation (<16 weeks' vs. ≥16 weeks' gestation), and whether a clinical test had been used to determine preeclampsia risk versus patient medical history or pregnancy characteristics. In addition, we stratified the analysis of harms by whether the studies were of women at elevated preeclampsia risk or low to average risk.

We conducted two sets of sensitivity analyses. In the first, we explored the effects of removing from the pooled analysis a trial with inconsistent findings and a protocol that differed substantively from the others.57 In the second, we explored the effects of dropping participants entered into the largest trial (Collaborative Low-dose Aspirin in Pregnancy [CLASP]) for the sole reason of elevated IUGR risk, leaving in the pooled analysis only women enrolled in trials based on their elevated preeclampsia risk.58 This sensitivity analysis was motivated by the observation that the smoking rate was very high in the IUGR-only risk group, and that prior IUGR from smoking, or current smoking, may have been the motivating risk factors for their selection for the trial. Our review aims to isolate the effect of aspirin prophylaxis on prevention in women at elevated risk of preeclampsia, and these study participants were not entered into the trial for preeclampsia prevention. Results of sensitivity analyses are discussed, but all study participants are included in pooled risk estimates.

We calculated the number needed to treat (NNT) by first estimating the absolute risk reduction based on the pooled risk ratio and two to three estimated levels of baseline risk of the outcome of interest (i.e., absolute risk reduction=(risk ratio-1)*baseline risk). Because there was a wide range of baseline risk for some of the outcomes (preeclampsia, IUGR, preterm birth), we chose baseline risk levels empirically using the included studies and roughly corresponding to the 20th, 50th, and 80th percentiles of risk. For abruption, we estimated the NNT separately for women known to be at risk of preeclampsia and for general- or low-risk women, using two levels of risk for each group based on the high and low values from included studies that had at least one event in the control group. From the absolute risk reduction for every level of baseline risk tested, NNT was calculated as the inverse of the absolute risk ratio.56

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the work of the USPSTF. The authors worked with three USPSTF liaisons at key points throughout the review process to develop and refine the scope, Analytic Framework, and KQs; to resolve issues around the review process; and to finalize the evidence synthesis. AHRQ had no role in study selection, quality assessment, or synthesis. AHRQ staff provided project oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review by outside experts, including representatives of professional societies and Federal agencies. The final published systematic evidence review was revised based on comments from these external reviewers.