# INTRODUCTION

## Condition Definition

Preeclampsia is a multisystem inflammatory syndrome that is not well understood. It is defined as the onset of hypertension (blood pressure ≥140/90) and proteinuria during the second half of pregnancy (>20 weeks' gestation). While the condition can remain mild until delivery, it can also evolve rapidly into severe hypertension, proteinuria, and eclampsia or hemolysis, elevated liver enzymes, and low platelets (HELLP) syndrome, with risk of organ and systemic complications and maternal or fetal death.1,2 Even when preeclampsia does not proceed to HELLP syndrome or eclampsia, severe preeclampsia can lead to neurological and visual disturbances, epigastric or right upper quadrant pain, pulmonary edema, or cyanosis. The only curative treatment once preeclampsia develops is delivery, with obvious implications for the health of the infant when it occurs preterm.

Systems for diagnosing and classifying the severity of disease vary across professional societies and organizations, including the American College of Obstetrics and Gynecology (ACOG), the American Society of Hypertension (ASH), and obstetrics and gynecology professional organizations in the United Kingdom, Canada, New Zealand, and Australia. ACOG defines severe preeclampsia as any case of preeclampsia that includes one or more of the following characteristics: severe hypertension (systolic ≥160 mm Hg or diastolic ≥110 mm Hg), severe proteinuria (ACOG: >5 g/24 hours; ASH: >3g/24 hours), severe oliguria (very low urine output), cerebral or visual disturbances (i.e., headache, blurry vision, scotomata), right upper quadrant pain, pulmonary edema or cyanosis, impaired liver function, thrombocytopenia, or fetal growth restriction. Other organizations include the timing of onset (<35 weeks), nausea or vomiting, and chest pain or dyspnea among diagnostic criteria for severe preeclampsia. Severe preeclampsia can also be retrospectively diagnosed after the occurrence of major maternal or fetal morbidity.3,4

Other pregnancy-related hypertensive conditions overlap and can co-occur with preeclampsia. Chronic hypertension, for example, is defined as hypertension predating the pregnancy and/or continuing beyond 12 weeks postpartum. Women with chronic hypertension are diagnosed with superimposed preeclampsia if proteinuria develops after 20 weeks' gestation. Pregnant women who develop hypertension during pregnancy (without proteinuria) that subsides within 12 weeks postpartum are defined as having gestational hypertension. Women can also develop atypical preeclampsia, in which they have only proteinuria or hypertension coupled with systemic manifestations or preeclampsia occurs before 20 weeks' gestation or more than 48 hours postpartum.

Physicians have used the concept of early- and late-onset preeclampsia to define different manifestations of the syndrome. This concept also allows providers to distinguish between cases developing before 34 weeks' gestation (<35 weeks' gestation according to ASH) and those developing later.3 This is important, as research has identified differences in the origins and outcomes of early-onset preeclampsia, which is thought to be related to aberrations in the placentation process.3,5 Later-onset disease, on the other hand, is thought to be associated with maternal constitutional and environmental factors, such as multiple pregnancies, high body mass index (BMI), comorbidities, and chronic hypertension. Early-onset preeclampsia is associated with more severe maternal and fetal outcomes.3

## Prevalence

Approximately 2 to 8 percent of pregnancies are affected by preeclampsia, which is the second leading cause of maternal mortality worldwide.6,7 In the United States, for example, 12 percent of maternal deaths are directly attributable to preeclampsia and eclampsia.8 Complications of preeclampsia also contribute to approximately one in 10 pregnancy-related deaths attributed to anesthesia, cardiomyopathy, and placental abruption.9 Serious morbidity, however, is far more common than mortality, and researchers have estimated that over one third of severe obstetric morbidities are related to preeclampsia.10 While the prevalence of hospitalizations from severe preeclampsia/eclampsia rose from 9.4 to 12.4 per 1,000 deliveries in the United States between 1998 and 2006,^11^ more recent data suggest that hospitalizations for eclampsia may be decreasing.12 In addition to risks to the mother, preeclampsia also dramatically increases risks to the fetus or neonate, including intrauterine growth restriction (IUGR), small for gestational age (SGA), low birth weight, premature birth, oligohydramnios, placental abruption, low Apgar scores, neonatal intensive care unit admission, stillbirth, and neonatal death.1 Because delivery is the only curative treatment, preeclampsia is a leading cause of iatrogenic preterm birth and low birth weight: 15 percent of U.S. preterm births are due to preeclampsia.13 Infants born before term (<37 weeks of gestation) are at increased risk of morbidity and mortality, with risks rising dramatically with earlier delivery. Early-onset preeclampsia has the highest likelihood of becoming severe and is therefore more likely to require early preterm delivery.

A diagnosis of preeclampsia increases the need for obstetric intervention relative to pregnancies without preeclampsia to reduce maternal and/or fetal risks. Interventions include induction of labor (preterm or term), intravenous magnesium sulfate treatment, and emergency or planned cesarean delivery. While these interventions can have health-protective benefits for maternal health, they also incur maternal and neonatal health risks. Finally, there are also mental health burdens associated with preterm birth and negative birth outcomes.14,15

### Disparities in Preeclampsia Risk and Prevalence

In the United States, the prevalence of preeclampsia and case-fatality rates reveal marked disparities. The greatest burden of preeclampsia is borne by nonHispanic black women. The rate of pregnancy-related death is four times greater in nonHispanic black women compared with nonHispanic white women, and death from preeclampsia is reported to be considerably higher in this population.9,16 National data on chronic and gestational hypertension show that these conditions are more common in nonHispanic black women and are increasing over time, with an 87 percent increase reported from 1990 to 2009; these conditions appear to be least common in Asian and Pacific Islander and Hispanic women.17 The increase in the rates of hypertensive conditions is especially troubling given that case-fatality rates from preeclampsia are three times higher in nonHispanic black women than whites, contributing to the large mortality disparity.9Approximately one third of the disparity in mortality from preeclampsia in black women stems from higher disease prevalence, but the higher case-fatality rates account for most of the difference.18 Disparities in risk factors for preeclampsia, such as chronic hypertension, diabetes, and high BMI, contribute to higher prevalence of preeclampsia in black women. Likewise, disparities in access to adequate prenatal care limit the opportunities to intervene before preeclampsia becomes more severe.19 Indeed, inadequate prenatal care is associated with higher case fatality from preeclampsia for all women, likely due to the reduced opportunity for monitoring, detection, and early intervention.9,16 Racial/ethnic disparities have also been observed, however, in a large study population (n=35,529) provided with early access to prenatal care. Minority women still experienced higher rates of preeclampsia than nonHispanic white women.20 Finally, recurrent preeclampsia in subsequent pregnancies is more severe for black women than for white or Hispanic women.21 Research is needed to assess whether low-dose aspirin could help to ameliorate this disparity in occurrence, severity, and fatality of preeclampsia in U.S. nonHispanic black women.

## Pathophysiology and Natural History

The etiology and pathophysiology of preeclampsia are subjects of considerable research and ongoing theory development. Preeclampsia is generally understood to be an inflammatory condition that involves the process of placentation, but the underlying causes and precipitating factors and conditions for its development are not fully understood. Recent theory postulates that preeclampsia may develop through two different processes that can occur either alone or in combination. Early-onset preeclampsia, which tends to have more severe outcomes, may arise from aberrations in the process of placental development, whereby trophoblast cells fail to fully activate transformation of uterine spiral arteries (at approximately 12 to 16 weeks of pregnancy), resulting in placental ischemia. This relative ischemia and lowered placental perfusion cause the release of damaging factors (i.e., cellular debris, oxidized lipids, antiangiogenic factors, soluble endoglin) into the maternal bloodstream, resulting in inflammation and oxidative stress. Alternatively or additionally, preeclampsia may develop as a result of overactive inflammatory responses to normal placentation. Preexisting hypertension, diabetes, and other inflammatory conditions (e.g., lupus), as well as twin or higher order pregnancies, are thought to precipitate a systemic inflammatory response and oxidative stress process. Consistent with this theory of two processes, women with early-onset placental preeclampsia exhibit abnormal uterine artery ultrasound Doppler readings and placental morphology compared with women without preeclampsia or with later-onset disease.2,3,22 Adding to this complexity, maternal and environmental factors may also contribute to the risk of developing preeclampsia involving problems with placental development. Thus, there is likely to be overlap between the two processes.

While we do not fully understand root causes of the placentation aberrations and inflammatory feedback loops that lead to preeclampsia, immune factors owing to the interaction of maternal physiology with fetal/paternal genes may play a role.23 The observation of heightened risk of preeclampsia during first pregnancies and in women who undergo in vitro fertilization with donor eggs has led to numerous investigations regarding a potential role of the immune system and paternal genetic influences.1 Pursuit of definitive findings to explain patterns of disease risk, however, has not yet led to a comprehensive etiological understanding. Instead, the view that preeclampsia is a complex disease with multiple causes and interactions leading to its clinical manifestation, as well as its intractability to effective treatment, make it an area of considerable scientific inquiry with important implications for women's health worldwide.

Significant maternal morbidities include cerebrovascular bleeding, retinal detachment, and complications from HELLP syndrome, such as major organ damage and failure.3 Eclampsia occurs in approximately 1 to 2 percent of preeclampsia cases, with complications such as brain damage, aspiration pneumonia, pulmonary edema, placental abruption, disseminated coagulopathy, acute renal failure, cardiopulmonary arrest, and coma.7

While some studies have found evidence that preeclampsia may be a long-term risk factor for poor cardiovascular health,24 common risk factors may explain this association. A recent study, for example, found elevated rates of cardiovascular mortality primarily in women with a history of preeclampsia, but the finding was found to be predominantly driven by those who had only one child.25 This could indicate confounding with other health issues, since women with only one child may have had their child later in life, had fertility problems, or had severe pregnancy or delivery complications limiting future childbearing. Other studies have found elevated risk of poor cardiovascular health in the offspring of pregnancies affected by preeclampsia.26 Whether or not preventing preeclampsia would benefit long-term cardiovascular health for women or their children is currently unknown. Notably, preeclampsia often remains mild and slowly progresses without any adverse health consequences for the mother or infant. Challenges in preventing and treating the disease are compounded by the difficulty of determining which patients will develop preeclampsia and go on to experience severe life-threatening complications. It has recently been suggested that preeclampsia may consist of multiple disease types with different causes, courses, and manifestations.27 As understanding of the disease becomes more nuanced, the ability to assess individual risk and to develop targeted preventive strategies is likely to expand. Currently, however, tools for predicting and preventing preeclampsia are limited.

## Risk Factors

There are no validated clinical tools or assays to predict early in pregnancy with sufficient sensitivity and specificity who will develop preeclampsia or experience adverse outcomes. Systematic review evidence for uterine artery Doppler ultrasound readings in the second trimester, particularly increased pulsatility index and bilateral notching, have reasonable test performance characteristics for identifying low- and high-risk women who will develop severe preeclampsia.28 However, when undertaken in the first trimester, the readings have only low to moderate predictive sensitivity and specificity. Reviews and test performance studies of existing and candidate biomarkers and clinical tests do not yet support their use in routine clinical care to identify women at increased risk of preeclampsia.29-31

The most consistent risk factors resulting in the highest preeclampsia incidence based on patient medical history are previous preeclampsia, certain chronic medical conditions (e.g., diabetes, chronic hypertension, renal disease, and autoimmune diseases such as systemic lupus erythematosus and antiphospholipid syndrome), and multifetal pregnancy.32 Moderately increased risk for preeclampsia is associated with first birth, older maternal age (i.e, ≥35 years), high BMI (≥35 kg/m^2^), family history of preeclampsia (mother, sister), and other personal history risk factors (e.g., pregnancy interval over 10 years, low birth weight).33 Risk factors with less consistent evidence that are the subject of ongoing research include changes in paternity between pregnancies, reduced exposure to paternal semen (in vitro fertilization, sperm donation), interpregnancy weight change,34 history of migraine headaches, and various biomarkers and clinical readings.1,35,36

Efforts to develop predictive models for identifying women who will develop preeclampsia and its adverse consequences have been undertaken, but are not yet sufficient.37,38 Multiple risk factors can heighten preeclampsia risk, and efforts to develop and validate multivariable algorithms for risk prediction are ongoing.39,40

## Interventions to Prevent and Treat Preeclampsia

Efforts to identify and evaluate interventions that would prevent or delay the onset of preeclampsia have included studies of diet, weight loss, activity level, vitamins, antioxidants, nitrates, and various candidate anticoagulant and antiplatelet medications, such as heparin, low-dose aspirin, and dipyridamole, either alone or in combination. While a few of these have shown benefit in initial studies, the most consistent and promising prophylaxis, showing modest benefit in rigorous randomized trials, has been low-dose aspirin.

Once preeclampsia develops, delivery of the placenta is the only treatment. Upon delivery, blood pressure and laboratory readings generally return to normal-range values within a few days, although some women experience persistent high blood pressure that usually resolves within 6 weeks.13 For women who develop severe preeclampsia, intravenous administration of magnesium sulfate is effective for reducing the risk of eclamptic seizures. Depending on the timing of the onset of preeclampsia, clinical decisions regarding expectant management or induction of labor are required, especially for preterm preeclampsia (<34 weeks); while continuation of pregnancy could confer improvements in neonatal outcomes, it risks stillbirth and maternal harm.

## Current Clinical Practice

The clinical application of low-dose aspirin to prevent the development of preeclampsia has increased over the past decade, as evidence suggesting its potential effectiveness has accrued. A 2010 analysis to investigate the clinical variation in therapeutic treatments for preeclampsia conducted in the United Kingdom found that 24 percent of pregnant women at high risk for developing preeclampsia had been prescribed low-dose aspirin (75 mg/day).41 Similarly, a survey of German obstetricians (n=717) found that 38.1 percent reported prescribing aspirin to patients with moderate or severe hypertension during pregnancy.42 A survey of South African obstetricians (n=432) that investigated the clinical management of hypertensive disorders in pregnancy found that 58 percent would prescribe low-dose aspirin to prevent preeclampsia in their patients.43 A study of Swedish obstetricians (n=92) reported that 8 percent would prescribe low-dose aspirin to patients with mild hypertension and 20 percent would prescribe aspirin to patients with severe hypertension.44 These international data demonstrate that, while obstetricians have begun to prescribe aspirin to their patients who are at risk of developing preeclampsia, clinical practice still varies considerably. Data on preeclampsia prevention practices using low-dose aspirin by U.S. physicians are not available.

In 2009, the National Institute for Health and Clinical Excellence (NICE) released evidence-based guidance for managing hypertensive disorders during pregnancy.45 It recommended that women at high risk for developing preeclampsia (women with a history of hypertensive disease in a previous pregnancy, chronic kidney disease, autoimmune disease, type 1 or 2 diabetes, or chronic hypertension) take 75 mg of aspirin a day starting at 12 weeks until the baby is born (Table 1). Similarly, it recommends that women with more than one moderate risk factor (first pregnancy, age ≥40 years, pregnancy interval of >10 years, BMI ≥35 kg/m^2^, family history of preeclampsia, or multiple pregnancies) take 75 mg of aspirin per day starting at 12 weeks' gestation and continuing until the baby is born.45

Table 1 Current Clinical Recommendations

Organization | Guideline | Definition of treatment population
National Institute for Health and Clinical Excellence (NICE), 2011 | NICE advises that women at high risk of preeclampsia or with more than one moderate risk factor take 75 mg of aspirin daily from 12 weeks until the birth of the baby. | High risk if any:; - Hypertensive disease during prior pregnancy; - Chronic kidney disease; - Autoimmune disease; - Type 1 or type 2 diabetes; - Chronic hypertension; High risk if > 1 of the following moderate risks:; - First pregnancy; - Age ≥40 years; - >10-year pregnancy interval; - BMI ≥35 kg/m^2^; - Family history of preeclampsia (mother, sister); - Multiple pregnancy
World Health Organization (WHO), 2011 | WHO recommends that women at high risk of preeclampsia take 75 mg of aspirin daily, initiated before 20 weeks of pregnancy. | High risk:^*^; - Previous preeclampsia; - Diabetes; - Chronic hypertension; - Renal disease; - Autoimmune disease; - Multiple pregnancy

* The WHO guidelines note that this is not an exhaustive list of high-risk factors.

In 2011, the World Health Organization (WHO) issued “Recommendations for Prevention and Treatment of Preeclampsia and Eclampsia,” which comprised 23 recommendations.46 Among these recommendations is use of low-dose aspirin (75 mg/day) by women deemed high-risk and initiation early during pregnancy (<20 weeks and as early as 12 weeks). In this review, WHO defined women as being at high risk of preeclampsia if they had any of the following in their health history: previous preeclampsia, diabetes, chronic hypertension, renal or autoimmune disease, or multiple pregnancies.46 In its recommendation, WHO cautioned that, while using low-dose aspirin appears to be beneficial for women who are at high risk of developing preeclampsia, there is a scarcity of evidence to suggest that further subgroups of high-risk women could benefit from aspirin therapy. The evidence used to support the recommendation was heavily based on a 2007 Cochrane review47 of 59 randomized controlled trials (RCTs) conducted in women considered to be at moderate or high risk of developing preeclampsia. This Cochrane review found a significant risk reduction in women who received any antiplatelet agent compared with women who received placebo or no treatment (relative risk [RR], 0.82 [95% CI, 0.78 to 0.89]). While this finding was apparent regardless of risk stratification, it was more pronounced in women deemed high risk (RR, 0.75 [95% CI, 0.66 to 0.85]). This review also investigated the role of aspirin dosage and found that increased risk reduction for developing preeclampsia was apparent with low-dose aspirin of 75 to 150 mg/day, but not in trials using less than 75 mg/day.46

## Previous USPSTF Recommendation

In 1996, the U.S. Preventive Services Task Force (USPSTF) concluded that there was insufficient evidence to recommend for or against the routine use of aspirin for the prevention of either preeclampsia or IUGR. The USPSTF found inadequate evidence that aspirin confers benefits to pregnant women at increased risk of preeclampsia. Benefits to infants of these mothers were suggested by significant reduction in preterm birth, but a lack of consistency in the inclusion criteria of studies and a lack of other health benefits in infants led to an overall assessment that evidence on benefits remained inadequate. Aspirin use had also been associated with risk of placental abruption in one included study. Therefore, the USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of aspirin prophylaxis to prevent preeclampsia in pregnant women at increased risk of preeclampsia.