# Additional Analyses Figures

Appendix F Figure 1 Funnel Plot of Perinatal Mortality With Pseudo 95% Confidence Limits (All Trials)

Appendix F Figure 1 is a funnel plot depicting risk of publication bias in all trials for the outcome of perinatal mortality.

Figure 2 Sensitivity Analysis of Perinatal Mortality Sorted by Sample Size (All Trials), Removing IUGR-Only Participants

Appendix F Figure 2 is a forest plot depicting the sensitivity analysis for the outcome of perinatal mortality sorted by sample size, excluding IUGR only participants.

Figure 3 Sensitivity Analysis of IUGR Stratified by Initiation Week (Trials of Women at Risk of Preeclampsia [MFMU Not Included])

Appendix F Figure 3 is a forest plot depicting the sensitivity analysis of IUGR stratified by initiation week and excluding participants from the MFMU trial.

Figure 4 Funnel Plot for IUGR With Pseudo 95% Confidence Limits (Trials of Women at Risk of Preeclampsia)

Appendix F Figure 4 is a funnel plot depicting risk of publication bias for IUGR in trials of women at risk for preeclampsia.

Figure 5 Funnel Plot for Preterm Birth With Pseudo 95% Confidence Limits (Trials of Women at Risk of Preeclampsia)

Appendix F Figure 5 is a funnel plot depicting risk of publication bias for preterm birth in trials of women at risk for preeclampsia.

Figure 6 Funnel Plot for Preeclampsia With Pseudo 95% Confidence Limits (Trials of Women at Risk of Preeclampsia)

Appendix F Figure 6 is a funnel plot depicting risk of publication bias for preeclampsia in trials of women at risk for preeclampsia.

Figure 7 Pooled Analysis of Preeclampsia Sorted by Initiation Week of Treatment

Appendix F Figure 7 is a forest plot depicting the relative risk for preeclampsia after aspirin prophylaxis sorted by initiation week of treatment.

Figure 8 Pooled Analysis of Preeclampsia Sorted by Dose of Aspirin (Trials of Women at Risk of Preeclampsia)

Appendix F Figure 8 is a forest plot depicting the relative risk for preeclampsia after aspirin prophylaxis sorted by aspirin dose.

Figure 9 Pooled Analysis of Perinatal Mortality Stratified by Risk Category (All Trials)

Appendix F Figure 9 is a forest plot depicting the relative risk for perinatal mortality after aspirin prophylaxis stratified by risk category.

Figure 10 Pooled Analysis of Abruption Stratified by Risk Category (All Trials)

Appendix F Figure 10 is a forest plot depicting the relative risk for abruption after aspirin prophylaxis stratified by risk category.

Figure 11 Pooled Analysis of Abruption Stratified by Aspirin Dose (All Trials)

Appendix F Figure 11 is a forest plot depicting the relative risk for abruption after aspirin prophylaxis stratified by aspirin dose.

Figure 12 Pooled Analysis of Abruption Stratified by Initiation Week of Treatment (All Trials)

Appendix F Figure 12 is a forest plot depicting the relative risk for abruption after aspirin prophylaxis stratified by initiation week of treatment.

Figure 13 Sensitivity Analysis of Preeclampsia Sorted by Sample Size (Trials of Women at Risk of Preeclampsia), Removing IUGR-Only Participants

Appendix F Figure 13 is a forest plot depicting a sensitivity analysis of relative risk of preeclampsia after aspirin prophylaxis, sorted by sample size, and excluding IUGR participants.

Figure 14 Sensitivity Analysis of Preterm Birth Sorted by Sample Size (Trials of Women at Risk of Preeclampsia), Removing IUGR-Only Participants

Appendix F Figure 14 is a forest plot depicting a sensitivity analysis of relative risk of preterm birth after aspirin prophylaxis, sorted by sample size, and excluding IUGR only participants.

Figure 15 Sensitivity Analysis of IUGR Sorted by Sample Size (All Trials), Removing IUGR-Only Participants

Appendix F Figure 15 is a forest plot depicting sensitivity analysis of relative risk for IUGR after aspirin prophylaxis sorted by sample size and excluding IUGR only participants.