# Included Study Details

We identified 15 trials that met inclusion criteria for the systematic review of potential preventive benefits of low-dose aspirin for women at elevated risk of preeclampsia, including two large trials (n>1000). An additional five randomized, controlled trials (RCTs) of low-dose aspirin to prevent preeclampsia in women at low preeclampsia risk72-76 and two observational cohort studies77,78 that measured aspirin exposure and outcomes during pregnancy were identified for inclusion in the evaluation of potential harms.

## Studies for Evaluation of Benefits

A large, good-quality trial in the United States of 60 mg aspirin (MFMU 1998) was conducted in women at elevated risk of preeclampsia (n=2,503).57 Women were recruited for participation at one of 13 study sites if they were 13 to 26 weeks pregnant and belonged to one of the following predefined preeclampsia risk categories: 1) pregestational diabetes mellitus, 2) chronic hypertension, 3) current multifetal gestation, and 4) preeclampsia in a prior pregnancy. Women with diabetes and hypertension were analyzed with the diabetes group, but women with multifetal pregnancies along with diabetes or hypertension were excluded. The risk criteria and recruitment sites generated a study population with a high preeclampsia incidence; in the control group, one in five women were diagnosed (20%). The majority of women recruited were racial and ethnic minorities; over half were black (56%), with smaller numbers of Hispanic and white participants. However, there was considerable variation in the distribution by risk group. Among the participants with diabetes, a majority were white (53%), whereas among women with previous preeclampsia, 71 percent were black, 4 percent Hispanic, and 25 percent white. Among study participants with multifetal gestations, 50 percent were black, 18 percent Hispanic, and 32 percent white, and among those with chronic hypertension, 61 percent were black, 12 percent Hispanic, and 27 percent white. The average BMI reported at baseline suggests that many participants were overweight, particularly in the chronic hypertension group (mean BMI, 33 [SD, 9]). In addition, reported smoking rates during pregnancy were high in women with diabetes (22%) and chronic hypertension (17%). Unlike the other included trials, the MFMU protocol instructed women to stop taking their medication if they developed preeclampsia, limiting the ability to observe any benefits that might accompany aspirin use in women once the condition develops.

The largest included study was a multinational trial of 60 mg aspirin managed by a U.K.-based collaborating center (n=9,364) (CLASP 1994).58 The CLASP group included 16 diverse study sites (e.g., Malaysia, Spain, United Arab Emirates, Hong Kong, Canada, Germany, the United States, Sweden), but two thirds of the study participants were recruited in the United Kingdom, and some sites contributed as few as seven participants (United States). CLASP was designed as a pragmatic trial, wherein women at elevated risk of developing preeclampsia or having preeclampsia or IUGR were identified based on personal and/or medical history. Prior preeclampsia or IUGR, chronic hypertension, renal disease or other risk factors, such as age, family history, or multifetal pregnancy were identified risk factors for preeclampsia. The study authors indicated that the “fundamental criterion for entry was that the responsible clinician was uncertain whether or not to recommend aspirin in the individual pregnancy.” Treatment could begin as early as 12 weeks' gestation and participants were instructed to continue until delivery. Nearly two thirds of study participants began treatment before 20 weeks' gestation.

CLASP participants were categorized according to whether they were enrolled in the study for prophylactic or therapeutic reasons. For the purpose of our review of the preventive benefits of aspirin for morbidity and mortality from preeclampsia, we include only the prophylactic participants in our pooled analyses where possible (maternal n=7,974; fetal n=8,257). The overall incidence of preeclampsia in the control arm of the prophylactic trial population was relatively low (8%).

An international trial by Yu et al (2003) of 150 mg aspirin was conducted at 10 sites: seven in the United Kingdom and one each in Brazil, Chile, and South Africa.71 The study enrolled 560 women considered at elevated risk of preeclampsia based on results of a transvaginal color Doppler assessment of the uterine artery. Women undergoing routine ultrasonography at 22 to 24 weeks' gestation were offered a test of their mean pulsatility index. Those with readings greater than 1.6 were eligible to participate in the trial. Aspirin or an identical placebo were taken from the time of recruitment until 35 weeks' gestation. The protocol obtained a population of women with preeclampsia incidence of 19 percent.

Two good-quality trials conducted in Spain by the same research group and published 15 years apart met the review inclusion criteria.59,64 Both trials tested 100 mg of aspirin started at 12 to16 weeks in women at elevated preeclampsia or gestational hypertension risk because they were receiving treatment at a hospital specializing in high-risk pregnancies. Reasons women could receive care at the unit included prior personal or family history of gestational or chronic hypertension or preeclampsia or cardiovascular, endocrine, bleeding, or metabolic disease, and a personal history of spontaneous abortion, multiple pregnancy, obesity, and adolescent or middle aged nulliparity, among other things. For both trials, women age 18 years and older and those with multifetal pregnancies, chronic hypertension, any condition requiring hypertension or antiplatelet medications, and other health conditions were excluded, as well as inability or unwillingness to comply with the trial protocols. The trial protocol was more demanding than for other preeclampsia trials we reviewed, because 24-hour blood pressure monitoring was conducted at recruitment and every 4 weeks until delivery. In addition, women were randomized to treatment or placebo and to three different medication administration times. The earlier trial64 analyzed data from 100 women enrolled between 1994 and 1996, and the more recent trial59 analyzed data from 350 women enrolled from 1997 to 2002. The incidence of preeclampsia in the control group was 14 percent for the earlier study and 13 percent for the later study. Both studies found evidence of an effect of the timing of aspirin administration on blood pressure and, in the more recent study, significant effects of aspirin on preeclampsia, IUGR, preterm birth, and any serious adverse outcome. The timing of administration was influential on the findings, with significant differences most pronounced when aspirin was taken either 8 hours after awakening, or most effectively, at bedtime.

### Smaller Trials With Pregnancy or Medical History Risk Populations

In Israel, a good-quality trial by Caspi et al (1994) randomized women pregnant with twins to 100 mg aspirin beginning from 15 to 23 weeks' gestation until delivery (n=47).61 All pregnant women with uncomplicated twin pregnancies were considered eligible for enrollment unless they had a history of chronic renal, cardiovascular, pulmonary, or hepatic disorders; past or present coagulopathy or peptic ulcers; gestational diabetes; or a known hypersensitivity to aspirin. The protocol obtained a population of women with preeclampsia incidence of 8.7 percent in the control group and no cases in the treatment group.

A fair-quality Finish trial by Viinikka et al (1993) randomized pregnant women with preexisting hypertension or a history of severe preeclampsia in a previous pregnancy to 50 mg aspirin beginning from 15 to 16 weeks of gestation until delivery (n=208).68 Exclusion criteria were not clearly specified. Study authors reported an incidence of preeclampsia in 9.3 percent of women treated with aspirin and 11.0 percent of women taking placebo.

An Italian trial (n=33) by Benigni et al (1989) recruited pregnant women with chronic hypertension or a history of fetal death due to placental insufficiency, severe IUGR, or early onset preeclampsia (<32 weeks) in a previous pregnancy (n=33).60 Women with antiphospholipid antibodies present were excluded. Trial participants were randomized to receive 60 mg of aspirin or a matching placebo starting at 12 weeks' gestation until delivery. Women with chronic hypertension were treated with 50 mg of atenolol or atenolol plus 75 mg hydralazine to ensure that their diastolic blood pressure remained below 90 mm Hg. Only the incidence of gestational hypertension was reported, not rates of preeclampsia.

In Australia, a fair-quality trial by Gallery et al (1997) randomized pregnant women with preexisting chronic hypertension or renal disease, or a history of preeclampsia in a previous pregnancy to receive 100 mg of aspirin beginning during 17 to 19 weeks of gestation until 2 weeks prior to the planned delivery date (n=108).62 Women with a history of an allergy to aspirin, aspirin-sensitive asthma, preexisting bleeding issues, or having a multifetal pregnancy were excluded. Incidence of preeclampsia was not reported; however, key indicators of preeclampsia were reported including rates of high systolic blood pressure (>140 mm Hg), uric acid (>3.5 mmol/L), and proteinuria (>300 mg/day). Leslie et al (1995) reported additional data on neonatal outcomes and was considered as an ancillary article to Gallery et al (1997).80

### Smaller Trials Employing a Clinical Screening Test to Determine Study Eligibility

A trial by Schiff et al (1989) conducted in Israel randomized white Jewish women with nulliparity, twin gestation, or a history of preeclampsia in addition to a positive rollover test at 28 or 29 weeks' gestation to 100 mg aspirin or placebo.66 Women with chronic hypertension were excluded. The rollover test consisted of multiple side-lying blood pressure measurements to establish a baseline, and then having the woman roll to a back-lying position and taking measurements at 5 and 5.5 minutes. A rise in the 15 mm Hg diastolic blood pressure from baseline was considered a positive rollover test. A trial in The Netherlands by Wallenburg (1986) randomized women to 60 mg aspirin from 28 weeks' gestation until delivery (n=46).70 The study enrolled women with uncomplicated pregnancies and no history of cardiovascular or renal disease who screened sensitive to angiotensin II infusion. Sensitivity was defined as an effective pressor dose (minimum infusion of angiotensin II that resulted in a 20 mm Hg diastolic blood pressure rise) less than 10 ng/kg/m. The incidence of preeclampsia in the control group was 22.6 percent and aspirin was found to significantly reduce preeclampsia (p<0.05).

A fair-quality Finish trial by Villa and colleagues (n=152) recruited pregnant women at their first ultrasound screening presenting with at least one of the following risk factors: age younger than 20 or older than 40 years; BMI greater than 30 kg/m^2^; chronic hypertension; a diagnosis of Sjorgren's syndrome or lupus; or a history of gestational diabetes, preeclampsia, small for gestational age, or fetal death.69 In addition to these risk factors, women were considered for inclusion if a second-degree diastolic notch was present on transvaginal color Doppler ultrasound at 12 to 13 weeks. Participants were randomized to receive 100 mg of aspirin or placebo starting at 12 to 13 weeks of gestation through 35 weeks (or delivery if preceding 35 weeks). The incidence of preeclampsia in women taking aspirin was less than in women taking placebo, though the difference was not significant (13.1 vs. 18.3%; RR, 0.7 [95% CI, 0.3 to 1.7]).

In the United Kingdom, McParland et al (1990) randomized pregnant women with repeat abnormal Doppler waveforms at 24 weeks of gestation to 75 mg aspirin or placebo until delivery (n=106).65 Women with a known allergy to aspirin, gestational diabetes, peptic ulcers, lupus, or a history of bleeding disorders were excluded from the trial. Preeclampsia was reported in significantly more women taking placebo compared with those taking aspirin (19% vs. 2%; p<0.02).

A fair-quality Finish trial by Vainio and colleagues (2002) recruited pregnant women at risk of preeclampsia or IUGR attending antenatal clinics who were found to have a bilateral diastolic notch on ultrasound screening at 12 to 14 weeks of gestation (n=86).67 Women with a history of asthma, peptic ulcers, or an allergy to aspirin were excluded. In addition, if participants had used prostaglandin inhibitors within 10 days prior to recruitment they were not considered for inclusion to the trial. Participants were randomized to receive 0.5 mg/kg daily (mean, 49 mg/day per calculation) of aspirin or placebo starting at 12 to 14 weeks of gestation through delivery. Rates of preeclampsia were reported to be significantly higher in women taking placebo compared with women taking aspirin (23.3% vs. 4.7%; RR, 0.02 [95% CI, 0.05 to 0.86]).

## Studies for Evaluation of Harms

To address KQ 3, we included trials of aspirin use in pregnant women regardless of their risk of preeclampsia. The trials described above for KQs 1 and 2 were also included for KQ 3. The key question additionally included four trials of low-dose aspirin use for healthy nulliparous women,72-74,76 and one with a general population of women presenting to a hospital in Barbados for prenatal care.75 In total, adding these five trials, there were 19 RCTs available for analysis of harms, although not all collected data for each outcome. We also identified two observational cohort studies77,78 that met inclusion and quality criteria; one examined the effect of any aspirin exposure during pregnancy on risk of miscarriage and the other on rates of cryptorchidism among male infants.

A good-quality study by Sibai et al (1993) randomized healthy, nulliparous women between 13 and 25 weeks' gestation at seven sites in the United States (n=3,135).72 A run-in was conducted before allocating eligible participants to 60 mg daily of aspirin or identical placebo to be taken until the time of delivery. Nearly half of the participants began treatment before 20 weeks' gestation. A majority of the women were from minority racial and ethnic backgrounds; half of the study participants were black and nearly one third were Hispanic women. Slightly more women were lost to followup in the aspirin group (5.4% vs. 4.2%). The harms included for pooled analysis were placental abruption, intracranial fetal bleeding, and postpartum hemorrhage. In addition, other blood loss related outcomes and adverse events were reported. The incidence of preeclampsia was 6.3 percent in the control group.

A good-quality 28-site study (Subtil 1993) conducted in France and Belgium randomized 3,294 healthy nulliparous women without contraindications to 100 mg aspirin or identical placebo between 14 and 20 weeks' gestation.74 Participants were instructed to stop taking the medication at 34 weeks' gestation. Although 16 percent of participants stopped study treatment, there were no differences in the reasons for withdrawal by study group and there was minimal loss to followup. Results on abruption, hemorrhage, and neonatal intraventricular bleeding were available for pooled analysis. The incidence of preeclampsia in the control group was very low (1.6%).

A good-quality, large single-site study in Barbados (Rotchell 1998) randomized healthy pregnant women between 12 and 32 weeks of gestation to receive 75 mg of aspirin or placebo through delivery (n=3,647).75 Women with an increased risk of bleeding, a known allergy to aspirin, a previous history of placental abruption, or a high likelihood of immediate delivery were excluded from the trial. It was reported that 42 percent of women took their assigned medication more than 95 percent of the time during the study period. Results on abruption, perinatal mortality, and hemorrhage were available for pooled analysis. The incidence of preeclampsia in the control group was low (2.5%).

In the United States, Hauth and colleagues (1993) randomized nulliparous women in Alabama age 28 years or younger to receive 60 mg of aspirin or placebo starting at 23 weeks until delivery (n=606).73 Participants were predominantly black (approximately 72%), with an average age of approximately 20 years. Women with a history of comorbidities that are known to increase the incidence of preeclampsia or gestational hypertension (e.g., renal disease, diabetes mellitus, multifetal gestation, chronic hypertension) were excluded from the trial. Results on abruption and perinatal mortality were available for pooled analysis. The incidence of preeclampsia in the control group was reported to be 5.6 percent.

A fair-quality trial in the United Kingdom (Davies 1995) randomized healthy nulliparous women to receive 75 mg of aspirin or a matching placebo starting at 18 weeks of gestation until delivery (n=122).76 Women with multifetal gestations, diabetes mellitus, recurrent spontaneous abortions, or any contraindication to aspirin were excluded from the trial. Results on abruption and perinatal mortality were available for pooled analysis. The incidence of preeclampsia in the control group was reported to be 11.7 percent.