# Intervention and Baseline Characteristics of Included Studies

Appendix D Table 1 Methodological and Intervention Characteristics of Included Studies

Appendix D Table 2 Study Population Baseline Characteristics of Included Studies