# Excluded Studies^*^ * This is a listing of studies excluded from the review by KQ. If a study was included for one KQ, but excluded for others, it would still be listed here with the excluded KQs noted.

Exclusion Code
E1 Study relevance
E2 Setting
E3 Population E3a: Nulliparous otherwise healthy women
E4: Study quality
E5: Study design
E6: No relevant outcomes
E7: Precedes search period
E8: Provides no new data not otherwise covered in other articles for this study
E9: Geography

1 Low-dose aspirin in prevention and treatment of intrauterine growth retardation and pregnancy-induced hypertension. Italian Study of Aspirin in Pregnancy. Lancet. Feb. 13. 1993;341(8842):396. KQ1E4, KQ2E4, KQ3E4. [pmid: 8094168].
2 Bakhti A, Vaiman D. Prevention of gravidic endothelial hypertension by aspirin treatment administered from the 8th week of gestation. [Erratum appears in Hypertens Res. 2012 Feb;35(2):244]. Hypertension Research - Clinical & Experimental. Oct. 2011;34(10):1116-20. KQ1E9, KQ2E9, KQ3E9. [pmid: 21881579].
3 Benigni A, Gregorini G, Frusca T, et al. Effect of low-dose aspirin on fetal and maternal generation of thromboxane by platelets in women at risk for pregnancy-induced hypertension. N Engl J Med. Aug. 10. 1989;321(6):357-62. KQ2E6. [pmid: 2664523].
4 Byaruhanga RN, Chipato T, Rusakaniko S. Effect of low-dose aspirin on fetal and maternal generation of thromboxane by platelets in women at risk for pregnancy-induced hypertension. International Journal of Gynecology & Obstetrics. Feb. 1998;60(2):129-35. KQ1E9, KQ2E9, KQ3E9. [pmid: 9509950].
5 Chandiramani M, Seed P, Poston L, et al. Antiplatelet agents for prevention of pre-eclampsia. Lancet. Nov. 17. 2007;370(9600):1685-6. KQ1E5, KQ2E5, KQ3E5. [pmid: 18022031].
6 Chiaffarino F, Parazzini F, Paladini D, et al. A small randomised trial of low-dose aspirin in women at high risk of pre-eclampsia. European Journal of Obstetrics & Gynecology and Reproductive Biology. Feb. 10. 2004;112(2):142-4. KQ1E4, KQ2E4, KQ3E4. [pmid: 14746947].
7 Cowchock S, Reece EA. Do low-risk pregnant women with antiphospholipid antibodies need to be treated? Organizing Group of the Antiphospholipid Antibody Treatment Trial. Am J Obstet Gynecol. May. 1997;176(5):1099-100. KQ1E3, KQ2E3, KQ3E6. [pmid: 9166175].
8 Cruickshank DJ, Robertson AA, Campbell DM, et al. Maternal Obstetric Outcome Measures in A Randomised Controlled Study of Labetalol in the Treatment of Hypertension in Pregnancy. Hypertension in Pregnancy. Jan. 1. 1991;b10(3):333-44. PMID: none. KQ1E1a, KQ2E1a, KQ3E1a.
9 Dasari R, Narang A, Vasishta K, et al. Effect of maternal low dose aspirin on neonatal platelet function. Indian Pediatr. Jun. 1998;35(6):507-11. KQ1E9, KQ2E9, KQ3E9. [pmid: 10216644].
10 Davies NJ, Gazvani MR, Farquharson RG, et al. Low-Dose Aspirin in the Prevention of Hypertensive Disorders of Pregnancy in Relatively Low-Risk Nulliparous Women. Hypertension in Pregnancy. 1995;14(1):49-55. PMID: none. KQ1E3a, KQ2E3a.
11 Ebrashy A, Ibrahim M, Marzook A, et al. Usefulness of aspirin therapy in high-risk pregnant women with abnormal uterine artery Doppler ultrasound at 14-16 weeks pregnancy: randomized controlled clinical trial. Croat Med J. Oct. 2005;46(5):826-31. KQ1E9, KQ2E9, KQ3E9. [pmid: 16158479].
12 Elder MG, de SM, Sullivan M. A randomised trial of low dose aspirin for primiparae in pregnancy (Golding)/Barbados low dose aspirin study in pregnancy (BLASP) (Rotchell et al.). Br J Obstet Gynaecol. Feb. 1999;106(2):180. KQ1E5, KQ2E5, KQ3E5. [pmid: 10426687].
13 Gallery EDM, Ross MR, Hawkins M, et al. Low-Dose Aspirin in High-Risk Pregnancy?. Hypertension in Pregnancy. Jan. 1997;16(2):229-38. PMID: none. KQ2E6.
14 Goffinet F, Breart G, Uzan S. ECPPA: randomised trial of low dose aspirin for the prevention of maternal and fetal complications in high risk pregnant women. Br J Obstet Gynaecol. Jul. 1996;103(7):719-20. KQ1E9, KQ2E9, KQ3E9. [pmid: 8688404].
15 Golding J. A randomised trial of low dose aspirin for primiparae in pregnancy. The Jamaica Low Dose Aspirin Study Group. Br J Obstet Gynaecol. Mar. 1998;105(3):293-9. KQ1E9, KQ2E9, KQ3E9. [pmid: 9532989].
16 Gunawardana L, Zammit S, Lewis G, et al. Examining the association between maternal analgesic use during pregnancy and risk of psychotic symptoms during adolescence. Schizophrenia Research. Mar. 2011;126(1-3):220-5. KQ1E1, KQ2E1, KQ3E4. [pmid: 21146371].
17 Hauth JC, Goldenberg RL, Parker CR Jr., et al. Low-dose aspirin therapy to prevent preeclampsia. Am J Obstet Gynecol. Apr. 1993;168(4):1083-91. KQ1E3a, KQ2E3a. [pmid: 8475955].
18 Hermida RC, Ayala DE, Iglesias M, et al. Time-dependent effects of low-dose aspirin administration on blood pressure in pregnant women. Hypertension. Sep. 1997;30(3 Pt 2):589-95. KQ3E6. [pmid: 9322987].
19 Hermida RC, Ayala DE, Fernandez JR, et al. Administration time-dependent effects of aspirin in women at differing risk for preeclampsia. Hypertension. Oct. 1999;34(4 Pt 2):1016-23. KQ1E6, KQ2E6, KQ3E6. [pmid: 10523401].
20 Hermida RC, Ayala DE, Iglesias M. Administration time-dependent influence of aspirin on blood pressure in pregnant women. Hypertension. Mar. 2003;41(3 Pt 2):651-6. KQ1E6, KQ2E6, KQ3E6. [pmid: 12623974].
21 Hernandez RK, Werler MM, Romitti P, et al. Nonsteroidal antiinflammatory drug use among women and the risk of birth defects. American Journal of Obstetrics & Gynecology. Mar. 2012;206(3):228. KQ1E5, KQ2E5, KQ3E4. [pmid: 22196851].
22 Jensen MS, Rebordosa C, Thulstrup AM, et al. Maternal use of acetaminophen, ibuprofen, and acetylsalicylic acid during pregnancy and risk of cryptorchidism. Epidemiology. Nov. 2010;21(6):779-85. KQ1E5, KQ2E5. [pmid: 20805751].
23 Jensen MS, Henriksen TB, Rebordosa C, et al. Analgesics during pregnancy and cryptorchidism: additional analyses. Epidemiology. Jul. 2011;22(4):610-2. KQ1E5, KQ2E5, KQ3E5. [pmid: 21642784].
24 Keim SA, Klebanoff MA. Aspirin use and miscarriage risk. Epidemiology. Jul. 2006;17(4):435-9. KQ1E5, KQ2E5. [pmid: 16755260].
25 Kincaid-Smith P, North RA, Fairley KF, et al. Prevention of pre-eclampsia in high risk women with renal disease: A prospective randomized trial of heparin and dipyridamole. Nephrology. Aug. 1. 1995;1(4):297-300. PMID: none. KQ1E1a, KQ2E1a, KQ3E1a.
26 Louden KA, Broughton PF, Symonds EM, et al. A randomized placebo-controlled study of the effect of low dose aspirin on platelet reactivity and serum thromboxane B2 production in non-pregnant women, in normal pregnancy, and in gestational hypertension. Br J Obstet Gynaecol. May. 1992;99(5):371-6. KQ1E10, KQ2E10. [pmid: 1622907].
27 Marret S, Marchand L, Kaminski M, et al. Prenatal low-dose aspirin and neurobehavioral outcomes of children born very preterm. Pediatrics. Jan. 2010;125(1):e29-e34. KQ1E5, KQ2E5, KQ3E3. [pmid: 20026499].
28 Michael CA, Walters BNJ. Low-dose aspirin in the prevention of pre-eclampsia: current evaluation. Teoh ERS, MacNaughton M, editors. Maternal Physiology and Pathology. Carnforth, UK. Parthenon Publishing Group Limited. 1992:183-9. KQ1E4, KQ2E4, KQ3E4.
29 Miller EA, Rasmussen SA, Siega-Riz AM, et al. Risk factors for non-syndromic holoprosencephaly in the National Birth Defects Prevention Study. American Journal of Medical Genetics. Feb. 15. 2010;Part(1):62-72. KQ1E5, KQ2E5, KQ3E4. [pmid: 20104597].
30 Newnham JP, Godfrey M, Walters BJ, et al. Low dose aspirin for the treatment of fetal growth restriction: a randomized controlled trial. Aust N Z J Obstet Gynaecol. Nov. 1995;35(4):370-4. KQ1E3, KQ2E3. [pmid: 8717556].
31 Ognjanovic S, Blair C, Spector LG, et al. Analgesic use during pregnancy and risk of infant leukaemia: a Children's Oncology Group study. British Journal of Cancer. Feb. 1. 2011;104(3):532-6. KQ1E4, KQ2E4, KQ3E4. [pmid: 21157452].
32 Porreco RP, Hickok DE, Williams MA, et al. Low-dose aspirin and hypertension in pregnancy. Lancet. Jan. 30. 1993;341(8840):312. KQ1E4, KQ2E4, KQ3E4. [pmid: 8093955].
33 Prakalapakorn SG, Rasmussen SA, Lambert SR, et al. Assessment of risk factors for infantile cataracts using a case-control study: National Birth Defects Prevention Study, 2000-2004. Ophthalmology. Aug. 2010;117(8):1500-5. KQ1E5, KQ2E5, KQ3E4. [pmid: 20363508].
34 Rai U, Chakravorty M, Juneja Y. Role of Low Dose Aspirin in PIH. Journal of Obstetrics and Gynecology of India. 1993:883-6. PMID: none. KQ1E9, KQ2E9, KQ3E9.
35 Ramaiya C, Mgaya HN. Low dose aspirin in prevention of pregnancy-induced hypertension in primigravidae at the Muhimbili Medical Center, Dar es Salaam. East Afr Med J. Nov. 1995;72(11):690-3. KQ1E9, KQ2E9, KQ3E9. [pmid: 8904056].
36 Riva-Echeverria C, E Y, Molina L, et al. Synergic use of aspirin, fish oil, and vitamins C and E for the prevention of precclampsia. Hypertens Pregnancy. 2000;2000(19):30. PMID: none. KQ1E9, KQ2E9, KQ3E9.
37 Roberts JM, Catov JM. Aspirin for pre-eclampsia: compelling data on benefit and risk. Lancet. May. 26. 2007;369(9575):1765-6. KQ1E5, KQ2E5, KQ3E5. [pmid: 17512047].
38 Rogers MS, Fung HY, Hung CY. Calcium and low-dose aspirin prophylaxis in women at high risk of pregnancy-induced hypertension. Hypertens Pregnancy. 1999;18(2):165-72. KQ1E4, KQ2E4, KQ3E4. [pmid: 10476618].
39 Rotchell YE, Cruickshank JK, Gay MP, et al. Barbados Low Dose Aspirin Study in Pregnancy (BLASP): a randomised trial for the prevention of pre-eclampsia and its complications. Br J Obstet Gynaecol. Mar. 1998;105(3):286-92. KQ1E3, KQ2E3. [pmid: 9532988].
40 Roy UK, Pan S. A study of use of low dose aspirin in prevention of pregnancy induced hypertension. J Indian Med Assoc. Jun. 1994;92(6):188-91. KQ1E9, KQ2E9, KQ3E9. [pmid: 7930659].
41 Schiff E, Barkai G, Ben-Baruch G, et al. Low-dose aspirin in primigravidae with positive roll-over test. Obstet Gynecol. Nov. 1990;76(5 Pt 1):742-4. PMID: none. KQ1E3, KQ2E3, KQ3E3. [pmid: 2216216].
42 Schrocksnadel H, Sitte B, Alge A, et al. Low-dose aspirin in primigravidae with positive roll-over test. Gynecol Obstet Invest. 1992;34(3):146-50. KQ1E4, KQ2E4, KQ3E4. [pmid: 1427414].
43 Seki H, Kuromaki K, Takeda S, et al. Trial of prophylactic administration of TXA2 synthetase inhibitor, ozagrel hydrochloride, for preeclampsia. Hypertens Pregnancy. 1999;18(2):157-64. KQ1E1a, KQ2E1a, KQ3E1a. [pmid: 10476617].
44 Shenoy S, Chandrika D, Pisharody R. RCT of low dose aspirin to prevent the progression of pregnancy induced hypertension grade A to B. Journal of Clinical Epidemiology. Mar. Supplement 1. 1999;52(0):28S. PMID: none. KQ1E9, KQ2E9, KQ3E9.
45 Sibai BM, Caritis SN, Thom E, et al. Prevention of preeclampsia with low-dose aspirin in healthy, nulliparous pregnant women. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. N Engl J Med. Oct. 21. 1993;329(17):1213-8. KQ1E3a, KQ2E3a. [pmid: 8413387].
46 Souza EV, Sass N, Atallah AN, et al. Aspirin and calcium to prevent pre eclampsia in chronic hypertension women with abnormal uterine artery doppler ultrasound [abstract]. Hypertension in Pregnancy. 2006;25:152. PMID: none. KQ1E1, KQ2E1, KQ3E1.
47 Subtil D, Goeusse P, Puech F, et al. Aspirin (100 mg) used for prevention of pre-eclampsia in nulliparous women: the Essai Regional Aspirine Mere-Enfant study (Part 1). BJOG. May. 2003;110(5):475-84. KQ1E3a, KQ2E3a. [pmid: 12742332].
48 Tewari S, Kaushish R, Sharma S, et al. Role of low dose aspirin in prevention of pregnancy induced hypertension. J Indian Med Assoc. Feb. 1997;95(2):43-4. 47. KQ1E9, KQ2E9, KQ3E9. [pmid: 9357241].
49 Tulppala M, Marttunen M, Soderstrom-Anttila V, et al. Low-dose aspirin in prevention of miscarriage in women with unexplained or autoimmune related recurrent miscarriage: effect on prostacyclin and thromboxane A2 production. Hum Reprod. Jul. 1997;12(7):1567-72. KQ1E3, KQ2E3, KQ3E3. [pmid: 9262298].
50 Tyler CP, Paneth N, Allred EN, et al. Brain damage in preterm newborns and maternal medication: the ELGAN Study. American Journal of Obstetrics & Gynecology. Sep. 2012;207(3):192-9. KQ1E3, KQ2E3, KQ3E3. [pmid: 22939723].
51 Uzan S, Beaufils M, Breart G, et al. Prevention of fetal growth retardation with low-dose aspirin: findings of the EPREDA trial. Lancet. Jun. 15. 1991;337(8755):1427-31. KQ1E1a, KQ2E1a, KQ3E1a. [pmid: 1675315].
52 Vaseie M. The effect of low-dose acetylsalicylic acid (ASA) on control of hypertensive in pregnancy [abstract]. Hypertension in Pregnancy. 2006;25:148. PMID: none. KQ1E2, KQ2E2, KQ3E2.
53 Villa P, Kajantie E, Raikkonen K, et al. Aspirin in the prevention of pre-eclampsia in high-risk women: a randomised placebo-controlled PREDO Trial and a meta-analysis of randomised trials. BJOG. Jan. 2013;120(1):64-74. KQ3E6. [pmid: 23126307].
54 Wallenburg HC, Dekker GA, Makovitz JW, et al. Effect of low-dose aspirin on vascular refractoriness in angiotensin-sensitive primigravid women. Am J Obstet Gynecol. May. 1991;164(5 Pt 1):1169-73. KQ1E6, KQ2E6, KQ3E6. [pmid: 2035557].
55 Wang Z, Li W. A prospective randomized placebo-controlled trial of low-dose aspirin for prevention of intra-uterine growth retardation. Chin Med J (Engl). Mar. 1996;109(3):238-42. KQ1E9, KQ2E9, KQ3E9. [pmid: 8758317].
56 Werler MM, Mitchell AA, Moore CA, et al. Is there epidemiologic evidence to support vascular disruption as a pathogenesis of gastroschisis?. American Journal of Medical Genetics. Jul. 2009;Part(7):1399-406. KQ1E5, KQ2E5, KQ3E4. [pmid: 19533769].
57 Werler MM, Bosco JL, Shapira SK, et al. Maternal vasoactive exposures, amniotic bands, and terminal transverse limb defects. Birth Defects Research. Jan. 2009;85(1):52-7. KQ3E4. [pmid: 19067400].
58 Wyatt-Ashmead J. Antenatal closure of the ductus arteriosus and hydrops fetalis. Pediatric & Developmental Pathology. Nov. 2011;14(6):469-74. KQ1E1, KQ2E1, KQ3E5. [pmid: 21985268].
59 Zimmermann P, Eiri V, Koskinen J, et al. Effect of low-dose aspirin treatment on vascular resistance in the uterine, uteroplacental, renal and umbilical arteries GÇö A prospective longitudinal study on a high risk population with persistent notch in the uterine arteries. European Journal of Ultrasound. Feb. 1997;5(1):17-30. KQ1E4, KQ2E4, KQ3E4.