# Ongoing or Recently Completed Studies

Study, Year initiated | Design | Aim | Location | Number of participants | Intervention description | Relevant outcomes | 2013 status
Odibo, 2012 | RCT | Determine the efficacy of low-dose aspirin for preventing preeclampsia in women identified as high risk by a first trimester multiparameter predictive model | United States | Estimated enrollment: 220 | Aspirin (81 mg per day) until 37 weeks of gestation or labor, whichever comes first | Preeclampsia | Estimated completion: September 2014
Nicolaides, 2011 | RCT | To examine if the prophylactic use of low-dose aspirin from the first-trimester of pregnancy in women at increased risk for preeclampsia can reduce the incidence and severity of the disease | United Kingdom | Estimated enrollment: 1,560 | Aspirin (75 mg per day) from 12 to 34 weeks of gestation or labor, whichever comes first | Preeclampsia, harms | Estimated completion: September 2016
Perrotin, 2012 | RCT | Determine the efficacy of low-dose aspirin, given at bedtime and started early during pregnancy, in nulliparous pregnant women selected as high-risk by the presence of a bilateral uterine artery notch or bilateral uterine artery PI ≥1.7 during the first trimester ultrasound scan, to prevent the occurrence of preeclampsia | France | Estimated enrollment: 4,972 | Aspirin (160 mg per day) until 34 weeks of gestation | Preeclampsia | Estimated completion: June 2015
Varea, 2012 | RCT | Determine whether low-dose aspirin improves trophoblastic invasion evaluated at third trimester in women defined as high-risk by abnormal uterine artery Doppler at first trimester | Spain | Estimated enrollment: 270 | Aspirin (150 mg per day) | Uterine artery mean pulsatility; preeclampsia | Estimated completion: December 2013