# Detailed Methods

Key Question Literature Search Strategies

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) <1946 to Present>, Ovid MEDLINE(R) Daily Update <January 21, 2013>

------------------------------------------------------------------------------------

1. Pregnancy/ (658667)
2. pregnan$.ti,ab. (341659)
3. Pre-Eclampsia/ (21883)
4. Hypertension, Pregnancy-Induced/ (1258)
5. Eclampsia/ (3575)
6. preeclamp$.ti,ab. (11205)
7. eclamp$.ti,ab. (10638)
8. ((edema or proteinuria or hypertension) adj5 gestosis).ti,ab. (80)
9. eph gestosis.ti,ab. (433)
10. (tox?emi$ adj3 (eph or pregnan$)).ti,ab. (3016)
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 (732271)
12. Aspirin/ (36192)
13. Platelet Aggregation Inhibitors/ (24185)
14. aspirin.ti,ab. (34133)
15. acetylsalicylic acid.ti,ab. (6934)
16. antiplatelet$.ti,ab. (14123)
17. anti platelet.ti,ab. (2694)
18. (platelet adj3 (inhibitor$ or antiaggregant$ or antagonist$)).ti,ab. (5766)
19. 12 or 13 or 14 or 15 or 16 or 17 or 18 (77920)
20. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. (648797)
21. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ (245203)
22. Meta-Analysis as Topic/ (12362)
23. clinical trial$.ti,ab. (187084)
24. controlled trial$.ti,ab. (97536)
25. random$.ti,ab. (623402)
26. 20 or 21 or 22 or 23 or 24 or 25 (1212442)
27. 11 and 19 and 26 (637)
28. Pregnancy/ (658667)
29. pregnan$.ti,ab. (341659)
30. 28 or 29 (730270)
31. adverse effects.fs. (1261233)
32. harm$.ti,ab. (86890)
33. adverse.ti,ab. (246918)
34. Hemorrhage/ (48479)
35. h?emorrhag$.ti,ab. (169627)
36. bleed$.ti,ab. (127314)
37. blood loss.ti,ab. (28329)
38. 31 or 32 or 33 or 34 or 35 or 36 or 37 (1735339)
39. Pregnancy complications/ (68804)
40. Maternal death/ (6)
41. Maternal mortality/ (7271)
42. Fetal death/ (22304)
43. Fetal mortality/ (213)
44. Congenital abnormalities/ (28816)
45. Postpartum hemorrhage/ (4314)
46. Abruptio Placentae/ (1704)
47. Abortion, Spontaneous/ (13505)
48. ((pregnan$ or maternal or f?etal or f?etus or neonat$) adj3 complication$).ti,ab. (12761)
49. ((congenital or birth or f?etal or f?etus) adj3 (defect$ or abnormal$ or anomal$)).ti,ab. (45623)
50. ((maternal or f?etal or f?etus) adj3 death$).ti,ab. (11168)
51. miscarr$.ti,ab. (7884)
52. spontaneous abortion$.ti,ab. (7888)
53. (placenta$ adj abruption$).ti,ab. (1207)
54. 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 (189547)
55. 30 and 38 (101741)
56. 54 or 55 (261683)
57. 19 and 56 (1649)
58. 27 or 57 (1904)
59. limit 58 to english language (1558)
60. limit 59 to yr=“2006 - 2013” (444)

Database: Cochrane Database of Systematic Reviews, CENTRAL

------------------------------------------------------------------------------------

#1 pregnan*:ti,ab,kw or preeclamp*:ti,ab,kw or eclamp*:ti,ab,kw from 2006 to 2013, in Trials 4981
#2 aspirin:ti,ab,kw or “acetylsalicylic acid ”:ti,ab,kw or antiplatelet*:ti,ab,kw or anti next platelet*:ti,ab,kw from 2006 to 2013, in Trials 1690
#3 platelet*:ti,ab,kw from 2006 to 2013, in Trials 2408
#4 inhibitor*:ti,ab,kw or antiaggregant*:ti,ab,kw or antagonist*:ti,ab,kw from 2006 to 2013, in Trials 15029
#5 #3 and #4 from 2006 to 2013, in Trials 1243
#6 #2 or #5 from 2006 to 2013, in Trials 2235
#7 #1 and #6 from 2006 to 2013, in Trials 49

Database: PubMed, publisher-supplied

------------------------------------------------------------------------------------

Search | Query | Items found
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6) AND English[Language] Filters: Publication date from 2006/01/01 to 2013/12/31 | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND publisher[sb] | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #4 | 364 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search random*[tiab] OR clinical trial*[tiab] OR controlled trial*[tiab] | 782669 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #2 | 1764 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search aspirin[tiab] OR antiplatelet*[tiab] OR anti platelet*[tiab] OR acetylsalicylic acid[tiab] | 52413 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search pregnan*[tiab] OR preeclamp*[tiab] OR eclamp*[tiab] | 355509 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)

Systematic Evidence Review Search

Database: AHRQ

------------------------------------------------------------------------------------

Aspirin Prophylaxis in Pregnancy [Chapter in Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. 2nd edition US Preventive Services Task Force.] 1996 **ARCHIVED**

http://www.ncbi.nlm.nih.gov/books/NBK15451/

Database: BMJ Clinical Evidence

------------------------------------------------------------------------------------

Pre-eclampsia, eclampsia, and hypertension, February 2011 (based on 2010 search) http://clinicalevidence.bmj.com/x/pdf/clinical-evidence/en-gb/systematic-review/1402.pdf

Database: Cochrane Database of Systematic Reviews (Issue 12 of 12, Dec 2012)

------------------------------------------------------------------------------------

#1 “preeclampsia”:ti,ab,kw
#2 “pre eclampsia”:ti,ab,kw
#3 “preeclamptic”:ti,ab,kw
#4 “pre eclamptic”:ti,ab,kw
#5 “hypertension”:ti,ab,kw
#6 “hypertensive”:ti,ab,kw
#7 #5 or #6
#8 “pregnancy”:ti,ab,kw
#9 “pregnant”:ti,ab,kw
#10 #8 or #9
#11 #7 and #10
#12 #1 or #2 or #3 or #4 or #11
#13 “aspirin”:ti,ab,kw
#14 “antiplatelet”:ti,ab,kw
#15 “anti platelet”:ti,ab,kw
#16 “antiplatelets”:ti,ab,kw
#17 “anti platelets”:ti,ab,kw
#18 #13 or #14 or #15 or #16 or #17
#19 #12 and #18 (limit to 2007-2012)

Database: DARE

------------------------------------------------------------------------------------

1. (preeclampsia) OR (preeclamptic) OR (pre eclampsia) OR (pre eclamptic)
2. (hypertension) OR (hypertensive)
3. (pregnant) OR (pregnancy)
4. #2 AND #3
5. #1 OR #4
6. (aspirin) OR (antiplatelet) OR (anti platelet) OR (antiplatelets) OR (anti platelets)
7. #5 AND #6 FROM 2007 TO 2012

Database: NICE

------------------------------------------------------------------------------------

Hypertension in pregnancy: NICE guideline. October 2012 http://www.nice.org.uk/nicemedia/live/13098/50418/50418.pdf

Database: Pubmed

------------------------------------------------------------------------------------

1. (“Hypertension, Pregnancy-Induced”[Mesh:NoExp] OR “Eclampsia”[Mesh:NoExp] OR “Pre-Eclampsia”[Mesh:NoExp])
2. (“Aspirin”[Mesh:noexp] OR “Platelet Aggregation Inhibitors” [Mesh:noexp] OR “Platelet Aggregation Inhibitors” [Pharmacological Action])
3. #1 AND #2
4. #3 AND systematic[sb]
5. (pre eclampsia[Title/Abstract] OR preeclampsia[Title/Abstract] OR pre eclamptic[Title/Abstract] OR preeclamptic[Title/Abstract])
6. (aspirin[Title/Abstract] OR antiplatelet[Title/Abstract] OR anti platelet[Title/Abstract] OR antiplatelets[Title/Abstract] OR anti platelets[Title/Abstract])
7. #5 AND #6
8. #7 AND systematic[sb]
9. #3 OR #8
10. limit to English[Language] AND (“2007”[Date - Publication] : “3000”[Date - Publication])

Appendix A Figure 1 Literature Flow Diagram

Figure 1 is a flow chart that summarizes the search and selection of articles. There were 543 citations identified by searching MEDLINE, the Database of Abstracts of Reviews of Effects, PubMed, and the Cochrane Collaboration Registry of Controlled Trials. An additional 62 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 525 unique citations were screened at the title/abstract stage. The full-text of 73 citations were examined for inclusion for one or more of the three Key Questions. The following number of articles were included for Key Question 1 (n=54), Key Question 2 (n=56), Key Question 3 (n=74). Reasons for excluding the other articles are available in Appendix C.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Populations | Efficacy (KQs 1, 2): Pregnant women at elevated risk for preeclampsia based on: Patient characteristics, medical history, diagnostic measurements or assays (e.g., uterine artery Doppler, biomarkers) Chemoprevention harms (KQ 3): Pregnant women, fetuses, infants | Nonhuman populations; males; nonpregnant women; studies that only/exclusively include individuals seeking fertility treatment; other selected nongeneralizable populations
Disease/condition | Primary prevention of preeclampsia | Secondary and tertiary prevention of preeclampsia
Setting | Developed countries, as defined by the Human Development Index in “very high human development” category. | Countries not categorized as “very high human development,” concern for nutritional deficiencies in developing countries
Interventions | Aspirin (50 to 150 mg) | Nonaspirin antiplatelet medications or aspirin combined with other potentially active interventions
Comparisons | Placebo or no treatment | Any active substance or intervention (e.g., nonaspirin medication, dietary supplements, dietary change, bed rest, weight loss)
Outcomes | Maternal:; ■ Organ/system injury or failure:; - HELLP syndrome (hemolysis, elevated liver enzymes, and low platelet count); - Eclampsia, puerperal cerebrovascular disorder, cerebrovascular hemorrhage, edema, or embolus; - Renal or hepatic injury/failure; - Pulmonary edema, Adult Respiratory Distress Syndrome; - Disseminated Intravascular Coagulation; ■ Failed induction of labor; ■ Caesarean delivery (medically indicated or due to failed induction of labor and/or complications of labor); ■ Abruptio placentae; ■ Mental health; ■ Maternal mortality; Fetal:; ■ Preterm birth (<37 weeks), very preterm birth (<32 weeks), extremely preterm birth (<28 weeks); mean gestational age; ■ Low birth weight (≤2500 g), very low birth weight (≤1500 g), extremely low birth weight (≤1000 g); ■ Intrauterine growth restriction/small for gestational age (<10^th^ percentile weight for gestational age); ■ Complications from Caesarean delivery, labor induction, or eclampsia prophylaxis (e.g., low Apgar score, ventilation needed); ■ Perinatal/neonatal mortality; Harms from treatment:; ■ Abruptio placentae, intracranial fetal bleeding, postpartum hemorrhage, fetal malformations, behavioral or developmental problems | ■ Intermediate outcomes, such as length of hospital stay (without indication); ■ Intensive care unit admission; ■ Neonatal intensive care unit admission
Study Designs | Efficacy (KQs 1, 2): RCT only Chemoprevention harms (KQ 3): RCT or observational study (case series, cohort, registry) data | Efficacy (KQs 1, 2): Any design other than RCT Harms (KQ 3): Editorial, narrative review, commentary, postmarketing surveillance, case reports
Study Quality | Good and fair quality | Poor quality
Language | English | Non-English studies

Appendix A Table 2 Quality Assessment Criteria

Design | U.S. Preventive Services Task Force Quality Rating Criteria48 | National Institute for Health and Clinical Excellence Methodology Checklists51
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - Study addresses an appropriate and clearly focused question; - Description of the methodology used is included; - Literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - Study addresses an appropriate and clearly focused question; - Cases and controls are taken from comparable populations; - Same exclusion criteria are used for both cases and controls; - Percentage of each group (cases and controls) that participated in the study is reported; - Comparison is made between participants and nonparticipants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - It is clearly established that controls are noncases; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid, and reliable way; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided
Randomized, controlled trials | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes are considered | - Study addresses an appropriate and clearly focused question; - Assignment of subjects to treatment groups is randomized; - Adequate concealment method is used; - Subjects and investigators are kept “blind” about treatment allocation; - Treatment and control groups are similar at the start of the trial; - Only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of the individuals or clusters recruited into each treatment arm of the study that dropped out before the study was completed is reported; - All subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - When the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes are considered | - Study addresses an appropriate and clearly focused question; - Two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - Study indicates how many of the people asked to take part did so, in each of the groups being studied; - Likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each arm of the study that dropped out before the study was completed is reported; - Comparison is made between full participants and those lost to followup, by exposure status; - Outcomes are clearly defined; - Assessment of outcome is made blind to exposure status; - When blinding is not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - Measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - Main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals are provided