# References

1 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for Asymptomatic Carotid Artery Stenosis. Evidence Synthesis No. 50. AHRQ Publication No. 08-05102-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2007.
2 Wolff T, Guirguis-Blake J, Miller T, et al. Screening for carotid artery stenosis: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2007;147(12):860-70. [pmid: 18087057].
3 U.S. Preventive Services Task Force. Screening for carotid artery stenosis: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2007;147(12):854-9. [pmid: 18087056].
4 Hall H. Ultrasound screening: misleading the public. 2008. http://www.sciencebasedmedicine.org/ultrasound-screening-misleading-the-public. October 18, 2013.
5 Kochanek KD, Xu J, Murphy SL, et al. Deaths: Final Data for 2009. Hyattsville, MD. National Center for Health Statistics. 2011. http://www.cdc.gov/nchs/data/nvsr/nvsr60/nvsr60_03.pdf.
6 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics—2012 update: a report from the American Heart Association. Circulation. 2012;125(1):e2-e220. [pmid: 22179539].
7 Centers for Disease Control and Prevention. Prevalence of stroke—United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2012;61(20):379-82. [pmid: 22622094].
8 Kistler JP, Furie KL. Carotid endarterectomy revisited. N Engl J Med. 2000;342(23):1743-5. [pmid: 10841879].
9 Centers for Disease Control and Prevention. Prevalence and most common causes of disability among adults—United States, 2005. MMWR Morb Mortal Wkly Rep. 2009;58(16):421-6. [pmid: 19407734].
10 Kelly-Hayes M, Beiser A, Kase CS, et al. The influence of gender and age on disability following ischemic stroke: the Framingham study. J Stroke Cerebrovasc Dis. 2003;12(3):119-26. [pmid: 17903915].
11 Brown DL, Boden-Albala B, Langa KM, et al. Projected costs of ischemic stroke in the United States. Neurology. 2006;67(8):1390-5. [pmid: 16914694].
12 de Weerd M, Greving JP, de Jong AW, et al. Prevalence of asymptomatic carotid artery stenosis according to age and sex: systematic review and metaregression analysis. Stroke. 2009;40(4):1105-13. [pmid: 19246704].
13 O'Leary DH, Polak JF, Kronmal RA, et al. Distribution and correlates of sonographically detected carotid artery disease in the Cardiovascular Health Study. The CHS Collaborative Research Group. Stroke. 1992;23(12):1752-60. [pmid: 1448826].
14 Longstreth WT Jr., Shemanski L, Lefkowitz D, et al. Asymptomatic internal carotid artery stenosis defined by ultrasound and the risk of subsequent stroke in the elderly. The Cardiovascular Health Study. Stroke. 1998;29(11):2371-6. [pmid: 9804651].
15 Lewis RF, Abrahamowicz M, Cote R, et al. Predictive power of duplex ultrasonography in asymptomatic carotid disease. Ann Intern Med. 1997;127(1):13-20. [pmid: 9214247].
16 Muluk SC, Muluk VS, Sugimoto H, et al. Progression of asymptomatic carotid stenosis: a natural history study in 1004 patients. J Vasc Surg. 1999;29(2):208-14. discussion 14-6. [pmid: 9950979].
17 Mansour MA, Mattos MA, Faught WE, et al. The natural history of moderate (50% to 79%) internal carotid artery stenosis in symptomatic, nonhemispheric, and asymptomatic patients. J Vasc Surg. 1995;21(2):346-56. discussion 56-7. [pmid: 7853606].
18 Nehler MR, Moneta GL, Lee RW, et al. Improving selection of patients with less than 60% asymptomatic internal carotid artery stenosis for follow-up carotid artery duplex scanning. J Vasc Surg. 1996;24(4):580-5. discussion 5-7. [pmid: 8911406].
19 Rockman CB, Riles TS, Lamparello PJ, et al. Natural history and management of the asymptomatic, moderately stenotic internal carotid artery. J Vasc Surg. 1997;25(3):423-31. [pmid: 9081121].
20 Nadareishvili ZG, Rothwell PM, Beletsky V, et al. Long-term risk of stroke and other vascular events in patients with asymptomatic carotid artery stenosis. Arch Neurol. 2002;59(7):1162-6. [pmid: 12117365].
21 Goldstein LB, Bushnell CD, Adams RJ, et al. Guidelines for the primary prevention of stroke: a guideline for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2011;42(2):517-84. [pmid: 21127304].
22 Makris GC, Lavida A, Nicolaides AN, et al. The effect of statins on carotid plaque morphology: a LDL-associated action or one more pleiotropic effect of statins?. Atherosclerosis. 2010;213(1):8-20. [pmid: 20494361].
23 Patel MR, Greiner MA, DiMartino LD, et al. Geographic variation in carotid revascularization among Medicare beneficiaries, 2003-2006. Arch Intern Med. 2010;170(14):1218-25. [pmid: 20660840].
24 Halm EA, Tuhrim S, Wang JJ, et al. Has evidence changed practice?: appropriateness of carotid endarterectomy after the clinical trials. Neurology. 2007;68(3):187-94. [pmid: 17224571].
25 Kansara A, Miller D, Damani R, et al. Variability in carotid endarterectomy practice patterns within a metropolitan area. Stroke. 2012;43(11):3105-7. [pmid: 22933589].
26 Nallamothu BK, Lu M, Rogers MA, et al. Physician specialty and carotid stenting among elderly medicare beneficiaries in the United States. Arch Intern Med. 2011;171(20):1804-10. [pmid: 21824938].
27 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville: MD. Agency for Healthcare Research and Quality. 2011. Chapters available at: http://www.effectivehealthcare.ahrq.gov.
28 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
29 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Report. AHRQ Publication No. 10-EHC070-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
30 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
31 Endarterectomy for asymptomatic carotid artery stenosis. Executive Committee for the Asymptomatic Carotid Atherosclerosis Study. JAMA. 1995;273(18):1421-8. [pmid: 7723155].
32 Halliday A, Harrison M, Hayter E, et al. 10-year stroke prevention after successful carotid endarterectomy for asymptomatic stenosis (ACST-1): a multicentre randomised trial. Lancet. 2010;376(9746):1074-84. [pmid: 20870099].
33 Wilson EB. Probable inference, the law of succession, and statistical inference. J Am Stat Assoc. 1927;22:209-12.
34 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
35 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
36 Higgins JPT, Green ST, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration. Available from www.cochrane-handbook.org; Updated March 2011.
37 Kontopantelis E, Reeves D. metaan: Random-effects meta-analysis. Stata J. 2010;10(3):395-407.
38 Kontopantelis E, Springate DA, Reeves D. A re-analysis of the Cochrane Library data: the dangers of unobserved heterogeneity in meta-analyses. PLoS One. 2013;8(7):e69930. [pmid: 23922860].
39 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. 1996;15(6):619-29. [pmid: 8731004].
40 Jackson D, White IR, Thompson SG. Extending DerSimonian and Laird's methodology to perform multivariate random effects meta-analyses. Stat Med. 2010;29(12):1282-97. [pmid: 19408255].
41 Suri MF, Ezzeddine MA, Lakshminarayan K, et al. Validation of two different grading schemes to identify patients with asymptomatic carotid artery stenosis in general population. J Neuroimaging. 2008;18(2):142-7. [pmid: 18380694].
42 Jacobowitz GR, Rockman CB, Gagne PJ, et al. A model for predicting occult carotid artery stenosis: screening is justified in a selected population. J Vasc Surg. 2003;38(4):705-9. [pmid: 14560217].
43 Qureshi AI, Janardhan V, Bennett SE, et al. Who should be screened for asymptomatic carotid artery stenosis? Experience from the Western New York Stroke Screening Program. J Neuroimaging. 2001;11(2):105-11. [pmid: 11296578].
44 Lloyd-Jones DM. Cardiovascular risk prediction: basic concepts, current status, and future directions. Circulation. 2010;121(15):1768-77. [pmid: 20404268].
45 Hosmer DW, Lemeshow S. Applied Logistic Regression. New York, NY. John Wiley & Sons. 2000.
46 Jahromi AS, Cina CS, Liu Y, et al. Sensitivity and specificity of color duplex ultrasound measurement in the estimation of internal carotid artery stenosis: a systematic review and meta-analysis. J Vasc Surg. 2005;41(6):962-72. [pmid: 15944595].
47 Nederkoorn PJ, Graaf Y, Hunink M. Duplex ultrasound and magnetic resonance angiography compared with digital subtraction angiography in carotid artery stenosis: a systematic review. (structured abstract). Stroke. 2003;34(5):1324-31. [pmid: 12690221].
48 Blakeley DD, Oddone EZ, Hasselblad V, et al. Noninvasive carotid artery testing. A meta-analytic review. Ann Intern Med. 1995;122(5):360-7. [pmid: 7847648].
49 Jogestrand T, Lindqvist M, Nowak J. Diagnostic performance of duplex ultrasonography in the detection of high grade internal carotid artery stenosis. Eur J Vasc Endovasc Surg. 2002;23(6):510-8. [pmid: 12093067].
50 Nowak J, Jogestrand T. Duplex ultrasonography is an efficient diagnostic tool for the detection of moderate to severe internal carotid artery stenosis. Clin Physiol Funct Imaging. 2007;27(3):144-7. [pmid: 17445064].
51 Sabeti S, Schillinger M, Mlekusch W, et al. Quantification of internal carotid artery stenosis with duplex US: comparative analysis of different flow velocity criteria. Radiology. 2004;232(2):431-9. [pmid: 15286315].
52 Hwang CS, Liao KM, Lee JH, et al. Measurement of carotid stenosis: comparisons between duplex and different angiographic grading methods. J Neuroimaging. 2003;13(2):133-9. [pmid: 12722495].
53 Rothwell PM, Gibson RJ, Slattery J, et al. Equivalence of measurements of carotid stenosis. A comparison of three methods on 1001 angiograms. European Carotid Surgery Trialists' Collaborative Group. Stroke. 1994;25(12):2435-9. [pmid: 7974586].
54 Rothwell PM, Gutnikov SA, Warlow CP. Reanalysis of the final results of the European Carotid Surgery Trial. Stroke. 2003;34(2):514-23. [pmid: 12574569].
55 Hoskins PR. A review of the measurement of blood velocity and related quantities using Doppler ultrasound. Proc Inst Mech Eng H. 1999;213(5):391-400. [pmid: 10581966].
56 Nicolaides AN, Shifrin EG, Bradbury A, et al. Angiographic and duplex grading of internal carotid stenosis: can we overcome the confusion?. J Endovasc Surg. 1996;3(2):158-65. [pmid: 8798134].
57 Tola M, Yurdakul M. Effect of Doppler angle in diagnosis of internal carotid artery stenosis. J Ultrasound Med. 2006;25(9):1187-92. [pmid: 16929020].
58 Kuntz KM, Polak JF, Whittemore AD, et al. Duplex ultrasound criteria for the identification of carotid stenosis should be laboratory specific. Stroke. 1997;28(3):597-602. [pmid: 9056618].
59 Alexandrov AV, Vital D, Brodie DS, et al. Grading carotid stenosis with ultrasound. An interlaboratory comparison. Stroke. 1997;28(6):1208-10. [pmid: 9183353].
60 Nicolaides AN, Kakkos SK, Kyriacou E, et al. Asymptomatic internal carotid artery stenosis and cerebrovascular risk stratification. J Vasc Surg. 2010;52(6):1486-96 e1-5. [pmid: 21146746].
61 Calvillo-King L, Xuan L, Zhang S, et al. Predicting risk of perioperative death and stroke after carotid endarterectomy in asymptomatic patients: derivation and validation of a clinical risk score. Stroke. 2010;41(12):2786-94. [pmid: 21051669].
62 Goodney PP, Likosky DS, Cronenwett JL. Factors associated with stroke or death after carotid endarterectomy in Northern New England. J Vasc Surg. 2008;48(5):1139-45. [pmid: 18586446].
63 Bertges DJ, Goodney PP, Zhao Y, et al. The Vascular Study Group of New England Cardiac Risk Index (VSG-CRI) predicts cardiac complications more accurately than the Revised Cardiac Risk Index in vascular surgery patients. J Vasc Surg. 2010;52(3):674-83. 83 e1. 83 e3. [pmid: 20570467].
64 Momjian-Mayor I, Kuzmanovic I, Momjian S, et al. Accuracy of a novel risk index combining degree of stenosis of the carotid artery and plaque surface echogenicity. Stroke. 2012;43(5):1260-5. [pmid: 22403049].
65 Prati P, Tosetto A, Casaroli M, et al. Carotid plaque morphology improves stroke risk prediction: usefulness of a new ultrasonographic score. Cerebrovasc Dis. 2011;31(3):300-4. [pmid: 21212660].
66 Folkersen L, Persson J, Ekstrand J, et al. Prediction of ischemic events on the basis of transcriptomic and genomic profiling in patients undergoing carotid endarterectomy. Mol Med. 2012;18:669-75. [pmid: 22371308].
67 Halliday A, Mansfield A, Marro J, et al. Prevention of disabling and fatal strokes by successful carotid endarterectomy in patients without recent neurological symptoms: randomised controlled trial. Lancet. 2004;363(9420):1491-502. [pmid: 15135594].
68 Halliday AW, Thomas D, Mansfield A. The Asymptomatic Carotid Surgery Trial (ACST). Rationale and design. Steering Committee. Eur J Vasc Surg. 1994;8(6):703-10. [pmid: 7828747].
69 Halliday AW, Thomas DJ, Mansfield AO. The asymptomatic carotid surgery trial (ACST). Int angiol. 1995;14(1):18-20. [pmid: 7658099].
70 Young B, Moore WS, Robertson JT, et al. An analysis of perioperative surgical mortality and morbidity in the asymptomatic carotid atherosclerosis study. Stroke. 1996;27(12):2216-24. [pmid: 8969784].
71 Baker WH, Howard VJ, Howard G, et al. Effect of contralateral occlusion on long-term efficacy of endarterectomy in the asymptomatic carotid atherosclerosis study (ACAS). ACAS Investigators. Stroke. 2000;31(10):2330-4. [pmid: 11022059].
72 Asymptomatic Carotid Atherosclerosis Study Group. Study design for randomized prospective trial of carotid endarterectomy for asymptomatic atherosclerosis. Stroke. 1989;20(7):844-9. [pmid: 2665205].
73 Hobson RW 2nd, Weiss DG, Fields WS, et al. Efficacy of carotid endarterectomy for asymptomatic carotid stenosis. The Veterans Affairs Cooperative Study Group. N Engl J Med. 1993;328(4):221-7. [pmid: 8418401].
74 Towne JB, Weiss DG, Hobson RW. First phase report of cooperative Veterans Administration asymptomatic carotid stenosis study—operative morbidity and mortality. J Vasc Surg. 1990;11(2):252-8. discussion 8-9. [pmid: 2405197].
75 Role of carotid endarterectomy in asymptomatic carotid stenosis. A Veterans Administration Cooperative Study. Stroke. 1986;17(3):534-9. [pmid: 2872740].
76 den Hartog AG, Halliday AW, Hayter E, et al. Risk of stroke from new carotid artery occlusion in the Asymptomatic Carotid Surgery Trial-1. Stroke. 2013;44(6):1652-9. [pmid: 23632980].
77 Chambers BR, Donnan GA. Carotid endarterectomy for asymptomatic carotid stenosis. Cochrane Database Syst Rev. 2005;(4):CD001923. [pmid: 16235289].
78 Raman G, Moorthy D, Hadar N, et al. Management strategies for asymptomatic carotid stenosis: a systematic review and meta-analysis. Ann Intern Med. 2013;158(9):676-85. [pmid: 23648949].
79 Raman G, Kitsios GD, Moorthy D, et al. Management of Asymptomatic Carotid Artery Stenosis. Technology Assessment Report. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
80 Benavente O, Moher D, Pham B. Carotid endarterectomy for asymptomatic carotid stenosis: a meta-analysis. BMJ. 1998;317(7171):1477-80. [pmid: 9831572].
81 Guay J, Ochroch EA. Carotid endarterectomy plus medical therapy or medical therapy alone for carotid artery stenosis in symptomatic or asymptomatic patients: a meta-analysis. (Structured abstract). Cardiothorac Vasc Anesth. 2012;26(5):835-44.
82 Carotid surgery versus medical therapy in asymptomatic carotid stenosis. The CASANOVA Study Group. Stroke. 1991;22(10):1229-35. [pmid: 1926232].
83 Wiebers DO. Results of a randomized controlled trial of carotid endarterectomy for asymptomatic carotid stenosis. Mayo Clin Proc. 1992;67(6):513-8. [pmid: 1434877].
84 Brott TG, Hobson RW 2nd, Howard G, et al. Stenting versus endarterectomy for treatment of carotid-artery stenosis. N Engl J Med. 2010;363(1):11-23. [pmid: 20505173].
85 Silver FL, Mackey A, Clark WM, et al. Safety of stenting and endarterectomy by symptomatic status in the Carotid Revascularization Endarterectomy Versus Stenting Trial (CREST). Stroke. 2011;42(3):675-80. [pmid: 21307169].
86 Yadav JS, Wholey MH, Kuntz RE, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. N Engl J Med. 2004;351(15):1493-501. [pmid: 15470212].
87 Fairman R, Gray WA, Scicli AP, et al. The CAPTURE registry: analysis of strokes resulting from carotid artery stenting in the post approval setting: timing, location, severity, and type. Ann Surg. 2007;246(4):551-6. discussion 6-8. [pmid: 17893491].
88 Chaturvedi S, Matsumura JS, Gray W, et al. Carotid artery stenting in octogenarians: periprocedural stroke risk predictor analysis from the multicenter Carotid ACCULINK/ACCUNET Post Approval Trial to Uncover Rare Events (CAPTURE 2) clinical trial. Stroke. 2010;41(4):757-64. [pmid: 20185789].
89 Matsumura JS, Gray W, Chaturvedi S, et al. CAPTURE 2 risk-adjusted stroke outcome benchmarks for carotid artery stenting with distal embolic protection. J Vasc Surg. 2010;52(3):576-83. 83 e1. 83 e2. [pmid: 20576398].
90 Gray WA, Chaturvedi S, Verta P. Thirty-day outcomes for carotid artery stenting in 6320 patients from 2 prospective, multicenter, high-surgical-risk registries. Circ Cardiovasc Interv. 2009;2(3):159-66. [pmid: 20031712].
91 CaRESS Steering Committee. Carotid revascularization using endarterectomy or stenting systems (CARESS): Phase I clinical trial. J Endovasc Ther. 2003;10(6):1021-30. [pmid: 14723574].
92 White RA, Diethrich E, Fogarty TJ, et al. Carotid Revascularization Using Endarterectomy or Stenting Systems (CaRESS) phase I clinical trial: 1-Year results. J Vasc Surg. 2005;42(2):213-9. [pmid: 16102616].
93 Zarins CK, White RA, Diethrich EB, et al. Carotid revascularization using endarterectomy or stenting systems (CaRESS): 4-year outcomes. J Endovasc Ther. 2009;16(4):397-409. [pmid: 19702339].
94 Kresowik TF, Bratzler DW, Kresowik RA, et al. Multistate improvement in process and outcomes of carotid endarterectomy. J Vasc Surg. 2004;39(2):372-80. [pmid: 14743139].
95 Kresowik TF, Bratzler D, Karp HR, et al. Multistate utilization, processes, and outcomes of carotid endarterectomy. J Vasc Surg. 2001;33(2):227-34. discussion 34-5. [pmid: 11174772].
96 Bratzler DW, Oehlert WH, Murray CK, et al. Carotid endarterectomy in Oklahoma Medicare beneficiaries: patient characteristics and outcomes. J Okla State Med Assoc. 1996;89(12):423-9. [pmid: 8997882].
97 Cebul RD, Snow RJ, Pine R, et al. Indications, outcomes, and provider volumes for carotid endarterectomy. JAMA. 1998;279(16):1282-7. [pmid: 9565009].
98 Halm EA, Tuhrim S, Wang JJ, et al. Risk factors for perioperative death and stroke after carotid endarterectomy: results of the new york carotid artery surgery study. Stroke. 2009;40(1):221-9. [pmid: 18948605].
99 Halm EA, Chassin MR, Tuhrim S, et al. Revisiting the appropriateness of carotid endarterectomy. Stroke. 2003;34(6):1464-71. [pmid: 12738896].
100 Rockman CB, Halm EA, Wang JJ, et al. Primary closure of the carotid artery is associated with poorer outcomes during carotid endarterectomy. J Vasc Surg. 2005;42(5):870-7. [pmid: 16275440].
101 Halm EA, Hannan EL, Rojas M, et al. Clinical and operative predictors of outcomes of carotid endarterectomy. J Vasc Surg. 2005;42(3):420-8. [pmid: 16171582].
102 Press MJ, Chassin MR, Wang J, et al. Predicting medical and surgical complications of carotid endarterectomy: comparing the risk indexes. Arch Intern Med. 2006;166(8):914-20. [pmid: 16636219].
103 Karp HR, Flanders WD, Shipp CC, et al. Carotid endarterectomy among Medicare beneficiaries: a statewide evaluation of appropriateness and outcome. Stroke. 1998;29(1):46-52. [pmid: 9445327].
104 Kresowik TF, Hemann RA, Grund SL, et al. Improving the outcomes of carotid endarterectomy: results of a statewide quality improvement project. J Vasc Surg. 2000;31(5):918-26. [pmid: 10805882].
105 Hopkins LN, Roubin GS, Chakhtoura EY, et al. The Carotid Revascularization Endarterectomy versus Stenting Trial: credentialing of interventionalists and final results of lead-in phase. J Stroke Cerebrovasc Dis. 2010;19(2):153-62. [pmid: 20189092].
106 Giacovelli JK, Egorova N, Dayal R, et al. Outcomes of carotid stenting compared with endarterectomy are equivalent in asymptomatic patients and inferior in symptomatic patients. J Vasc Surg. 2010;52(4):906-13. 13 e1. 4. [pmid: 20620010].
107 Vouyouka AG, Egorova NN, Sosunov EA, et al. Analysis of Florida and New York state hospital discharges suggests that carotid stenting in symptomatic women is associated with significant increase in mortality and perioperative morbidity compared with carotid endarterectomy. J Vasc Surg. 2012;56(2):334-42. [pmid: 22583852].
108 Yuo TH, Degenholtz HS, Chaer RA, et al. Effect of hospital-level variation in the use of carotid artery stenting versus carotid endarterectomy on perioperative stroke and death in asymptomatic patients. J Vasc Surg. 2013;57(3):627-34. [pmid: 23312937].
109 McPhee JT, Hill JS, Ciocca RG, et al. Carotid endarterectomy was performed with lower stroke and death rates than carotid artery stenting in the United States in 2003 and 2004. J Vasc Surg. 2007;46(6):1112-8. [pmid: 18154987].
110 McPhee JT, Schanzer A, Messina LM, et al. Carotid artery stenting has increased rates of postprocedure stroke, death, and resource utilization than does carotid endarterectomy in the United States, 2005. J Vasc Surg. 2008;48(6):1442-50. 50 e1. [pmid: 18829236].
111 Timaran CH, Veith FJ, Rosero EB, et al. Intracranial hemorrhage after carotid endarterectomy and carotid stenting in the United States in 2005. J Vasc Surg. 2009;49(3):623-8. discussion 8-9. [pmid: 19268766].
112 Giles KA, Hamdan AD, Pomposelli FB, et al. Stroke and death after carotid endarterectomy and carotid artery stenting with and without high risk criteria. J Vasc Surg. 2010;52(6):1497-504. [pmid: 20864299].
113 Young KC, Jahromi BS. Does current practice in the United States of carotid artery stent placement benefit asymptomatic octogenarians?. AJNR Am J Neuroradiol. 2011;32(1):170-3. [pmid: 20864521].
114 Woo K, Garg J, Hye RJ, et al. Contemporary results of carotid endarterectomy for asymptomatic carotid stenosis. Stroke. 2010;41(5):975-9. [pmid: 20339122].
115 Garg J, Frankel DA, Dilley RB. Carotid endarterectomy in academic versus community hospitals: the national surgical quality improvement program data. Ann Vasc Surg. 2011;25(4):433-41. [pmid: 21435832].
116 Wallaert JB, De Martino RR, Finlayson SR, et al. Carotid endarterectomy in asymptomatic patients with limited life expectancy. Stroke. 2012;43(7):1781-7. [pmid: 22550053].
117 Fokkema M, Bensley RP, Lo RC, et al. In-hospital versus postdischarge adverse events following carotid endarterectomy. J Vasc Surg. 2013;57(6):1568-75. 75 e1. 3. [pmid: 23388394].
118 Horner RD, Oddone EZ, Stechuchak KM, et al. Racial variations in postoperative outcomes of carotid endarterectomy: evidence from the Veterans Affairs National Surgical Quality Improvement Program. Med Care. 2002;40(1 Suppl):I35-43. [pmid: 11789630].
119 Samsa G, Oddone EZ, Horner R, et al. To what extent should quality of care decisions be based on health outcomes data? Application to carotid endarterectomy. Stroke. 2002;33(12):2944-9. [pmid: 12468795].
120 Mercado N, Cohen DJ, Spertus JA, et al. Carotid artery stenting of a contralateral occlusion and in-hospital outcomes: results from the CARE (Carotid Artery Revascularization and Endarterectomy) registry. JACC Cardiovasc Interv. 2013;6(1):59-64. [pmid: 23347862].
121 Rajamani K, Kennedy KF, Ruggiero NJ, et al. Outcomes of carotid endarterctomy in the elderly: A report from the care registry(registered trademark). Stroke. 2012;43(2).
122 Theiss W, Hermanek P, Mathias K, et al. Predictors of death and stroke after carotid angioplasty and stenting: a subgroup analysis of the Pro-CAS data. Stroke. 2008;39(8):2325-30. [pmid: 18583556].
123 Palombo D, Lucertini G, Mambrini S, et al. Carotid endarterectomy: results of the Italian Vascular Registry. J Cardiovasc Surg. 2009;50(2):183-7. [pmid: 19282808].
124 Micari A, Stabile E, Cremonesi A, et al. Carotid artery stenting in octogenarians using a proximal endovascular occlusion cerebral protection device: a multicenter registry. Catheter Cardiovasc Interv. 2010;76(1):9-15. [pmid: 20578188].
125 Menyhei G, Bjorck M, Beiles B, et al. Outcome following carotid endarterectomy: lessons learned from a large international vascular registry. Eur J Vasc Endovasc Surg. 2011;41(6):735-40. [pmid: 21450496].
126 Lindstrom D, Jonsson M, Formgren J, et al. Outcome after 7 years of carotid artery stenting and endarterectomy in Sweden - single centre and national results. Eur J Vasc Endovasc Surg. 2012;43(5):499-503. [pmid: 22342694].
127 Sidawy AN, Zwolak RM, White RA, et al. Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. J Vasc Surg. 2009;49(1):71-9. [pmid: 19028045].
128 Jim J, Rubin BG, Ricotta JJ 2nd, et al. Society for Vascular Surgery (SVS) Vascular Registry evaluation of comparative effectiveness of carotid revascularization procedures stratified by Medicare age. J Vasc Surg. 2012;55(5):1313-20. discussion 21. [pmid: 22459755].
129 Schermerhorn ML, Fokkema M, Goodney P, et al. The impact of Centers for Medicare and Medicaid Services high-risk criteria on outcome after carotid endarterectomy and carotid artery stenting in the SVS Vascular Registry. J Vasc Surg. 2013;57(5):1318-24. [pmid: 23406712].
130 Lal BK, Meschia JF, Brott TG. CREST-2: guiding treatments for asymptomatic carotid disease. Endovascular Today. 2013;(September):73-6.
131 Abbott AL. Medical (nonsurgical) intervention alone is now best for prevention of stroke associated with asymptomatic severe carotid stenosis: results of a systematic review and analysis. Stroke. 2009;40(10):e573-83. [pmid: 19696421].
132 Brewer NT, Salz T, Lillie SE. Systematic review: the long-term effects of false-positive mammograms. Ann Intern Med. 2007;146(7):502-10. [pmid: 17404352].
133 Hewlett J, Waisbren SE. A review of the psychosocial effects of false-positive results on parents and current communication practices in newborn screening. J Inherit Metab Dis. 2006;29(5):677-82. [pmid: 16917730].
134 Carlsson S, Aus G, Wessman C, et al. Anxiety associated with prostate cancer screening with special reference to men with a positive screening test (elevated PSA) - Results from a prospective, population-based, randomised study. Eur J Cancer. 2007;43(14):2109-16. [pmid: 17643983].
135 Esserman LJ, Thompson IM Jr., Reid B. Overdiagnosis and overtreatment in cancer: an opportunity for improvement. JAMA. 2013;310(8):797-8. [pmid: 23896967].
136 Welch HG, Black WC. Overdiagnosis in cancer. J Natl Cancer Inst. 2010;102(9):605-13. [pmid: 20413742].
137 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Rockville, MD. Agency for Healthcare Research and Quality. 1996.
138 Ratchford EV, Jin Z, Di Tullio MR, et al. Carotid bruit for detection of hemodynamically significant carotid stenosis: the Northern Manhattan Study. Neurol Res. 2009;31(7):748-52. [pmid: 19133168].
139 Cournot M, Boccalon H, Cambou JP, et al. Accuracy of the screening physical examination to identify subclinical atherosclerosis and peripheral arterial disease in asymptomatic subjects. J Vasc Surg. 2007;46(6):1215-21. [pmid: 18154997].
140 Johansson EP, Wester P. Carotid bruits as predictor for carotid stenoses detected by ultrasonography: an observational study. BMC Neurol. 2008;8:23. [pmid: 18577216].
141 Cheng SW, Wu LL, Ting AC, et al. Screening for asymptomatic carotid stenosis in patients with peripheral vascular disease: a prospective study and risk factor analysis. Cardiovasc Surg. 1999;7(3):303-9. [pmid: 10386747].
142 Paraskevas KI, Mikhailidis DP, Liapis CD, et al. Critique of the Carotid Revascularization Endarterectomy versus Stenting Trial (CREST): flaws in CREST and its interpretation. Eur J Vasc Endovasc Surg. 2013;45(6):539-45. [pmid: 23602856].
143 Rothwell PM. Carotid stenting: more risky than endarterectomy and often no better than medical treatment alone. Lancet. 2010;375(9719):957-9. [pmid: 20304225].
144 Raman G, Kitsios GD, Moorthy D, et al. Management of Asymptomatic Carotid Stenosis: Technology Assessment Report. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
145 Helfand M, Buckley DI, Freeman M, et al. Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(7):496-507. [pmid: 19805772].
146 Takaya N, Yuan C, Chu B, et al. Association between carotid plaque characteristics and subsequent ischemic cerebrovascular events: a prospective assessment with MRI—initial results. Stroke. 2006;37(3):818-23. [pmid: 16469957].
147 King A, Shipley M, Markus H. Optimizing protocols for risk prediction in asymptomatic carotid stenosis using embolic signal detection: the Asymptomatic Carotid Emboli Study. Stroke. 2011;42(10):2819-24. [pmid: 21852607].
148 Hoke M, Speidl W, Schillinger M, et al. Polymorphism of the complement 5 gene and cardiovascular outcome in patients with atherosclerosis. Eur J Clin Invest. 2012;42(9):921-6. [pmid: 22452399].
149 Molloy J, Markus HS. Asymptomatic embolization predicts stroke and TIA risk in patients with carotid artery stenosis. Stroke. 1999;30(7):1440-3. [pmid: 10390320].
150 Spence JD, Tamayo A, Lownie SP, et al. Absence of microemboli on transcranial Doppler identifies low-risk patients with asymptomatic carotid stenosis. Stroke. 2005;36(11):2373-8. [pmid: 16224084].
151 Brott TG, Halperin JL, Abbara S, et al. 2011 ASA/ACCF/AHA/AANN/AANS/ACR/ ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS guideline on the management of patients with extracranial carotid and vertebral artery disease. Stroke. 2011;42(8):e464-540. [pmid: 21282493].
152 Ricotta JJ, Aburahma A, Ascher E, et al. Updated Society for Vascular Surgery guidelines for management of extracranial carotid disease. J Vasc Surg. 2011;54(3):e1-31. [pmid: 21889701].