# Discussion

## Summary of Evidence

No studies directly addressed our overarching question (KQ 1), and no studies randomly assigned patients, practices, or providers to screening and comparator groups and subsequently provided interventions for persons with positive screening results.

### Detection of Asymptomatic CAS

Duplex ultrasonography is a widely available, noninvasive screening test with estimated sensitivity and specificity of 94 percent and 92 percent, respectively, for detecting CAS at 60 to 99 percent. Reliability of ultrasound is questionable, as accuracy can vary considerably between laboratories.

Use of duplex ultrasonography in a low-prevalence population would result in many false-positive tests. For example, in a population of 100,000 adults with an asymptomatic CAS prevalence of 1 percent, duplex ultrasonography would result in 940 true positives and 7,920 false positives (Table 6).

Table 6 Projected 5-Year Outcomes of Screening 100,000 Asymptomatic Adults for CAS With Duplex Ultrasonography Followed by Confirmatory Testing With MRA

Screening Cascade Component | Variable | CEA | Medical Treatment
Detection | Patients with CAS, n | 1,000 | 1,000
Detection | Positive screening test result (false positive/true positive), n (n/n) | 8,860 (7,920/940) | 8,860 (7,920/940)
Detection | Patients sent to surgery after MRA confirmation (false positive/true positive), n (n/n) | 1,685 (792/893) | NA
Benefits^a^ | Any nonperioperative stroke for those with true positive test results, n | 53 | 102
Harms | Perioperative strokes or death, estimated using trial results; using cohort results (false positive/true positive), n (n/n) | 41 (19/22); 57 (27/30) | 14 (7/7); 2 (1/1)
Harms | Nonfatal perioperative MI, estimated using trial results; using cohort studies (false positive/true positive), n (n/n) | 14 (7/7); 14 (7/7) | 1 (1/1); 1 (1/1)
Harms | Cranial nerve injuries | 64 (30/34) | 0 (0/0); 0 (0/0)
Harms | Other complications of surgery: pulmonary embolism, pneumonia, other infection, local hematoma requiring surgery | ≤1% estimated each | NA
Harms | Potential psychological harms | Unknown | Unknown
Net for major cardiovascular events avoided or caused^b^ | Perioperative stroke/death/MI or any subsequent stroke in patients with either false positive or true positive results: using trial results; using cohort results, n | 108; 124 | 117; 105
Net for major cardiovascular events avoided or caused^b^ | Difference between CEA and medical therapy, using trial results; using cohort results | 9 fewer events;19 more events | 10 more events; 19 fewer events
NNS | To prevent 1 major cardiovascular event over about 5 years: using trial results; cohort results | 11,111; net harm | NA

Projected benefits and harms were determined for the 1,685 people who would be sent for CEA after MRA confirmation. When relevant, projected outcomes are shown as overall and in parentheses for people who had false positives and those who had true positives to illustrate how many people would undergo unnecessary intervention with resulting harm.

Assumptions were as follows:

1. The true prevalence is 1% in the general asymptomatic primary care population of adults age 65 years and older.
2. Outcomes table based on our findings for CEA; our results suggest that projected outcomes for CAAS are similar or worse; projected outcomes for CAAS were not included in the table.
3. Screening test is carotid duplex ultrasonography, with sensitivity and specificity for CAS of 60% to 99% and 0.94 and 0.92, respectively.
4. Confirmatory test is MRA (sensitivity, 0.95; specificity, 0.90).47
5. Rate for any nonperioperative stroke for those with true positive test was based on our meta-analysis, which found a risk difference of -0.055, with rates of 5.9% for the CEA group and 11.4% for the medical therapy group.
6. Perioperative stroke or death rate for CEA is 2.4% when using trial results and 3.3% when using cohort studies of the general population of surgeons and patients.
7. Perioperative stroke or death rate for medical therapy is 0.79% when using trial data and 0.09% when using observational data. We did not estimate zero events for perioperative (i.e., 30-day) stroke or death for the medical therapy group, because some people will have events during that time period.
8. Perioperative nonfatal MI rate for CEA is 0.79% (pooled estimate from ACST and VACS) and 0.056% for medical therapy based on trial results, regardless of whether the test was a true positive or false positive; we estimated a rate of 0.825% for CEA when using cohort studies.99,103
9. Cranial nerve injury rate for CEA is 3.8% (as in VACS). The authors reported that functional recovery was observed in all cases and there was no permanent disability. Certainty of this estimate is low as few fair-quality trials or observational studies reported data. One study (CASANOVA) reported higher rates of permanent cranial nerve injury (4.2%).82 Another study reported a rate of 1.1% for minor cranial nerve injuries.83
10. Patients with false positive screening results receive no benefit from either medical therapy or CEA.

a Estimates for benefits were based on trial data that have limited applicability to current clinical practice, primarily because medical therapy in trials was ill-defined, varying, and would not have included treatments that are now standard medical therapy. Further, advances in medical therapy have reduced the rate of stroke in people with asymptomatic CAS in recent decades. The true rates for benefit are unknown, and likely less than those reported in trials.

b Does not include some important harms from above: cranial nerve injuries, other complications of surgery (pulmonary embolism, pneumonia, other infection, local hematoma requiring surgery), or potential psychological harms.

Abbreviations: CAAS = carotid angioplasty and stenting; CAS = carotid artery stenosis; CEA = carotid endarterectomy; MI = myocardial infarction; MRA = magnetic resonance angiography; NNS = number needed to screen.

If no confirmatory tests are done and all persons with positive tests are referred for intervention, many unnecessary interventions and harms would occur. If all positive tests are followed by angiography (which is not typically done in clinical practice), up to 1.2 percent of persons will have a resulting stroke.31 If all positive tests are followed by MRA (95% sensitivity and 90% specificity47), many patients would still be sent for unnecessary intervention. In the example above, 792 false positives would still be sent for intervention, almost as many as true positives sent for intervention (893).

If externally validated, reliable risk stratification tools were available to distinguish persons who are more likely to have CAS, allowing identification of a subset of the population with higher prevalence, then the ratio of true positives to false positives for screening with duplex ultrasonography (with or without confirmatory testing) would improve. However, the only study attempting external validation of such a tool found inadequate discrimination; it was little better than chance (c-statistic for ≥50% CAS, 0.60 [95% CI, 0.56 to 0.64]).

### Benefits and Harms of Interventions for Asymptomatic CAS

An accurate estimate of overall benefit for the current general primary care population is difficult to obtain. Although our meta-analyses of RCTs comparing CEA with medical therapy found an absolute risk reduction of 3.5 percent for the composite of perioperative stroke or death or any subsequent stroke over approximately 5 years, the applicability of the evidence to current clinical practice is substantially limited. Medical therapy was often not clearly defined or standardized, was not kept constant during the study, and would not have included treatments now considered to be current standard medical therapy, including aggressive management of blood pressure and lipids. To address some applicability limitations of previous studies, including those related to current standard medical therapy, the new CREST-2 trial130 (enrollment to begin in 2014) will compare both a) CAAS with medical therapy versus medical therapy alone and b) CEA with medical therapy versus medical therapy alone. None of the identified trials focused on a population found by screening in primary care. Definitions of asymptomatic status varied across the trials and included subjects with a history of contralateral stroke or transient ischemic attack (25% in ACAS; 32% in VACS; not reported in ACST), nonrecent ipsilateral symptoms, and prior contralateral CEA.

The trials comparing CEA with medical therapy used highly selected surgeons, requiring low rates of complications to allow participation, and stipulated no further enrollment by surgeons or institutions that showed unacceptably high morbidity or mortality during the trial, providing some disincentive to report harms. A relatively low perioperative stroke or death rate is required for CEA to have a reasonable likelihood of resulting in more benefit than harm for persons with asymptomatic CAS; overall benefit depends on surviving the perioperative period without experiencing significant harms. Our meta-analyses of trial data found 30-day perioperative rates of stroke or death of 2.4 percent for CEA and 3.1 percent for CAAS. Observational data suggest higher rates: 3.3 percent for CEA and 3.8 percent for CAAS. Observational data also revealed a wide range of these rates for CEA across states, as high as 6.7 percent in some states.95

The potential benefits of CEA or CAAS depend on the risk for an asymptomatic lesion eventually resulting in a stroke, and evidence from systematic reviews suggests that this risk has decreased in recent decades, most likely due to advances in medical therapy.78,131 The best recent evidence suggests that the incidence rate of ipsilateral stroke is nearing 1 percent per year,78 approaching the rate achieved in the surgical arms of trials comparing CEA with medical therapy. This would significantly reduce the potential benefits of surgery. Current medical intervention alone has also been estimated to be three to eight times more cost effective.131

In theory, patients at higher risk for ipsilateral stroke might be more likely to benefit from surgery or intervention. However, no externally validated, reliable risk stratification tools are available that can distinguish persons with asymptomatic CAS who are at decreased or increased risk for stroke caused by CAS, despite current standard medical therapy, or for persons at decreased or increased risk for harms from CEA or CAAS. One might expect that persons with greater reduction of the carotid diameter would have greater potential for benefit (e.g., perhaps persons with 80% to 99% CAS vs. 60% to 79% CAS), but subgroup analyses from trials comparing CEA with medical therapy found no significant difference by percent CAS.31,32

Notably, the main estimates of overall benefit (i.e., perioperative stroke or death or any subsequent stroke) from the trials comparing CEA with medical therapy do not include some important harms, such as nonfatal MI. More recently published head-to-head trials comparing CEA and CAAS used composite primary outcomes that include periprocedural MI.84,86 The trials comparing CEA with medical therapy reported rates of perioperative nonfatal MI of 0.7 percent (ACST) to 1.9 percent (VACS).

Other important harms reported in trials or observational studies include permanent cranial nerve damage, pulmonary embolism, pneumonia, wound infection, acute renal failure, urinary tract infection, deep venous thrombosis, and local hematoma requiring surgery. Most studies we reviewed did not report on harms other than perioperative stroke or death. Thus, lack of reporting or underreporting of some harms is possible. Some studies with more detailed reporting of harms suggest higher rates of major complications from surgery compared with ACAS, ACST, and VACS. For example, 7.9 percent of participants randomized to CEA in the CASANOVA trial reported at least one major complication (including death, stroke, pulmonary embolism, MI, or permanent cranial nerve damage). It is unclear whether these seemingly high rates were identified due to a more complete ascertainment of harms or for other reasons. Studies using NSQIP data from 2005 to 2007 reported rates for peripheral nerve injury (0.32%), wound infection (0.68%), pneumonia (0.66%),114 and for wound disruption, unplanned intubation, pulmonary embolism, acute renal failure, urinary tract infection, deep venous thrombosis, and sepsis (<1% each).115 Although we rated the studies using NSQIP data as poor quality, primarily due to high risk for selection bias and ascertainment bias, we were concerned that rates of some harms reported in these studies underestimate, rather than overestimate, actual rates of harms.

Timing of events is another important concept not addressed by the main estimates of overall benefit reported in trials of CEA compared with medical therapy. Consolidating all stroke and death events together into one composite outcome does not reflect different values that patients may have for a stroke or death caused by surgery than for a stroke or death that is caused by natural progression.

Life expectancy is another important consideration when assessing the potential for overall benefit. Based on the data from randomized trials, a life expectancy of at least 5 years would be needed to have a reasonable chance of benefit of CEA. Somewhat related are issues associated with advanced age (older than 75 years). Potential for benefit decreases with advanced age because of competing hazards. The mean age of patients in trials comparing CEA with medical therapy was in the mid- to upper-60s. But, the mean age of Medicare patients undergoing CEA is 75 years,23 raising the question of whether many persons having surgical intervention are likely too old to benefit.

### Potential Psychological Harms of Screening for CAS

The CAS screening cascade has potential psychological harms. Anxiety and distress occur frequently after positive screening tests for many conditions;132-134 this result may also occur after positive ultrasound screening for CAS. At least some of these positive screening tests will be false positives. The longer-term experience of persons with false-positive results is unknown. Some persons may have a “near positive” Doppler screening test. In these situations, standard clinical practice will likely involve surveillance over time, with repeated ultrasound testing to determine a point where intervention might be considered. The psychological effect of this surveillance—prolonging the period of uncertainty before resolution—is potentially problematic, although unstudied.

In addition to false-positive screening tests, some persons who would have never had a cerebrovascular event will receive positive confirmatory tests and/or proceed to CEA or CAAS. These persons will have been overdiagnosed and, likely, overtreated135,136 with CEA or CAAS to prevent a problem from which they never would have suffered. In addition to the obvious potential physical harms involved, important psychological harms are possible. Diagnosing a person with CAS may lead to anxiety about the possibility of having a stroke; it may also lead to intrusive thoughts and distraction about the future, thus disturbing quality of life. If prevalence of CAS is about 1 percent, then many more persons will likely experience overdiagnosis than will avoid a stroke. We were unable to find research describing the frequency of these important potential psychological harms.

### Hypothetical Outcomes of a General Population Screening Program

The hypothetical outcomes of a screening program for asymptomatic CAS in the general population are illustrated in Table 6. Assumptions used to determine the hypothetical outcomes include a CAS prevalence of 1 percent and the use of duplex ultrasonography as the screening test followed by confirmatory testing with MRA; this strategy results in a better ratio of benefits to harms than no confirmatory testing or angiography confirmation (i.e., best possible scenario for screening to show overall benefit2). A detailed list of assumptions is provided below Table 6. Hypothetical outcomes were calculated using both trial and cohort results. Trial data for benefits and harms suggest that nine major cardiovascular events (composite of perioperative stroke, death, MI, and any subsequent stroke) would be prevented over 5 years by screening 100,000 persons and intervening with CEA. Trial data estimates for benefits and observational data for estimates of harms found that screening followed by CEA resulted in net harm (19 more events). The hypothetical outcomes likely overestimate the potential benefits of CEA because the estimates of benefit come from trials that did not compare CEA with current standard medical therapy. Further, the number needed to screen and the net for major cardiovascular events do not include cranial nerve injuries, other complications of surgery (pulmonary embolism, pneumonia, other infection, local hematoma requiring surgery), or potential psychological harms.

### Auscultation for Carotid Bruit

In 1996, the USPSTF concluded that auscultation for carotid bruits has low sensitivity and specificity and considerable interobserver variation in the interpretation of key auditory characteristics.137 Assessment of carotid bruits was not included in the 2007 systematic review because it was determined that the evidence had likely not changed appreciably.1,2 We searched the literature covering 1996 to early 2013 and found no evidence that auscultation has improved as a screening tool to detect clinically significant levels of asymptomatic CAS. We identified four studies reporting screening accuracy by auscultation.138-141 Minimum cutoff values for CAS ranged from 50 to 70 percent. All studies used ultrasound as the gold standard for comparison; none used angiography. The reported sensitivities ranged from 46 to 77 percent, and specificities ranged from 71 to 98 percent. Only two studies involved patients from the general population (one in the United States138 and the other in France);139 one study included Swedish patients referred to a hospital for carotid surgery investigation,140 and the fourth study was in Chinese patients with peripheral vascular disease.141

### Limitations

The limitations primarily reflect the published literature. We found no eligible studies addressing our overarching question (KQ 1), questions about externally validated, reliable risk stratification tools to distinguish persons with asymptomatic CAS who have increased or decreased risk for ipsilateral stroke or of harms after CEA or CAAS (KQ 4), and whether additional medications (e.g., aspirin, statins) provide incremental benefit beyond current standard medical therapy including treatment of traditional risk factors (e.g., hypertension, hypercholesterolemia)—that is, we found no evidence that the potential to intensify medical therapy justifies screening for CAS (KQ 6).

Most key issues limiting the applicability of the evidence are described in the Discussion above: no trials compared CEA or CAAS with current standard medical therapy, trials used highly selected surgeons and participants, certain perioperative harms may be underreported, and applicability of the trial evidence to the general asymptomatic primary care population is limited.

Most evidence focused on CEA. We found no trials comparing CAAS with medical therapy. Head-to-head trials have reported that CAAS was not inferior to CEA in high-risk patients for a composite outcome (death, stroke, or MI within 30 days of intervention or death or ipsilateral stroke between 31 days and 1 year; SAPPHIRE, n=334)86 or that the two interventions did not differ significantly for a slightly different composite outcome (stroke, MI, or death from any cause during the periprocedural period or any ipsilateral stroke within 4 years; CREST, n=2,502).84 Several critics have explained why CREST does not actually demonstrate equivalence of CEA and CAAS and why it actually shows that CAAS is more risky than CEA.142,143 For example, mostly minor MIs (that occurred more frequently in the CAS group) were given equal weight to strokes and death in the periprocedural composite endpoint, but not in the 4-year, long-term endpoint (and the CAAS group had more MIs over the long-term).142

Some changes in technology, standard medical therapy, surgical procedures, and stroke rates may not be reflected in some of the included literature (e.g., studies conducted in the 1990s). Recent reviews and meta-analyses found moderate strength of evidence that standard medical therapy has reduced the rate of ipsilateral stroke over time.131,143,144 Our review did not evaluate the use of carotid intima-media thickness in assessing coronary heart disease risk, but a previous review for the USPSTF concluded that evidence does not support its use.145

The single study we identified for KQ 2 had several important limitations. The study tested relatively basic prediction tools: simple and weighted scores. Multivariate modeling is likely to produce more robust prediction. Next, the scores used a limited number of predictive variables. Testing inclusion of additional and alternate clinical variables will be important to improve predictive ability. Finally, it used a limited set of validation measures. Testing calibration (the ability of the tool to correctly categorize risk compared with observed events) as well as discrimination (the ability of the tool to correctly classify persons with disease at higher risk than persons without disease) would provide a better sense of the model's utility in clinical practice.

## Future Research Needs

Good-quality studies are needed to establish: 1) an externally validated, reliable risk stratification tool to identify populations with higher prevalence of CAS; 2) improved screening strategies for CAS that generate fewer false-positive results and unnecessary harms; 3) an externally validated, reliable risk stratification tool to distinguish persons who are more likely to benefit after intervention from persons who are more likely to be harmed; and 4) the comparative benefits and harms of current standard medical therapy, CEA, and CAAS.

Even if future research develops externally validated, reliable risk stratification tools that identify populations with higher prevalence of CAS, such tools would not be sufficient to warrant routine screening for asymptomatic CAS. Given the limitations of the applicability of ACST, ACAS, and VACS, new trials would be needed to establish whether surgery or intervention have overall benefit over current standard medical therapy for the higher prevalence population.131 Similar limitations apply to risk stratification tools that distinguish persons who are more likely to benefit after intervention from persons who are more likely to be harmed.

Although we found no externally validated, reliable risk stratification tools addressing KQ 4, we identified publications that derive risk prediction tools that could be informative for future research or could be targets for future external validation.60-66 These tools included risk factors and are focused on various outcomes. We did not critically appraise these publications, and they may have important limitations. We also identified risk factor studies, particularly for associations between clinical or radiologic factors and stroke outcomes in persons with known CAS. These studies suggest multiple variables beyond the traditional risk factors that should be considered for inclusion and testing in risk prediction models developed in the future (e.g., plaque characteristics, genetic markers, embolic signal detection146-150). Future studies should use a variety of validation measures.

Our searches of clinical trial registries identified four trials that are ongoing or not yet published comparing CEA or CAAS with medical therapy (AMTEC [Aggressive Medical Treatment Evaluation for Asymptomatic Carotid Artery Stenosis, NCT00805311], SPACE-2 [Stent-Protected Angioplasty in Asymptomatic Carotid Artery Stenosis vs. Endarterectomy: Two Two-Arm Clinical Trials, ISRCTN78592017], ECST-2 [ISRCTN97744893], and NCT00497094) and three comparing CEA with CAAS (ACT-1 [Carotid Stenting vs. Surgery of Severe Carotid Artery Disease and Stroke Prevention in Asymptomatic Patients, NCT00106938], ACST-2 [NCT00883402], and NCT00772278).

Despite the potential future research we suggested above, these needs may be relatively low priority considering that the potential preventable burden of disease is fairly low from a larger resource and public health perspective. Several studies have illustrated that patients with asymptomatic CAS are more likely to suffer MI or nonstroke vascular deaths than ipsilateral stroke, suggesting that preventive strategies for these patients should perhaps concentrate on coronary risk more than stroke.20 In ACST, about five times as many nonstroke vascular deaths as nonperioperative stroke deaths were observed (267 and 68 deaths for the medical therapy group, respectively; 298 and 39 for the CEA group, respectively).32

## Response to Public Comment

A draft version of this report was posted for public comment on the USPSTF Web site from February 18 to March 17, 2014. We received a comment from one clinician. The commenter thought that the report should consider that the ability of carotid ultrasound to detect the atherosclerotic process could lead to earlier initiation or intensification of medical therapy and ultimately to better outcomes. We attempted to evaluate evidence of such possible benefit with KQ 6, but we found no evidence that the potential to intensify medical therapy justifies screening for CAS. Thus, we did not make changes to the report in response to the comment.

The commenter also recommended that there should be a caveat for patients at higher risk. However, externally validated, reliable risk stratification tools are not available.

## Conclusion

Asymptomatic CAS has low prevalence in the general adult population. Noninvasive screening with ultrasound would result in many false-positive results; confirmatory testing with MRA appears to be the best strategy to optimize benefits and harms (compared with no confirmatory testing or angiography confirmation), but still yields a significant number of false-positive results. Externally validated, reliable risk stratification tools to distinguish persons who are more likely to have CAS are not available. Furthermore, current evidence does not sufficiently establish incremental overall benefit of CEA beyond current standard medical therapy, primarily because medical therapy in trials was ill-defined, varying, and often lacked treatments that are now standard. Advances in medical therapy have reduced the rate of stroke in persons with asymptomatic CAS in recent decades. No RCTs compared CAAS with medical therapy. Externally validated, reliable risk stratification tools that can distinguish persons with asymptomatic CAS who have increased or decreased risk for ipsilateral stroke or harms after CEA or CAAS are not available.