# Results

## Literature Search

Of the 3,938 unique records identified, we assessed 477 full texts for eligibility (Figure 2). After excluding 399 articles (see Appendix C), we included 78 published articles reporting on 56 studies. Of the included studies (articles), three (12) were RCTs comparing CEA with medical management, eight (10) were systematic reviews, one (3) assessed risk stratification tools for KQ 2, three (4) were primary studies assessing accuracy or reliability of screening for KQ 3, and 41 (49) were multi-institution studies reporting rates of relevant harms for KQs 7 or 8. We rated the quality of 21 studies as poor. Details are provided under the relevant KQs in this chapter, and full quality assessments are provided in Appendix D.

Figure 2 Summary of Evidence Search and Selection

* Includes methods papers for included trials.

Abbreviation: WHO ICTRP = World Health Organization International Clinical Trials Registry Platform.

The figure is a flow chart that summarizes the search and selection of articles. There were 5,076 references identified by searchingPubMed (N=2,879), EMBASE (N=1,805), and the Cochrane Library (N=392). In addition, 46 references were suggested by public commenters; 345 references were identified in the gray literature searches (including ClinicalTrials.gov, the Cochrane trials registry, and the WHO ICTRP); and searches of reference sections of key papers yielded 96 results. After removal of duplicate citations, the titles and abstracts of 3,938 references were screened for potential inclusion. Of these, 477 were deemed appropriate for full-text review to determine eligibility. After full-text review, 399 were excluded: 8 were the wrong type of publication; 113 dealt with the wrong population; 25 used the wrong intervention; 90 used a wrong comparator; 31 did not report an outcome of intrest; 2 were not in an outpatient setting; and 130 were the wrong study design. 78 articles representing 56 studies are included in this report's qualitative synthesis, and 21 studies are included in quantitative analyses.

## Results of Included Studies

### Key Question 1 Direct Evidence That Screening for Asymptomatic CAS Reduces Fatal or Nonfatal Ipsilateral Stroke

We found no eligible studies that addressed this question.

### Key Question 2 Externally Validated, Reliable Risk Stratification Tools to Distinguish Persons Who Are More or Less Likely to Have CAS

We found one study41 that attempted to externally validate two previously developed tools for predicting the likelihood of significant CAS in asymptomatic general populations (Table 1). One of the tools42 assigned one point each for the presence of several risk factors (existing coronary artery disease [CAD], smoking, hypertension, and high cholesterol) to predict the likelihood of CAS at 50 percent or greater. The other tool43 assigned weighted points for each of an overlapping set of risk factors (existing CAD = 2 points, smoking = 1 point, high cholesterol = 1 point, age greater than 65 years = 4 points) to predict the likelihood of CAS at 60 percent or greater. The publication that attempted to externally validate both tools used a cohort of 5,449 persons from the Cardiovascular Health Study.41 Mean age in this cohort was 72 years. Forty-two percent of the cohort were male, and 82 percent were white. Eight percent reported known CAD.

Table 1 Studies Attempting to Externally Validate Risk Stratification Tools to Distinguish Persons Who Are More or Less Likely to Have CAS

Author, Year Country | Derivation Cohort (N) | External Validation Cohort (N) | Predicted Outcome | Model Components | % With Actual CAS | % With CAS by Risk Score | Model Assessment: AUROC C-statistic | Model Assessment: Other | % Studied in Effectiveness or CE Studies | Quality
Suri, 2008 United States | Jacobowitz, 2003 (394) Mean age: 71.3 y Male: 32% White: 86% DM: NR HTN: 64% HChol: 45% Sm: 8% CAD: 17.3% Qureshi, 2001 (887) Mean age: 66 y Male: 31% White: NR DM: 7% HTN: 53% HChol: 15% Sm: 11% CAD: 11 % | (5,795) Mean age: 72 y Male: 42% White: 84% DM: NR HTN: 54% HChol: 57% Sm: 11% CAD: 8% | CAS ≥50% CAS ≥75% | Jacobowitz^a^: Sm, HChol, HTN, CAD Qureshi^b^: Age >65 y, Sm, HChol, CAD | Suri, full cohort: ≥50%: 4.2 50%-74%: 3.2 ≥75%: 1.0 75%-99%: 0.7 Jacobowitz model: >50%: 9.6 >75%: NR Qureshi model: >60%: 18.0 (full sample) >75%: NR | Jacobowitz model, ≥50% by score: 1: 2.9 2: 5.1 3: 8.1 4: 20.7 ≥75% by score: 1: 0.7 2: 1.1 3: 2.1 4: 3.4 Qureshi model, ≥50% by score: 1: 4.0 2: 5.3 3: 7.4 4: 18.9 ≥75% by score: 1: 0.8 2: 1.8 3: 2.1 4: 2.7 | For CAS ≥50%: Jacobowitz model: 0.60 (95% CI, 0.56 to 0.64) Qureshi model: 0.56 (95% CI, 0.53 to 0.60) For CAS ≥75%: Jacobowitz model: 0.60 (95% CI, 0.52 to 0.68) Qureshi model: 0.58 (95% CI, 0.50 to 0.67) | LR for ≥50% CAS: Jacobowitz: Score 4: 6 Qureshi^c^ Score 4: 5.4 LR for ≥75% CAS: Jacobowitz: Score 4: 3.7 Qureshi^c^ Score 4: 2.9 HL chi square: NA Net reclassification: NA | NR | Fair for attempted external validation of Jacobowitz model Poor for Qureshi model

a Jacobowitz risk score: 1 point for each risk factor (range, 0–4); predicts stenosis >50%.

b Qureshi risk score: 1 point for smoking, 2 points for CAD, 1 point for HChol, 4 points for age >65 years; predicts stenosis >60%.

c Age not used in risk calculation for validation because all participants were older than age 65 years.

Abbreviations: AUROC = area under receiver operating characteristic; CAS = carotid artery stenosis; CAD = coronary artery disease; CE = comparative effectiveness; DM = diabetes mellitus; Hchol = hypercholesterolemia; HTN = hypertension; LR = likelihood ratio; M = male; NA = not applicable; N = sample size; NR = not reported; Sm = smoker; W = white.

The attempts to externally validate the two risk prediction tools provided limited information regarding predictive validity. We rated the external validation of the tool that assigned weighted points as poor quality, mainly because its prediction of CAS risk levels and its testing of an altered scoring system that differed from those used in the derivation cohort. In the best-quality attempted external validation,41,42 persons with the highest risk score were more likely to have CAS at 50 percent or greater than persons with lower risk scores (4 points = 21%, 3 points = 8%, 2 points = 5%, 1 point = 3%, and 0 points = 3%). The likelihood of a positive test was higher in persons with CAS at 50 percent or greater than in persons with CAS less than 50 percent (+LR 6 for a score of 4). However, the tool's overall discrimination (i.e., its ability to correctly assign persons with CAS at 50 percent or greater to a higher score than persons with lesser CAS) was little better than chance (c-statistic, 0.60 [95% CI, 0.56 to 0.64]). A c-statistic less than 0.70 is thought to indicate inadequate discrimination.44,45 Calibration, often assessed by plotting the predicted risk versus the observed event rate,44 was not reported.

### Key Question 3 Accuracy and Reliability of Duplex Ultrasonography

We included three meta-analyses46-48 and three primary studies49-52 assessing the accuracy and/or reliability of duplex ultrasonography to detect CAS. Two of the three primary studies were rated as poor quality. The most recent good-quality meta-analysis46 included studies published from 1966 to 2003 and assessed the accuracy of duplex ultrasonography using digital subtraction angiography as the reference standard. For detecting CAS at 50 percent or greater, the authors reported a sensitivity of 98 percent (95% CI, 97 to 100) and a specificity of 88 percent (95% CI, 76 to 100). For detecting CAS at 70 percent or greater, the sensitivity and specificity were 90 percent (95% CI, 84 to 94) and 94 percent (95% CI, 88 to 97), respectively. The 2007 evidence report for the USPSTF1 used information from the meta-analysis to estimate the sensitivity and specificity for detecting stenosis at 60 percent or greater as 94 percent and 92 percent, respectively. The findings of the other meta-analyses and the primary studies are generally consistent with these results, however, specificities from two of the primary studies were lower. Results of all included studies are provided in Appendix E. The other meta-analyses were either relatively outdated (published in 1995^48^) or only included studies published during a selected time period (1993 to 2001^47^). None of the included studies reported whether (or what proportion of) asymptomatic patients were included.

The reliability of duplex ultrasonography to detect potentially clinically important CAS is limited. The good-quality meta-analysis reported wide variation in measurement properties between laboratories, with clinically important variation in the magnitude of the variation.46 Potential sources of measurement heterogeneity include differences in patients, study designs, equipment, techniques, or training.46 For example, different methods of classification will diagnose CAS at different degrees. The European Carotid Surgery Trial (ECST) method compares the diameter of the residual lumen at the site of the maximal luminal narrowing with the estimated normal lumen at the same site, however, the NASCET (the North American Symptomatic Carotid Endarterectomy Trial) method compares the maximal luminal narrowing diameter with the normal diameter of the artery distal to the stenosis. The ECST method generally yields a higher degree of CAS than the NASCET method and with clinically important differences between the two methods. Two analyses53,54 found that the ECST method resulted in between 12^54^ and 51^53^ percent more stenoses classified as 70 to 99 percent, than with the NASCET method. Sabeti et al.51 studied 1,006 carotid arteries and found poor agreement between readers for the differentiation of stenoses less than 70 percent (45% agreement; kappa 0.26 [95% CI, 0.23 to 0.29]), but excellent agreement for stenosis at 70 percent or greater (96% agreement; kappa 0.85 [95% CI, 0.83 to 0.87]). Hwang et al. reported little variability in sensitivity, but significant differences in specificity when they compared the ECST with the NASCET method.52 Results of duplex ultrasonography screening can also vary based on the type of scanner,55 velocity cutpoints and/or ratios used,56 Doppler angle employed,50,57 and inherent variability between facilities and observers.58,59

We did not find any eligible studies that directly addressed whether accuracy and reliability differ for subgroups defined by age, sex, race, or ethnicity.

### Key Question 4 Externally Validated, Reliable Risk Stratification Tools to Distinguish Persons With Asymptomatic CAS Who Are at Decreased or Increased Risk for Stroke Caused by CAS or Decreased or Increased Risk for Harms From CEA or CAAS

We found no eligible studies that addressed this question. Some publications reported risk stratification tools to predict who is at decreased or increased risk for complications from CEA or CAAS (see the Discussion section), but those tools have not been externally validated.60-66 We found no studies that reported risk stratification tools to predict who is at decreased or increased risk for ipsilateral stroke or death caused by CAS.

### Key Question 5 Incremental Benefit of CEA or CAAS Beyond Current Standard Medical Therapy for Reduction of Fatal or Nonfatal Ipsilateral Stroke

We included three RCTs described in 12 publications31,32,67-76 comparing CEA with medical therapy and three good- or fair-quality systematic reviews described in five publications.1,2,77-79 Two systematic reviews were rated as poor quality.80,81 We found no eligible studies that compared CAAS with medical therapy and no studies that compared CEA with current standard medical therapy.

#### Trial Characteristics

Table 2 summarizes the characteristics of the RCTs. A total of 5,226 patients were enrolled. ACAS and VACS were conducted in North America, and ACST involved 30 countries, primarily in Europe. None of the trials focused on a population identified by screening in primary care. Mean age of subjects was 65 to 68 years. The vast majority (87% to 95%) of subjects were white in the two North American trials (data not reported for ACST). Two thirds of enrolled subjects (ACAS and ACST) or more (100% in VACS) were men.

Table 2 Characteristics of Included Randomized, Controlled Trials of CEA Compared With Medical Management for Asymptomatic CAS

Study, year | N | Country | Source of Patients | Medical Management Description | Followup | Age | % White | % Male | % DM % HTN % HChol % Sm % CAD | % Prior contralateral CEA | % Contralateral occlusion | % Contralateral TIA/stroke | Pre-randomization evaluation & required stenosis | Quality
ACAS, 1995 | 1,662 | United States & Canada | U/S labs, practitioners who found bruits or carotid stenosis during evaluation for peripheral vascular surgery or contralateral CEA | All patients received 325 mg of regular or enteric-coated aspirin daily. Also had risk factor discussion and modification at randomization, subsequent interviews, and telephone followup | 2.7 y | 67 y | 95 | 66 | 23 64 NR 26 69 | 20 | 9 | 25 | U/S or angiogram: ≥60% | Good for the 2.7-y data that was based on actual events; Fair for the 5-y estimates; only 9% had followup to 5 y
ACST, 2004 and 2010 | 3,120 | 30 countries (most in Europe; also included Russia, Israel, and 16 subjects from United States) | Medical and surgical clinics | Left to discretion of clinicians, usually included antiplatelet and antihypertensive therapy; in later years of the trial, lipid-lowering therapy was common^a^ | Median in survivors: 9 y (IQR, 6 to 11)^b^ | 68 y | NR | 66 | 20 65 27 (≥250 mg/dL) NR Non-DM CAD: 27 | 24 | 9 | NR | U/S: ≥60% | Fair
VACS, 1993 | 444 | United States | 11 VAMCs, patients scheduled for surgery who had asymptomatic stenoses, patients with unilateral symptomatic lesions found to have contralateral asymptomatic stenosis on arteriography, and patients with incidental cervical bruits and positive noninvasive screening tests | 650 mg aspirin BID, reduced to 325 mg daily if not tolerated | 4 y | 65 y | 87 | 100 | 27-30 63-64 NR 49-52 Hx of MI: 25-28 | NR | NR | 32 | Angiogram: ≥50% | Good

a At study entry, 17% of subjects randomized in 1993 to 1996 were on lipid-lowering therapy; it increased to 58% in 2000 to 2003. At the last followup in 2002 to 2003, >90% of the survivors were on antiplatelet therapy, 81% were on antihypertensives, and 70% were on lipid-lowering therapy. At followup in 2002 or 2003, mean blood pressure was 148/79 mm Hg in both groups.

b Followup to death or at least year 3 is 98% complete (3,062/3,120).

Abbreviations: ACAS = Asymptomatic Carotid Atherosclerosis Study; ACST = Asymptomatic Carotid Surgery Trial; CAD = coronary artery disease; CEA = carotid endarterectomy; DM = diabetes mellitus; Hchol = hypercholesterolemia; HTN = hypertension; N = sample size; PVD = peripheral vascular disease; Sm = smoker; TIA = transient ischemic attack; U/S = ultrasound; VACS = Veterans' Affairs Cooperative Study; VAMC = Veterans Administration Medical Center.

Although subjects were deemed asymptomatic with relation to the ipsilateral carotid artery, 20 to 24 percent had a history of prior contralateral CEA and 25 to 32 percent had a history of contralateral transient ischemic attack or stroke in trials reporting baseline data for these characteristics. Requirements for asymptomatic status differed slightly across the trials. For example, ACST enrolled subjects with no transient ischemic attack or stroke attributable to the ipsilateral artery for the past 6 months; ACAS enrolled persons with no history of cerebrovascular events in the distribution of the ipsilateral carotid artery or the vertebrobasilar system, and no symptoms referable to the contralateral artery for the past 45 days. For inclusion, subjects were required to have at least 50 percent (VACS) or at least 60 percent (ACAS and ACST) CAS.

Medical therapy varied across trials and was often not clearly defined or standardized. All subjects received aspirin in ACAS and VACS. ACAS also included a risk factor discussion and modification at randomization, subsequent interviews, and telephone followup. ACST left medical therapy to the discretion of clinicians, reporting that it usually included antiplatelet and antihypertensive therapy and, in later years of the trial, lipid-lowering therapy.

Surgeons with a history of low complication rates were selected for the three trials. They submitted records of their last 50 cases (ACAS and ACST) or previous 24 months of experience with CEA (VACS) and were selected based on demonstrated acceptability of morbidity and mortality (either based on review by a committee or a morbidity and mortality rate less than 3%). In addition, ACAS and ACST trial protocols included stipulations to prevent further enrollment by surgeons or institutions that showed unacceptably high morbidity or mortality during the trial.

#### Trial Results

Table 3 summarizes the main results of the three trials, and Appendix F includes complete results of our meta-analyses. Risk differences represent absolute differences over approximately 5 years.

Table 3 Main Results of Randomized, Controlled Trials of CEA Compared With Medical Management for Asymptomatic CAS

Study, year | Require preoperative angiogram? | Angiogram complication rate | Perioperative (30-d) stroke or death | Perioperative (30-d) nonfatal MI | Rate of perioperative stroke/death & any subseqent stroke (95% CI) | Rate of perioperative stroke/death & subsequent ipsilateral stroke (95% CI) | All-cause mortality (# of deaths) | Any stroke or death | QOL or functional status
ACAS, 1995 | Yes | 1.2% (5 patients had CVAs, 1 of whom died; 414 had angiograms) | 2.7%^a^ Sex: W: 3.6% M: 1.7% p=0.12 | NR | 5-y estimate: MM: 17.5% CEA: 12.4% RRR: 29% (-5% to 52%) ARR: 5.1% Observed events, median 2.7-y followup: MM: 10.3% CEA: 7.3% ARR: 3% By age, sex, race, ethnicity: NR | 5-y estimate: MM: 11% (NR) CEA: 5.1% (NR) RRR: 53% (22% to 72%) ARR: 5.9% (NR) Observed events, median 2.7-y followup: MM: 6.2% CEA: 4% ARR: 2.2% 5-y RRR: [underlined: Sex] W: 17% (-96% to 65%) M: 66% (36% to 82%) [underlined: Age] <68 y: 60% (11% to 82%) ≥68 y: 43% (-7% to 70%) | MM: 89 CEA: 83 | 5-y estimate: MM: 31.9% CEA: 25.6% RRR: 20% (-2% to 37%) ARR: 6.3% Observed events, median 2.7-y followup: MM: 18.6% CEA: 15.4% ARR: 3.2% | NR
ACST, 2004 and 2010 | No | NA | 2.9% (2.1 to 3.8)^b^ No significant difference for subgroups of age, sex, or extent of stenosis^c^ | 0.7% | 10-y estimate: MM: 13.1% CEA: 9.2% RR: 0.70 (0.57 to 0.86) ARR: 3.9% By age, sex, race, ethnicity: NR^d^ | MM: 6.9% CEA: 5.3% RR: 0.76 (0.57 to 1.00) ARR: 1.6% | MM: 570 CEA: 610^e^ | MM: 49.4% CEA: 47.2% RR: 0.95 (0.89 to 1.03) | Proportion of nonperioperative strokes that were disabling or fatal: 57.8% (166/287). Reduction in disabling or fatal nonperioperative stroke: 0.61 (95% CI, 0.41 to 0.92)
VACS, 1993 | Yes | 0.4% (3 nonfatal strokes/714 angiograms) | 4.7%^f^ By age, sex, race, ethnicity: NR | 1.9% (4/211) | MM: 12.9% CEA: 10.4% RR: 0.81 (0.48 to 1.36) ARR: 2.5% By age, sex, race, ethnicity: NR | MM: 10.3% CEA: 6.6% RR: 0.64 (0.34 to 1.21) ARR: 3.7%^g^ | MM: 78 CEA: 70 | MM: 44.2% CEA: 41.2% RR: 0.92 (0.69 to 1.22) | Mean stroke severity score^h^: MM: 4.1 CEA: 3.6 P: NS

a During the perioperative period, 2.3% of surgical patients (n=19) had a stroke or died (95% CI, 1.28 to 3.32) compared with 0.4% of patients in the medical group (95% CI, 0.0% to 0.8%). It was estimated that if all 724 patients receiving CEA had undergone arteriography as part of the ACAS (some had an angiogram in the 60 days prior to the study) that 2.7% of surgical patients would have had stroke or death from the procedure.

b 2.9% (44 of 1,532 CEAs performed) was the rate of perioperative stroke or death for the immediate CEA group; when including the delayed group that underwent CEA, the rate was 3.0% (95% CI, 2.4 to 3.9).

c Data not shown; reported in text only in the 10-year followup publication of ACST. The 5-year publication reported rates of 3.6% for women, 2.5% for men, 2.6% for those age <65 years, 2.6% for those ages 65 to 74 years, and 3.7% for those age ≥75 years; these data are from an online table referenced in the initial results paper from ACST and do not include all 1,532 CEAs reported in the later publication. The denominator was 1,405 CEAs performed in the immediate CEA group.

d Not reported by subgroups for this outcome, but reported for some other outcomes. First nonperioperative stroke, by sex: W, 0.57 (95% CI, 0.34 to 0.97); M, 0.52 (95% CI, 0.36 to 0.75). First nonperioperative stroke, by age: <65 years at entry, 0.46 (95% CI, 0.26 to 0.82); 65 to 74 years at entry, 0.48 (95% CI, 0.31 to 0.75); ≥75 years at entry, 0.81 (95% CI, 0.43 to 1.51).

e Obtained from online Appendix Table 2A. Cause-specific number of deaths within 10 years for MM (deferral) vs. immediate CEA: perioperative (i.e., after CEA), 3 vs. 17 (p=0.002); nonperioperative stroke, 68 vs. 39 (p=0.006); vascular, 267 vs. 298 (p=0.15); neoplastic, 101 vs. 111 (p=0.44); other/unknown, 131 vs. 145 (p=0.33).

f 30-day operative mortality was 1.9% (4/211), with 3 deaths from MI and 1 from MI followed by stroke. During the perioperative period, 4.7% of surgical patients had a stroke or died, when including the complications of arteriography, compared with 1 death due to suicide (0.4%), 1 stroke (0.4%), and 1 TIA (0.4%) in the medical group.

g Incidence of all ipsilateral neurologic events (TIA, transient monocular blindness, fatal stroke, and nonfatal stroke): MM, 48 (20.6%) vs. CEA, 17 (8%); RR, 0.38 (95% CI, 0.22 to 0.67). Incidence of ipsilateral stroke (fatal and nonfatal): MM, 22 (9.4%) vs. 10 (4.7%); 95% CI, NR.

h 1 to 11 scale: 1 to 3 = no impairment, 4 = minor impairment, ≥5 = major impairment in at least one domain of functioning.

Abbreviations: ACAS = Asymptomatic Carotid Atherosclerosis Study; ACST = Asymptomatic Carotid Surgery Trial; ARR = absolute risk reduction; CEA = carotid endarterectomy; CI = confidence interval; CVA = cerebrovascular accident; M = men; MI = myocardial infarction; MM = medical management; NA = not applicable; NR = not reported; NS = not significant; RR = relative risk; RRR = relative risk reduction; W = women.

Perioperative stroke or death or subsequent ipsilateral stroke. Our meta-analyses found that 2.0 percent fewer subjects treated with CEA had perioperative stroke or death or subsequent ipsilateral stroke compared with subjects in medical therapy groups (risk difference [RD], -0.020 [95% CI, -0.033 to -0.007]).

Perioperative stroke or death or any subsequent stroke. Our meta-analyses found that 3.5 percent fewer subjects treated with CEA had perioperative stroke or death or any subsequent stroke compared with subjects in medical therapy groups (RD, -0.035 [95% CI, -0.051 to -0.018]).

All-cause mortality. Our meta-analyses found no difference between CEA and medical therapy (RD, 0.01 [95% CI, -0.02 to 0.03]).

Any stroke or death. Our meta-analyses found that 2.7 percent fewer subjects treated with CEA had any stroke or death compared with subjects in medical therapy groups (RD, -0.027 [95% CI, -0.051 to -0.003]).

Ipsilateral stroke (nonperioperative). Our meta-analyses found that 4.1 percent fewer subjects treated with CEA had ipsilateral stroke compared with subjects in medical therapy groups (RD, -0.041 [95% CI, -0.054 to -0.027]), not including the perioperative period.

Any nonperioperative stroke. Our meta-analyses found that 5.5 percent fewer subjects treated with CEA had any stroke after the perioperative period compared with subjects in medical therapy groups (RD, -0.055 [95% CI, -0.070 to -0.039]).

Quality of life and functional status. None of the included trials assessed quality of life using validated instruments (e.g., SF-36), but two reported some information about stroke severity. In ACST, more than half (57.8% or 166/287) of nonperioperative strokes were disabling or fatal and the proportional reduction in disabling or fatal stroke (RR, 0.61 [95% CI, 0.41 to 0.92]) was similar to that for any stroke (RR, 0.54 [95% CI, 0.43 to 0.68]).32 In VACS, mean stroke severity scores were 3.6 and 4.1 for the CEA and medical therapy groups, respectively (range not reported, p value reported as not statistically significant), indicating minor impairment on average (1 to 11 scale, with scores of 1 to 3 indicating no impairment, score of 4 indicating minor impairment, and scores of 5 or greater indicating major impairment in at least one domain of functioning).73

Persons at decreased, average, or increased risk for ipsilateral stroke. As described in KQ 4, we did not find any externally validated, reliable risk stratification tools to distinguish persons with asymptomatic CAS who are at decreased or increased risk for stroke caused by CAS. Therefore, evidence does not allow reliable determination of whether the potential benefits of CEA or CAAS differ for persons at decreased, average, and increased risk for ipsilateral stroke caused by CAS.

Age, sex, race, and ethnicity. None of the trials reported subgroup information by race or ethnicity. The ACAS and ACST provided subgroup analyses for some outcomes by sex and age. In ACAS, the estimated 5-year rate of perioperative stroke or death and subsequent ipsilateral stroke showed a statistically significant reduction for men (RRR, 66% [95% CI, 36 to 82]), but not for women (17% [95% CI, -96 to 65]). Subgroup analyses by age for the same outcome showed a significant reduction for persons younger than age 68 years (RRR, 60% [95% CI, 11 to 82]), but not for persons age 68 years and older (43% [95% CI, -7 to 70]). Subgroup analyses by percent CAS (60% to 69.9%, 70% to 79.9%, and 80% to 99.9%) found no statistically significant gradation in reduction, but sample sizes were small.

In ACST, reduction in first nonperioperative stroke was statistically significant for both sex subgroups (men RR, 0.52 [95% CI, 0.36 to 0.75]; women RR, 0.57 [95% CI, 0.34 to 0.97]). For subgroups defined by age, reduction in the first nonperioperative stroke was significant for persons younger than age 75 years, but not for persons age 75 and older (age <65 years RR, 0.46 [95% CI, 0.26 to 0.82]; age 65 to 74 years RR, 0.48 [95% CI, 0.31 to 0.75]; age ≥75 years RR, 0.81 [95% CI, 0.43 to 1.51]). Subgroup analyses by percent CAS (<70%, 70% to 79%, 80% to 89%, 90% to 99%) found similar point estimates for patients with varying degrees of CAS.

#### Systematic Reviews

Two of the three reviews included good- or fair-quality systematic reviews comparing CEA with medical management were conducted prior to the most recent ACST publication,32 and thus had preliminary ACST data; these reviews were the last review for the USPSTF2 and a review on CEA for asymptomatic CAS from the Cochrane Collaboration.77 The third review compared management strategies for asymptomatic CAS and included a meta-regression to evaluate the effect of time (to reflect improvements in medical therapy) on incidence rates of stroke.78 The investigators found that the incidence rate of ipsilateral stroke was lower in studies that completed recruitment from 2000 to 2010 than in studies that completed recruitment in earlier years (1.13% vs. 2.38% per year; p<0.001).78

### Key Question 6 Incremental Benefit of Additional Medications Beyond Current Standard Medical Therapy

We found no eligible studies that addressed this question.

### Key Question 7 Harms Associated With Screening or Confirmatory Testing

The potential harms of screening or confirmatory testing for asymptomatic CAS include harms associated with false-positive screening tests (e.g., anxiety, labeling) and harms of any confirmatory workup, such as angiography. We found no studies on anxiety or labeling in persons with false-positive results. Two RCTs reported strokes after angiography. In ACAS,31 5 of 414 patients (1.2%) who underwent angiograms developed strokes; one of these five patients died subsequently. In VACS,73 3 of 714 patients (0.4%) had nonfatal strokes following angiography. Evidence was insufficient to determine whether the harms differ for subgroups defined by age, sex, race, ethnicity, or comorbidities.

### Key Question 8 Harms Associated With CEA or CAAS

We included three RCTs described in 11 publications31,32,67-75 that compared CEA with medical therapy and 41 additional multi-institutional trials or cohort studies (including registries) that reported rates of relevant harms for either CEA or CAAS, regardless of the comparator. Of these, we rated 17 as poor quality, usually for high risk for selection bias and/or ascertainment bias. Characteristics and results of studies rated as poor quality are not described in detail in the main report; they are available in Appendix E Tables 2 and 3. Most studies reported perioperative death or stroke and did not report on other harms (e.g., nerve injuries, other postoperative harms, psychological harms).

#### Trial Characteristics

The RCTs comparing CEA with medical therapy are described in Table 2 and KQ 5. Characteristics of other included trials are presented in Table 4; these included four RCTs,82-86 three uncontrolled trials,87-89 one pooled analysis of two uncontrolled trials,90 and one nonrandomized trial rated as poor quality.91-93

Table 4 Characteristics of Additional Studies Rated as Good or Fair Quality and Reporting Rates of Periprocedural Complications of CEA or CAAS for Adults With Asymptomatic CAS

Study, Year | Design Study Period | Procedure N Total (N Asymp) | Setting and Source Population | Sample Selection Criteria | Sample Subjects' Characteristics^a^ | Threats to Internal and External Validity | Quality
Cohort studies
Bratzler, 1996 | Cohort study 1/1993-12/1994 | CEA 813 (347); 774 patients | Oklahoma Medicare beneficiaries, 8 hospitals | Medicare claims used to identify all CEA cases. Asymptomatic defined as no prior TIA or stroke in the distribution of the operated carotid artery. | Median Age: 73 y White: NR Female: NR DM: 26% CAD: 67% COPD: 20% HF: 10% HTN: 71% Smoker: 26% Stenosis: 96% >60% CAS Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment; definition of symptomatic CAS required documentation of past TIA or stroke in the distribution of the carotid being operated on. | Fair
Cebul, 1998 | Cohort study 7/1993-6/1994 | CEA 678 (167) | Ohio non-HMO Medicare beneficiaries, 115 hospitals and at least 478 surgeons | Medicare part A claims used to identify all non-HMO Medicare beneficiaries who underwent CEA; random sample of the 4120 CEAs performed. Asymptomatic if no record of any neurologic symptoms or signs; categorized as nonspecific symptoms if had nonlateralizing symptoms or signs (e.g., dizziness, dementia) | Mean Age: 73 y White: 94% Female: 46% DM: 26% CAD: NR COPD: 15% HF: 9% HTN: 71% Smoker: 31% Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment; interrater reliability for determining indication for surgery (TIA, stroke, asymptomatic or nonspecific symptoms) of 77% (kappa, 0.69). | Fair
Giacovelli, 2010 | Cohort study 2005-2007 | CEA + CAAS 47,752 total CAAS+CEA (42,236) 4,919 (4,353) used in the matched propensity analysis comparing CAAS and CEA | New York and California state hospital discharge databases | ICD-9 codes to identify patients who had CAAS or CEA. Uses “present on admission” (POA) flag in discharge diagnoses to identify symptom status. | Mean Age:^b^ CEA: 73 y; CAAS: 71 y White: CEA: 86%; CAAS: 77% Female: CEA: 43%; CAAS: 39% DM: CEA: 27%; CAAS: 30% CAD/HF: CEA: 44%; CAAS: 57% COPD: CEA: 14%; CAAS: 13% HTN: CEA: 71%; CAAS: 74% Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used present on admission designations to determine symptom status at baseline; used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only. | Fair
Giles, 2010 | Cohort study 10/2004-12/2007 | CEA + CAAS 538,958 (52.937) CAAS: 56,564 (49,126) CEA: 482,394 (436,895) | NIS database^c^ | ICD-9 codes from NIS database. Patients with symptomatic carotid stenosis were identified by ICD-9 diagnosis codes of TIA, amaurosis fugax, or stroke. Patients also classified as CMS high risk based on prespecified criteria. | Mean Age: CEA: 71 y; CAAS: 70 y White: NR Female: CEA: 43%; CAAS: 40% DM: NR CAD (Previous MI): CEA: 11%; CAAS: 10% COPD: CEA: 22%; CAAS: 19% HF: CEA: 7%; CAAS: 11% HTN: NR Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only; potential for bias due to misclassification of symptom status and whether stroke was the indication or a perioperative harm. | Fair
Halm, 2003; Rockma, 2005; Halm, 2005; Press, 2006 | Cohort study 1/1997-12/1998 | CEA 2,124 (1,413) (N varies slightly across publications) | 6 hospitals in New York (4 university and 2 community hospitals); 67 surgeons | Used administrative databases from 6 hospitals; consecutive CEAs (identified by ICD-9 codes). Indication for surgery based on acuity of the presenting neurologic symptoms in the 12 months before surgery (stroke-in-evolution, stroke, carotid TIA, asymptomatic, etc.). | Mean Age: 72 y White: 87% Female: 43% DM: 29% CAD: 55% COPD: 9% HF: 8% HTN: 73% Smoker: NR% Stenosis: 90.1% had 70%-99% CAS: Prior contralateral CEA: NR Contralateral occlusion: 6% Contralateral TIA/stroke: NR | May have missed readmissions to other hospitals (only included readmissions to the index hospital); data from 1 region of New York; no comprehensive exam by neurologist for outcome assessment. | Fair
Halm, 2007; Halm, 2009 | Cohort study (NYCAS) 1/1998-6/1999 | CEA 9,588 (6,932) | New York state Medicare beneficiaries; 166 hospitals; 488 surgeons | Any NY state Medicare claims for CEA and NY state hospital discharge database. | Mean Age: 75 y White: 93% Female: 44% DM: 30% CAD: 62% COPD: 19% HF: 10% HTN: 79% Smoker: NR Stenosis: 94% with 70%-99%; 1% with 100% occlusion; 2.9% with 60%-69% Prior contralateral CEA: NR Contralateral occlusion: 5% with 100%; 24% with 70%-99%; 5% with 60%-69% Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment. Data abstractors had to pass a series of quality assurances and interrater reliability tests. Data reported had kappa from 0.60 to 1.0. | Fair
Hopkins, 2010 | Cohort study (lead-in/credentialing phase of CREST) 11/2000-4/2008 | CAAS 1,565 (1,151) | Lead-in case data were reviewed prospectively for 427 potential interventionalists | Asymptomatic subjects had to have >70% stenosis by angiography. Ascertainment of symptom status is unclear; cases were submitted by potential interventionalists to a multidisciplinary committee for review. | Mean Age: 70 y White: 88% Female: 37% DM: 33% CAD: 24% with previous CABG COPD: NR HF: NR HTN: 84% Smoker: 18% Stenosis: 79% Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Unclear whether cases are representative of the source population. | Fair
Karp, 1998 | Cohort study 1/1993-12/1993 | CEA 1,945 (1,002) | Georgia Medicare beneficiaries | Georgia Medicare claims; ICD-9 codes used to identify patients who underwent CEA. Asymptomatic defined following ACAS (absence of symptoms in distribution of the operated carotid artery). | Mean Age: 72 y White: 91% Female: 47% DM: 20% CAD: NR COPD: 24% HF: 8% HTN: NR Smoker: NR Stenosis: 22% had 56%-75%; 70% had >75% Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment. | Fair
Kresowik, 2000 | Cohort study 1/1994-12/1994 and 6/1995-5/1996 | CEA 2,063 CEAs (671 CEAs; 1994 only: 159) | Iowa Medicare beneficiaries, 30 hospitals; 79 surgeons | Claims for CEA (ICD-9) from Medicare Provider Analysis and Review (MEDPAR) Part A claims; Part B files for CPT codes also used. Considered asymptomatic if no history prior to CEA of CV symptoms or events in either the anterior or posterior circulations. | Median Age: 74 y White: NR Female: 40%-41% DM: NR CAD: NR COPD: NR HF: NR HTN: NR Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment. | Fair
Kresowik, 2001 | Cohort study 6/1995-5/1996 | CEA 10,561 (3,891); 10,030 patients | Medicare beneficiaries from 10 US states^d^ | Used ICD-9 code for CEA among Medicare Provider Analysis and Review (MEDPAR) Part A claims. Considered asymptomatic if no history prior to CEA of CV symptoms or events in either the anterior or posterior circulations. | Mean age: 74 y White: NR Female: 43% DM: NR CAD: NR COPD: NR HF: NR HTN: NR Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment. | Fair
Kresowik, 2004 | Cohort study 6/1995-5/1996 and 6/1998-5/1999 | CEA 19,690 (1995-1996: 3,891; 1998-1999: 4,093) | Medicare beneficiaries from 10 US states^d^ | ICD-9 code for CEA among Medicare Provider Analysis and Review (MEDPAR) Part A claims. Considered asymptomatic if there was no history prior to CEA of CV symptoms or events in either the anterior or posterior circulations. | Median Age: 74 y White: NR Female: 43%-44% DM: NR CAD: NR COPD: NR HF: NR HTN: NR Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | May have missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization; no comprehensive exam by neurologist for outcome assessment. | Fair
McPhee, 2007 | Cohort study 1/2003-12/2004 | CEA + CAAS 259,080 CEAs/CAASs (238,389 CEAs/CAASs) 245,045 CEAs (226,111 CEAs) 14,035 CAASs (12,278 CAASs) | NIS (Nationwide Inpatient Sample)^c^ | ICD-9 codes from NIS database | Mean Age: CEA: 71 y; CAAS: 71 y Median Age: CEA: 72 y; CAAS: 72 y White: NR Female: CEA: 43%; CAAS: 41% DM: CEA: 25%; CAAS: 26% CAD/MI: CEA: 12%; CAAS: 12% COPD: CEA: 19%; CAAS: 15% HF: CEA: 6%; CAAS: 9% HTN: CEA: 71%; CAAS: 67% Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Before 10/2004 no specific CAAS ICD-9 code existed, so required 2-step method to identify CAAS procedures with potential for misclassification. Used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only; potential for bias due to misclassification of symptom status and whether stroke was the indication or a perioperative harm. | Fair
McPhee, 2008 | Cohort study 2005 | CEA + CAAS 135,701 (122,986) CEA: 122,786 (111,684) CAAS: 12,914 (11,302) | NIS database^c^ | ICD-9 codes from NIS database | Mean Age:^b^ CEA: 71; CAAS: 72 White: NR Female: CEA: 43%; CAAS: 37% DM: CEA: 27%; CAAS: 27% CAD/MI: CEA: 11%; CAAS: 12% COPD: CEA: 21%; CAAS: 18% HF: CEA: 7%; CAAS: 11% HTN: CEA: 72%; CAAS: 66% Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only; potential for bias due to misclassification of symptom status and whether stroke was the indication or a perioperative harm. | Fair
Timaran, 2009 | Cohort study 2005 | CEA + CAAS CAAS:13,093 (11,836) CEA:122,984 (113,514) | NIS database^c^ | ICD-9 codes from NIS database | Median Age: CEA: 72 y; CAAS: 72 y White: NR Female: CEA: 43%; CAAS: 38% DM: CEA: 29%; CAAS: 28% Previous MI: CEA: 12%; CAAS: 11% COPD: CEA: 21%; CAAS: 18% HF: CEA: 8%; CAAS: 12% HTN: CEA: 76%; CAAS: 69% Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only; potential for bias due to misclassification of symptom status and whether stroke was the indication or a perioperative harm. | Fair
Vouyouka, 2012 | Cohort study 2007-2009 | CEA + CAAS 20,613 CEAs/CAASs (18,519) CEA: 18,320 (16,576) CAAS: 2,263 (1,943) | New York and Florida state discharge databases to identify women who underwent CEA or CAAS | ICD-9 codes to identify patients who had CAAS or CEA. Uses POA flag in discharge diagnoses to identify symptom status. | Mean Age:^b^ 72 y White: 90% Female: 100% DM: 30% CAD: 37% COPD: 2% HF: 6% HTN: 80% Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used present on admission designations to determine symptom status at baseline; used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only. | Fair
Young, 2011 | Cohort study 2006-2007 | CEA + CAAS 249,592 (all asymptomatic) CAAS: 31,197 (all) CEA: 218,395 (all) | NIS database^c^ | ICD-9 codes from NIS database. Asymptomatic precerebral stenosis codes as indication for CAS/CEA, excluding TIA as indication for CAAS/CEA. Also stratified patients by age <80 years and ≥80 years. | Mean Age: 71 y; CEA: 71 y; CAAS: 71 y White: 66%; CEA: 65%; CAAS: 68% Female: 43%; CEA: 43%; CAAS: 40% DM: 31%; CEA: 31%; CAAS: 30% CAD (previous MI): 50%; CEA: 49%; CAAS: 57% COPD: 18%; CEA: 19%; CAAS: 18% HF: 8%; CEA: 7%; CAAS: 12% HTN: 79%; CEA: 79%; CAAS: 75% Smoker: 34%; CEA: 35%; CAAS: 27% Stenosis: NR Prior contralateral CEA: NR Contralateral stenosis: 17%; CEA: 17%; CAAS: 20% Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only; potential for bias due to misclassification of symptom status and whether stroke was the indication or a perioperative harm. | Fair
Yuo, 2013 | Cohort study 2005-2009 | CEA + CAAS 30,317 (all asymptomatic) CAAS: 3,476 (all) CEA: 26,841 (all) | California hospital discharge data | ICD-9 codes to identify cerebral revascularization procedures. Symptom status determined by presence ofadmission or diagnosis codes for hemispheric cerebral ischemia or ophthalmic artery occlusion or embolism. | Age >70 y: CEA: 66%; CAAS: 62% White: CEA; 90%; CAAS: 83% Female: CEA: 43%; CAAS: 44% DM, complicated: CEA: 5%; CAAS: 4% Previous MI: NR COPD: CEA: 20%; CAAS: 17% HF: CEA: 8%; CAAS: 11% HTN, complicated: CEA: 10%; CAAS: 11% Smoker: NR Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Used present on admission designations to determine symptom status at baseline; used ICD-9 codes only for outcome ascertainment; no supplementation with review of medical records; in-hospital outcomes only | Fair
Trials
Brott, 2010 ; Silver, 2010 | RCT (CREST) 12/2000-7/2008; asymptomatic patients were only included from 2005 forward | CEA + CAAS CEA: 1,240 (587) CAAS: 1,262 (594) | Multicenter (117 sites) | Asymptomatic patients had to have at least 60% stenosis by angiography, at least 70% by ultrasound, or at least 80% by CT or MR angiography (if the stenosis by ultrasound was initially read as 50%-60%). Asymptomatic defined as symptoms referable only to the hemisphere contralateral to the target vessel or symptoms in either hemisphere >180 days prior to randomization, or vertebrobasilar symptoms only. | CEA/CAAS^e^ Mean Age: 70/69 y White: 95%/94% Female: 33%/36% DM: 34%/33% CAD: 44% COPD: NR HF: NR HTN: 88%/88% Smoker: 22%/26% Stenosis: 92%/93% with ≥70% stenosis Prior contralateral CEA: NR Contralateral occlusion: 3%/2% Contralateral TIA/stroke: NR | Unclear whether cases are representative of the source population. A comprehensive training and credentialing process was required of participating interventionalists; only those with low complication rates were invited to participate in the study. | Fair
CASANOVA study group, 1991 | RCT 1982-1988 | CEA: 410 (all) 216 in the group in which all patients had CEA | Patient population recruited from ultrasound labs | Asymptomatic stenosis >50% and <90% Exclusion of MI within past 6 months, renal failure, dementia, severely limited life expectancy | Mean age: 64 White: NR Female: 27% DM: 26% CAD: 44% COPD: NR HF: NR HTN: 59% Smoker: 29% Stenosis: 100% had >50% and <90%; 50% had >70% Prior contralateral CEA: 27% Contralateral occlusion: NR Contralateral TIA/stroke: NR | Subjects from one arm of an RCT; unclear how representative subjects were of overall source population. | Fair
Chaturvedi, 2010 Matsumura, 2010 | Uncontrolled trial (CAPTURE-2) 3/2006-1/2009 | CAAS: 5,297 (4,337) <80 y: 4,131 (3,388) ≥80 y: 1,177 (949) | CAPTURE-2 is “post-approval” trial to capture rare events | Asymptomatic patients had to have >80% stenosis to have CAAS. Asymptomatic patients had no TIA, amaurosis fugax, or stroke in the territory supplied by the target vessel within 180 days. | Mean Age: 73 y^f^ White: NR Female: 39% DM: 37% CAD: 74% COPD: 23% HF: 19% HTN: 89% Smoker: 22% Stenosis: 86% Prior contralateral CEA: 17% Contralateral occlusion: 17% Contralateral TIA/stroke: NR | Unclear whether cases are representative of the source population | Fair
Fairman, 2007 | Uncontrolled trial 10/2004-03/2006 | CAAS: 3,500 (3,018) | CAPTURE registry: prospective multicenter registry (353 interventionalists) that enrolled high risk surgical patients from 144 sites in US | CAPTURE registry data evaluating stroke rates by various criteria (timing, age, symptom status). Asymptomatic if no TIA, amaurosis fugax, or stroke in the hemisphere supplied by the target vessel within 180 days before procedure. | Mean age: 73 y White: NR Female: 39% DM: 35% CAD: NR COPD: NR HF: 17% HTN: 88% Smoker: 21% Stenosis: mean, 85% Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Unclear whether cases are representative of the source population | Fair
Gray, 2009 | Pooled analysis of data from 2 uncontrolled trials CAPTURE-2 (3/2006-ongoing as of publication) EXACT (11/2005-4/2007) | CAAS Combined: 6,320 (5,558) EXACT: 2,145 (1,932) Capture-2: 4,175 (3,627) | CAPTURE-2 and EXACT databases; 280 sites and 672 investigators Both are post-marketing registries of CAAS (2 specific devices) | No specific inclusion or exclusion criteria. Asymptomatic patients had no TIA, amaurosis fugax, or stroke in the territory supplied by the target vessel within 180 days. | Combined: Mean Age: 73 y White: NR Female: 38% DM: 36% CAD: 72% COPD: 20% HF: 18% HTN: 90% Smoker: 20% Stenosis: 86% Prior contralateral CEA: NR Contralateral occlusion: 15% Contralateral TIA/stroke: NR | Stroke outcomes assessors were masked, but MI and death were reported by the sites. | Fair
MACE study group, 1992 | RCT 1987-1990 | CEA: 36 in surgical arm | Mayo Clinic sites (Rochester, Jacksonville, Scottsdale) | Exclusions: age <18 y, women of childbearing age, unstable angina or MI in last 6 months, afib/flutter, severe valvular disease, moderate to severe CHF, severe COPD, cancer, other terminal illness, dementia, other psychiatric illness, renal failure, uncontrolled HTN or DM | Age: 69% >65 y White: 97% Female: 44% DM: 19% CAD: 42% COPD: 0 HF: 0 HTN: 64% Smoker: 25% current; 67% ever Stenosis: NR Prior contralateral CEA: NR Contralateral occlusion: NR Contralateral TIA/stroke: NR | Subjects from one arm of an RCT | Fair
Yadav, 2004 | RCT (SAPPHIRE) 8/2000-7/2002 | CEA + CAAS: 334 (96) CEA: 167 (46) CAAS: 167 (46) | Multicenter (29 sites) | Symptom status was assessed by a neurologist. Asymptomatic patients were required to have >80% stenosis. All participants had to have one high risk criteria (e.g. severe pulmonary disease, age >80 y). | Mean Age: 73 y White: NR Female: 33% DM: 26% CAD: 81% COPD: 15% HF: 18% HTN: 85% Smoker: 17% Stenosis: NR (inclusion criteria require >80% in asymptomatic patients) Prior contralateral CEA: NR Contralateral occlusion: 24% Contralateral TIA/stroke: NR | Unclear whether cases are representative of the source population. Highly selected surgeons and interventionalists; participating interventionalists had to demonstrate a low complication rate with CEA or CAAS in order to participate in the trial. Unclear whether symptom status was determined using valid and reliable methods. | Fair

Note: Data are for followup years; reported ages are the mean unless otherwise specified.

a Sample characteristics are of entire cohort (symptomatic and asymptomatic patients) unless otherwise noted.

b Characteristics are for the asymptomatic subgroup, not whole sample.

c Database of abstracted discharge data from national survey of 20% of all nonfederal hospitals in United States; linked to American Hospital Association annual survey of hospitals; asymptomatic if principal discharge diagnosis was CAS “without mention of stroke” with no accompanying secondary diagnoses for TIA.

d Arkansas, Georgia, Illinois, Indiana, Iowa, Kentucky, Michigan, Nebraska, Ohio, and Oklahoma.

e Patient characteristics are given for asymptomatic patients.

f These are for the asymptomatic patient population.

Abbreviations: ACAS = Asymptomatic Carotid Atherosclerosis Study; CAAS = carotid angioplasty and stenting; CABG = coronary artery bypass graft; CAD = coronary artery disease; CAS = carotid artery stenosis; CEA = carotid endarterectomy; CHF = congestive heart failure; COPD = chronic obstructive pulmonary disease; CPT = Current Procedure Terminology; CT = computed tomography; CV = cerebrovascular; DM = diabetes mellitus; HF = heart failure; HMO = health maintenance organization; HTN = hypertension; ICD = International Classification of Diseases; MI = myocardial infarction; MR = magnetic resonance; N = sample size; NIS = Nationwide Inpatient Sample; NR = not reported; RCT = randomized, controlled trial; TIA = transient ischemic attack; U/S = ultrasound.

Two RCTs comparing CEA with different control groups that were not included in KQ 5 provide relevant rates of harms following CEA. The first, CASANOVA (Carotid Artery Stenosis with Asymptomatic Narrowing: Operation Versus Aspirin trial), was a multicenter RCT conducted in Germany in 410 patients randomized to CEA or control.82 Nearly half of the patients randomized to the control group eventually received surgery due to development of 90 percent or greater stenosis in one artery, development of bilateral stenosis at 50 percent or greater, or development of symptomatic CAS.82 The second trial, MACE (Mayo Asymptomatic Carotid Endarterectomy trial), compared low-dose aspirin with CEA and no aspirin.83 MACE was terminated early because of high rates of MI and transient ischemic attack in the surgical group attributed to aspirin being withheld. We only included these two trials for the perioperative harms for the groups assigned to CEA. Both MACE and CASANOVA were conducted in the early 1990s in patients with 50 percent to 99 percent CAS, confirmed by angiography. Subjects in both trials were predominately male (56% to 63%) and most had hypertension (60% to 64%); 42 to 44 percent had CAD.

Two other multicenter RCTs compared CEA with CAAS: CREST (Carotid Revascularization Endarterectomy Versus Stenting Trial)84,85 and SAPPHIRE (Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy trial).86 SAPPHIRE required that participants have at least one condition suggesting high surgical risk (e.g. age greater than 80 years, severe pulmonary disease, contralateral carotid occlusion). Participants were similar in the prevalence of hypertension (85% to 88%) and diabetes (25 to 33%). More subjects in SAPPHIRE had CAD than in CREST (81% vs. 44%). In both trials, interventionalists had to demonstrate low complication rates prior to participating.

Three studies used post-marketing surveillance data to provide rates following CAAS: two uncontrolled trials (CAPTURE [Carotid ACCULINK/ACCUNET Post Approval Trial to Uncover Rare Events trial] and CAPTURE-2)87-89 and one pooled analysis of two uncontrolled trials (using CAPTURE-2 and EXACT [Emboshield® and Xact® Post Approval Carotid Stent Trial]).90 The CAPTURE registry collected data prospectively from multiple sites that enrolled patients deemed high risk for surgery and who elected to undergo CAAS for asymptomatic stenosis.87 Similarly, the CAPTURE-2 registry was a postapproval trial designed to capture rare events associated with CAAS.88,89 All three studies had pre- and postintervention neurologic evaluation and independent adjudication of neurological outcomes. Across all three trials, the mean age of participants was 73 years, approximately 38 percent were female, a third had diabetes, approximately 90 percent had hypertension, and the mean degree of stenosis was 85 to 86 percent.

#### Observational Study Characteristics

Eight fair-quality, multi-institution cohort studies described in 12 publications reported perioperative harms of CEA (Table 4).24,94-104 All eight used Medicare claims or enrollment databases to identify included populations; harms were identified using both claims data and medical chart review. Most were conducted in Medicare beneficiaries of single states,24,96-104 and two studies used data from 10 states.94,95

One cohort conducted during the lead-in (credentialing) phase of CREST included rates of postoperative harms following CAAS cases prospectively submitted by 427 potential interventionalists prior to selecting operators for the CAAS arm of CREST.105 The study reported data on 1,151 patients undergoing CAAS for asymptomatic CAS at 70 percent or greater, determined by angiography.

An additional eight fair-quality studies reported in-hospital (but not 30-day) perioperative events following CEA or CAAS (Table 4). Three utilized state discharge databases,106-108 and five used the Nationwide Inpatient Sample (NIS).109-113 The NIS data originates from a national survey of 20 percent of all nonfederal hospitals.109,110 The results of these studies are provided in Table 5, with the results of the other studies rated as good or fair quality that reported rates of periprocedural harms, but are not included in this text because they only capture in-hospital events.

Table 5 Results From Additional Studies Rated as Good or Fair Quality and Reporting Rates of Periprocedural Complications of CEA or CAAS for Adults With Asymptomatic CAS

Study, Year | Method of Outcome Assessment | In-Hospital Rates | 30-Day Rates
Cohort studies
Bratzler, 1996 | Standard data collection form; abstractors used administrative data and medical records; also used MedPRO data to identify patients who died or were readmitted with a principal diagnosis of stroke within 30 days. | NR | Combined^a^ stroke or death: Overall: 3.7% High^b^ volume hospitals: 3.5% Low volume hospitals: 5.2% Stroke: Overall: 2.6% High volume hospitals: 2.8% Low volume hospitals: 1.7% Death: Overall: 1.2% High volume hospitals: 0.7% Low volume hospitals: 3.4%
Cebul, 1998 | Administrative data and chart review; trained nurse reviewers to identify outcomes during hospitalization; Medicare Provider Analysis and Review claims to identify all deaths and readmissions within 30 days of CEA, and the records of those were reviewed for occurrence of strokes. | NR | Stroke or death: Overall: 2.4% High volume hospitals: 0% Low volume hospitals: 4.9% Being operated on in a higher volume hospital conferred a 71% reduction in risk for 30-day stroke or death, controlling for indications, comorbid conditions, and surgeon's volume (OR, 0.29 [95% CI, 0.12 to 0.69]). Outcomes did not differ significantly by surgeon volume.
Giacovelli, 2010 | ICD-9 codes | Postoperative stroke (Propensity matched): CEA: 1.75%; CAAS: 2.04% Postoperative TIA (Propensity matched): CEA: 0.30%; CAAS: 0.32% Postoperative mortality (Propensity matched): CEA: 0.39%; CAAS: 0.55% Combined postoperative stroke/death (Propensity matched): CEA: 1.93%; CAAS: 2.37% | NR
Giles, 2010 | ICD-9 codes | Postoperative stroke: CEA: 0.6%; CAAS: 1.0% Postoperative mortality: CEA: 0.4%; CAAS: 0.8% Combined postoperative stroke/death: CEA: 0.9%; CAAS: 1.6% | NR
Halm, 2003; Rockma, 2005; Halm, 2005; Press, 2006 | Abstracted from inpatient and outpatient medical records, including all readmissions; 2 investigators independently reviewed records of all those who sustained strokes or TIAs, including 1 neurologist. | NR | Death: 0.57 Nonfatal stroke: 1.69 Death/stroke: 2.26 Nonfatal MI: 0.85
Halm, 2007; Halm, 2009 | Medicare claims; ICD-9 codes; hospital records. Research nurses abstracted data from index admission and all readmissions within 30 days of surgery for death, stroke, or TIA. Confirmed by 2 study physicians (including a neurologist). Disagreements resolved by consensus. | NR | Death and stroke: 3.01% Death or stroke in those with high comorbidity: 7.13%^c^ Death or stroke rate in those without high comorbidity: 2.69%^c^
Hopkins, 2010 CREST (lead-in/credentialing) | Stroke severity was judged by a single physician based on chart review. | NR | Death, stroke and MI: 4.8% Death, any stroke: 3.8% Death, major stroke: 1.8% Death: 0.5% Major stroke: 1.6% Minor stroke: 2.0% Age ≤75/>75 Death, stroke and MI: 3.3%/9.1% Death, any stroke: 2.4%/7.5% Death, major stroke: 1.2%/3.2% Death: 0.5%/0.7% Major stroke: 1.1%/2.9% Minor stroke: 1.2%/4.3%
Karp, 1998 | Claims and medical records. Trained medical abstractors pulled from medical records; a physician reviewed all records in which the abstractor determined that the patient had a stroke to verify and to determine the severity; Deaths from Medicare claims and from Social Security files if the patient died at home. | NR | All strokes:^d^ 2.4% Moderate/severe strokes: 1.0% Stroke-related death: 0.2% MI: 0.8% MI-related death: 0.6% Statistically significant increase in morbidity, mortality, and less severe complications at hospitals performing 10 or less CEAs.
Kresowik, 2000 | Abstraction from medical records by trained abstractors for index hospitalization and any readmissions; Medicare beneficiary data set to identify deaths within 30 days. | Combined stroke or death: Overall: 2.8% 1994: 2.5% 1995-1996: 2.9% | Combined stroke or death: Overall: 3.4% 1994: 3.8% 1995-1996: 3.3%
Kresowik, 2004 | MEDPAR files; ICD-9 codes; Medicare Enrollment Database to identify deaths; comprehensive review of all medical records for the index hospitalization and all admissions within 30 days by trained abstractors. | NR | Combined stroke or death: 1995-1996: 4.1% 1998-1999: 3.8% Death: 1995-1996: 1.1% 1998-1999: 1.0% Combined stroke and death rates (1998-1999) ranged from 1.4% to 6.0% across 10 states; 3 states differed significantly from the mean.
Kresowik, 2001 | MEDPAR files; ICD-9 codes; Medicare Enrollment Database to identify deaths; comprehensive review of all medical records for the index hospitalization and all admissions within 30 days by trained abstractors; independent review of strokes by 2 clinicians with expertise in stroke; subset of those classified as having no stroke was also independently reviewed by 2 clinicians. | NR | Combined stroke or death: 3.7%^e^ Death: 1.1% Combined stroke and death rates ranged from 2.3% to 6.7% across 10 states; 2 states differed significantly from the mean. Mortality rate ranged from 0.5% to 2.5% across 10 states; 1 state differed significantly from the mean.
McPhee, 2007 | ICD-9 codes. | Postoperative stroke: CEA: 0.86%; CAAS: 1.8% Postoperative mortality: CEA: 0.34%; CAAS: 0.44% Postoperative MI: CEA: 1.7%; CAAS: 2.0% | NR
McPhee, 2008 | ICD-9 codes | In-hospital mortality: CEA: 0.38%; CAAS: 0.57% Postoperative stroke: CEA: 0.88%; CAAS: 1.6% | NR
Timaran, 2009 | ICD-9 codes | Postoperative stroke: CEA: 1.0%; CAAS: 1.8% In-hospital mortality: CEA: 0.5%; CAAS: 0.7% | NR
Vouyouka, 2012 | ICD-9 codes | Postoperative stroke: CEA: 1.54%; CAAS: 2.62%; Propensity Matched: CEA: 2.05%; CAAS: 2.67% Postoperative mortality: CEA: 0.33%; CAAS: 0.82%; Propensity Matched: CEA: 0.39%; CAAS: 0.78% Combined postoperative stroke/death: CEA: 1.71%; CAAS: 3.09%; Propensity Matched: CEA: 2.17%; CAAS: 3.11% | NR
Young, 2011 | ICD-9 codes | In-hospital stroke: CEA: 0.88%; CAAS: 1.31% In-hospital death: CEA: 0.39%; CAAS: 0.57% Combined in-hospital stroke/death: CEA: 1.16%; CAAS: 1.69% In-hospital cardiac complications: CEA: 1.86%; CAAS: 2.15% Combined in-hospital stroke/death/cardiac complications: CEA: 2.90%; CAAS: 3.66% | NR
Yuo, 2013 | ICD-9 codes | In-hospital stroke: CEA: 1.5%; CAAS: 3.2% In-hospital death: CEA: 0.5%; CAAS: 1.4% Combined in-hospital stroke/death: CEA: 1.8%; CAAS: 4.1% | NR
Trials
Brott, 2010 ; Silver, 2010 | Neurological exam, including NIHSS assessment and TIA-stroke questionnaire. Study committees unaware of treatment assignment adjudicated stroke and MI events. | NR | CAAS: All patients/patients <80 y MI: 1.2%/0.9% Any stroke: 2.5%/2.4% Major stroke: 0.5%/0.5% Minor stroke: 2.0%/1.8% Any stroke or death: 2.5%/2.4% Any stroke, death or MI: 3.5%/3.1% CEA: MI: 2.2%/2.2% Any stroke: 1.4%/1.5% Major stroke: 0.3%/0.4% Minor stroke: 1.0%/1.1% Any stroke or death: 1.4%/1.5% Any stroke, death or MI: 3.6%/3.7%
CASANOVA study group, 1991 | CT scan, neurologic consultant blinded to group assignment. | NR | Death: 1.4% Stroke or death: 3.2% Minor stroke: 0% Lung embolism: 1.4% MI: 0.0% Cranial nerve damage (permanent): 4.2% TIA: 1.9% Cranial nerve damage: 1.4% Pneumonia: 1.4% Local infection: 0% Local hematoma (requiring surgery): 2.8% Other major complication: 1.9% Other minor complication: 0.9%
Chaturvedi, 2010 Matsumura, 2010 | Neurologic assessment at baseline, 24 hours, and 30 days using Health Stroke Scale by an independent neurologist (nonoperator). All strokes and suspected strokes were adjudicated by an independent Clinical Events Adjudication Committee. Death and MI reported by sites. | NR | Death/stroke/MI: 3.0% Death/stroke: 2.8% Death/major stroke: 1.2% Death: 0.7% All stroke: 2.3% Major stroke (all): 0.7% Major ipsilateral stroke: 0.6% Major contralateral stroke: 0.1% Minor stroke (all): 1.6% Minor ipsilateral stroke: 1.4% Minor contralateral stroke: 0.2% MI: 0.3%
Fairman, 2007 | Neurologic assessment at baseline, 24 hours, and 30 days using Health Stroke Scale by an independent neurologist (nonoperator). All strokes and suspected strokes were adjudicated by an independent Clinical Events Adjudication Committee (2 independent neurologists). Death and MI reported by sites. | NR | Stroke: 4.1% Major stroke: 1.6%
Gray, 2009 | Neurologic assessment at baseline, 24 hours, and 30 days using Health Stroke Scale by an independent neurologist (nonoperator). All strokes and suspected strokes were adjudicated by an independent Clinical Events Adjudication Committee. Death and MI reported by sites. | NR | Full asx sample: Death and stroke: 3.2% Death and major stroke: 1.3% In asx patients age <80 y: Death/stroke: 2.9% Death/major stroke: 1.1% Death: 0.8% Minor stroke: 1.8% Major stroke: 0.6% In asx patients with unfavorable anatomic factors: Death/stroke: 2.7% Death/major stroke: 0.8% Death: 0.3% Minor stroke: 1.9% Major stroke: 0.5%
MACE study group, 1992 | Occurrence and severity of endpoints were adjudicated by 2 participating neurologists and surgeons who were not involved in the management of the patient and who were unaware of the treatment arm; included phone interview 30days after intervention. | NR | TIA: 4% Stroke: 4% MI: 8.3% Minor cranial nerve injury: 11%
Yadav, 2004 | Neurological examination, including NIHSS assessment. Major adverse clinical events were adjudicated by an independent, blinded clinical events committee. | NR | CEA: Death, stroke or MI: 10.2% CAAS: Death, stroke or MI: 5.4%

Data are for followup years; reported ages are the mean unless otherwise specified.

a The article also reports HTN (3%), wound hematoma (2%), pneumonia (2%), TIA (1%), return to operating room (1%), nerve palsy (1%), acute CHF (<1%), MI (<1%), wound infection (<1%), and other (3%), but the data were not reported separately by symptom status.

b High volume = more than 100 Medicare CEAs over the 2 years.

c High comorbidity = end stage disease, severe disability, or ≥3 Revised Cardiac Risk Index risk factors.

d Article also reports “less serious complications”: hematoma (4%) and pneumonia (1.5%), but does not separate by symptom status.

e The 1995-1996 data are also included in Kresowik 2004, but results were adjusted for independent clinician validation in Kresowik 2001 (i.e., Kresowik 2004 results were unadjusted, so the numbers are not identical).

Abbreviations: CAAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CHF = congestive heart failure; COPD = chronic obstructive pulmonary disease; CV = cerebrovascular; HTN = hypertension; ICD = International Classification of Diseases; MI = myocardial infarction; N = sample size; NR = not reported; TIA = transient ischemic attack; U/S = ultrasound.

Sixteen other observational studies were rated as poor quality, usually due to high risk for selection bias and/or ascertainment bias. These included published data from the National Surgery Quality Improvement Program (NSQIP) database,114-117 the Veteran's Administration NSQIP,118,119 the Carotid Artery Revascularization and Endarterectomy (CARE) registry,120,121 international registries,122-126 and the Society for Vascular Surgery Vascular Registry (SVS-VR).127-129 Additional details about the results and quality ratings of these studies are provided in Appendix D and E, respectively.

#### Trial Results

CEA compared with medical therapy. Table 3 summarizes the main results of the VACS, ACAS, and ACST. Appendix F includes complete results of our meta-analyses.

Perioperative (30-day) stroke or death. Our meta-analysis found that 1.9 percent more persons treated with CEA had perioperative stroke or death within 30 days compared with subjects in medical therapy groups (RD, 0.019 [95% CI, 0.012 to 0.026]).

Perioperative (30-day) nonfatal MI. Two of the trials reported this outcome. The ACST found a significant increase in events in subjects who were treated with CEA (10 events) compared with subjects who were treated with medical therapy (one event) (RD, 0.006 [95% CI, 0.002 to 0.010]). The VACS reported four events in the CEA group and none in the medical therapy group.

Age, sex, race, or ethnicity. None of the trials reported subgroup information by race or ethnicity. The ACAS and ACST provided some subgroup information for perioperative stroke or death. In ACAS, the crude rate of perioperative stroke or death was higher in women than men, but the difference was not statistically significant (3.6% vs. 1.7%, p=0.12). In ACST, the perioperative hazards of CEA did not differ by subgroups of age, sex, or extent of stenosis (data not reported).

Rates of perioperative harms after CEA or CAAS. Table 5 summarizes the main results of studies rated as good or fair quality that reported rates of periprocedural harms.

Perioperative (30-day) death or stroke after CEA. Our meta-analysis of seven cohort studies (n=17,474) that all used Medicare claims data and medical records found a rate of 3.3 percent (95% CI, 2.7 to 3.9) for death or stroke in the 30 days after CEA. Sensitivity analysis, including poor-quality cohort studies (including vascular registries and NSQIP data), found a rate of 2.8 percent; statistical heterogeneity was considerable (95% CI, 2.1 to 3.5; I^2^ = 92.5%). This considerable heterogeneity was expected given the significant differences in sample selection, ascertainment methods, and quality.

In all trials that included a CEA arm, regardless of the comparator, the rate of 30-day death or stroke was 2.4 percent (95% CI, 1.7 to 3.1).

Perioperative (30-day) death or stroke after CAAS. One cohort study, the CREST lead-in, found a rate of 3.8 percent (95% CI, 2.86 to 5.09) for death or stroke in the 30 days after CAAS. Our meta-analysis of trials (n=6,152; 2 trials) found a rate of 3.1 percent (95% CI, 2.68 to 3.56).

Perioperative (30-day) MI after CEA. One cohort study including 1,378 Medicare beneficiaries undergoing CEA for asymptomatic CAS at six hospitals in New York state during 1997 to 1998 reported a 0.85 percent rate of nonfatal MI.99A similar study in Georgia Medicare beneficiaries (n=1,002) during 1993 reported a 0.8 percent rate of MI, and a 0.6 percent rate of MI-related death.103 One RCT (CREST) reported a 2.2 percent rate of any MI following CEA.85

Perioperative (30-day) MI after CAAS. One RCT (CREST) reported a 1.2 percent rate of any MI in the 30 days following CAAS.85

Nerve injuries, infection, and other postoperative harms. In VACS, 3.8 percent of persons undergoing CEA (8 of 211) had cranial nerve injuries. Functional recovery was observed in all patients, and there was no permanent disability. The CASANOVA trial reported a 1.4 percent rate of lung embolism, 4.2 percent rate of permanent cranial nerve damage, 1.4 percent rate of pneumonia, and 2.8 percent rate of local hematoma requiring surgery in the 206 patients randomized to the immediate surgical arm.82 The total frequency of major complications (e.g., death, stroke, minor stroke, MI, permanent cranial nerve damage) in the group randomized to immediate surgery was 7.9 percent. The MACE study reported a 1.1 percent rate of minor cranial nerve injury in the 36 patients randomized to CEA.83

Age, sex, race, or ethnicity. One cohort study (CREST lead-in) reported a 2.4 percent rate of perioperative death or stroke following CAAS for patients younger than age 75 years and 7.5 percent for persons older than age 75 years. It also reported a perioperative death, stroke, and MI rate of 3.3 percent for persons younger than age 75 years and 9.1 percent for persons older than age 75 years.105

In a pooled analysis of data from two uncontrolled trials (CAPTURE-2 and EXACT) the rate of death or stroke following CAAS in patients younger than age 80 years was 2.9 percent compared with a rate of 4.4 percent in persons age 80 years and older.90

Comorbidities. We found one fair-quality cohort study reporting rates of harms by comorbidity following CEA for asymptomatic CAS in 1998 and 1999. It reported a 30-day death or stroke rate of 7.13 percent in persons with high comorbidity versus 2.69 percent in persons with low comorbidity in Medicare beneficiaries at 150 hospitals in New York (6,932 patients).24 High comorbidity was defined as any end-stage disease, severe disability, or three or more Revised Cardiac Risk Index risk factors (history of ischemic heart disease, congestive heart failure, stroke/transient ischemic attack, diabetes requiring insulin, creatinine >2, or undergoing a high-risk surgery).

Variation in rates of perioperative stroke or death following CEA by center volume. One study of Medicare beneficiaries who underwent CEA (350 procedures) during 1993 to 1994 in Oklahoma found a combined stroke and death rate at high-volume hospitals (>100 Medicare CEAs over the study period) of 3.5 percent, and a stroke and death rate at low-volume centers of 5.2 percent.96 A similar study of Medicare beneficiaries undergoing CEA at 115 hospitals in Ohio (167 procedures) reported a stroke or death rate of 0 percent at high-volume centers and 4.9 percent at low-volume centers during 1993 to 1994.^97^

Variation in rates of perioperative stroke or death following CEA by state. Two studies using cohorts of Medicare beneficiaries reported varying rates across 10 states.94,95 Rates ranged from 2.3 to 6.7 percent using data from 1995 to 1996^95^ and from 1.4 to 6.0 percent using data from 1998 to 1999.^94^